# Included Studies

Table D-1 lists all included studies by primary article in alphabetical order, companion article (if applicable), and study designation (if applicable). Full bibliographic citations follow the table.

Table D-1 Studies included in SMI comparative effectiveness review

Primary Article | Companion Article | Study Designation
Alvarez-Jimenez, 2006^1^ | Alvarez-Jimenez, 2010^2^ | NA
Assuncao, 2006^3^ | NA | NA
Atmaca, 2003^4^ | NA | NA
Atmaca, 2004^5^ | NA | NA
Ball, 2011^6^ | NA | NA
Borba, 2011^7^ | NA | NA
Brar, 2005^8^ | NA | NA
Brown, 2011^9^ | NA | NA
Bustillo, 2003^10^ | NA | NA
Carrizo, 2009^11^ | Fernandez, 2010^12^ | NA
Cavazzoni, 2003^13^ | NA | NA
Deberdt, 2008^14^ | NA | NA
Elmslie, 2006^15^ | NA | NA
Evans, 2005^16^ | NA | NA
Fleischhacker, 2010^17^ | NA | NA
Forsberg, 2008^18^ | NA | NA
Gillhoff, 2010^19^ | NA | NA
Graham, 2005^20^ | NA | NA
Hoffmann, 2012^21^ | NA | NA
Kwon, 2006^22^ | NA | NA
Karagianis, 2009^23^ | Karagianis, 2010^24^ | PLATYPUS
Khazaal, 2007^25^ | NA | NA
Littrell, 2003^26^ | NA | NA
Mauri, 2008^27^ | NA | NA
McDonnell, 2011^28^ | NA | NA
McElroy, 2012^29^ | NA | NA
McKibbin, 2006^30^ | Leutwyler, 2010^31^ McKibbin, 2010^32^ | Diabetes Awareness and Rehabilitation Training (DART)
Narula, 2010^33^ | NA | NA
Newcomer, 2008^34^ | NA | NA
Nickel, 2005^35^ | NA | NA
Skrinar, 2005^36^ | NA | NA
Stroup, 2011^37^ | NA | Comparison of Antipsychotics for Metabolic Problems (CAMP)
Wang 2012^38^ | NA | NA
Wu, 2008^39^ | NA | NA
Wu, 2012^40^ | NA | NA

Abbreviations: NA=not applicable; SMI-serious mental illness

## References Cited in Appendix D

1 Alvarez-Jimenez M, Gonzalez-Blanch C, Vazquez-Barquero JL, et al. Attenuation of antipsychotic-induced weight gain with early behavioral intervention in drug-naive first-episode psychosis patients: A randomized controlled trial. J Clin Psychiatry. 2006;67(8):1253-60. [pmid: 16965204].
2 Alvarez-Jimenez M, Martinez-Garcia O, Perez-Iglesias R, et al. Prevention of antipsychotic-induced weight gain with early behavioural intervention in first-episode psychosis: 2-year results of a randomized controlled trial. Schizophr Res. 2010;116(1):16-9. [pmid: 19896336].
3 Assuncao SS, Ruschel SI, de Rosa LC, et al. Weight gain management in patients with schizophrenia during treatment with olanzapine in association with nizatidine. Rev Bras Psiquiatr. 2006;28(4):270-6. [pmid: 17242805].
4 Atmaca M, Kuloglu M, Tezcan E, et al. Nizatidine treatment and its relationship with leptin levels in patients with olanzapine-induced weight gain. Hum Psychopharmacol. 2003;18(6):457-61. [pmid: 12923824].
5 Atmaca M, Kuloglu M, Tezcan E, et al. Nizatidine for the treatment of patients with quetiapine-induced weight gain. Hum Psychopharmacol. 2004;19(1):37-40. [pmid: 14716710].
6 Ball MP, Warren KR, Feldman S, et al. Placebo-controlled trial of atomoxetine for weight reduction in people with schizophrenia treated with clozapine or olanzapine. Clin Schizophr Relat Psychoses. 2011;5(1):17-25. [pmid: 21459735].
7 Borba CP, Fan X, Copeland PM, et al. Placebo-controlled pilot study of ramelteon for adiposity and lipids in patients with schizophrenia. J Clin Psychopharmacol. 2011;31(5):653-8. [pmid: 21869685].
8 Brar JS, Ganguli R, Pandina G, et al. Effects of behavioral therapy on weight loss in overweight and obese patients with schizophrenia or schizoaffective disorder. J Clin Psychiatry. 2005;66(2):205-12. [pmid: 15705006].
9 Brown C, Goetz J, Hamera E. Weight loss intervention for people with serious mental illness: a randomized controlled trial of the RENEW program. Psychiatr Serv. 2011;62(7):800-2. [pmid: 21724796].
10 Bustillo JR, Lauriello J, Parker K, et al. Treatment of weight gain with fluoxetine in olanzapine-treated schizophrenic outpatients. Neuropsychopharmacology. 2003;28(3):527-9. [pmid: 12629532].
11 Carrizo E, Fernandez V, Connell L, et al. Extended release metformin for metabolic control assistance during prolonged clozapine administration: a 14 week, double-blind, parallel group, placebo-controlled study. Schizophr Res. 2009;113(1):19-26. [pmid: 19515536].
12 Fernandez E, Carrizo E, Fernandez V, et al. Polymorphisms of the LEP- and LEPR genes, metabolic profile after prolonged clozapine administration and response to the antidiabetic metformin. Schizophr Res. 2010;121(1–3):213-7. [pmid: 20591628].
13 Cavazzoni P, Tanaka Y, Roychowdhury SM, et al. Nizatidine for prevention of weight gain with olanzapine: a double-blind placebo-controlled trial. Eur Neuropsychopharmacol. 2003;13(2):81-5. [pmid: 12650950].
14 Deberdt W, Lipkovich I, Heinloth AN, et al. Double-blind, randomized trial comparing efficacy and safety of continuing olanzapine versus switching to quetiapine in overweight or obese patients with schizophrenia or schizoaffective disorder. Ther Clin Risk Manag. 2008;4(4):713-20. [pmid: 19209252].
15 Elmslie JL, Porter RJ, Joyce PR, et al. Carnitine does not improve weight loss outcomes in valproate-treated bipolar patients consuming an energy-restricted, low-fat diet. Bipolar Disord. 2006;8(5 Pt 1):503-7. [pmid: 17042889].
16 Evans S, Newton R, Higgins S. Nutritional intervention to prevent weight gain in patients commenced on olanzapine: a randomized controlled trial. Aust N Z J Psychiatry. 2005;39(6):479-86. [pmid: 15943650].
17 Fleischhacker WW, Heikkinen ME, Olie JP, et al. Effects of adjunctive treatment with aripiprazole on body weight and clinical efficacy in schizophrenia patients treated with clozapine: a randomized, double-blind, placebo-controlled trial. Int J Neuropsychopharmacol. 2010;13(8):1115-25. [pmid: 20459883].
18 Forsberg KA, Bjorkman T, Sandman PO, et al. Physical health--a cluster randomized controlled lifestyle intervention among persons with a psychiatric disability and their staff. Nord J Psychiatry. 2008;62(6):486-95. [pmid: 18843564].
19 Gillhoff K, Gaab J, Emini L, et al. Effects of a multimodal lifestyle intervention on body mass index in patients with bipolar disorder: a randomized controlled trial. Prim Care Companion J Clin Psychiatry. 2010;12(5). [pmid: 21274359].
20 Graham KA, Gu H, Lieberman JA, et al. Double-blind, placebo-controlled investigation of amantadine for weight loss in subjects who gained weight with olanzapine. Am J Psychiatry. 2005;162(9):1744-6. [pmid: 16135638].
21 Hoffmann VP, Case M, Jacobson JG. Assessment of treatment algorithms including amantadine, metformin, and zonisamide for the prevention of weight gain with olanzapine: a randomized controlled open-label study. J Clin Psychiatry. 2012;73(2):216-23. [pmid: 21672497].
22 Kwon JS, Choi JS, Bahk WM, et al. Weight management program for treatment-emergent weight gain in olanzapine-treated patients with schizophrenia or schizoaffective disorder: A 12-week randomized controlled clinical trial. J Clin Psychiatry. 2006;67(4):547-53. [pmid: 16669719].
23 Karagianis J, Grossman L, Landry J, et al. A randomized controlled trial of the effect of sublingual orally disintegrating olanzapine versus oral olanzapine on body mass index: the PLATYPUS Study. Schizophr Res. 2009;113(1):41-8. [pmid: 19535229].
24 Karagianis J, Landry J, Hoffmann VP, et al. An exploratory analysis of factors associated with weight change in a 16-week trial of oral vs. orally disintegrating olanzapine: the PLATYPUS study. Int J Clin Pract. 2010;64(11):1520-9. [pmid: 20846199].
25 Khazaal Y, Fresard E, Rabia S, et al. Cognitive behavioural therapy for weight gain associated with antipsychotic drugs. Schizophr Res. 2007;91(1–3):169-77. [pmid: 17306507].
26 Littrell KH, Hilligoss NM, Kirshner CD, et al. The effects of an educational intervention on antipsychotic-induced weight gain. J Nurs Scholarsh. 2003;35(3):237-41. [pmid: 14562491].
27 Mauri M, Simoncini M, Castrogiovanni S, et al. A psychoeducational program for weight loss in patients who have experienced weight gain during antipsychotic treatment with olanzapine. Pharmacopsychiatry. 2008;41(1):17-23. [pmid: 18203047].
28 McDonnell DP, Kryzhanovskaya LA, Zhao F, et al. Comparison of metabolic changes in patients with schizophrenia during randomized treatment with intramuscular olanzapine long-acting injection versus oral olanzapine. Hum Psychopharmacol. 2011;26(6):422-433. [pmid: 21823172].
29 McElroy SL, Winstanley E, Mori N, et al. A randomized, placebo-controlled study of zonisamide to prevent olanzapine-associated weight gain. J Clin Psychopharmacol. 2012;32(2):165-72. [pmid: 22367654].
30 McKibbin CL, Patterson TL, Norman G, et al. A lifestyle intervention for older schizophrenia patients with diabetes mellitus: a randomized controlled trial. Schizophr Res. 2006;86(1–3):36-44. [pmid: 16842977].
31 Leutwyler HC, Wallhagen M, McKibbin C. The impact of symptomatology on response to a health promoting intervention among older adults with schizophrenia. Diabetes Educ. 2010;36(6):945-55. [pmid: 21119068].
32 McKibbin CL, Golshan S, Griver K, et al. A healthy lifestyle intervention for middle-aged and older schizophrenia patients with diabetes mellitus: a 6-month follow-up analysis. Schizophr Res. 2010;121(1–3):203-6. [pmid: 20434886].
33 Narula PK, Rehan HS, Unni KE, et al. Topiramate for prevention of olanzapine associated weight gain and metabolic dysfunction in schizophrenia: a double-blind, placebo-controlled trial. Schizophr Res. 2010;118(1–3):218-23. [pmid: 20207521].
34 Newcomer JW, Campos JA, Marcus RN, et al. A multicenter, randomized, double-blind study of the effects of aripiprazole in overweight subjects with schizophrenia or schizoaffective disorder switched from olanzapine. J Clin Psychiatry. 2008;69(7):1046-56. [pmid: 18605811].
35 Nickel MK, Nickel C, Muehlbacher M, et al. Influence of topiramate on olanzapine-related adiposity in women: a random, double-blind, placebo-controlled study. J Clin Psychopharmacol. 2005;25(3):211-7. [pmid: 15876898].
36 Skrinar GS, Huxley NA, Hutchinson DS, et al. The role of a fitness intervention on people with serious psychiatric disabilities. Psychiatr Rehabil J. 2005;29(2):122-7. [pmid: 16268007].
37 Stroup TS, McEvoy JP, Ring KD, et al. A randomized trial examining the effectiveness of switching from olanzapine, quetiapine, or risperidone to aripiprazole to reduce metabolic risk: comparison of antipsychotics for metabolic problems (CAMP). Am J Psychiatry. 2011;168(9):947-56. [pmid: 21768610].
38 Wang M, Tong JH, Zhu G, et al. Metformin for treatment of antipsychotic-induced weight gain: a randomized, placebo-controlled study. Schizophr Res. 2012;138(1):54-7. [pmid: 22398127].
39 Wu RR, Zhao JP, Jin H, et al. Lifestyle intervention and metformin for treatment of antipsychotic-induced weight gain: a randomized controlled trial. JAMA. 2008;299(2):185-93. [pmid: 18182600].
40 Wu RR, Jin H, Gao K, et al. Metformin for Treatment of Antipsychotic-Induced Amenorrhea and Weight Gain in Women With First-Episode Schizophrenia: A Double-Blind, Randomized, Placebo-Controlled Study. Am J Psychiatry. 2012;169(8):813-21. [pmid: 22711171].