# Efficacy–Effectiveness Rating Form

[underlined: Directions]: For each article, rate the study along eight dimensions. For each dimension, consider whether, on balance, the study is most consistent with the definition of efficacy or effectiveness. Make your best judgment, but if the article does not give adequate information to make a determination, choose “unclear.”

Table B-1 Efficacy–Effectiveness Rating Form

Dimension | Efficacy/Explanatory Trial | Effectiveness/Pragmatic Trial
1. Setting/practitioner expertise [] Efficacy [] Effectiveness [] Unclear | Highly specialized setting: Research clinic/integrated MH-Gen Med Health OR referral population OR Academic medical Center OR restricted to practitioners with additional training in the intervention | Reflects typical care setting: Community settings (e.g. CMHC, PC) or full range of usual care settings AND practitioners do not have any special intervention training
2. Eligibility criteria [] Efficacy [] Effectiveness [] Unclear | Captures narrow spectrum of SMI population: Convenience sample OR sample selection criteria that excludes typical psychiatric comorbidities (e.g., mood or anxiety disorder), medical comorbidities (e.g., stable DM, HTN) or medications (e.g., antidepressants, mood stabilizers) OR those less likely to adhere to treatment (fail run-in period); OR small proportion of those evaluated are eligible (<25%) | Captures full spectrum of SMI population: Consecutive patients OR allows usual comorbidities and those less likely to be adherent, AND a high proportion of those evaluated are eligible
3. Health outcomes [] Efficacy [] Effectiveness [] Unclear | Focus on intermediate outcomes: Does not include clinical events (e.g., MI, stroke, major DM complications), physical function, mortality or health-related quality of life | Clinically important outcomes included: In the methods section, specifies ≥ 1 of the following outcomes: clinical events, mortality, physical function, or HRQOL
4. Study duration/clinically relevant intervention [] Efficacy [] Effectiveness [] Unclear | Short duration/Fixed intervention: Intervention duration and dose is fixed, OR outcomes are short-term only (<6 months) | Longer duration/Flexible intervention: Intervention dose or duration given to clinical endpoints or Intervention is flexible and responds to clinical status, AND outcomes are longer-term (≥ 6 months)
5. Assessment of adverse events [] Efficacy [] Effectiveness [] Unclear | Adverse events are [underlined: not] measured/reported carefully: Does not report discontinuation due to AE and ≥ 1 other predefined, important AE; OR measures are [underlined: not] obtained with a scale | Adverse events are measured/reported carefully: Reports discontinuation due to AE, and ≥ 1 other predefined, important AE; measures are obtained with a scale
6. Adequate sample size for health outcomes [] Efficacy [] Effectiveness [] Unclear | Inadequate/Unspecified sample size: Sample size not given for clinical events, physical function, mortality or HRQOL | Adequate sample size: Sample size calculation given clinical events, physical function, mortality or HRQOL
7. ITT analysis [] Efficacy [] Effectiveness [] Unclear | No ITT analysis: Completers analysis or excludes those with protocol deviations | ITT analysis: Follows intent-to-treat principle for analysis (includes all patients regardless of compliance, eligibility)
Study quality | Captured from quality rating tool | Captured from quality rating tool
Experimental domain
8. Comparison intervention [] Efficacy [] Effectiveness [] Unclear | Comparison is placebo rather than the best alternative management strategy | Usual practice or the best alternative management strategy, offering practitioners considerable leeway in deciding how to apply it

Comments: