# Exact Search Strings

## PubMed^®^ Search Strategy (July 20, 2012)

Table A-1 PubMed search strings for KQ 1

Set # | Terms
#1 | Schizophrenia[tiab] OR schizophrenia[mesh] OR bipolar disorder[mesh:noexp] OR “bipolar disorder”[tiab] OR “psychotic disorders”[tiab] OR schizoaffective[tiab] OR mania[ti] OR manic[ti] OR “bipolar affective disorder”[tiab] OR “serious mental illness”[tiab] OR “severe mental illness”[tiab] OR “severe psychiatric illness”[tiab] OR (“depressive disorder”[mesh] AND psychotic[tiab]) OR “affective disorders, psychotic”[mesh] OR “psychotic disorders”[mesh]
#2 | overweight[mesh] OR overweight[tiab] OR obesity[mesh] OR obesity[tiab] OR obese[tiab] OR weight[tiab] OR Body weights and measures[mesh] OR “body mass index”[tw] OR bmi[tw]
#3 | chlorpromazine[MeSH] OR chlorpromazine[tw] OR thorazine[tw] OR fluphenazine[MeSH] OR fluphenazine[tw] OR haloperidol[MeSH] OR haloperidol[tw] OR haldol[tw] OR iloperidone[Supplementary Concept] OR iloperidone[tw] OR fanapt[tw] OR loxapine[MeSH] OR loxapine[tw] OR loxitane[tw] OR molindone[MeSH] OR molindone[tw] OR moban[tw] OR chlorpromazine[MeSH] OR chlorpromazine[tw] OR thorazine[tw] OR perphenazine[MeSH] OR perphenazine[tw] OR pimozide[MeSH] OR pimozide[tw] OR orap[tw] OR thioridazine[MeSH] OR thioridazine[tw] OR thiothixene[MeSH] OR thiothixene[tw] OR navane[tw] OR trifluoperazine[MeSH] OR trifluoperazine[tw] OR stelazine[tw] OR clozapine[MeSH] OR clozapine[tw] OR clozaril[tw] OR risperidone[MeSH] OR risperidone[tw] OR risperidal[tw] OR olanzapine[Supplementary Concept] OR olanzapine[tw] OR zyprexa[tw] OR quetiapine[Supplementary Concept] OR quetiapine[tw] OR seroquel[tw] OR ziprasidone[Supplementary Concept] OR ziprasidone[tw] OR geodon[tw] OR aripiprazole[Supplementary Concept] OR aripiprazole[tw] OR abilify[tw] OR 9-hydroxy-risperidone[Supplementary Concept] OR “9-hydroxy-risperidone”[tw] OR paliperidone[tw] OR invega[tw] OR antipsychotic agents[mh] OR antipsychotic agents[pharmacological action] OR antipsychotic[tiab] OR antipsychotics[tiab]
#4 | #1 AND (#2 OR #3)
#5 | orlistat[Supplementary Concept] OR orlistat[tw] OR topiramate[Supplementary Concept] OR topiramate[tw] OR metformin[MeSH] OR metformin[tw] OR amantadine[MeSH] OR amantadine[tw] OR “Appetite Depressants”[Mesh] OR “Appetite Depressants” [Pharmacological Action] OR “Anti-Obesity Agents”[Mesh] OR “Anti-Obesity Agents” [Pharmacological Action]
#6 | “Nutrition Therapy”[Mesh] OR “Exercise”[Mesh] OR “Exercise Therapy”[Mesh] OR “Exercise Movement Techniques”[Mesh] OR “diet therapy”[mesh] OR exercise[tiab] OR “physical activity”[tiab] OR diet[tiab] OR diets[tiab] OR “weight management”[tiab] OR “Behavior Therapy”[Mesh] OR health education[mesh] OR health promotion[mesh] OR counsel*[tiab] OR counseling[mesh] OR “disease management”[mesh] OR “cognitive behavioral therapy”[tiab] OR “lifestyle modification”[tiab] OR (“life style”[mesh] AND modification[tiab]) OR “Patient Compliance”[Mesh] OR adher*[tiab] OR “self-monitoring”[tiab] OR “Recurrence/prevention and control”[Mesh] OR “relapse prevention”[tiab] OR “skills training”[tiab] OR “motivational interviewing”[tiab] OR educat*[tiab]
#7 | social support[mesh] OR family[tiab] OR peer[tiab]
#8 | Drug substitution[mesh] OR substitut*[tw] switch[tiab] OR switched[tiab] OR switching[tiab] OR change[tiab] OR changed[tiab] OR changing[tiab] OR replace[tiab] OR replaced[tiab] OR replacing[tiab] OR replacement[tiab] OR abandon*[tiab]
#9 | #5 OR #6 OR #7 OR #8
#10 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#11 | #4 AND #9 AND #10, Limits: English

Table A-2 PubMed search strings for KQ 2

Set # | Terms
#1 | Schizophrenia[tiab] OR schizophrenia[mesh] OR bipolar disorder[mesh:noexp] OR “bipolar disorder”[tiab] OR “psychotic disorders”[tiab] OR schizoaffective[tiab] OR mania[ti] OR manic[ti] OR “bipolar affective disorder”[tiab] OR “serious mental illness”[tiab] OR “severe mental illness”[tiab] OR “severe psychiatric illness”[tiab] OR (“depressive disorder”[mesh] AND psychotic[tiab]) OR “affective disorders, psychotic”[mesh] OR “psychotic disorders”[mesh]
#2 | Diabetes mellitus[mesh] OR diabetes[tiab]
#3 | chlorpromazine[MeSH] OR chlorpromazine[tw] OR thorazine[tw] OR fluphenazine[MeSH] OR fluphenazine[tw] OR haloperidol[MeSH] OR haloperidol[tw] OR haldol[tw] OR iloperidone[Supplementary Concept] OR iloperidone[tw] OR fanapt[tw] OR loxapine[MeSH] OR loxapine[tw] OR loxitane[tw] OR molindone[MeSH] OR molindone[tw] OR moban[tw] OR chlorpromazine[MeSH] OR chlorpromazine[tw] OR thorazine[tw] OR perphenazine[MeSH] OR perphenazine[tw] OR pimozide[MeSH] OR pimozide[tw] OR orap[tw] OR thioridazine[MeSH] OR thioridazine[tw] OR thiothixene[MeSH] OR thiothixene[tw] OR navane[tw] OR trifluoperazine[MeSH] OR trifluoperazine[tw] OR stelazine[tw] OR clozapine[MeSH] OR clozapine[tw] OR clozaril[tw] OR risperidone[MeSH] OR risperidone[tw] OR risperidal[tw] OR olanzapine[Supplementary Concept] OR olanzapine[tw] OR zyprexa[tw] OR quetiapine[Supplementary Concept] OR quetiapine[tw] OR seroquel[tw] OR ziprasidone[Supplementary Concept] OR ziprasidone[tw] OR geodon[tw] OR aripiprazole[Supplementary Concept] OR aripiprazole[tw] OR abilify[tw] OR 9-hydroxy-risperidone[Supplementary Concept] OR “9-hydroxy-risperidone”[tw] OR paliperidone[tw] OR invega[tw] OR antipsychotic agents[mh] OR antipsychotic agents[pharmacological action] OR antipsychotic[tiab] OR antipsychotics[tiab]
#4 | #1 AND (#2 OR #3)
#5 | “exenatide”[Supplementary Concept] OR Byetta[tiab] OR exenatide[tiab] OR “pramlintide”[Supplementary Concept] OR Symlin[tiab] OR pramlintide [tiab] OR “sitagliptin”[Supplementary Concept] OR Januvia[tiab] OR sitagliptin[tiab] OR glargine[supplementary concept] OR Lantus[tiab] OR “insulin glargine”[tiab] OR “saxagliptin”[Supplementary Concept] OR Onglyza[tiab] OR saxagliptin[tiab] OR “miglitol”[Supplementary Concept] OR Glyset[tiab] OR miglitol[tiab] OR “rosiglitazone”[Supplementary Concept] OR Avandia[tiab] OR rosiglitazone[tiab] OR “pioglitazone”[Supplementary Concept] OR Actos[tiab] OR pioglitazone[tiab] OR “repaglinide”[Supplementary Concept] OR Prandin[tiab] OR repaglinide[tiab] OR “nateglinide”[Supplementary Concept] OR Starlix[tiab] OR nateglinide[tiab] OR “glyburide”[MeSH] OR Diabeta[tiab] OR glyburide[tiab] OR “glimepiride”[Supplementary Concept]OR Amaryl[tiab] OR glimepiride[tiab] OR “metformin”[MeSH] OR Glumetza[tiab] OR metformin[tiab] OR Riomet[tiab] OR Fortamet[tiab] OR “BI 1356”[Supplementary Concept] OR Tradjenta[tiab] OR linagliptin[tiab] OR “liraglutide”[Supplementary Concept]OR Victoza[tiab] OR liraglutide[tiab] OR “colesevelam”[Supplementary Concept] OR WelChol[tiab] OR colesevelam[tiab] OR “bromocriptine”[MeSH] OR Cycloset[tiab] OR bromocriptine[tiab] OR Parlodel[tiab] OR “Hypoglycemic Agents”[Mesh] OR “Hypoglycemic Agents” [Pharmacological Action]
#6 | “Diabetes Mellitus/prevention and control”[Mesh] OR “diabetes management”[tiab] OR “Behavior Therapy”[Mesh] OR health education[mesh] OR health promotion[mesh] OR counsel*[tiab] OR counseling[mesh] OR “disease management”[mesh] OR “cognitive behavioral therapy”[tiab] OR “lifestyle modification”[tiab] OR (“life style”[mesh] AND modification[tiab]) OR “Patient Compliance”[Mesh] OR adher*[tiab] OR “self-monitoring”[tiab] OR “Recurrence/prevention and control”[Mesh] OR “relapse prevention”[tiab] OR “skills training”[tiab] OR “motivational interviewing”[tiab] OR educat*[tiab]
#7 | social support[mesh] OR family[tiab] OR peer[tiab]
#8 | Drug substitution[mesh] OR substitut*[tw] switch[tiab] OR switched[tiab] OR switching[tiab] OR change[tiab] OR changed[tiab] OR changing[tiab] OR replace[tiab] OR replaced[tiab] OR replacing[tiab] OR replacement[tiab] OR abandon*[tiab]
#9 | #5 OR #6 OR #7 OR #8
#10 | #4 AND #9
#11 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#12 | #10 AND #11, Limits: English

Table A-3 PubMed search strings for KQ 3

Set # | Terms
#1 | Schizophrenia[tiab] OR schizophrenia[mesh] OR bipolar disorder[mesh:noexp] OR “bipolar disorder”[tiab] OR “psychotic disorders”[tiab] OR schizoaffective[tiab] OR mania[ti] OR manic[ti] OR “bipolar affective disorder”[tiab] OR “serious mental illness”[tiab] OR “severe mental illness”[tiab] OR “severe psychiatric illness”[tiab] OR (“depressive disorder”[mesh] AND psychotic[tiab]) OR “affective disorders, psychotic”[mesh] OR “psychotic disorders”[mesh]
#2 | “Dyslipidemias”[Mesh] OR “Hyperlipidemias”[Mesh] OR dyslipidemia[tiab] OR dyslipidemias[tiab] OR hyperlipidemia[tiab] OR hyperlipidemias[tiab]
#3 | chlorpromazine[MeSH] OR chlorpromazine[tw] OR thorazine[tw] OR fluphenazine[MeSH] OR fluphenazine[tw] OR haloperidol[MeSH] OR haloperidol[tw] OR haldol[tw] OR iloperidone[Supplementary Concept] OR iloperidone[tw] OR fanapt[tw] OR loxapine[MeSH] OR loxapine[tw] OR loxitane[tw] OR molindone[MeSH] OR molindone[tw] OR moban[tw] OR chlorpromazine[MeSH] OR chlorpromazine[tw] OR thorazine[tw] OR perphenazine[MeSH] OR perphenazine[tw] OR pimozide[MeSH] OR pimozide[tw] OR orap[tw] OR thioridazine[MeSH] OR thioridazine[tw] OR thiothixene[MeSH] OR thiothixene[tw] OR navane[tw] OR trifluoperazine[MeSH] OR trifluoperazine[tw] OR stelazine[tw] OR clozapine[MeSH] OR clozapine[tw] OR clozaril[tw] OR risperidone[MeSH] OR risperidone[tw] OR risperidal[tw] OR olanzapine[Supplementary Concept] OR olanzapine[tw] OR zyprexa[tw] OR quetiapine[Supplementary Concept] OR quetiapine[tw] OR seroquel[tw] OR ziprasidone[Supplementary Concept] OR ziprasidone[tw] OR geodon[tw] OR aripiprazole[Supplementary Concept] OR aripiprazole[tw] OR abilify[tw] OR 9-hydroxy-risperidone[Supplementary Concept] OR “9-hydroxy-risperidone”[tw] OR paliperidone[tw] OR invega[tw] OR antipsychotic agents[mh] OR antipsychotic agents[pharmacological action] OR antipsychotic[tiab] OR antipsychotics[tiab]
#4 | #1 AND (#2 OR #3)
#5 | “Hypolipidemic Agents”[Mesh] OR “Hypolipidemic Agents” [Pharmacological Action] OR “Hydroxymethylglutaryl-CoA Reductase Inhibitors”[Mesh] OR “Hydroxymethylglutaryl-CoA Reductase Inhibitors” [Pharmacological Action] OR statins[tiab] OR statin[tiab] OR “Simvastatin”[Mesh] OR simvastatin[tiab] OR “Lovastatin”[Mesh] OR lovastatin[tiab] OR “atorvastatin” [Supplementary Concept] OR atorvastatin[tiab] OR “Pravastatin”[Mesh] OR pravastatin[tiab] OR “fluvastatin” [Supplementary Concept] OR fluvastatin[tiab] OR “pitavastatin” [Supplementary Concept] OR pitavastatin[tiab] OR “ezetimibe” [Supplementary Concept] OR Ezetimibe[tiab] OR “Niacin”[Mesh] OR niacin[tiab] OR “Fenofibrate”[Mesh] OR fenofibrate[tiab] OR “Fibric Acids”[Mesh] OR “fibric acid”[tiab] OR “fibric acids”[tiab] OR fibrates[tiab] OR fibrate[tiab] OR “Gemfibrozil”[Mesh] OR gemfibrozil[tiab] OR “Colestipol”[Mesh] OR “Cholestyramine Resin”[Mesh] OR Colestipol[tiab] OR Cholestyramine[tiab] OR “colesevelam” [Supplementary Concept] OR colesevelam[tiab]
#6 | “Nutrition Therapy”[Mesh] OR “Exercise”[Mesh] OR “Exercise Therapy”[Mesh] OR “Exercise Movement Techniques”[Mesh] OR “diet therapy”[mesh] OR exercise[tiab] OR “physical activity”[tiab] OR diet[tiab] OR diets[tiab] OR “weight management”[tiab] OR “Behavior Therapy”[Mesh] OR health education[mesh] OR health promotion[mesh] OR counsel*[tiab] OR counseling[mesh] OR “disease management”[mesh] OR “cognitive behavioral therapy”[tiab] OR “lifestyle modification”[tiab] OR (“life style”[mesh] AND modification[tiab]) OR “Patient Compliance”[Mesh] OR adher*[tiab] OR “self-monitoring”[tiab] OR “Recurrence/prevention and control”[Mesh] OR “relapse prevention”[tiab] OR “skills training”[tiab] OR “motivational interviewing”[tiab] OR educat*[tiab]
#7 | social support[mesh] OR family[tiab] OR peer[tiab]
#8 | Drug substitution[mesh] OR substitut*[tw] switch[tiab] OR switched[tiab] OR switching[tiab] OR change[tiab] OR changed[tiab] OR changing[tiab] OR replace[tiab] OR replaced[tiab] OR replacing[tiab] OR replacement[tiab] OR abandon*[tiab]
#9 | #5 OR #6 OR #7 OR #8
#10 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#11 | #4 AND #9 AND #10, Limits: English

Table A-4 PubMed search strings for KQ 4

Set # | Terms
#1 | Schizophrenia[tiab] OR schizophrenia[mesh] OR bipolar disorder[mesh:noexp] OR “bipolar disorder”[tiab] OR “psychotic disorders”[tiab] OR schizoaffective[tiab] OR mania[ti] OR manic[ti] OR “bipolar affective disorder”[tiab] OR “serious mental illness”[tiab] OR “severe mental illness”[tiab] OR “severe psychiatric illness”[tiab] OR (“depressive disorder”[mesh] AND psychotic[tiab]) OR “affective disorders, psychotic”[mesh] OR “psychotic disorders”[mesh]
#2 | “Cardiovascular Diseases”[Mesh] OR “Hyperlipidemias”[Mesh] OR hypertension[tiab] OR ((cardiovascular[tiab] OR heart[tiab] OR coronary[tiab]) AND (disease[tiab] OR diseases[tiab] OR risk[tiab]))
#3 | chlorpromazine[MeSH] OR chlorpromazine[tw] OR thorazine[tw] OR fluphenazine[MeSH] OR fluphenazine[tw] OR haloperidol[MeSH] OR haloperidol[tw] OR haldol[tw] OR iloperidone[Supplementary Concept] OR iloperidone[tw] OR fanapt[tw] OR loxapine[MeSH] OR loxapine[tw] OR loxitane[tw] OR molindone[MeSH] OR molindone[tw] OR moban[tw] OR chlorpromazine[MeSH] OR chlorpromazine[tw] OR thorazine[tw] OR perphenazine[MeSH] OR perphenazine[tw] OR pimozide[MeSH] OR pimozide[tw] OR orap[tw] OR thioridazine[MeSH] OR thioridazine[tw] OR thiothixene[MeSH] OR thiothixene[tw] OR navane[tw] OR trifluoperazine[MeSH] OR trifluoperazine[tw] OR stelazine[tw] OR clozapine[MeSH] OR clozapine[tw] OR clozaril[tw] OR risperidone[MeSH] OR risperidone[tw] OR risperidal[tw] OR olanzapine[Supplementary Concept] OR olanzapine[tw] OR zyprexa[tw] OR quetiapine[Supplementary Concept] OR quetiapine[tw] OR seroquel[tw] OR ziprasidone[Supplementary Concept] OR ziprasidone[tw] OR geodon[tw] OR aripiprazole[Supplementary Concept] OR aripiprazole[tw] OR abilify[tw] OR 9-hydroxy-risperidone[Supplementary Concept] OR “9-hydroxy-risperidone”[tw] OR paliperidone[tw] OR invega[tw] OR antipsychotic agents[mh] OR antipsychotic agents[pharmacological action] OR antipsychotic[tiab] OR antipsychotics[tiab]
#4 | #1 AND (#2 OR #3)
#5 | atorvastatin[Supplementary Concept] OR cholestyramine resin[MeSH] OR colesevelam[Supplementary Concept] colestipol[MeSH] OR ezetimibe[Supplementary Concept] OR fenofibrate[MeSH] OR fluvastatin[Supplementary Concept] OR lovastatin[MeSH] OR pitavastatin[Supplementary Concept] OR pravastatin[MeSH] OR rosuvastatin[Supplementary Concept] OR simvastatin[MeSH] OR acebutolol[Mesh] OR aliskiren[Supplementary Concept] OR amiloride[Mesh] OR amlodipine[Mesh] OR atenolol[Mesh] OR “2-ethoxy-1-((2′-(5-oxo-2,5-dihydro-1,2,4-oxadiazol-3-yl)-biphenyl-4-yl)methyl)-1H-benzimidazole-7-carboxylic acid”[Supplementary Concept] OR benazepril[Supplementary Concept] OR betaxolol[Mesh] OR bisoprolol[Mesh] OR candesartan[Supplementary Concept] OR carvedilol[Supplementary Concept] OR chlorothiazide[Mesh] OR chlorthalidone[Mesh] OR clonidine[Mesh] OR diltiazem[Mesh] OR irbesartan[Supplementary Concept] OR isradipine[Mesh] OR labetalol[Mesh] OR lisinopril[Mesh] OR losartan[Mesh] OR metolazone[Mesh] OR metoprolol[Mesh] OR moexipril[Supplementary Concept] OR nebivolol[Supplementary Concept] OR nicardipine[Mesh] OR nifedipine[Mesh] OR nisoldipine[Mesh] OR olmesartan[Supplementary Concept] OR penbutolol[Mesh] OR perindopril[Mesh] OR pindolol[Mesh] OR prazosin[Mesh] OR propranolol[Mesh] OR quinapril[Supplementary Concept] OR ramipril[Mesh] OR telmisartan[Supplementary Concept] OR torsemide[Supplementary Concept] OR trandolapril[Supplementary Concept] OR valsartan[Supplementary Concept] OR verapamil[Mesh] OR Lipitor[tiab] OR atorvastatin[tiab] OR Caduet[tiab] OR Prevalite[tiab] OR cholestyramine[tiab] OR Questran[tiab] OR WelChol[tiab] OR colesevelam[tiab] OR Colestid[tiab] OR colestipol[tiab] OR Zetia[tiab] OR ezetimibe[tiab] OR Tricor[tiab] OR fenofibrate[tiab] OR Lescol[tiab] OR fluvastatin[tiab] OR Mevacor[tiab] OR lovastatin[tiab] OR Livalo[tiab] OR pitavastatin[tiab] OR Pravachol[tiab] OR pravastatin[tiab] OR Crestor[tiab] OR rosuvastatin[tiab] OR Zocor[tiab] OR simvastatin[tiab] OR Sectral[tiab] OR Acebutolol[tiab] OR Tekturna[tiab] OR Aliskiren[tiab] OR Tekamlo[tiab] OR Valturna[tiab] OR Midimor[tiab] OR Amiloride[tiab] OR Norvasc[tiab] OR Amlodipine[tiab] OR Caduet[tiab] OR Lotrel[tiab] OR Tenormin[tiab] OR Atenolol[tiab] OR Tenoretic[tiab] OR Edarbi[tiab] OR Azilsartan[tiab] OR Lotensin[tiab] OR Benazepril[tiab] OR Kerlone[tiab] OR Betaxolol[tiab] OR Zebeta[tiab] OR Bisoprolol[tiab] OR Atacand[tiab] OR Candesartan[tiab] OR Coreg[tiab] OR Carvedilol[tiab] OR Diuril[tiab] OR Chlorothiazide[tiab] OR Thalitone[tiab] OR Chlorthalidone[tiab] OR Clorpres[tiab] OR Catapres[tiab] OR Clonidine[tiab] OR Cardizem[tiab] OR diltiazem[tiab] OR Cartia[tiab] OR Dilacor[tiab] OR Dilt[tiab] OR Diltia[tiab] OR Matzim[tiab] OR Taztia[tiab] OR Tiamate[tiab] OR Tiazac[tiab] OR Avapro[tiab] OR irbesartan[tiab] OR Dynacirc[tiab] OR isradipine[tiab] OR Trandate[tiab] OR labetalol[tiab] OR Prinivil[tiab] OR lisinopril[tiab] OR Zestril[tiab] OR Cozaar[tiab] OR losartan[tiab] OR Zaroxloyn[tiab] OR metolazone[tiab] OR Lopressor[tiab] OR metoprolol[tiab] OR Toprol[tiab] OR Univasc[tiab] OR moexipril[tiab] OR Corgard[tiab] OR nadalol[tiab] OR Bystolic[tiab] OR nebivolol[tiab] OR Cardene[tiab] OR nicardipine[tiab] OR Procardia[tiab] OR nifedipine[tiab] OR Sular[tiab] OR nisoldipine[tiab] OR Benicar[tiab] OR olmesartan[tiab] OR Levitol[tiab] OR penbutolol[tiab] OR Aceon[tiab] OR perindopril[tiab] OR Pindolol[tiab] OR pindolol[tiab] OR Minipress[tiab] OR prazosin[tiab] OR Inderal[tiab] OR propranolol[tiab] OR Accupril[tiab] OR quinapril[tiab] OR Altace[tiab] OR ramipril[tiab] OR Micardis[tiab] OR telmisartan[tiab] OR Demadex[tiab] OR torsemide[tiab] OR Mavik[tiab] OR trandolapril[tiab] OR Diovan[tiab] OR valsartan[tiab] OR Calan[tiab] OR verapamil[tiab] OR Covera[tiab] OR Isoptin[tiab] OR Verelan[tiab] OR “Antihypertensive Agents”[Mesh] OR “Antihypertensive Agents” [Pharmacological Action] OR “Hypolipidemic Agents”[Mesh] OR “Nicotinic Agonists”[Mesh] OR “Nicotinic Agonists” [Pharmacological Action] OR “Cardiovascular Agents”[Mesh] OR “Cardiovascular Agents” [Pharmacological Action] OR “Heparin”[Mesh] OR “Heparin, Low-Molecular-Weight”[Mesh] OR “Warfarin”[Mesh] OR heparin[tiab] OR warfarin[tiab] OR bupropion[tiab] OR “Bupropion”[Mesh]
#6 | Smoking cessation[mesh] OR smoking[tiab] OR tobacco[tiab] OR “Nutrition Therapy”[Mesh] OR “Exercise”[Mesh] OR “Exercise Therapy”[Mesh] OR “Exercise Movement Techniques”[Mesh] OR diet therapy[mesh] OR exercise[tiab] OR “physical activity”[tiab] OR diet[tiab] OR diets[tiab] OR “Behavior Therapy”[Mesh] OR health education[mesh] OR health promotion[mesh] OR counsel*[tiab] OR counseling[mesh] OR “disease management”[mesh] OR “cognitive behavioral therapy”[tiab] OR “lifestyle modification”[tiab] OR (“life style”[mesh] AND modification[tiab]) OR “Patient Compliance”[Mesh] OR adher*[tiab] OR “self-monitoring”[tiab] OR “Recurrence/prevention and control”[Mesh] OR “relapse prevention”[tiab] OR “skills training”[tiab] OR “motivational interviewing”[tiab] OR educat*[tiab]
#7 | social support[mesh] OR family[tiab] OR peer[tiab]
#8 | Drug substitution[mesh] OR substitut*[tw] switch[tiab] OR switched[tiab] OR switching[tiab] OR change[tiab] OR changed[tiab] OR changing[tiab] OR replace[tiab] OR replaced[tiab] OR replacing[tiab] OR replacement[tiab] OR abandon*[tiab]
#9 | #5 OR #6 OR #7 OR #8
#10 | (randomized controlled trial[pt] OR controlled clinical trial[pt] OR randomized[tiab] OR randomised[tiab] OR randomization[tiab] OR randomisation[tiab] OR placebo[tiab] OR randomly[tiab] OR trial[tiab] OR groups[tiab]) NOT (animals[mh] NOT humans[mh]) NOT (Editorial[ptyp] OR Letter[ptyp] OR Case Reports[ptyp] OR Comment[ptyp])
#11 | #4 AND #9 AND #10, Limits: English

## Embase^®^ Search Strategy (July 20, 2012)

Platform: Embase.com

Table A-5 Embase search strings for KQ 1

Set # | Terms
#1 | ‘schizophrenia’/exp OR ‘bipolar disorder’/exp OR ‘affective psychosis’/exp OR ‘depressive psychosis’/exp OR ‘manic depressive psychosis’/exp OR schizophrenia:ab,ti OR ‘bipolar disorder’:ab,ti OR ‘psychotic disorders’:ab,ti OR schizoaffective:ab,ti OR mania:ti OR manic:ti OR ‘bipolar affective disorder’:ab,ti OR ‘serious mental illness’:ab,ti OR ‘severe mental illness’:ab,ti OR ‘severe psychiatric illness’:ab,ti
#2 | ‘obesity’/exp OR ‘body weight’/exp OR ‘body mass’/exp OR overweight:ab,ti OR obesity:ab,ti OR obese:ab,ti OR weight:ab,ti OR “body mass index”:ab,ti OR bmi:ab,ti
#3 | ‘chlorpromazine’/exp OR chlorpromazine:ab,ti OR thorazine:ab,ti OR ‘fluphenazine’/exp OR fluphenazine:ab,ti OR ‘haloperidol’/exp OR haloperidol:ab,ti OR haldol:ab,ti OR ‘iloperidone’/exp OR iloperidone:ab,ti OR fanapt:ab,ti OR ‘loxapine’/exp OR loxapine:ab,ti OR loxitane:ab,ti OR ‘molindone’/exp OR molindone:ab,ti OR moban:ab,ti OR ‘chlorpromazine’/exp OR chlorpromazine:ab,ti OR thorazine:ab,ti OR ‘perphenazine’/exp OR perphenazine:ab,ti OR ‘pimozide’/exp OR pimozide:ab,ti OR orap:ab,ti OR ‘thioridazine’/exp OR thioridazine:ab,ti OR ‘tiotixene’/exp OR thiothixene:ab,ti OR navane:ab,ti OR ‘trifluoperazine’/exp OR trifluoperazine:ab,ti OR stelazine:ab,ti OR ‘clozapine’/exp OR clozapine:ab,ti OR clozaril:ab,ti OR ‘risperidone’/exp OR risperidone:ab,ti OR risperidal:ab,ti OR ‘olanzapine’/exp OR olanzapine:ab,ti OR zyprexa:ab,ti OR ‘quetiapine’/exp OR quetiapine:ab,ti OR seroquel:ab,ti OR ‘ziprasidone’/exp OR ziprasidone:ab,ti OR geodon:ab,ti OR ‘aripiprazole’/exp OR aripiprazole:ab,ti OR abilify:ab,ti OR “9-hydroxy-risperidone”:ab,ti OR paliperidone:ab,ti OR invega:ab,ti OR ‘neuroleptic agent’/exp OR antipsychotic:ab,ti OR antipsychotics:ab,ti
#4 | #1 AND (#2 OR #3)
#5 | ‘tetrahydrolipstatin’/exp OR orlistat:ab,ti OR ‘topiramate’/exp OR topiramate:ab,ti OR ‘metformin’/exp OR metformin:ab,ti OR ‘amantadine’/exp OR amantadine:ab,ti OR ‘anorexigenic agent’/exp OR ‘antiobesity agent’/exp
#6 | ‘diet therapy’/exp OR ‘exercise’/exp OR ‘kinesiotherapy’/exp OR ‘low calory diet’/exp OR exercise:ab,ti OR “physical activity”:ab,ti OR diet:ab,ti OR diets:ab,ti OR ‘weight reduction’/exp OR “weight management”:ab,ti OR ‘behavior therapy’/exp OR ‘cognitive therapy’/exp OR ‘health education’ OR counsel*:ab,ti OR ‘counseling’/exp OR ‘disease management’/exp OR ‘lifestyle modification’/exp OR “lifestyle modification”:ab,ti OR ‘patient compliance’/exp OR “cognitive behavioral therapy”:ab,ti OR adher*:ab,ti OR “self-monitoring”:ab,ti OR ‘recurrent disease’/exp/dm_pc OR “relapse prevention”:ab,ti OR “skills training”:ab,ti OR “motivational interviewing”:ab,ti OR educat*:ab,ti
#7 | ‘social support’/exp OR family:ab,ti OR peer:ab,ti
#8 | ‘drug substitution’/exp OR substitut*:ab,ti switch:ab,ti OR switched:ab,ti OR switching:ab,ti OR change:ab,ti OR changed:ab,ti OR changing:ab,ti OR replace:ab,ti OR replaced:ab,ti OR replacing:ab,ti OR replacement:ab,ti OR abandon*:ab,ti
#9 | #5 OR #6 OR #7 OR #8
#10 | ‘controlled clinical trial’/exp OR randomized:ab,ti OR randomised:ab,ti OR randomization:ab,ti OR randomisation:ab,ti OR placebo:ab,ti OR randomly:ab,ti OR trial:ab,ti OR groups:ab,ti NOT (‘case report’/exp OR ‘case study’/exp OR ‘editorial’/exp OR ‘letter’/exp OR ‘note’/exp)
#11 | #4 AND #9 AND #10
#12 | #11 AND [embase]/lim NOT [medline]/lim, Limits: English, Human

Table A-6 Embase search strings for KQ 2

Set # | Terms
#1 | 'schizophrenia'/exp OR 'bipolar disorder'/exp OR 'affective psychosis'/exp OR 'depressive psychosis'/exp OR 'manic depressive psychosis'/exp OR schizophrenia:ab,ti OR 'bipolar disorder':ab,ti OR 'psychotic disorders':ab,ti OR schizoaffective:ab,ti OR mania:ti OR manic:ti OR 'bipolar affective disorder':ab,ti OR 'serious mental illness':ab,ti OR 'severe mental illness':ab,ti OR 'severe psychiatric illness':ab,ti
#2 | 'diabetes mellitus'/exp OR diabetes:ab,ti
#3 | 'chlorpromazine'/exp OR chlorpromazine:ab,ti OR thorazine:ab,ti OR 'fluphenazine'/exp OR fluphenazine:ab,ti OR 'haloperidol'/exp OR haloperidol:ab,ti OR haldol:ab,ti OR 'iloperidone'/exp OR iloperidone:ab,ti OR fanapt:ab,ti OR 'loxapine'/exp OR loxapine:ab,ti OR loxitane:ab,ti OR 'molindone'/exp OR molindone:ab,ti OR moban:ab,ti OR 'chlorpromazine'/exp OR chlorpromazine:ab,ti OR thorazine:ab,ti OR 'perphenazine'/exp OR perphenazine:ab,ti OR 'pimozide'/exp OR pimozide:ab,ti OR orap:ab,ti OR 'thioridazine'/exp OR thioridazine:ab,ti OR 'tiotixene'/exp OR thiothixene:ab,ti OR navane:ab,ti OR 'trifluoperazine'/exp OR trifluoperazine:ab,ti OR stelazine:ab,ti OR 'clozapine'/exp OR clozapine:ab,ti OR clozaril:ab,ti OR 'risperidone'/exp OR risperidone:ab,ti OR risperidal:ab,ti OR 'olanzapine'/exp OR olanzapine:ab,ti OR zyprexa:ab,ti OR 'quetiapine'/exp OR quetiapine:ab,ti OR seroquel:ab,ti OR 'ziprasidone'/exp OR ziprasidone:ab,ti OR geodon:ab,ti OR 'aripiprazole'/exp OR aripiprazole:ab,ti OR abilify:ab,ti OR "9-hydroxy-risperidone":ab,ti OR paliperidone:ab,ti OR invega:ab,ti OR 'neuroleptic agent'/exp OR antipsychotic:ab,ti OR antipsychotics:ab,ti
#4 | #1 AND (#2 OR #3)
#5 | 'exendin 4'/exp OR Byetta:ab,ti OR exenatide:ab,ti OR 'pramlintide'/exp OR Symlin:ab,ti OR pramlintide:ab,ti OR 'sitagliptin'/exp OR Januvia:ab,ti OR sitagliptin:ab,ti OR 'insulin glargine'/exp OR Lantus:ab,ti OR “insulin glargine”:ab,ti OR 'saxagliptin'/exp OR Onglyza:ab,ti OR saxagliptin:ab,ti OR 'miglitol'/exp OR Glyset:ab,ti OR miglitol:ab,ti OR 'rosiglitazone'/exp OR Avandia:ab,ti OR rosiglitazone:ab,ti OR 'pioglitazone'/exp OR Actos:ab,ti OR pioglitazone:ab,ti OR 'repaglinide'/exp OR Prandin:ab,ti OR repaglinide:ab,ti OR 'nateglinide'/exp OR Starlix:ab,ti OR nateglinide:ab,ti OR 'glibenclamide'/exp OR Diabeta:ab,ti OR glyburide:ab,ti OR 'glimepiride'/exp OR Amaryl:ab,ti OR glimepiride:ab,ti OR 'metformin'/exp OR Glumetza:ab,ti OR metformin:ab,ti OR Riomet:ab,ti OR Fortamet:ab,ti OR 'linagliptin'/exp OR Tradjenta:ab,ti OR linagliptin:ab,ti OR 'liraglutide'/exp OR Victoza:ab,ti OR liraglutide:ab,ti OR 'colesevelam'/exp OR WelChol:ab,ti OR colesevelam:ab,ti OR 'bromocriptine'/exp OR Cycloset:ab,ti OR bromocriptine:ab,ti OR Parlodel:ab,ti OR 'antidiabetic agent'/exp
#6 | 'diabetes mellitus'/exp/dm_dm OR “diabetes management”:ab,ti OR 'diet therapy'/exp OR 'exercise'/exp OR 'kinesiotherapy'/exp OR 'low calory diet'/exp OR exercise:ab,ti OR "physical activity":ab,ti OR diet:ab,ti OR diets:ab,ti OR 'weight reduction'/exp OR “weight management”:ab,ti OR 'behavior therapy'/exp OR 'cognitive therapy'/exp OR 'health education' OR counsel*:ab,ti OR 'counseling'/exp OR 'disease management'/exp OR 'lifestyle modification'/exp OR “lifestyle modification”:ab,ti OR 'patient compliance'/exp OR “cognitive behavioral therapy”:ab,ti OR adher*:ab,ti OR “self-monitoring”:ab,ti OR 'recurrent disease'/exp/dm_pc OR “relapse prevention”:ab,ti OR “skills training”:ab,ti OR “motivational interviewing”:ab,ti OR educat*:ab,ti
#7 | 'social support'/exp OR family:ab,ti OR peer:ab,ti
#8 | 'drug substitution'/exp OR substitut*:ab,ti switch:ab,ti OR switched:ab,ti OR switching:ab,ti OR change:ab,ti OR changed:ab,ti OR changing:ab,ti OR replace:ab,ti OR replaced:ab,ti OR replacing:ab,ti OR replacement:ab,ti OR abandon*:ab,ti
#9 | #5 OR #6 OR #7 OR #8
#10 | 'controlled clinical trial'/exp OR randomized:ab,ti OR randomised:ab,ti OR randomization:ab,ti OR randomisation:ab,ti OR placebo:ab,ti OR randomly:ab,ti OR trial:ab,ti OR groups:ab,ti NOT ('case report'/exp OR 'case study'/exp OR 'editorial'/exp OR 'letter'/exp OR 'note'/exp)
#11 | #4 AND #9 AND #10
#12 | #11 AND [embase]/lim NOT [medline]/lim, Limits: English, Human

Table A-7 Embase search strings for KQ 3

Set # | Terms
#1 | 'schizophrenia'/exp OR 'bipolar disorder'/exp OR 'affective psychosis'/exp OR 'depressive psychosis'/exp OR 'manic depressive psychosis'/exp OR schizophrenia:ab,ti OR 'bipolar disorder':ab,ti OR 'psychotic disorders':ab,ti OR schizoaffective:ab,ti OR mania:ti OR manic:ti OR 'bipolar affective disorder':ab,ti OR 'serious mental illness':ab,ti OR 'severe mental illness':ab,ti OR 'severe psychiatric illness':ab,ti
#2 | 'dyslipidemia'/exp OR 'hyperlipidemia'/exp OR dyslipidemia:ab,ti OR dyslipidemias:ab,ti OR hyperlipidemia:ab,ti OR hyperlipidemias:ab,ti
#3 | 'chlorpromazine'/exp OR chlorpromazine:ab,ti OR thorazine:ab,ti OR 'fluphenazine'/exp OR fluphenazine:ab,ti OR 'haloperidol'/exp OR haloperidol:ab,ti OR haldol:ab,ti OR 'iloperidone'/exp OR iloperidone:ab,ti OR fanapt:ab,ti OR 'loxapine'/exp OR loxapine:ab,ti OR loxitane:ab,ti OR 'molindone'/exp OR molindone:ab,ti OR moban:ab,ti OR 'chlorpromazine'/exp OR chlorpromazine:ab,ti OR thorazine:ab,ti OR 'perphenazine'/exp OR perphenazine:ab,ti OR 'pimozide'/exp OR pimozide:ab,ti OR orap:ab,ti OR 'thioridazine'/exp OR thioridazine:ab,ti OR 'tiotixene'/exp OR thiothixene:ab,ti OR navane:ab,ti OR 'trifluoperazine'/exp OR trifluoperazine:ab,ti OR stelazine:ab,ti OR 'clozapine'/exp OR clozapine:ab,ti OR clozaril:ab,ti OR 'risperidone'/exp OR risperidone:ab,ti OR risperidal:ab,ti OR 'olanzapine'/exp OR olanzapine:ab,ti OR zyprexa:ab,ti OR 'quetiapine'/exp OR quetiapine:ab,ti OR seroquel:ab,ti OR 'ziprasidone'/exp OR ziprasidone:ab,ti OR geodon:ab,ti OR 'aripiprazole'/exp OR aripiprazole:ab,ti OR abilify:ab,ti OR "9-hydroxy-risperidone":ab,ti OR paliperidone:ab,ti OR invega:ab,ti OR 'neuroleptic agent'/exp OR antipsychotic:ab,ti OR antipsychotics:ab,ti
#4 | #1 AND (#2 OR #3)
#5 | 'antilipemic agent'/exp OR 'hydroxymethylglutaryl coenzyme A reductase inhibitor'/exp OR statins:ab,ti OR statin:ab,ti OR 'simvastatin'/exp OR simvastatin:ab,ti OR 'mevinolin'/exp OR lovastatin:ab,ti OR 'atorvastatin'/exp OR atorvastatin:ab,ti OR 'pravastatin'/exp OR pravastatin:ab,ti OR 'fluindostatin'/exp OR fluvastatin:ab,ti OR 'pitavastatin'/exp OR pitavastatin:ab,ti OR 'ezetimibe'/exp OR Ezetimibe:ab,ti OR 'nicotinic acid'/exp OR niacin:ab,ti OR 'fenofibrate'/exp OR fenofibrate:ab,ti OR 'fibric acid derivative'/exp OR "fibric acid":ab,ti OR "fibric acids":ab,ti OR fibrates:ab,ti OR fibrate:ab,ti OR 'gemfibrozil'/exp OR gemfibrozil:ab,ti OR 'colestipol'/exp OR 'colestyramine'/exp OR Colestipol:ab,ti OR Cholestyramine:ab,ti OR 'colesevelam'/exp OR colesevelam:ab,ti
#6 | 'diet therapy'/exp OR 'exercise'/exp OR 'kinesiotherapy'/exp OR 'low calory diet'/exp OR exercise:ab,ti OR "physical activity":ab,ti OR diet:ab,ti OR diets:ab,ti OR 'weight reduction'/exp OR “weight management”:ab,ti OR 'behavior therapy'/exp OR 'cognitive therapy'/exp OR 'health education' OR counsel*:ab,ti OR 'counseling'/exp OR 'disease management'/exp OR 'lifestyle modification'/exp OR “lifestyle modification”:ab,ti OR 'patient compliance'/exp OR “cognitive behavioral therapy”:ab,ti OR adher*:ab,ti OR “self-monitoring”:ab,ti OR 'recurrent disease'/exp/dm_pc OR “relapse prevention”:ab,ti OR “skills training”:ab,ti OR “motivational interviewing”:ab,ti OR educat*:ab,ti
#7 | 'social support'/exp OR family:ab,ti OR peer:ab,ti
#8 | 'drug substitution'/exp OR substitut*:ab,ti switch:ab,ti OR switched:ab,ti OR switching:ab,ti OR change:ab,ti OR changed:ab,ti OR changing:ab,ti OR replace:ab,ti OR replaced:ab,ti OR replacing:ab,ti OR replacement:ab,ti OR abandon*:ab,ti
#9 | #5 OR #6 OR #7 OR #8
#10 | 'controlled clinical trial'/exp OR randomized:ab,ti OR randomised:ab,ti OR randomization:ab,ti OR randomisation:ab,ti OR placebo:ab,ti OR randomly:ab,ti OR trial:ab,ti OR groups:ab,ti NOT ('case report'/exp OR 'case study'/exp OR 'editorial'/exp OR 'letter'/exp OR 'note'/exp)
#11 | #4 AND #9 AND #10
#12 | #11 AND [embase]/lim NOT [medline]/lim, Limits: English, Human

Table A-8 Embase search strings for KQ 4

Set # | Terms
#1 | 'schizophrenia'/exp OR 'bipolar disorder'/exp OR 'affective psychosis'/exp OR 'depressive psychosis'/exp OR 'manic depressive psychosis'/exp OR schizophrenia:ab,ti OR 'bipolar disorder':ab,ti OR 'psychotic disorders':ab,ti OR schizoaffective:ab,ti OR mania:ti OR manic:ti OR 'bipolar affective disorder':ab,ti OR 'serious mental illness':ab,ti OR 'severe mental illness':ab,ti OR 'severe psychiatric illness':ab,ti
#2 | 'cardiovascular disease'/exp AND 'hypertension'/exp OR 'hyperlipidemia'/exp OR hypertension:ab,ti OR ((cardiovascular:ab,ti OR heart:ab,ti OR coronary:ab,ti) AND (disease:ab,ti OR diseases:ab,ti OR risk:ab,ti))
#3 | 'chlorpromazine'/exp OR chlorpromazine:ab,ti OR thorazine:ab,ti OR 'fluphenazine'/exp OR fluphenazine:ab,ti OR 'haloperidol'/exp OR haloperidol:ab,ti OR haldol:ab,ti OR 'iloperidone'/exp OR iloperidone:ab,ti OR fanapt:ab,ti OR 'loxapine'/exp OR loxapine:ab,ti OR loxitane:ab,ti OR 'molindone'/exp OR molindone:ab,ti OR moban:ab,ti OR 'chlorpromazine'/exp OR chlorpromazine:ab,ti OR thorazine:ab,ti OR 'perphenazine'/exp OR perphenazine:ab,ti OR 'pimozide'/exp OR pimozide:ab,ti OR orap:ab,ti OR 'thioridazine'/exp OR thioridazine:ab,ti OR 'tiotixene'/exp OR thiothixene:ab,ti OR navane:ab,ti OR 'trifluoperazine'/exp OR trifluoperazine:ab,ti OR stelazine:ab,ti OR 'clozapine'/exp OR clozapine:ab,ti OR clozaril:ab,ti OR 'risperidone'/exp OR risperidone:ab,ti OR risperidal:ab,ti OR 'olanzapine'/exp OR olanzapine:ab,ti OR zyprexa:ab,ti OR 'quetiapine'/exp OR quetiapine:ab,ti OR seroquel:ab,ti OR 'ziprasidone'/exp OR ziprasidone:ab,ti OR geodon:ab,ti OR 'aripiprazole'/exp OR aripiprazole:ab,ti OR abilify:ab,ti OR "9-hydroxy-risperidone":ab,ti OR paliperidone:ab,ti OR invega:ab,ti OR 'neuroleptic agent'/exp OR antipsychotic:ab,ti OR antipsychotics:ab,ti
#4 | #1 AND (#2 OR #3)
#5 | 'cardiovascular agent'/exp OR 'antilipemic agent'/exp OR 'nicotinic agent'/exp OR 'heparin'/exp OR 'warfarin'/exp OR 'low molecular weight heparin'/exp OR 'amfebutamone'/exp OR 'atorvastatin'/exp OR 'simvastatin'/exp OR 'pitavastatin'/exp OR 'rosuvastatin'/exp OR 'pravastatin'/exp OR 'colestyramine'/exp OR 'colesevelam'/exp OR 'colestipol'/exp OR 'ezetimibe'/exp OR 'fenofibrate'/exp OR 'fluindostatin'/exp OR 'mevinolin'/exp OR 'acebutolol'/exp OR 'aliskiren'/exp OR 'amiloride'/exp OR 'amlodipine'/exp OR 'atenolol'/exp OR 'azilsartan'/exp OR 'benazepril'/exp OR 'betaxolol'/exp OR 'bisoprolol'/exp OR 'candesartan'/exp OR 'carvedilol'/exp OR 'chlorothiazide'/exp OR 'chlortalidone'/exp OR 'clonidine'/exp OR 'diltiazem'/exp OR 'irbesartan'/exp OR 'isradipine'/exp OR 'labetalol'/exp OR 'lisinopril'/exp OR 'losartan'/exp OR 'metolazone'/exp OR 'metoprolol'/exp OR 'moexipril'/exp OR 'nebivolol'/exp OR 'nicardipine'/exp OR 'nifedipine'/exp OR 'nisoldipine'/exp OR 'olmesartan'/exp OR 'penbutolol'/exp OR 'perindopril'/exp OR 'pindolol'/exp OR 'prazosin'/exp OR 'propranolol'/exp OR 'quinapril'/exp OR 'ramipril'/exp OR 'telmisartan'/exp OR 'torasemide'/exp OR 'trandolapril'/exp OR 'valsartan'/exp OR 'verapamil'/exp OR Lipitor:ab,ti OR atorvastatin:ab,ti OR Caduet:ab,ti OR Prevalite:ab,ti OR cholestyramine:ab,ti OR Questran:ab,ti OR WelChol:ab,ti OR colesevelam:ab,ti OR Colestid:ab,ti OR colestipol:ab,ti OR Zetia:ab,ti OR ezetimibe:ab,ti OR Tricor:ab,ti OR fenofibrate:ab,ti OR Lescol:ab,ti OR fluvastatin:ab,ti OR Mevacor:ab,ti OR lovastatin:ab,ti OR Livalo:ab,ti OR pitavastatin:ab,ti OR Pravachol:ab,ti OR pravastatin:ab,ti OR Crestor:ab,ti OR rosuvastatin:ab,ti OR Zocor:ab,ti OR simvastatin:ab,ti OR Sectral:ab,ti OR Acebutolol:ab,ti OR Tekturna:ab,ti OR Aliskiren:ab,ti OR Tekamlo:ab,ti OR Valturna:ab,ti OR Midimor:ab,ti OR Amiloride:ab,ti OR Norvasc:ab,ti OR Amlodipine:ab,ti OR Caduet:ab,ti OR Lotrel:ab,ti OR Tenormin:ab,ti OR Atenolol:ab,ti OR Tenoretic:ab,ti OR Edarbi:ab,ti OR Azilsartan:ab,ti OR Lotensin:ab,ti OR Benazepril:ab,ti OR Kerlone:ab,ti OR Betaxolol:ab,ti OR Zebeta:ab,ti OR Bisoprolol:ab,ti OR Atacand:ab,ti OR Candesartan:ab,ti OR Coreg:ab,ti OR Carvedilol:ab,ti OR Diuril:ab,ti OR Chlorothiazide:ab,ti OR Thalitone:ab,ti OR Chlorthalidone:ab,ti OR Clorpres:ab,ti OR Catapres:ab,ti OR Clonidine:ab,ti OR Cardizem:ab,ti OR diltiazem:ab,ti OR Cartia:ab,ti OR Dilacor:ab,ti OR Dilt:ab,ti OR Diltia:ab,ti OR Matzim:ab,ti OR Taztia:ab,ti OR Tiamate:ab,ti OR Tiazac:ab,ti OR Avapro:ab,ti OR irbesartan:ab,ti OR Dynacirc:ab,ti OR isradipine:ab,ti OR Trandate:ab,ti OR labetalol:ab,ti OR Prinivil:ab,ti OR lisinopril:ab,ti OR Zestril:ab,ti OR Cozaar:ab,ti OR losartan:ab,ti OR Zaroxloyn:ab,ti OR metolazone:ab,ti OR Lopressor:ab,ti OR metoprolol:ab,ti OR Toprol:ab,ti OR Univasc:ab,ti OR moexipril:ab,ti OR Corgard:ab,ti OR nadalol:ab,ti OR Bystolic:ab,ti OR nebivolol:ab,ti OR Cardene:ab,ti OR nicardipine:ab,ti OR Procardia:ab,ti OR nifedipine:ab,ti OR Sular:ab,ti OR nisoldipine:ab,ti OR Benicar:ab,ti OR olmesartan:ab,ti OR Levitol:ab,ti OR penbutolol:ab,ti OR Aceon:ab,ti OR perindopril:ab,ti OR Pindolol:ab,ti OR pindolol:ab,ti OR Minipress:ab,ti OR prazosin:ab,ti OR Inderal:ab,ti OR propranolol:ab,ti OR Accupril:ab,ti OR quinapril:ab,ti OR Altace:ab,ti OR ramipril:ab,ti OR Micardis:ab,ti OR telmisartan:ab,ti OR Demadex:ab,ti OR torsemide:ab,ti OR Mavik:ab,ti OR trandolapril:ab,ti OR Diovan:ab,ti OR valsartan:ab,ti OR Calan:ab,ti OR verapamil:ab,ti OR Covera:ab,ti OR Isoptin:ab,ti OR Verelan:ab,ti OR heparin:ab,ti OR warfarin:ab,ti OR bupropion:ab,ti
#6 | 'smoking cessation'/exp OR 'smoking cessation program'/exp OR smoking:ab,ti OR tobacco:ab,ti OR 'diet therapy'/exp OR 'exercise'/exp OR 'kinesiotherapy'/exp OR 'low calory diet'/exp OR exercise:ab,ti OR "physical activity":ab,ti OR diet:ab,ti OR diets:ab,ti OR 'weight reduction'/exp OR “weight management”:ab,ti OR 'behavior therapy'/exp OR 'cognitive therapy'/exp OR 'health education' OR counsel*:ab,ti OR 'counseling'/exp OR 'disease management'/exp OR 'lifestyle modification'/exp OR “lifestyle modification”:ab,ti OR 'patient compliance'/exp OR “cognitive behavioral therapy”:ab,ti OR adher*:ab,ti OR “self-monitoring”:ab,ti OR 'recurrent disease'/exp/dm_pc OR “relapse prevention”:ab,ti OR “skills training”:ab,ti OR “motivational interviewing”:ab,ti OR educat*:ab,ti
#7 | 'social support'/exp OR family:ab,ti OR peer:ab,ti
#8 | 'drug substitution'/exp OR substitut*:ab,ti switch:ab,ti OR switched:ab,ti OR switching:ab,ti OR change:ab,ti OR changed:ab,ti OR changing:ab,ti OR replace:ab,ti OR replaced:ab,ti OR replacing:ab,ti OR replacement:ab,ti OR abandon*:ab,ti
#9 | #5 OR #6 OR #7 OR #8
#10 | 'controlled clinical trial'/exp OR randomized:ab,ti OR randomised:ab,ti OR randomization:ab,ti OR randomisation:ab,ti OR placebo:ab,ti OR randomly:ab,ti OR trial:ab,ti OR groups:ab,ti NOT ('case report'/exp OR 'case study'/exp OR 'editorial'/exp OR 'letter'/exp OR 'note'/exp)
#11 | #4 AND #9 AND #10
#12 | #11 AND [embase]/lim NOT [medline]/lim, Limits: English, Human

## Cochrane Search Strategy (July 20, 2012)

Platform: Wiley

Database searched: Cochrane Database of Systematic Reviews (CDSR)

Table A-9 CDSR search strings for KQ 1

Set # | Terms
#1 | [underlined: MeSH descriptor Affective Disorders, Psychotic explode all trees] OR MeSH descriptor Schizophrenia and Disorders with Psychotic Features explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=2) OR Schizophrenia:ti,ab OR schizoaffective:ti,ab OR mania:ti OR manic:ti OR "bipolar affective disorder":ti,ab OR "serious mental illness":ti,ab OR “severe mental illness”:ti,ab OR “severe psychiatric illness”:ti,ab OR (“depressive disorder”:kw AND psychotic:ti,ab)
#2 | MeSH descriptor Body Weights and Measures explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=5) OR overweight:ti,ab OR obesity:ti,ab OR obese:ti,ab OR weight:ti,ab OR "body mass index":ti,ab,kw OR bmi:ti,ab,kw
#3 | MeSH descriptor Antipsychotic Agents explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=8) OR chlorpromazine:ti,ab,kw OR thorazine:ti,ab,kw OR fluphenazine:ti,ab,kw OR haloperidol:ti,ab,kw OR haldol:ti,ab,kw OR iloperidone:ti,ab,kw OR fanapt:ti,ab,kw OR loxapine:ti,ab,kw OR loxitane:ti,ab,kw OR molindone:ti,ab,kw OR moban:ti,ab,kw OR OR chlorpromazine:ti,ab,kw OR thorazine:ti,ab,kw OR perphenazine:ti,ab,kw OR pimozide:ti,ab,kw OR orap:ti,ab,kw OR thioridazine:ti,ab,kw OR thiothixene:ti,ab,kw OR navane:ti,ab,kw OR trifluoperazine:ti,ab,kw OR stelazine:ti,ab,kw OR clozapine:ti,ab,kw OR clozaril:ti,ab,kw OR risperidone:ti,ab,kw OR risperidal:ti,ab,kw OR olanzapine:ti,ab,kw OR zyprexa:ti,ab,kw OR quetiapine:ti,ab,kw OR seroquel:ti,ab,kw OR ziprasidone:ti,ab,kw OR geodon:ti,ab,kw OR OR aripiprazole:ti,ab,kw OR abilify:ti,ab,kw OR "9-hydroxy-risperidone":ti,ab,kw OR paliperidone:ti,ab,kw OR invega:ti,ab,kw OR antipsychotic:ti,ab,kw OR antipsychotics:ti,ab,kw
#4 | #1 AND (#2 OR #3)
#5 | MeSH descriptor Appetite Depressants explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=12) OR MeSH descriptor Anti-Obesity Agents explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=13) OR orlistat:ti,ab,kw OR OR topiramate:ti,ab,kw OR metformin:ti,ab,kw OR OR amantadine:ti,ab,kw
#6 | MeSH descriptor Nutrition Therapy explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=16) OR 7 MeSH descriptor Exercise explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=17) OR MeSH descriptor Exercise Therapy explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=18) OR MeSH descriptor Exercise Movement Techniques explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=19) OR MeSH descriptor Recurrence explode all trees with qualifier: PC (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=20) OR MeSH descriptor Behavior Therapy explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=21) OR MeSH descriptor Disease Management explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=22) OR MeSH descriptor Patient Compliance explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=23) OR MeSH descriptor Life Style explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=24) OR MeSH descriptor Counseling explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=25) OR exercise:ti,ab OR "physical activity":ti,ab OR diet:ti,ab OR diets:ti,ab OR “weight management”:ti,ab OR health education[mesh] OR health promotion[mesh] OR counsel*:ti,ab OR “cognitive behavioral therapy”:ti,ab OR “lifestyle modification”:ti,ab OR adher*:ti,ab OR “self-monitoring”:ti,ab OR “relapse prevention”:ti,ab OR “skills training”:ti,ab OR “motivational interviewing”:ti,ab OR educat*:ti,ab
#7 | MeSH descriptor Social Support explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=28) OR family:ti,ab OR peer:ti,ab
#8 | [underlined: MeSH descriptor Drug Substitution explode all trees] OR substitut*:ti,ab OR switch:ti,ab OR switched:ti,ab OR switching:ti,ab OR change:ti,ab OR changed:ti,ab OR changing:ti,ab OR replace:ti,ab OR replaced:ti,ab OR replacing:ti,ab OR replacement:ti,ab OR abandon*:ti,ab
#9 | #5 OR #6 OR #7 OR #8,
#10 | #4 AND #9

Table A-10 CDSR search strings for KQ 2

Set # | Terms
#1 | [underlined: MeSH descriptor Affective Disorders, Psychotic explode all trees] OR MeSH descriptor Schizophrenia and Disorders with Psychotic Features explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=2) OR Schizophrenia:ti,ab OR schizoaffective:ti,ab OR mania:ti OR manic:ti OR "bipolar affective disorder":ti,ab OR "serious mental illness":ti,ab OR “severe mental illness”:ti,ab OR “severe psychiatric illness”:ti,ab OR (“depressive disorder”:kw AND psychotic:ti,ab)
#2 | Diabetes mellitus[mesh] OR diabetes:ti,ab
#3 | MeSH descriptor Antipsychotic Agents explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=8) OR chlorpromazine:ti,ab,kw OR thorazine:ti,ab,kw OR fluphenazine:ti,ab,kw OR haloperidol:ti,ab,kw OR haldol:ti,ab,kw OR iloperidone:ti,ab,kw OR fanapt:ti,ab,kw OR loxapine:ti,ab,kw OR loxitane:ti,ab,kw OR molindone:ti,ab,kw OR moban:ti,ab,kw OR OR chlorpromazine:ti,ab,kw OR thorazine:ti,ab,kw OR perphenazine:ti,ab,kw OR pimozide:ti,ab,kw OR orap:ti,ab,kw OR thioridazine:ti,ab,kw OR thiothixene:ti,ab,kw OR navane:ti,ab,kw OR trifluoperazine:ti,ab,kw OR stelazine:ti,ab,kw OR clozapine:ti,ab,kw OR clozaril:ti,ab,kw OR risperidone:ti,ab,kw OR risperidal:ti,ab,kw OR olanzapine:ti,ab,kw OR zyprexa:ti,ab,kw OR quetiapine:ti,ab,kw OR seroquel:ti,ab,kw OR ziprasidone:ti,ab,kw OR geodon:ti,ab,kw OR OR aripiprazole:ti,ab,kw OR abilify:ti,ab,kw OR "9-hydroxy-risperidone":ti,ab,kw OR paliperidone:ti,ab,kw OR invega:ti,ab,kw OR antipsychotic:ti,ab,kw OR antipsychotics:ti,ab,kw
#4 | #1 AND (#2 OR #3)
#5 | MeSH descriptor Hypoglycemic Agents explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=40) OR Byetta:ti,ab,kw OR exenatide:ti,ab,kw OR Symlin:ti,ab,kw OR pramlintide:ti,ab,kw OR Januvia:ti,ab,kw OR sitagliptin:ti,ab,kw OR Lantus:ti,ab,kw OR “insulin glargine”:ti,ab,kw OR Onglyza:ti,ab,kw OR saxagliptin:ti,ab,kw OR Glyset:ti,ab,kw OR miglitol:ti,ab,kw OR Avandia:ti,ab,kw OR rosiglitazone:ti,ab,kw OR Actos:ti,ab,kw OR pioglitazone:ti,ab,kw OR Prandin:ti,ab,kw OR repaglinide:ti,ab,kw OR Starlix:ti,ab,kw OR nateglinide:ti,ab,kw OR Diabeta:ti,ab,kw OR glyburide:ti,ab,kw OR Amaryl:ti,ab,kw OR glimepiride:ti,ab,kw OR Glumetza:ti,ab,kw OR metformin:ti,ab,kw OR Riomet:ti,ab,kw OR Fortamet:ti,ab,kw OR Tradjenta:ti,ab,kw OR linagliptin:ti,ab,kw OR Victoza:ti,ab,kw OR liraglutide:ti,ab,kw OR WelChol:ti,ab,kw OR colesevelam:ti,ab,kw OR Cycloset:ti,ab,kw OR bromocriptine:ti,ab,kw OR Parlodel:ti,ab,kw
#6 | MeSH descriptor Diabetes Mellitus explode all trees with qualifier: PC (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=43) OR MeSH descriptor Recurrence explode all trees with qualifier: PC (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=20) OR MeSH descriptor Behavior Therapy explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=21) OR MeSH descriptor Disease Management explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=22) OR MeSH descriptor Patient Compliance explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=23) OR MeSH descriptor Life Style explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=24) OR MeSH descriptor Counseling explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=25) OR “diabetes management”:ti,ab OR counsel*:ti,ab OR “cognitive behavioral therapy”:ti,ab OR “lifestyle modification”:ti,ab OR adher*:ti,ab OR “self-monitoring”:ti,ab OR “relapse prevention”:ti,ab OR “skills training”:ti,ab OR “motivational interviewing”:ti,ab OR educat*:ti,ab
#7 | MeSH descriptor Social Support explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=28) OR family:ti,ab OR peer:ti,ab
#8 | MeSH descriptor Drug Substitution explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=30) OR substitut*:ti,ab OR switch:ti,ab OR switched:ti,ab OR switching:ti,ab OR change:ti,ab OR changed:ti,ab OR changing:ti,ab OR replace:ti,ab OR replaced:ti,ab OR replacing:ti,ab OR replacement:ti,ab OR abandon*:ti,ab
#9 | #5 OR #6 OR #7 OR #8
#10 | #4 AND #9

Table A-11 CDSR search strings for KQ 3

Set # | Terms
#1 | MeSH descriptor Affective Disorders, Psychotic explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=1) OR MeSH descriptor Schizophrenia and Disorders with Psychotic Features explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=2) OR Schizophrenia:ti,ab OR schizoaffective:ti,ab OR mania:ti OR manic:ti OR "bipolar affective disorder":ti,ab OR "serious mental illness":ti,ab OR “severe mental illness”:ti,ab OR “severe psychiatric illness”:ti,ab OR (“depressive disorder”:kw AND psychotic:ti,ab)
#2 | MeSH descriptor Dyslipidemias explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=48) OR MeSH descriptor Hyperlipidemias explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=49) OR dyslipidemia:ti,ab OR dyslipidemias:ti,ab OR hyperlipidemia:ti,ab OR hyperlipidemias:ti,ab
#3 | MeSH descriptor Antipsychotic Agents explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=8) OR chlorpromazine:ti,ab,kw OR thorazine:ti,ab,kw OR fluphenazine:ti,ab,kw OR haloperidol:ti,ab,kw OR haldol:ti,ab,kw OR iloperidone:ti,ab,kw OR fanapt:ti,ab,kw OR loxapine:ti,ab,kw OR loxitane:ti,ab,kw OR molindone:ti,ab,kw OR moban:ti,ab,kw OR OR chlorpromazine:ti,ab,kw OR thorazine:ti,ab,kw OR perphenazine:ti,ab,kw OR pimozide:ti,ab,kw OR orap:ti,ab,kw OR thioridazine:ti,ab,kw OR thiothixene:ti,ab,kw OR navane:ti,ab,kw OR trifluoperazine:ti,ab,kw OR stelazine:ti,ab,kw OR clozapine:ti,ab,kw OR clozaril:ti,ab,kw OR risperidone:ti,ab,kw OR risperidal:ti,ab,kw OR olanzapine:ti,ab,kw OR zyprexa:ti,ab,kw OR quetiapine:ti,ab,kw OR seroquel:ti,ab,kw OR ziprasidone:ti,ab,kw OR geodon:ti,ab,kw OR OR aripiprazole:ti,ab,kw OR abilify:ti,ab,kw OR "9-hydroxy-risperidone":ti,ab,kw OR paliperidone:ti,ab,kw OR invega:ti,ab,kw OR antipsychotic:ti,ab,kw OR antipsychotics:ti,ab,kw
#4 | #1 AND (#2 OR #3)
#5 | MeSH descriptor Hypolipidemic Agents explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=53) OR MeSH descriptor Hydroxymethylglutaryl-CoA Reductase Inhibitors explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=54) OR MeSH descriptor Fibric Acids explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=55) OR statins:ti,ab,kw OR statin:ti,ab,kw OR simvastatin:ti,ab,kw OR lovastatin:ti,ab,kw OR atorvastatin:ti,ab,kw OR pravastatin:ti,ab,kw OR fluvastatin:ti,ab,kw OR pitavastatin:ti,ab,kw OR Ezetimibe:ti,ab,kw OR niacin:ti,ab,kw OR fenofibrate:ti,ab,kw OR "fibric acid":ti,ab,kw OR "fibric acids":ti,ab,kw OR fibrates:ti,ab,kw OR fibrate:ti,ab,kw OR gemfibrozil:ti,ab,kw] OR Colestipol:ti,ab,kw OR Cholestyramine:ti,ab,kw OR colesevelam:ti,ab,kw
#6 | MeSH descriptor Nutrition Therapy explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=16) OR 7 MeSH descriptor Exercise explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=17) OR MeSH descriptor Exercise Therapy explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=18) OR MeSH descriptor Exercise Movement Techniques explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=19) OR MeSH descriptor Recurrence explode all trees with qualifier: PC (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=20) OR MeSH descriptor Behavior Therapy explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=21) OR MeSH descriptor Disease Management explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=22) OR MeSH descriptor Patient Compliance explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=23) OR MeSH descriptor Life Style explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=24) OR MeSH descriptor Counseling explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=25) OR exercise:ti,ab OR "physical activity":ti,ab OR diet:ti,ab OR diets:ti,ab OR “weight management”:ti,ab OR health education[mesh] OR health promotion[mesh] OR counsel*:ti,ab OR “cognitive behavioral therapy”:ti,ab OR “lifestyle modification”:ti,ab OR adher*:ti,ab OR “self-monitoring”:ti,ab OR “relapse prevention”:ti,ab OR “skills training”:ti,ab OR “motivational interviewing”:ti,ab OR educat*:ti,ab
#7 | MeSH descriptor Social Support explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=28) OR family:ti,ab OR peer:ti,ab
#8 | MeSH descriptor Drug Substitution explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=30) OR substitut*:ti,ab OR switch:ti,ab OR switched:ti,ab OR switching:ti,ab OR change:ti,ab OR changed:ti,ab OR changing:ti,ab OR replace:ti,ab OR replaced:ti,ab OR replacing:ti,ab OR replacement:ti,ab OR abandon*:ti,ab
#9 | #5 OR #6 OR #7 OR #8
#10 | #4 AND #9

Table A-12 CDSR search strings for KQ 4

Set # | Terms
#1 | MeSH descriptor Affective Disorders, Psychotic explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=1) OR MeSH descriptor Schizophrenia and Disorders with Psychotic Features explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=2) OR Schizophrenia:ti,ab OR schizoaffective:ti,ab OR mania:ti OR manic:ti OR "bipolar affective disorder":ti,ab OR "serious mental illness":ti,ab OR “severe mental illness”:ti,ab OR “severe psychiatric illness”:ti,ab OR (“depressive disorder”:kw AND psychotic:ti,ab)
#2 | MeSH descriptor Cardiovascular Diseases explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=60) OR MeSH descriptor Hyperlipidemias explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=61) OR hypertension:ti,ab OR ((cardiovascular:ti,ab OR heart:ti,ab OR coronary:ti,ab) AND (disease:ti,ab OR diseases:ti,ab OR risk:ti,ab))
#3 | MeSH descriptor Antipsychotic Agents explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=8) OR chlorpromazine:ti,ab,kw OR thorazine:ti,ab,kw OR fluphenazine:ti,ab,kw OR haloperidol:ti,ab,kw OR haldol:ti,ab,kw OR iloperidone:ti,ab,kw OR fanapt:ti,ab,kw OR loxapine:ti,ab,kw OR loxitane:ti,ab,kw OR molindone:ti,ab,kw OR moban:ti,ab,kw OR OR chlorpromazine:ti,ab,kw OR thorazine:ti,ab,kw OR perphenazine:ti,ab,kw OR pimozide:ti,ab,kw OR orap:ti,ab,kw OR thioridazine:ti,ab,kw OR thiothixene:ti,ab,kw OR navane:ti,ab,kw OR trifluoperazine:ti,ab,kw OR stelazine:ti,ab,kw OR clozapine:ti,ab,kw OR clozaril:ti,ab,kw OR risperidone:ti,ab,kw OR risperidal:ti,ab,kw OR olanzapine:ti,ab,kw OR zyprexa:ti,ab,kw OR quetiapine:ti,ab,kw OR seroquel:ti,ab,kw OR ziprasidone:ti,ab,kw OR geodon:ti,ab,kw OR OR aripiprazole:ti,ab,kw OR abilify:ti,ab,kw OR "9-hydroxy-risperidone":ti,ab,kw OR paliperidone:ti,ab,kw OR invega:ti,ab,kw OR antipsychotic:ti,ab,kw OR antipsychotics:ti,ab,kw
#4 | #1 AND (#2 OR #3)
#5 | MeSH descriptor Antihypertensive Agents explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=65) OR MeSH descriptor Hypolipidemic Agents explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=66) OR MeSH descriptor Nicotinic Agonists explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=67) OR MeSH descriptor Cardiovascular Agents explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=68) OR Lipitor:ti,ab,kw OR atorvastatin:ti,ab,kw OR Caduet:ti,ab,kw OR Prevalite:ti,ab,kw OR cholestyramine:ti,ab,kw OR Questran:ti,ab,kw OR WelChol:ti,ab,kw OR colesevelam:ti,ab,kw OR Colestid:ti,ab,kw OR colestipol:ti,ab,kw OR Zetia:ti,ab,kw OR ezetimibe:ti,ab,kw OR Tricor:ti,ab,kw OR fenofibrate:ti,ab,kw OR Lescol:ti,ab,kw OR fluvastatin:ti,ab,kw OR Mevacor:ti,ab,kw OR lovastatin:ti,ab,kw OR Livalo:ti,ab,kw OR pitavastatin:ti,ab,kw OR Pravachol:ti,ab,kw OR pravastatin:ti,ab,kw OR Crestor:ti,ab,kw OR rosuvastatin:ti,ab,kw OR Zocor:ti,ab,kw OR simvastatin:ti,ab,kw OR Sectral:ti,ab,kw OR Acebutolol:ti,ab,kw OR Tekturna:ti,ab,kw OR Aliskiren:ti,ab,kw OR Tekamlo:ti,ab,kw OR Valturna:ti,ab,kw OR Midimor:ti,ab,kw OR Amiloride:ti,ab,kw OR Norvasc:ti,ab,kw OR Amlodipine:ti,ab,kw OR Caduet:ti,ab,kw OR Lotrel:ti,ab,kw OR Tenormin:ti,ab,kw OR Atenolol:ti,ab,kw OR Tenoretic:ti,ab,kw OR Edarbi:ti,ab,kw OR Azilsartan:ti,ab,kw OR Lotensin:ti,ab,kw OR Benazepril:ti,ab,kw OR Kerlone:ti,ab,kw OR Betaxolol:ti,ab,kw OR Zebeta:ti,ab,kw OR Bisoprolol:ti,ab,kw OR Atacand:ti,ab,kw OR Candesartan:ti,ab,kw OR Coreg:ti,ab,kw OR Carvedilol:ti,ab,kw OR Diuril:ti,ab,kw OR Chlorothiazide:ti,ab,kw OR Thalitone:ti,ab,kw OR Chlorthalidone:ti,ab,kw OR Clorpres:ti,ab,kw OR Catapres:ti,ab,kw OR Clonidine:ti,ab,kw OR Cardizem:ti,ab,kw OR diltiazem:ti,ab,kw OR Cartia:ti,ab,kw OR Dilacor:ti,ab,kw OR Dilt:ti,ab,kw OR Diltia:ti,ab,kw OR Matzim:ti,ab,kw OR Taztia:ti,ab,kw OR Tiamate:ti,ab,kw OR Tiazac:ti,ab,kw OR Avapro:ti,ab,kw OR irbesartan:ti,ab,kw OR Dynacirc:ti,ab,kw OR isradipine:ti,ab,kw OR Trandate:ti,ab,kw OR labetalol:ti,ab,kw OR Prinivil:ti,ab,kw OR lisinopril:ti,ab,kw OR Zestril:ti,ab,kw OR Cozaar:ti,ab,kw OR losartan:ti,ab,kw OR Zaroxloyn:ti,ab,kw OR metolazone:ti,ab,kw OR Lopressor:ti,ab,kw OR metoprolol:ti,ab,kw OR Toprol:ti,ab,kw OR Univasc:ti,ab,kw OR moexipril:ti,ab,kw OR Corgard:ti,ab,kw OR nadalol:ti,ab,kw OR Bystolic:ti,ab,kw OR nebivolol:ti,ab,kw OR Cardene:ti,ab,kw OR nicardipine:ti,ab,kw OR Procardia:ti,ab,kw OR nifedipine:ti,ab,kw OR Sular:ti,ab,kw OR nisoldipine:ti,ab,kw OR Benicar:ti,ab,kw OR olmesartan:ti,ab,kw OR Levitol:ti,ab,kw OR penbutolol:ti,ab,kw OR Aceon:ti,ab,kw OR perindopril:ti,ab,kw OR Pindolol:ti,ab,kw OR pindolol:ti,ab,kw OR Minipress:ti,ab,kw OR prazosin:ti,ab,kw OR Inderal:ti,ab,kw OR propranolol:ti,ab,kw OR Accupril:ti,ab,kw OR quinapril:ti,ab,kw OR Altace:ti,ab,kw OR ramipril:ti,ab,kw OR Micardis:ti,ab,kw OR telmisartan:ti,ab,kw OR Demadex:ti,ab,kw OR torsemide:ti,ab,kw OR Mavik:ti,ab,kw OR trandolapril:ti,ab,kw OR Diovan:ti,ab,kw OR valsartan:ti,ab,kw OR Calan:ti,ab,kw OR verapamil:ti,ab,kw OR Covera:ti,ab,kw OR Isoptin:ti,ab,kw OR Verelan:ti,ab,kw OR heparin:ti,ab,kw OR warfarin:ti,ab,kw OR bupropion:ti,ab,kw
#6 | MeSH descriptor Smoking Cessation explode all trees MeSH descriptor Nutrition Therapy explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=72) OR 7 MeSH descriptor Exercise explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=17) OR MeSH descriptor Exercise Therapy explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=18) OR MeSH descriptor Exercise Movement Techniques explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=19) OR MeSH descriptor Recurrence explode all trees with qualifier: PC (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=20) OR MeSH descriptor Behavior Therapy explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=21) OR MeSH descriptor Disease Management explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=22) OR MeSH descriptor Patient Compliance explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=23) OR MeSH descriptor Life Style explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=24) OR MeSH descriptor Counseling explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=25) OR exercise:ti,ab OR "physical activity":ti,ab OR diet:ti,ab OR diets:ti,ab OR “weight management”:ti,ab OR health education[mesh] OR health promotion[mesh] OR counsel*:ti,ab OR “cognitive behavioral therapy”:ti,ab OR “lifestyle modification”:ti,ab OR adher*:ti,ab OR “self-monitoring”:ti,ab OR “relapse prevention”:ti,ab OR “skills training”:ti,ab OR “motivational interviewing”:ti,ab OR educat*:ti,ab OR smoking:ti,ab OR tobacco:ti,ab
#7 | MeSH descriptor Social Support explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=28) OR family:ti,ab OR peer:ti,ab
#8 | MeSH descriptor Drug Substitution explode all trees (http://onlinelibrary.wiley.com/o/cochrane/searchHistory?mode=runquery&qnum=30) OR substitut*:ti,ab OR switch:ti,ab OR switched:ti,ab OR switching:ti,ab OR change:ti,ab OR changed:ti,ab OR changing:ti,ab OR replace:ti,ab OR replaced:ti,ab OR replacing:ti,ab OR replacement:ti,ab OR abandon*:ti,ab
#9 | #5 OR #6 OR #7 OR #8
#11 | #4 AND #9

## PsycINFO^®^ Search Strategy (July 20, 2012)

Table A-13 PsycINFO search strings for KQ 1

Set # | Terms
#1 | (((DE "Schizophrenia" OR DE "Acute Schizophrenia" OR DE "Catatonic Schizophrenia" OR DE "Childhood Schizophrenia" OR DE "Paranoid Schizophrenia" OR DE "Process Schizophrenia" OR DE "Schizophrenia (Disorganized Type)" OR DE "Schizophreniform Disorder" OR DE "Undifferentiated Schizophrenia") OR (DE "Bipolar Disorder" OR DE "Cyclothymic Personality")) OR (DE "Schizoaffective Disorder")) OR (DE "Psychosis") OR ( DE "Major Depression" OR DE "Anaclitic Depression" OR DE "Dysthymic Disorder" OR DE "Endogenous Depression" OR DE "Postpartum Depression" OR DE "Reactive Depression" OR DE "Recurrent Depression" OR DE "Treatment Resistant Depression" ) AND ( (TI psychotic OR AB psychotic) ) OR TI (mania OR manic OR Schizophrenia OR "bipolar disorder" OR “psychotic disorders” OR schizoaffective OR "bipolar affective disorder" OR "serious mental illness" OR “severe mental illness” OR “severe psychiatric illness”) OR AB (Schizophrenia OR "bipolar disorder" OR “psychotic disorders” OR schizoaffective OR "bipolar affective disorder" OR "serious mental illness" OR “severe mental illness” OR “severe psychiatric illness”)
#2 | DE "Body Weight" OR DE "Birth Weight" OR DE "Overweight" OR DE "Underweight" OR DE "Weight Gain" OR DE "Weight Loss" OR TI (overweight OR obesity OR obese OR weight OR "body mass index" OR bmi) OR AB (overweight OR obesity OR obese OR weight OR "body mass index" OR bmi)
#3 | DE "Chlorpromazine" OR DE "Fluphenazine" OR DE "Haloperidol" OR DE "Loxapine" OR DE "Molindone" OR DE "Perphenazine" OR DE "Pimozide" OR DE "Thioridazine" OR DE "Thiothixene" OR DE "Trifluoperazine" OR DE "Clozapine" OR DE "Risperidone" OR DE "Olanzapine" OR DE "Quetiapine" OR DE "Aripiprazole" OR DE "Neuroleptic Drugs" OR DE "Aripiprazole" OR DE "Clozapine" OR DE "Molindone" OR DE "Nialamide" OR DE "Olanzapine" OR DE "Quetiapine" OR DE "Reserpine" OR DE "Risperidone" OR DE "Spiroperidol" OR DE "Sulpiride" OR DE "Tetrabenazine" OR TI (chlorpromazine OR thorazine OR fluphenazine OR haloperidol OR haldol OR iloperidone OR fanapt OR loxapine OR loxitane OR molindone OR moban OR chlorpromazine OR thorazine OR perphenazine OR pimozide OR orap OR thioridazine OR thiothixene OR navane OR trifluoperazine OR stelazine OR clozapine OR clozaril OR risperidone OR risperidal OR olanzapine OR zyprexa OR quetiapine OR seroquel OR ziprasidone OR geodon OR aripiprazole OR abilify OR "9-hydroxy-risperidone" OR paliperidone OR invega OR antipsychotic OR antipsychotics) OR AB (chlorpromazine OR thorazine OR fluphenazine OR haloperidol OR haldol OR iloperidone OR fanapt OR loxapine OR loxitane OR molindone OR moban OR chlorpromazine OR thorazine OR perphenazine OR pimozide OR orap OR thioridazine OR thiothixene OR navane OR trifluoperazine OR stelazine OR clozapine OR clozaril OR risperidone OR risperidal OR olanzapine OR zyprexa OR quetiapine OR seroquel OR ziprasidone OR geodon OR aripiprazole OR abilify OR "9-hydroxy-risperidone" OR paliperidone OR invega OR antipsychotic OR antipsychotics)
#4 | #1 AND (#2 OR #3)
#5 | (DE "Amantadine") OR (DE "Appetite Depressing Drugs" OR DE "Amphetamine" OR DE "Dextroamphetamine" OR DE "Fenfluramine" OR DE "Phenmetrazine") OR TI (orlistat OR topiramate OR metformin OR amantadine OR (Appetite AND (drugs OR drug)) OR ((antiobesity OR anti-obesity) AND (drugs OR drug))) OR AB (orlistat OR topiramate OR metformin OR amantadine OR (Appetite AND (drugs OR drug)) OR ((antiobesity OR anti-obesity) AND (drugs OR drug)))
#6 | DE "Diets" OR DE "Aerobic Exercise" OR DE "Weightlifting" OR DE "Yoga" OR DE "Movement Therapy" OR DE "Physical Activity" OR DE "Exercise" OR DE "Behavior Therapy" OR DE "Aversion Therapy" OR DE "Conversion Therapy" OR DE "Dialectical Behavior Therapy" OR DE "Exposure Therapy" OR DE "Implosive Therapy" OR DE "Reciprocal Inhibition Therapy" OR DE "Response Cost" OR DE "Systematic Desensitization Therapy" OR DE "Cognitive Behavior Therapy" OR DE "Acceptance and Commitment Therapy" OR DE "Health Education" OR DE "Drug Education" OR DE "Sex Education" AND DE "Counseling" OR DE "Educational Counseling" OR DE "Group Counseling" OR DE "Microcounseling" OR DE "Peer Counseling" OR DE "Psychotherapeutic Counseling" OR DE "Family Therapy" OR DE "Disease Management" OR DE "Lifestyle Changes" OR DE "Treatment Compliance" OR DE "Relapse Prevention" OR DE "Motivational Interviewing" OR DE "Self Monitoring" OR DE "Weight Loss" OR TI (exercise OR "physical activity" OR diet OR diets OR “weight management” OR counsel* OR “cognitive behavioral therapy” OR “lifestyle modification” OR adher* OR “self-monitoring” OR “relapse prevention” OR “skills training” OR “motivational interviewing” OR educat*) OR AB (exercise OR "physical activity" OR diet OR diets OR “weight management” OR counsel* OR “cognitive behavioral therapy” OR “lifestyle modification” OR adher* OR “self-monitoring” OR “relapse prevention” OR “skills training” OR “motivational interviewing” OR educat*)
#7 | DE "Social Support" OR TI (family OR peer) OR AB (family OR peer)
#8 | TI ( substitut* OR switch OR switched OR switching OR change OR changed OR changing OR replace OR replaced OR replacing OR replacement OR abandon* ) AND AB ( substitut* OR switch OR switched OR switching OR change OR changed OR changing OR replace OR replaced OR replacing OR replacement OR abandon* )
#9 | #8 AND #3
#10 | #5 OR #6 OR #7 OR #9
#11 | #4 AND #10 Limiters - English; Methodology: TREATMENT OUTCOME/CLINICAL TRIAL

Table A-14 PsycINFO search strings for KQ 2

Set # | Terms
#1 | (((DE “Schizophrenia” OR DE “Acute Schizophrenia” OR DE “Catatonic Schizophrenia” OR DE “Childhood Schizophrenia” OR DE “Paranoid Schizophrenia” OR DE “Process Schizophrenia” OR DE “Schizophrenia (Disorganized Type)” OR DE “Schizophreniform Disorder” OR DE “Undifferentiated Schizophrenia”) OR (DE “Bipolar Disorder” OR DE “Cyclothymic Personality”)) OR (DE “Schizoaffective Disorder”)) OR (DE “Psychosis”) OR ( DE “Major Depression” OR DE “Anaclitic Depression” OR DE “Dysthymic Disorder” OR DE “Endogenous Depression” OR DE “Postpartum Depression” OR DE “Reactive Depression” OR DE “Recurrent Depression” OR DE “Treatment Resistant Depression” ) AND ( (TI psychotic OR AB psychotic) ) OR TI (mania OR manic OR Schizophrenia OR “bipolar disorder” OR “psychotic disorders” OR schizoaffective OR “bipolar affective disorder” OR “serious mental illness” OR “severe mental illness” OR “severe psychiatric illness”) OR AB (Schizophrenia OR “bipolar disorder” OR “psychotic disorders” OR schizoaffective OR “bipolar affective disorder” OR “serious mental illness” OR “severe mental illness” OR “severe psychiatric illness”)
#2 | DE “Diabetes Mellitus” OR TI diabetes OR AB diabetes
#3 | DE “Chlorpromazine” OR DE “Fluphenazine” OR DE “Haloperidol” OR DE “Loxapine” OR DE “Molindone” OR DE “Perphenazine” OR DE “Pimozide” OR DE “Thioridazine” OR DE “Thiothixene” OR DE “Trifluoperazine” OR DE “Clozapine” OR DE “Risperidone” OR DE “Olanzapine” OR DE “Quetiapine” OR DE “Aripiprazole” OR DE “Neuroleptic Drugs” OR DE “Aripiprazole” OR DE “Clozapine” OR DE “Molindone” OR DE “Nialamide” OR DE “Olanzapine” OR DE “Quetiapine” OR DE “Reserpine” OR DE “Risperidone” OR DE “Spiroperidol” OR DE “Sulpiride” OR DE “Tetrabenazine” OR TI (chlorpromazine OR thorazine OR fluphenazine OR haloperidol OR haldol OR iloperidone OR fanapt OR loxapine OR loxitane OR molindone OR moban OR chlorpromazine OR thorazine OR perphenazine OR pimozide OR orap OR thioridazine OR thiothixene OR navane OR trifluoperazine OR stelazine OR clozapine OR clozaril OR risperidone OR risperidal OR olanzapine OR zyprexa OR quetiapine OR seroquel OR ziprasidone OR geodon OR aripiprazole OR abilify OR “9-hydroxy-risperidone” OR paliperidone OR invega OR antipsychotic OR antipsychotics) OR AB (chlorpromazine OR thorazine OR fluphenazine OR haloperidol OR haldol OR iloperidone OR fanapt OR loxapine OR loxitane OR molindone OR moban OR chlorpromazine OR thorazine OR perphenazine OR pimozide OR orap OR thioridazine OR thiothixene OR navane OR trifluoperazine OR stelazine OR clozapine OR clozaril OR risperidone OR risperidal OR olanzapine OR zyprexa OR quetiapine OR seroquel OR ziprasidone OR geodon OR aripiprazole OR abilify OR “9-hydroxy-risperidone” OR paliperidone OR invega OR antipsychotic OR antipsychotics)
#4 | #1 AND (#2 OR #3)
#5 | TI ( Byetta OR exenatide OR pramlintide OR Symlin OR Januvia OR sitagliptin OR glargine OR Lantus OR Onglyza OR saxagliptin OR miglitol OR Glyset OR Avandia OR rosiglitazone OR Actos OR pioglitazone OR Prandin OR repaglinide OR Starlix OR nateglinide OR glyburide OR Diabeta OR glyburide OR glimepiride OR Amaryl OR metformin OR Glumetza OR Riomet OR Fortamet OR Tradjenta OR linagliptin OR Victoza OR liraglutide OR colesevelam OR WelChol OR Cycloset OR bromocriptine OR Parlodel OR Hypoglycemic ) OR AB ( Byetta OR exenatide OR pramlintide OR Symlin OR Januvia OR sitagliptin OR glargine OR Lantus OR Onglyza OR saxagliptin OR miglitol OR Glyset OR Avandia OR rosiglitazone OR Actos OR pioglitazone OR Prandin OR repaglinide OR Starlix OR nateglinide OR glyburide OR Diabeta OR glyburide OR glimepiride OR Amaryl OR metformin OR Glumetza OR Riomet OR Fortamet OR Tradjenta OR linagliptin OR Victoza OR liraglutide OR colesevelam OR WelChol OR Cycloset OR bromocriptine OR Parlodel OR Hypoglycemic )
#6 | TI diabetes management OR AB diabetes management OR DE “Behavior Therapy” OR DE “Aversion Therapy” OR DE “Conversion Therapy” OR DE “Dialectical Behavior Therapy” OR DE “Exposure Therapy” OR DE “Implosive Therapy” OR DE “Reciprocal Inhibition Therapy” OR DE “Response Cost” OR DE “Systematic Desensitization Therapy” OR DE “Cognitive Behavior Therapy” OR DE “Acceptance and Commitment Therapy” OR DE “Health Education” OR DE “Drug Education” OR DE “Sex Education” AND DE “Counseling” OR DE “Educational Counseling” OR DE “Group Counseling” OR DE “Microcounseling” OR DE “Peer Counseling” OR DE “Psychotherapeutic Counseling” OR DE “Family Therapy” OR DE “Disease Management” OR DE “Lifestyle Changes” OR DE “Treatment Compliance” OR DE “Relapse Prevention” OR DE “Motivational Interviewing” OR DE “Self Monitoring” OR DE “Weight Loss” OR TI (counsel* OR “cognitive behavioral therapy” OR “lifestyle modification” OR adher* OR “self-monitoring” OR “relapse prevention” OR “skills training” OR “motivational interviewing” OR educat*) OR AB (counsel* OR “cognitive behavioral therapy” OR “lifestyle modification” OR adher* OR “self-monitoring” OR “relapse prevention” OR “skills training” OR “motivational interviewing” OR educat*)
#7 | DE “Social Support” OR TI (family OR peer) OR AB (family OR peer)
#8 | TI ( substitut* OR switch OR switched OR switching OR change OR changed OR changing OR replace OR replaced OR replacing OR replacement OR abandon* ) AND AB ( substitut* OR switch OR switched OR switching OR change OR changed OR changing OR replace OR replaced OR replacing OR replacement OR abandon* )
#9 | #8 AND #3
#10 | #5 OR #6 OR #7 OR #9
#11 | #4 AND #10 Limiters - English; Methodology: TREATMENT OUTCOME/CLINICAL TRIAL

Table A-15 PsycINFO search strings for KQ 3

Set # | Terms
#1 | (((DE “Schizophrenia” OR DE “Acute Schizophrenia” OR DE “Catatonic Schizophrenia” OR DE “Childhood Schizophrenia” OR DE “Paranoid Schizophrenia” OR DE “Process Schizophrenia” OR DE “Schizophrenia (Disorganized Type)” OR DE “Schizophreniform Disorder” OR DE “Undifferentiated Schizophrenia”) OR (DE “Bipolar Disorder” OR DE “Cyclothymic Personality”)) OR (DE “Schizoaffective Disorder”)) OR (DE “Psychosis”) OR ( DE “Major Depression” OR DE “Anaclitic Depression” OR DE “Dysthymic Disorder” OR DE “Endogenous Depression” OR DE “Postpartum Depression” OR DE “Reactive Depression” OR DE “Recurrent Depression” OR DE “Treatment Resistant Depression” ) AND ( (TI psychotic OR AB psychotic) ) OR TI (mania OR manic OR Schizophrenia OR “bipolar disorder” OR “psychotic disorders” OR schizoaffective OR “bipolar affective disorder” OR “serious mental illness” OR “severe mental illness” OR “severe psychiatric illness”) OR AB (Schizophrenia OR “bipolar disorder” OR “psychotic disorders” OR schizoaffective OR “bipolar affective disorder” OR “serious mental illness” OR “severe mental illness” OR “severe psychiatric illness”)
#2 | TI (Dyslipidemias OR Hyperlipidemias OR dyslipidemia OR hyperlipidemia) OR AB (Dyslipidemias OR Hyperlipidemias OR dyslipidemia OR hyperlipidemia)
#3 | DE “Chlorpromazine” OR DE “Fluphenazine” OR DE “Haloperidol” OR DE “Loxapine” OR DE “Molindone” OR DE “Perphenazine” OR DE “Pimozide” OR DE “Thioridazine” OR DE “Thiothixene” OR DE “Trifluoperazine” OR DE “Clozapine” OR DE “Risperidone” OR DE “Olanzapine” OR DE “Quetiapine” OR DE “Aripiprazole” OR DE “Neuroleptic Drugs” OR DE “Aripiprazole” OR DE “Clozapine” OR DE “Molindone” OR DE “Nialamide” OR DE “Olanzapine” OR DE “Quetiapine” OR DE “Reserpine” OR DE “Risperidone” OR DE “Spiroperidol” OR DE “Sulpiride” OR DE “Tetrabenazine” OR TI (chlorpromazine OR thorazine OR fluphenazine OR haloperidol OR haldol OR iloperidone OR fanapt OR loxapine OR loxitane OR molindone OR moban OR chlorpromazine OR thorazine OR perphenazine OR pimozide OR orap OR thioridazine OR thiothixene OR navane OR trifluoperazine OR stelazine OR clozapine OR clozaril OR risperidone OR risperidal OR olanzapine OR zyprexa OR quetiapine OR seroquel OR ziprasidone OR geodon OR aripiprazole OR abilify OR “9-hydroxy-risperidone” OR paliperidone OR invega OR antipsychotic OR antipsychotics) OR AB (chlorpromazine OR thorazine OR fluphenazine OR haloperidol OR haldol OR iloperidone OR fanapt OR loxapine OR loxitane OR molindone OR moban OR chlorpromazine OR thorazine OR perphenazine OR pimozide OR orap OR thioridazine OR thiothixene OR navane OR trifluoperazine OR stelazine OR clozapine OR clozaril OR risperidone OR risperidal OR olanzapine OR zyprexa OR quetiapine OR seroquel OR ziprasidone OR geodon OR aripiprazole OR abilify OR “9-hydroxy-risperidone” OR paliperidone OR invega OR antipsychotic OR antipsychotics)
#4 | #1 AND (#2 OR #3)
#5 | TI ( Hypolipidemic OR Hydroxymethylglutaryl-CoA Reductase Inhibitors OR statins OR statin OR simvastatin OR lovastatin OR atorvastatin OR pravastatin OR fluvastatin OR pitavastatin OR Ezetimibe OR niacin OR fenofibrate OR Fibric Acids OR fibric acid OR fibrates OR fibrate OR gemfibrozil OR Colestipol OR Cholestyramine Resin OR Cholestyramine OR colesevelam ) OR AB ( Hypolipidemic OR Hydroxymethylglutaryl-CoA Reductase Inhibitors OR statins OR statin OR simvastatin OR lovastatin OR atorvastatin OR pravastatin OR fluvastatin OR pitavastatin OR Ezetimibe OR niacin OR fenofibrate OR Fibric Acids OR fibric acid OR fibrates OR fibrate OR gemfibrozil OR Colestipol OR Cholestyramine Resin OR Cholestyramine OR colesevelam ) OR KW ( Hypolipidemic OR Hydroxymethylglutaryl-CoA Reductase Inhibitors OR statins OR statin OR simvastatin OR lovastatin OR atorvastatin OR pravastatin OR fluvastatin OR pitavastatin OR Ezetimibe OR niacin OR fenofibrate OR Fibric Acids OR fibric acid OR fibrates OR fibrate OR gemfibrozil OR Colestipol OR Cholestyramine Resin OR Cholestyramine OR colesevelam )
#6 | DE “Diets” OR DE “Aerobic Exercise” OR DE “Weightlifting” OR DE “Yoga” OR DE “Movement Therapy” OR DE “Physical Activity” OR DE “Exercise” OR DE “Behavior Therapy” OR DE “Aversion Therapy” OR DE “Conversion Therapy” OR DE “Dialectical Behavior Therapy” OR DE “Exposure Therapy” OR DE “Implosive Therapy” OR DE “Reciprocal Inhibition Therapy” OR DE “Response Cost” OR DE “Systematic Desensitization Therapy” OR DE “Cognitive Behavior Therapy” OR DE “Acceptance and Commitment Therapy” OR DE “Health Education” OR DE “Drug Education” OR DE “Sex Education” AND DE “Counseling” OR DE “Educational Counseling” OR DE “Group Counseling” OR DE “Microcounseling” OR DE “Peer Counseling” OR DE “Psychotherapeutic Counseling” OR DE “Family Therapy” OR DE “Disease Management” OR DE “Lifestyle Changes” OR DE “Treatment Compliance” OR DE “Relapse Prevention” OR DE “Motivational Interviewing” OR DE “Self Monitoring” OR DE “Weight Loss” OR TI (exercise OR “physical activity” OR diet OR diets OR “weight management” OR counsel* OR “cognitive behavioral therapy” OR “lifestyle modification” OR adher* OR “self-monitoring” OR “relapse prevention” OR “skills training” OR “motivational interviewing” OR educat*) OR AB (exercise OR “physical activity” OR diet OR diets OR “weight management” OR counsel* OR “cognitive behavioral therapy” OR “lifestyle modification” OR adher* OR “self-monitoring” OR “relapse prevention” OR “skills training” OR “motivational interviewing” OR educat*)
#7 | DE “Social Support” OR TI (family OR peer) OR AB (family OR peer)
#8 | TI ( substitut* OR switch OR switched OR switching OR change OR changed OR changing OR replace OR replaced OR replacing OR replacement OR abandon* ) AND AB ( substitut* OR switch OR switched OR switching OR change OR changed OR changing OR replace OR replaced OR replacing OR replacement OR abandon* )
#9 | #8 AND #3
#10 | #5 OR #6 OR #7 OR #9
#11 | #4 AND #10 Limiters - English; Methodology: TREATMENT OUTCOME/CLINICAL TRIAL

Table A-16 PsycINFO search strings for KQ 4

Set # | Terms
#1 | (((DE “Schizophrenia” OR DE “Acute Schizophrenia” OR DE “Catatonic Schizophrenia” OR DE “Childhood Schizophrenia” OR DE “Paranoid Schizophrenia” OR DE “Process Schizophrenia” OR DE “Schizophrenia (Disorganized Type)” OR DE “Schizophreniform Disorder” OR DE “Undifferentiated Schizophrenia”) OR (DE “Bipolar Disorder” OR DE “Cyclothymic Personality”)) OR (DE “Schizoaffective Disorder”)) OR (DE “Psychosis”) OR ( DE “Major Depression” OR DE “Anaclitic Depression” OR DE “Dysthymic Disorder” OR DE “Endogenous Depression” OR DE “Postpartum Depression” OR DE “Reactive Depression” OR DE “Recurrent Depression” OR DE “Treatment Resistant Depression” ) AND ( (TI psychotic OR AB psychotic) ) OR TI (mania OR manic OR Schizophrenia OR “bipolar disorder” OR “psychotic disorders” OR schizoaffective OR “bipolar affective disorder” OR “serious mental illness” OR “severe mental illness” OR “severe psychiatric illness”) OR AB (Schizophrenia OR “bipolar disorder” OR “psychotic disorders” OR schizoaffective OR “bipolar affective disorder” OR “serious mental illness” OR “severe mental illness” OR “severe psychiatric illness”)
#2 | DE “Cardiovascular Disorders” OR DE “Aneurysms” OR DE “Arteriosclerosis” OR DE “Blood Pressure Disorders” OR DE “Cerebrovascular Disorders” OR DE “Embolisms” OR DE “Heart Disorders” OR DE “Hemorrhage” OR DE “Hypertension” OR DE “Ischemia” OR DE “Thromboses” OR TI (hypertension OR ((cardiovascular OR heart OR coronary) AND (disease OR diseases OR risk))) OR AB (hypertension OR ((cardiovascular OR heart OR coronary) AND (disease OR diseases OR risk)))
#3 | DE “Chlorpromazine” OR DE “Fluphenazine” OR DE “Haloperidol” OR DE “Loxapine” OR DE “Molindone” OR DE “Perphenazine” OR DE “Pimozide” OR DE “Thioridazine” OR DE “Thiothixene” OR DE “Trifluoperazine” OR DE “Clozapine” OR DE “Risperidone” OR DE “Olanzapine” OR DE “Quetiapine” OR DE “Aripiprazole” OR DE “Neuroleptic Drugs” OR DE “Aripiprazole” OR DE “Clozapine” OR DE “Molindone” OR DE “Nialamide” OR DE “Olanzapine” OR DE “Quetiapine” OR DE “Reserpine” OR DE “Risperidone” OR DE “Spiroperidol” OR DE “Sulpiride” OR DE “Tetrabenazine” OR TI (chlorpromazine OR thorazine OR fluphenazine OR haloperidol OR haldol OR iloperidone OR fanapt OR loxapine OR loxitane OR molindone OR moban OR chlorpromazine OR thorazine OR perphenazine OR pimozide OR orap OR thioridazine OR thiothixene OR navane OR trifluoperazine OR stelazine OR clozapine OR clozaril OR risperidone OR risperidal OR olanzapine OR zyprexa OR quetiapine OR seroquel OR ziprasidone OR geodon OR aripiprazole OR abilify OR “9-hydroxy-risperidone” OR paliperidone OR invega OR antipsychotic OR antipsychotics) OR AB (chlorpromazine OR thorazine OR fluphenazine OR haloperidol OR haldol OR iloperidone OR fanapt OR loxapine OR loxitane OR molindone OR moban OR chlorpromazine OR thorazine OR perphenazine OR pimozide OR orap OR thioridazine OR thiothixene OR navane OR trifluoperazine OR stelazine OR clozapine OR clozaril OR risperidone OR risperidal OR olanzapine OR zyprexa OR quetiapine OR seroquel OR ziprasidone OR geodon OR aripiprazole OR abilify OR “9-hydroxy-risperidone” OR paliperidone OR invega OR antipsychotic OR antipsychotics)
#4 | #1 AND (#2 OR #3)
#5 | TI ( Lipitor OR atorvastatin OR Caduet OR Prevalite OR cholestyramine OR Questran OR WelChol OR colesevelam OR Colestid OR colestipol OR Zetia OR ezetimibe OR Tricor OR fenofibrate OR Lescol OR fluvastatin OR Mevacor OR lovastatin OR Livalo OR pitavastatin OR Pravachol OR pravastatin OR Crestor OR rosuvastatin OR Zocor OR simvastatin OR Sectral OR Acebutolol OR Tekturna OR Aliskiren OR Tekamlo OR Valturna OR Midimor OR Amiloride OR Norvasc OR Amlodipine OR Caduet OR Lotrel OR Tenormin OR Atenolol OR Tenoretic OR Edarbi OR Azilsartan OR Lotensin OR Benazepril OR Kerlone OR Betaxolol OR Zebeta OR Bisoprolol OR Atacand OR Candesartan OR Coreg OR Carvedilol OR Diuril OR Chlorothiazide OR Thalitone OR Chlorthalidone OR Clorpres OR Catapres OR Clonidine OR Cardizem OR diltiazem OR Cartia OR Dilacor OR Dilt OR Diltia OR Matzim OR Taztia OR Tiamate OR Tiazac OR Avapro OR irbesartan OR Dynacirc OR isradipine OR Trandate OR labetalol OR Prinivil OR lisinopril OR Zestril OR Cozaar OR losartan OR Zaroxloyn OR metolazone OR Lopressor OR metoprolol OR Toprol OR Univasc OR moexipril OR Corgard OR nadalol OR Bystolic OR nebivolol OR Cardene OR nicardipine OR Procardia OR nifedipine OR Sular OR nisoldipine OR Benicar OR olmesartan OR Levitol OR penbutolol OR Aceon OR perindopril OR Pindolol OR pindolol OR Minipress OR prazosin OR Inderal OR propranolol OR Accupril OR quinapril OR Altace OR ramipril OR Micardis OR telmisartan OR Demadex OR torsemide OR Mavik OR trandolapril OR Diovan OR valsartan OR Calan OR verapamil OR Covera OR Isoptin OR Verelan OR Antihypertensive OR antihypertensives OR Hypolipidemic OR hypolipidemics OR “Nicotinic Agonists” OR Heparin OR Warfarin OR anticoagulant OR anticoagulants OR bupropion ) OR AB ( Lipitor OR atorvastatin OR Caduet OR Prevalite OR cholestyramine OR Questran OR WelChol OR colesevelam OR Colestid OR colestipol OR Zetia OR ezetimibe OR Tricor OR fenofibrate OR Lescol OR fluvastatin OR Mevacor OR lovastatin OR Livalo OR pitavastatin OR Pravachol OR pravastatin OR Crestor OR rosuvastatin OR Zocor OR simvastatin OR Sectral OR Acebutolol OR Tekturna OR Aliskiren OR Tekamlo OR Valturna OR Midimor OR Amiloride OR Norvasc OR Amlodipine OR Caduet OR Lotrel OR Tenormin OR Atenolol OR Tenoretic OR Edarbi OR Azilsartan OR Lotensin OR Benazepril OR Kerlone OR Betaxolol OR Zebeta OR Bisoprolol OR Atacand OR Candesartan OR Coreg OR Carvedilol OR Diuril OR Chlorothiazide OR Thalitone OR Chlorthalidone OR Clorpres OR Catapres OR Clonidine OR Cardizem OR diltiazem OR Cartia OR Dilacor OR Dilt OR Diltia OR Matzim OR Taztia OR Tiamate OR Tiazac OR Avapro OR irbesartan OR Dynacirc OR isradipine OR Trandate OR labetalol OR Prinivil OR lisinopril OR Zestril OR Cozaar OR losartan OR Zaroxloyn OR metolazone OR Lopressor OR metoprolol OR Toprol OR Univasc OR moexipril OR Corgard OR nadalol OR Bystolic OR nebivolol OR Cardene OR nicardipine OR Procardia OR nifedipine OR Sular OR nisoldipine OR Benicar OR olmesartan OR Levitol OR penbutolol OR Aceon OR perindopril OR Pindolol OR pindolol OR Minipress OR prazosin OR Inderal OR propranolol OR Accupril OR quinapril OR Altace OR ramipril OR Micardis OR telmisartan OR Demadex OR torsemide OR Mavik OR trandolapril OR Diovan OR valsartan OR Calan OR verapamil OR Covera OR Isoptin OR Verelan OR Antihypertensive OR antihypertensives OR Hypolipidemic OR hypolipidemics OR “Nicotinic Agonists” OR Heparin OR Warfarin OR anticoagulant OR anticoagulants OR bupropion )
#6 | DE “Smoking Cessation” OR TI (smoking OR tobacco) OR AB (smoking OR tobacco) OR DE “Diets” OR DE “Aerobic Exercise” OR DE “Weightlifting” OR DE “Yoga” OR DE “Movement Therapy” OR DE “Physical Activity” OR DE “Exercise” OR DE “Behavior Therapy” OR DE “Aversion Therapy” OR DE “Conversion Therapy” OR DE “Dialectical Behavior Therapy” OR DE “Exposure Therapy” OR DE “Implosive Therapy” OR DE “Reciprocal Inhibition Therapy” OR DE “Response Cost” OR DE “Systematic Desensitization Therapy” OR DE “Cognitive Behavior Therapy” OR DE “Acceptance and Commitment Therapy” OR DE “Health Education” OR DE “Drug Education” OR DE “Sex Education” AND DE “Counseling” OR DE “Educational Counseling” OR DE “Group Counseling” OR DE “Microcounseling” OR DE “Peer Counseling” OR DE “Psychotherapeutic Counseling” OR DE “Family Therapy” OR DE “Disease Management” OR DE “Lifestyle Changes” OR DE “Treatment Compliance” OR DE “Relapse Prevention” OR DE “Motivational Interviewing” OR DE “Self Monitoring” OR DE “Weight Loss” OR TI (exercise OR “physical activity” OR diet OR diets OR “weight management” OR counsel* OR “cognitive behavioral therapy” OR “lifestyle modification” OR adher* OR “self-monitoring” OR “relapse prevention” OR “skills training” OR “motivational interviewing” OR educat*) OR AB (exercise OR “physical activity” OR diet OR diets OR “weight management” OR counsel* OR “cognitive behavioral therapy” OR “lifestyle modification” OR adher* OR “self-monitoring” OR “relapse prevention” OR “skills training” OR “motivational interviewing” OR educat*)
#7 | DE “Social Support” OR TI (family OR peer) OR AB (family OR peer)
#8 | TI ( substitut* OR switch OR switched OR switching OR change OR changed OR changing OR replace OR replaced OR replacing OR replacement OR abandon* ) AND AB ( substitut* OR switch OR switched OR switching OR change OR changed OR changing OR replace OR replaced OR replacing OR replacement OR abandon* )
#9 | #8 AND #3
#10 | #5 OR #6 OR #7 OR #9
#11 | #4 AND #10 Limiters - English; Methodology: TREATMENT OUTCOME/CLINICAL TRIAL

## Grey Literature Searches

ClinicalTrials.gov (July 25, 2012)

Table A-17 ClinicalTrials.gov

Set # | Terms
Search terms | antipsychotic OR antipsychotics OR weight OR obesity OR obese OR overweight OR diabetes OR dyslipidemia OR hyperlipidemia OR cardiovascular OR hypertension
Condition | Schizophrenia OR bipolar disorder OR “serious mental illness” OR psychotic depression OR “severe mental illness” OR “severe psychiatric illness”
Intervention | behavioral OR drug OR drugs OR switch OR switching OR substitute OR substitution
Limits | Intervention studies, Adults/Seniors