# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CI: confidence interval
CVD: cardiovascular disease
df: degree of freedom
HR: hazard ratio
HRQOL: health-related quality of life
kg: kilogram
KQ: Key Question
MI: myocardial infarction
NA: not available
NR: not reported
OR: odds ratio
PICOTS: population, intervention, comparator, outcomes, timing, setting
QOL: quality of life
RCT: randomized controlled trial
ROB: risk of bias
RR: risk ratio
SMI: serious mental illness
SOE: strength of evidence
TEP: Technical Expert Panel