# Results

The literature search yielded 4,023 citations. From these, 568 articles were provisionally accepted for review on the basis of the abstracts and titles (Figure 2). After screening their full texts, 37 studies, published in 42 articles, were judged to have met the inclusion criteria. The grey literature search yielded no additional studies. The most common reason for article rejection was that there were no direct comparisons between intravascular diagnostic techniques and angiography (278 articles). The other reasons for rejection included ineligible publication types, such as reviews or case reports (83 articles); irrelevant comparators (e.g., intravascular diagnostic compared with cardiac computed tomography; 56 articles); failing to address the Key Questions (46 articles); irrelevant outcomes (34 articles); no intravascular diagnostic techniques used (9 articles); within diagnostic technique comparisons (e.g., comparison between different criteria of the same diagnostic technique; 7 articles); irrelevant or incomplete measurement time points (e.g., comparison between intravascular diagnostic techniques and angiography only at followup; 9 articles); and no population of interest (4 articles). See Appendix B for a list of the excluded studies with the reason for exclusion.

Figure 2 Literature flow diagram

N = number

* Indicates some overlapping studies across Key Questions.

Literature Flow Diagram: Figure 2 is a flow chart that outlines study retrieval and selection process. It begins with the total number of citations retrieved from the literature searches and ends with the number of studies that satisfied the inclusion criteria of the report. This figure is described further in the Section entitled “Search Results” as follows: The literature search yielded 4023 citations. From these, 588 articles were provisionally accepted for review on the basis of the abstracts and titles (Figure 2). After screening their full texts, 37 studies, published in 42 articles, were judged to have met the inclusion criteria. The grey literature search yielded no additional studies. The most common reason for article rejection was that there were no direct comparisons between intravascular diagnostic techniques and angiography (278 articles). The other reasons for rejection included ineligible publication types, such as reviews or case reports (83 articles); irrelevant comparators (e.g., intravascular diagnostic compared with cardiac computed tomography; 56 articles); failing to address the Key Questions (46 articles); irrelevant outcomes (34 articles); no intravascular diagnostic techniques used (9 articles); within diagnostic technique comparisons (e.g., comparison between different criteria of the same diagnostic technique; 7 articles); irrelevant or incomplete measurement time points (e.g., comparison between intravascular diagnostic techniques and angiography only at followup; 9 articles); and no population of interest (4 articles). The 37 accepted, nonoverlapping studies (in 42 articles) had data addressing at least one of the five Key Questions are available for IVUS and FFR, and no comparative studies are available for the remaining investigational intravascular diagnostic techniques.

The 37 accepted, nonoverlapping studies (in 42 articles) had data addressing at least one of the five Key Questions are available for IVUS and FFR, and no comparative studies are available for the remaining investigational intravascular diagnostic techniques. Summary Tables with the descriptions of each study are in Appendix C.

## Key Question 1 In patients with CAD, what is the impact of using an intravascular diagnostic technique and angiography in deciding whether a coronary lesion requires intervention–when compared with angiography alone–on therapeutic decisionmaking, intermediate outcomes and patient-centered outcomes?

### Key Points

- There is a moderate strength of evidence favoring the adjunctive use of FFR during angiography in deciding to stent an intermediate coronary lesion (50% to 70% stenosis), using an FFR threshold <0.80; the use of FFR confers a lower risk of the composite endpoint of death or MI, or of MACE; and leads to fewer stents implanted and reduces the costs of the procedure.
- The evidence supporting the adjunctive use of FFR during angiography in deciding to stent an intermediate coronary lesion was derived from studies that focused on men with intermediate coronary disease and lower grade angina, and excluded patients with left main disease.
- There is insufficient evidence regarding the use of any techniques other than FFR, as none of the studies reviewed techniques other than FFR to decide whether a coronary lesion required stenting.

### Summary of Evidence

Our appraisal of the strength of evidence relied on studies rated as being at a low- or medium risk of bias. Overall, there is a moderate strength of evidence (drawn from one RCT with low risk of bias and one nonrandomized study with medium risk of bias) favoring the use of FFR during angiography in deciding whether to stent an intermediate coronary lesion (≥50% to 70% stenosis), using an FFR threshold <0.80. The use of FFR in these lesions to decide whether to stent led to fewer stents being implanted, reduced the cost of the procedure, and conferred a lower risk of the composite endpoint of death or MI, or of major adverse cardiac events (MACE). The evidence was derived from studies that focused on men with lower grade angina, and excluded patients with left main disease or acute MI. Therefore, the use of FFR to decide which lesions require stenting is most applicable in patients with stable multivessel disease and intermediate coronary stenosis, excluding left main disease and acute MI.

For therapeutic decisionmaking, there is a moderate strength of evidence that the adjunctive use of FFR during angiography aids in deciding whether to stent a coronary lesion, and which coronary vessels to stent, as compared with angiography alone. For intermediate outcomes, there is a moderate strength of evidence that the use of FFR reduces resource utilization in the short term (up to 30 days after the procedure), as compared with angiography alone, and insufficient evidence for stent-related outcomes at any time point. For patient-centered outcomes, there is a moderate strength of evidence that the use of FFR, as compared with angiography alone, improves combined clinical endpoints (e.g., death and MI or MACE) in the medium term (>30 days to 1 year) and long term (>1 year). None of the studies reported patient-centered outcomes at 30 days after the procedure.

With respect to Key Question 1, there is insufficient evidence regarding the use of any intravascular diagnostic technique aside from FFR, as none of the studies reviewed other techniques.

### Available Evidence

We identified three studies, including one RCT (Fractional Flow Reserve versus Angiography for Multivessel Evaluation [FAME] trial in three publications) and two nonrandomized studies evaluating the use of FFR to decide whether a coronary lesion needs intervention, as compared with angiography. No eligible studies on other intravascular diagnostic techniques were found to address this Key Question. Three studies in five publications compared the use of FFR-guided stenting with stenting guided by angiography alone.18-22 Two related RCTs—DEFER13 and FAME II12—in this field were excluded for the following reasons: the DEFER trial examined appropriateness of stenting a functionally nonsignificant stenosis, and did not compare FFR-guided stenting versus stenting guided by angiography alone; and in the FAME II trial, all patients underwent FFR during angiography and the trial compared FFR-guided stenting plus optimal medical therapy with optimal medical therapy alone.

One RCT (with three publications), the FAME trial, followed 1,005 adult patients with at least a ≥50 percent diameter stenosis in two or more major epicardial vessels, over 2 years.18,20,21 Also included were patients with a recent nonST-segment elevation MI for less than 5 days if their peak creatine kinase (CK)-MB was <1,000 IU or if they had undergone PCI in the past. Excluded were patients with left main coronary artery disease, previous CABG, or a recent ST-segment elevation MI within 5 days. The average age of these patients was 64 years, and the proportion of included men was 74 percent. The proportion of patients with diabetes was 25 percent, hypertension 67 percent, and dyslipidemia 73 percent. The majority of patients had Canadian Cardiovascular Society angina grade I to III; less than 20 percent of the included patients had grade IV angina. After randomization, lesions in the FFR-guided PCI group had drug-eluting stent implantation only if the FFR was 0.80 or less in epicardial vessels that demonstrated a ≥50 percent diameter stenosis by angiogram. In the angiography-guided PCI group, all lesions underwent drug-eluting stent implantation. The choice of stent implantation was at the discretion of the surgeon. The FAME trial was rated as being at a low risk of bias.

Two nonrandomized studies compared the use of FFR-guided stenting with stenting guided by angiography alone.19,22 One followed 137 patients prospectively for more than 2 years.22 In this study, patients who had stable angina with stenoses in two or more coronary arteries were included; excluded patients were those who had undergone a previous CABG, experienced a recent acute MI, or those with an ejection fraction <50 percent. The average age of included patients was 62 years; 77 percent were men. The proportion of patients with diabetes was 38 percent, hypertension 74 percent, and dyslipidemia 63 percent. The study lacked data on other baseline characteristics. The study was rated as being at a medium risk of bias due to the lack of adjusted analyses.

The second nonrandomized study followed 154 consecutive first-time acute MI patients with totally occluded lesions (142 of the 155 total stenotic lesions).19 Patients in the intervention group were prospectively followed for 2 years; however, the comparison group was a historical cohort from the same single-center. The average age of included patients was 63 years; 76 percent were men. The proportion of patients with diabetes was 16 percent and dyslipidemia 23 percent. The proportion of patients with left-anterior descending culprit stenoses was significantly higher in the FFR-guided stenting compared with stenting guided by angiography alone. The proportion of patients with hypertension was not documented, and the study lacked data on other baseline characteristics. The study was rated as being at a high risk of bias due to comparisons to a historical control and the lack of adjusted analyses.

#### Therapeutic Decisionmaking

Overall, the adjunctive use of FFR during angiography aids in deciding whether to stent an intermediate coronary lesion (≥50% stenosis), using an FFR threshold <0.80. All three studies included for Key Question 1^18-22^ reported data for therapeutic decisionmaking outcomes comparing FFR-guided stenting with stenting guided by angiography alone.

The therapeutic decisions whether or not to stent were made on the basis of FFR threshold; though the threshold used varied considerably across the three studies. Among patient referred for revascularization, stent implantation was conducted in 874 of the 1,387 lesions (63%) with an FFR ≤0.80 in the FAME trial. No stents were placed in the remaining 513 (37%) lesions with FFR >0.80 in patients with stable multivessel coronary disease.21 In the prospective nonrandomized comparative study, PCI was deferred in 75 of the total 128 vessels (58% with an average FFR of 0.86) and the remaining 53 vessels with an average FFR of 0.67 underwent PCI and stenting in patients with stable multivessel coronary disease.22 In the prospective nonrandomized comparative study with a historical comparator, stent implantation in patients with acute MI was performed in 40 lesions (FFR <0.94); the remaining 37 lesions (FFR≥0.94) underwent direct angioplasty without stenting.19

#### Intermediate Outcomes

##### Resource Utilization

Overall, the use of FFR reduces resource utilization in the short term (up to 30 days after the procedure), as compared with angiography alone. In the FAME trial, the number of hospital days at baseline admission was significantly lower in the FFR-guided group, as compared with the group who received stenting guided by angiography alone (3.4 vs. 3.7 days; p=0.05).21 The remaining two nonrandomized comparative studies did not report this outcome.19,22

None of the included studies reported data on medication use during the procedural time period. The number of stents implanted per patient was significantly lower in the FFR-guided group, as compared with the group receiving stenting guided by angiography alone, in both the FAME trial21 and in one prospective nonrandomized comparative study.22 The number of stents implanted per patient was 1.9 versus 2.7 in the FAME trial,21 and 1.04 versus 1.28 in the prospective nonrandomized study.22 The second prospective nonrandomized study (with a historical control) did not report this outcome.19

The cost of procedure was reported in all three studies.19,21,22 The cost of the procedure, including materials used during PCI, was significantly lower in the FFR-guided group, as compared with the group who received stenting guided by angiography alone, in all three studies. Both the FAME trial and one prospective nonrandomized study reported cost individually per material used during PCI.18,22 In the FAME trial, individual cost per material was lower with FFR-guided stenting than in with angiography-guided stenting, although no formal statistical comparisons of individual cost per material were reported between groups. In the prospective study, the cost of the guidewires was significantly higher in the FFR-guided stenting group; however, this was off-set by the increased use and cost of balloons and stents in the group whose stents were guided by angiography alone.22

There were no significant differences in procedure time between the groups, based on the findings of the FAME trial21 and one prospective nonrandomized comparative study.22 In the FAME trial, contrast use was significantly lower in the FFR-guided stenting than in the angiography-guided stenting (272 vs. 302 mL; p<0.001). However, no significant difference in the use of contrast was observed between the two groups in the nonrandomized comparative study. Radiation exposure time was similar between the two groups in this study.

##### QCA Process Outcomes

Two nonrandomized comparative studies, reported data for in-hospital process outcomes comparing FFR-guided stenting with stenting guided by angiography alone.19,22

The net changes in the minimal lumen diameter measurements of the FFR and angiography alone groups, from baseline to postprocedure, reported in two prospective nonrandomized comparative studies, was inconsistent.19,22 One was rated as being at a medium risk of bias, and reported no significant difference between the two groups (MLD net difference 0.02 mm; not significant (NS) and diameter stenosis net difference 1%; NS).22 The second, with a historical control and rated as being at a high risk of bias, reported an unfavorable effect for FFR-guided stenting over stenting guided by angiography alone (MLD net difference -0.3 mm; p<0.001 and diameter stenosis net difference 9.0%; p<0.001).19

The net changes in percent diameter stenosis measurements between the FFR-guided group and the group who received stenting guided by angiography alone, from baseline to postprocedure (reported in two prospective nonrandomized studies), were inconsistent.19,22 One (rated as being at a medium risk of bias) reported no significant difference in percent diameter stenosis between the groups. The second (with a historical control; rated as being at a high risk of bias) reported a favorable effect for FFR-guided stenting over stenting guided by angiography alone (percent diameter stenosis net difference -0.3; p<0.001).19

##### Stent-Related Outcomes

One prospective nonrandomized comparative study with a historical control reported nonsignificantly higher rates of reocclusion and restenosis with FFR-guided stenting, as compared with stenting guided by angiography alone.19 None of the included studies reported data on acute stent thrombosis.

#### Patient-Centered Outcomes

There was no incidence of in-hospital complications of CABG or death reported in any of the three included studies.19,21,22 Only one prospective study (nonrandomized) reported data on repeat target lesion revascularization during in-hospital stay, and found no statistically significant difference between groups.22

The FAME trial reported periprocedural infarctions diagnosed on the basis of increases in CK-MB (three to five times the upper limit of normal) as 2.4 percent in the FFR-guided stenting versus 3.2 percent angiography-guided stenting.20 The FAME trial reported the absolute mean difference of MACE at discharge as -2.2 percent between the two groups (no statistical significance was provided).20 One of the nonrandomized comparative studies, reported a nonsignificantly lower proportion of in-hospital non-Q wave MI and cumulative MACE with FFR-guided stenting, as compared with stenting guided by angiography alone.22 The prospective nonrandomized comparative study (with a historical comparator) reported no cardiac deaths during in-hospital stay.19 None of the included studies reported patient-centered outcomes at 30 days after the procedure.

All three studies reported no significant difference between groups for the outcome of death in either the medium or long terms.19,21,22 There was no significant difference in MI between groups in the FAME trial at 1 year but at 2 years there was a significant decrease in the risk of MI in the FFR group (relative risk [RR] 0.62, 95% CI 0.40, 0.95).21,22 The FFR group also displayed a significant decrease in the composite outcome of death or MI (RR 0.66, 95% CI 0.44, 0.98 at 1 year; RR 0.65, 95% CI 0.45, 0.94 at 2 years). For repeat revascularization, defined as CABG or repeat PCI, a favorable effect in the FFR group did not reach statistical significance (RR 0.68, 95% CI 0.40, 1.05 at 1 year; RR 0.84, 95% CI 0.59, 1.18 at 2 years). While the FAME trial significantly favored FFR (RR 0.72, 95% CI 0.54, 0.96) for the primary outcome of MACE—defined as death, MI, and repeat revascularization at 1 year—this did not reach statistical significance at 2 years (RR 0.80, 95% CI 0.62, 1.02).20,21

In the prospective nonrandomized study, there was no significant difference in MI between groups at more than 2 years. For the composite outcome of MACE (defined as death, MI, and target lesion revascularization) in this study, significant results favored FFR over angiography at more than 2 years (8% in FFR vs. 27% in angiography alone; p<0.01).22 The other prospective nonrandomized comparative study (which employed a historical control), did not report clinical outcomes other than death.

##### Other Outcomes

In the FAME trial, the average overall costs at 1 year were significantly less in the FFR group, as compared with angiography alone group ($14,315 vs. $16,700, respectively; p<0.001).

Only the FAME trial examined data on patient-reported outcomes, including the number of patients free from angina, composite endpoint of the number of patients without event and free from angina, and intake of antianginal medications at 1 and 2 year followup.20,21 The trial also reported the European Quality of Life-5 Dimensions (EQ-5D) score, at 1 year followup. There was no significant difference in EQ-5D between groups (66.5 in the FFR vs. 64.7 in the angiography alone). Although a higher proportion of patients were without an event and were free from angina (73% in the FFR-guided stenting group vs. 68% in the group receiving stenting guided by angiography alone), there was no significant difference between the groups for all patient-reported outcomes.

## Key Question 2 For patients undergoing PCI, what is the impact of using an intravascular diagnostic technique and angiography to guide stent placement (either immediately prior to or during the procedure)—when compared with angiography alone—on therapeutic decisionmaking, intermediate outcomes, and patient-centered outcomes?

### Key Points

- When using IVUS to guide stent deployment, there is a moderate strength of evidence from nine RCTs and 22 nonrandomized studies that supports a reduction in repeat revascularization and restenosis, but no significant differences in mortality and MI, as compared with angiography alone.
- The evidence supporting adjunctive use of IVUS during angiography to guide stent deployment was derived mostly from studies conducted before 2000 that focused on men, excluded patients with left main disease and acute MI, and used a previous generation of bare-metal stents, which limits applicability of the evidence.
- There is insufficient evidence for all techniques other than IVUS (one available study regarding the use of FFR, and no studies for all other techniques) to guide and optimize stent deployment.

### Summary of Evidence

Overall, there is a moderate strength of evidence that supports a significant reduction in repeat revascularization and restenosis, but no significant difference in mortality and MI, when using IVUS to guide stent deployment, as compared with angiography alone. The evidence was derived mostly from studies conducted before 2000 that focused on men, excluded patients with left main disease and acute MI, and used a previous generation of bare-metal stents. With regards to therapeutic decisionmaking, there is a moderate strength of evidence that the use of IVUS during PCI can aid the operator in optimizing stent deployment, as compared with angiography alone. For intermediate outcomes, there is a moderate strength of evidence that the use of IVUS during PCI to optimize stent deployment increases resource utilization in the short-term, reveals no statistically significant differences in QCA outcomes in the short- and medium-terms, and lowers the risk of stent-related outcome of restenosis in the medium-term, as compared with angiography alone. For patient-centered clinical outcomes, there is a moderate strength of evidence that supports no significant difference in mortality, MI, and MACE, but reveals a significant benefit in decreasing repeat revascularization, when using IVUS to guide bare-metal stent deployment, as compared with angiography alone.

There is insufficient evidence from one nonrandomized study regarding the use of FFR in determining the need for additional therapy (dilation) after stent deployment. There is insufficient evidence for all other techniques to answer Key Question 2, as no comparative studies evaluated techniques other than IVUS and FFR.

### Available Evidence

We identified 32 studies reporting direct comparisons of two intravascular diagnostic techniques, IVUS (31 studies) and FFR (1 study), with angiography alone in optimizing stent deployment.

#### IVUS Versus Angiography Alone in Stent Deployment

We identified nine RCTs (in 11 publications)23-33 and 22 nonrandomized comparative studies34-55 comparing IVUS-guided stent deployment with stenting guided by angiography alone.

Two RCTs were rated as being at a low risk of bias,29,32 six at a medium risk of bias,23,25-27,31,33 and one at a high risk of bias.28 Among the RCTs, sample sizes ranged from 42 to 800, and the average ages of patients ranged from 55 to 66 years. Followup durations ranged from 6 months to 2.5 years. The proportion of men ranged from 62 to 100 percent. The proportion of patients with diabetes ranged from 7.5 to 100 percent (9 RCTs). The proportion of patients with dyslipidemia ranged from 42 to 94.5 percent (9 RCTs), and those with hypertension ranged from 22 to 69.5 percent (9 RCTs). All but one RCT27 excluded patients with left main disease or acute MI. All but two RCTs recruited patients before 2000;^26,27^ both were conducted in Eastern Europe. One RCT evaluated PCI with long stent implantation.31

Among the 22 included nonrandomized comparative studies, eight nonrandomized comparative studies were rated as being at a high risk of bias,37-40,46,47,49,51 while the rest at a medium risk of bias.34-36,41,42,44,45,48-50,52-55 Six were conducted prospectively35,38,41,45,50,55 and eight retrospectively,34,36,37,39,42,43,47 seven were registry-based (two single center and five multicenter),40,44,48,49,52-54 and one was cross-sectional.51 Sample sizes ranged from 34 to 9,070, and the average ages of patients ranged from 55 to 66 years (19 studies). Followup durations ranged from 30 days to 3 years. The proportion of patients with diabetes ranged from 7.1 to 47.1 percent (22 studies). The proportion of patients with dyslipidemia ranged from 25.5 to 91.2 percent (21 studies34-49,51-55). The proportion of patients with hypertension ranged from 19 to 91.2 percent (21 studies34-49,51-55). Three of the 22 total nonrandomized comparative studies excluded patients with left main disease or acute MI.35,47,48 Three evaluated patients with only acute MI;40,52,55 one compared patients with distal and nondistal left main disease;47 and two others included patients with only unprotected left main disease.43,49

In total, 29 studies reported data for in-hospital outcomes (nine RCTs and 19 nonrandomized comparative).23,25-29,31-51,53,55 Reported in-hospital outcomes of interest included clinical outcomes, diagnostic and therapeutic decisionmaking, process outcomes, periprocedural complications, and stent-related outcomes. Short-term outcomes (30 day outcome) was reported in eight studies (two RCTs29,31 and six nonrandomized comparative40,44,52-55). Medium-term outcomes (>30 days to 1 year) were reported in 24 studies (seven RCTs23,24,26,29,31-33 and 17 nonrandomized comparative studies34-46,52-55), and long-term outcomes (>1 year) were reported in nine studies (three RCTs25,27,30 and six nonrandomized comparative studies47-49,53-55).

##### Therapeutic Decisionmaking

Overall, the use of IVUS during PCI can aid the operator in optimizing stent deployment, as compared with angiography alone. Three RCTs29,32,33 and three nonrandomized comparative studies38,43,47 reported data on changes in therapeutic decisionmaking resulting from the use of IVUS in optimizing stent placement. In the RCTs, a significantly higher proportion of patients achieved optimal stent placement on the basis of IVUS guidance;29 almost one-half of the patients received further therapy for an underexpanded stent and repeat balloon angioplasty;32 and more than one-third underwent additional dilation due to not reaching the IVUS criterion33 in the IVUS-guided PCI group as compared with the angiography-guided PCI group.

Three nonrandomized comparative studies reported a significantly higher proportion of patients achieving optimal stent placement on the basis of therapeutic decisionmaking guided by IVUS use , which included additional postdilation, debulking, and angioplasty, or a second stent deployment.38,43,47

##### Intermediate Outcomes

###### Resource Utilization

Meta-analysis of four RCTs26,27,29,31 revealed a nonstatistically significant increase in the use of glycoprotein IIb/IIIa inhibitor in the IVUS-guided stenting (summary RR 1.27; 95% CI 0.76, 2.12). One nonrandomized study reported a significant increase in the use of glycoprotein IIb/IIIa inhibitor in the IVUS group, as compared with the angiography alone group (16% vs. 2.8%; p<0.001).55. In contrast, another reported a significant decrease in the use of glycoprotein IIb/IIIa inhibitor in the IVUS group, over angiography alone (9.8% vs. 12.8%; p<0.001).

Across four RCTs23,25,27,29 and two nonrandomized comparative studies,36,51 two RCTs27,29 and one nonrandomized comparative study51 reported significantly longer procedure time in IVUS, while the two other RCTs31,33 and a nonrandomized comparative study reported no significant difference between groups.36

Three RCTs23,27,29 and one nonrandomized comparative study51 reported significantly longer fluoroscopy time in the IVUS group over angiography alone, while the other nonrandomized comparative study reported no significant difference between the two groups.36

Two RCTs27,29 reported a significantly increased volume of contrast medium used in the IVUS group over angiography alone, while the remaining RCT23 and both nonrandomized comparative studies36,51 reported no significant difference between groups.

The number of guidewires used was similar in both groups in one RCT29 and one nonrandomized comparative study.36 The use of stents was similar in both groups in four RCTs,23,25,27,29 and seven nonrandomized comparative studies, with two exceptions: more stents per patient were used in the IVUS group, compared with the group who received stents guided by angiography alone, in one RCT31 and one nonrandomized study.34 The average number of balloons utilized during procedure was similar between groups in two RCTs23,25 and one nonrandomized comparative study,36 while one RCT29 and two nonrandomized comparative studies44,55 showed the IVUS-guided group utilizing significantly more balloons compared with the group who received stents guided by angiography alone.

One RCT24 and two nonrandomized comparative studies36,51 reported an increase in initial cost in the IVUS group relative to the angiography alone group, owing to the extra procedure time and increased utilization of catheters, balloons, and stents. The hospitalization stay was similar between groups in the one RCT reporting data on hospitalization after procedure.29 No other studies reported data on this outcome.

In summary, the IVUS group had a significantly longer procedural time and fluoroscopy time, as compared with angiography alone. There was a nonsignificantly increased utilization of glycoprotein IIb/IIIa inhibitor, contrast medium, or other resources, including guidewires, stents, and balloons during the procedure in the IVUS group over angiography alone. Generally, there were no significant differences between groups for periprocedural complications or stent-related complications.

###### QCA Process Outcomes

###### In-Hospital MLD

Some studies reported QCA process outcomes by lesion and some by patients, complicating synthesis because each patient can contribute to multiple lesion-level data points (which are correlated). Treating data on lesions nested within patients as independent observations will underestimate the standard error of the effect size leading to bias. Meta-analyses of the net changes in MLD measurements between IVUS-guided stenting and stent deployment guided by angiography alone, from baseline to postprocedure, conducted across nine RCTs23,25-29,31-33 (six reporting by patients23,25-27,31,32 and three reporting by lesions28,29,56) revealed consistent small gains favoring IVUS, but no statistically significant difference between groups (Figure 3).

Figure 3 RCTs of in-hospital minimal lumen diameter: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n = number

Notes: Estimates favoring IVUS are in the direction of the arrow, in contrast to Figures 7-10 on diameter stenosis.

A confidence interval that crosses 0 indicates no significant mean difference; values >0 indicate that a larger minimal lumen diameter was achieved in the IVUS group over angiography alone group.

RCTs of in-hospital minimal lumen diameter: forest plot Figure 3 displays a forest plot of studies reporting the in-hospital minimal lumen diameter, IVUS-guided stent placement versus angiography-guided stent placement. The mean difference reported for individual studies by patients are: AVID by Russo 2009 (0.04, 95% CI -0.03, 0.11; Patients in IVUS 406, and Angio 394); Gaster 2003 (0.00, 95% CI -0.19, 0.19; Patients in IVUS 54, and Angio 54); TULIP by Oemrawsingh 2003 (0.18, 95% CI 0.05, 0.31; Patients in IVUS 73, and Angio 71); DIPOL by Gil 2007 (0.26, 95% CI 0.12, 0.40; Patients in IVUS 80, and Angio 83); SIPS by Frye 2000 (0.17, 95% CI 0.03, 0.31; Patients in IVUS 121, and Angio 148); HOME DES IVUS 2010 by Jakabcin (-0.06, 95% CI -0.15, 0.03; Patients in IVUS 105, and Angio 105). A meta-analysis of the six RCTs reporting data by patients (one rated as being at a low risk of bias; (Russo, 2009) five at a medium risk (Frey, 2000; Gaster, 2003; Gil, 2007; Jakabcin, 2010; Oemrawsingh, 2003) revealed no significant difference between IVUS-guided stent placement and angiography-guided stent placement: minimal lumen diameter summary net change = 0.09 mm (95 percent CI −0.00, 0.19; NS). The mean difference reported by lesions are: Kawata 1997 (0.39, 95% CI 0.32, 0.46; Patients in IVUS 19, and Angio 28); OPTICUS by Mudra 2001 (0.07, 95% CI -0.04, 0.18; Patients in IVUS 229, and Angio 228); RESIST by Schiele 1998 (0.08, 95% CI 0.05, 0.42; Patients in IVUS 79, and Angio 76). Meta-analysis of the three RCTs (one of each rated at a low, (Mudra, 2001) medium, (Schiele, 1998) and high risk of bias (Kawata, 1997) reporting lesion-level data revealed no significant difference between IVUS-guided and angiography-guided stent placement: minimal lumen diameter summary net change = 0.18 mm (95 percent CI −0.05, 0.42; nonsignificant [NS]).

Figure 7 RCTs of in-hospital percent diameter stenosis: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n = number

Note: A confidence interval that crosses 0 indicates no significant mean difference.

RCTs of in-hospital percent diameter stenosis: forest plot Figure 7 displays a forest plot of studies reporting the in-hospital percent diameter stenosis, IVUS-guided stent placement versus angiography-guided stent placement. The mean difference reported for individual studies by patients are: DIPOL by Gil 2007 (-5.00, 95% CI -8.54, -1.46; Patients in IVUS 80, and Angio 83); TULIP by Oemrawsingh 2003 (-1.00, 95% CI -4.41, 2.41; Patients in IVUS 73, and Angio 71); SIPS by Frey 2000 (-4.00, 95% CI -9.74, 1.74; Patients in IVUS 121, and Angio 148); Gaster 2003(-9.00, 95% CI -15.26, -2.74; Patients in IVUS 54, and Angio 54); HOME DES IVUS by Jakabcin 2010(-3.80, 95% CI -5.91, -1.69; Patients in IVUS 105, and Angio 105). Meta-analysis of the five RCTs reporting data by patients (all rated as being at a medium risk of bias[Frey, 2000; Gaster, 2003; Gil, 2007; Jakabcin, 2010; Oemrawsingh, 2003]) revealed a significant difference indicating a favorable effect for IVUS-guided stent placement over angiography-guided stent placement: percent diameter stenosis summary net change = −3.90 percent (95 percent CI −5.86, −1.94; P<0.001). The mean difference reported for individual studies by lesions are: RESIST by Schiele 1998 (-1.00, 95% CI -4.36, 2.36; Patients in IVUS 79, and Angio 76); OPTICUS by Mudra 2001 (-2.90, 95% CI -6.10, 0.30; Patients in IVUS 229, and Angio 228); Kawata 1997 (-12.10, 95% CI -14.48, -9.40; Patients in IVUS 19, and Angio 28). A Meta-analysis of the three RCTs (one of each rated at a low,(Mudra, 2001) medium,(Schiele, 1998) and high risk of bias (Kawata, 1997) reporting lesion-level data revealed no significant difference between IVUS-guided stent placement and angiography-guided stent placement: percent diameter stenosis summary net change = −5.39 percent (95 percent CI −12.45, 1.67; P=0.14).

Figure 8 Nonrandomized comparative studies of in-hospital percent diameter stenosis: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n = number.

Note: A confidence interval that crosses 0 indicates no significant mean difference.

Nonrandomized studies of in-hospital percent diameter stenosis: forest plot Figure 8 displays a forest plot of studies reporting the in-hospital diameter stenosis, IVUS-guided stent placement versus angiography-guided stent placement. The mean difference reported for individual studies by patients are: Blasini 1998 (-1.00, 95% CI -4.87, 2.87; Patients in IVUS 105, and Angio 107); KAMIR 2011 (-1.40, 95% CI -2.05, -0.75; Patients in IVUS 2127, and Angio 8235); Kim 2011 (0.20, 95% CI -1.74, 2.14; Patients in IVUS 487, and Angio 487); Orford 2004 (-1.90, 95% CI -3.29, -0.51; Patients in IVUS 731, and Angio 1434); Ozaki (BA) 2007 (0.11, 95% CI 0.02, 0.20; Patients in IVUS 122, and Angio 106); Ozaki (CBA) 2007 (-1.60, 95% CI -3.63, 0.43; Patients in IVUS 126, and Angio 99); Youn 2011 (-2.90, 95% CI -4.83, -0.97; Patients in IVUS 125, and Angio 216); Agostoni 2005 (2.80, 95% CI -3.25, 8.85; Patients in IVUS 24, and Angio 34). Meta-analysis of seven observational studies reporting lesion-level data (two rated as being at a medium risk of bias;(Albiero, 1997;Sakamoto, 1999) four at a high risk (Faulknier, 2004; Fitzgerald, 2000;Fujimoto, 2008;Maluenda, 2010;Yoshitomi, 1999) revealed no statistically significant difference between IVUS-guided and angiography-guided stent placement: percent diameter stenosis summary net change = −2.90 percent (95 percent CI −6.28, 0.49; P=0.09). Meta-analysis of seven observational studies reporting data by patients (five rated as being at a medium risk of bias;(Blasini, 1998;Kim, 2011;Orford, 2004;Ozaki, 2007; KAMIR 2011; Youn 2011) two at a high risk (Agostoni, 2005) revealed no statistically significant difference between IVUS-guided and angiography-guided stent placement: percent diameter stenosis summary net change = −1.04 percent (95 percent CI −2.04, -0.04; P=0.28). The mean difference reported for individual studies by lesions are: Albiero (early phase) 1997 (-15.10, 95% CI -18.67, -11.53; Patients in IVUS 76, and Angio 76); Albiero (late phase) 1997 (-5.40, 95% CI -11.96, 1.16; Patients in IVUS 97, and Angio 97); Sakamoto 1999 (-1.10, 95% CI -6.49, 4.29; Patients in IVUS 18, and Angio 19); Faulknier 2004 (1.25, 95% CI 0.53, 1.97; Patients in IVUS 70, and Angio 65); Fitzgerald 2000 (-0.30, 95% CI -2.44, 1.84; Patients in IVUS 290, and Angio 253); Fujimoto 2008 (-6.00, 95% CI -10.13, -1.87; Patients in IVUS 97, and Angio 271); Maluenda 2011 (-2.00, 95% CI -3.86, -0.14; Patients in IVUS 663, and Angio 811); Yoshitomi 1999 (5.40, 95% CI -0.25, 11.05; Patients in IVUS 40, and Angio 29). Meta-analysis of seven observational studies reporting data by patients (three rated as being at a medium risk of bias;(Albiero, 1997;Sakamoto, 1999;Faulknier, 2004) five at high risk (Fitzgerald, 2000; Fujimoto 2008; Youn 2011;Maluenda,2011;Yoshitomi,1999) revealed no statistically significant difference between IVUS-guided and angiography-guided stent placement: percent diameter stenosis summary net change = −2.90 percent (95 percent CI −6.28, 0.49; NS).

Figure 9 RCTs of medium-term percent diameter stenosis: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n=number

Note: A confidence interval that crosses 0 indicates no significant mean difference.

RCTs of medium-term percent diameter stenosis: forest plot Figure 9 displays a forest plot of RCTs reporting the up to 1 year duration percent diameter stenosis, IVUS-guided stent placement versus angiography-guided stent placement. The mean difference reported for individual studies (all reported by patients) are: OPTICUS by Mudra 2001 (0.01, 95% CI -0.08, 0.10; Patients in IVUS 229, and Angio 228); RESIST by Schiele 1998 (-5.00, 95% CI -10.42, 0.42; Patients in IVUS 79, and Angio 76); SIPS by Frye 2000 (-4.00, 95% CI -9.74, 1.74; Patients in IVUS 121, and Angio 148); TULIP by Oemrawsingh 2003 (-7.00, 95% CI -12.17, -1.83; Patients in IVUS 73, and Angio 71). Meta-analysis of the four RCTs (one of each rated at a low,(Mudra, 2001) medium,(Schiele, 1998;Frey, 2000;Oemrawsingh, 2003) revealed no significant difference between IVUS-guided stent placement and angiography-guided stent placement: summary mean difference -3.46 percent (95 percent CI -7.47, 0.55; NS).

Figure 10 Nonrandomized comparative studies of medium-term percent diameter stenosis: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n = number|

Note: A confidence interval that crosses 0 indicates no significant mean difference.

Nonrandomized comparative studies of medium-term percent diameter stenosis: forest plot Figure 10 displays a forest plot of studies reporting the intermediate duration percent diameter, IVUS-guided stent placement versus angiography-guided stent placement. The mean difference reported for individual studies by patients in one study included Blasini 1999 (-6.0 95 percent CI -11.49, -0.51).The mean difference reported for individual studies by lesions are: Albiero (late phase patients) 1997 (-5.40, 95% CI -11.96, 1.16; Patients in IVUS 97, and Angio 97); Albiero (early phase patients) 1997 (-15.40, 95% CI -21.63, -9.17; Patients in IVUS 76, and Angio 76); Sakamoto 1999 (-3.50, 95% CI -13.73, 6.73; Patients in IVUS 18, and Angio 19); Yoshitomi 1999 (-11.10, 95% CI -20.84, -1.36; Patients in IVUS 40, and Angio 29); Fujimoto 2008 (-1.10, 95% CI -1.40, 3.60; Patients in IVUS 97, and Angio 271). Meta-analysis of the four lesion-level observational studies (Albiero, 1997;Fujimoto, 2008;Sakamoto, 1999;Yoshitomi, 1999) two rated as being at a medium risk of bias; two at a high risk) revealed no significant difference between IVUS-guided stent placement and angiography-guided stent placement: summary mean difference -6.60 percent (95 percent CI -13.94, 0.74; NS).

However, meta-analysis of seven nonrandomized comparative studies reporting eight sets of patient-level data,35,41-43,47,48,55 and seven nonrandomized comparative studies reporting eight sets of lesion-level data,34,37-39,45,46,50 both revealed a significant difference, indicating a favorable effect for IVUS-guided stenting over stent placement guided by angiography alone (Figure 4), with significant statistical heterogeneity (I^2^ = 63% for patient-level; 94% for lesion-level analyses). Excluding studies rated as being at a high risk of bias did not change the estimates.

Figure 4 Nonrandomized comparative studies of in-hospital minimal lumen diameter: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n = number

Notes: Estimates favoring IVUS are in the direction of the arrow, in contrast to Figures 7-10 on diameter stenosis.

A confidence interval that crosses 0 indicates no significant mean difference; values >0 indicate that a larger minimal lumen diameter was achieved in the IVUS group over the angiography alone group.

Nonrandomized studies of in-hospital minimal lumen diameter: forest plot Figure 4 displays a forest plot of studies reporting the in-hospital minimal lumen diameter, IVUS-guided stent placement versus angiography-guided stent placement. The mean difference reported for individual studies by patients are: Blasini 1998 (-0.08, 95% CI -0.21, 0.05; Patients in IVUS 105, and Angio 107); Kim 2011 (0.00, 95% CI -0.07, 0.07; Patients in IVUS 487, and Angio 487); Youn 2011 (0.10, 95% CI 0.01, 0.19; Patients in IVUS 125, and Angio 216); Orford 2004 (0.13, 95% CI 0.08, 0.18; Patients in IVUS 731, and Angio 1434); Ozaki (CBA) 2007 (0.11, 95% CI 0.02, 0.20; Patients in IVUS 126, and Angio 99); Ozaki (BA) 2007 (0.14, 95% CI 0.05, 0.23; Patients in IVUS 122, and Angio 106); Park 2001 (0.00, 95% CI -0.20, 0.20; Patients in IVUS 77, and Angio 50); Agostoni 2005 (0.04, 95% CI -0.19, 0.27; Patients in IVUS 24, and Angio 34). Meta-analysis of the seven observational studies reporting data by patients (five rated as being at a medium risk of bias;(Blasini, 1998;Kim, 2011;Orford, 2004;Ozaki, 2007; Youn 2011) two at a high risk (Agostoni, 2005;Park, 2001) revealed no significant difference between IVUS-guided stent placement and angiography-guided stent placement: minimal lumen diameter summary net change = 0.07 mm (95 percent CI −0.01, 0.12; P=0.06). The mean difference reported for individual studies by lesions are: Sakamoto 1999 (0.22, 95% CI -0.04, 0.48; Patients in IVUS 18, and Angio 19); Albiero (late phase) 1997 (0.20, 95% CI -0.01, 0.41; Patients in IVUS 97, and Angio 97); Albiero (early phase) 1997 (0.48, 95% CI 0.35, 0.61; Patients in IVUS 76, and Angio 76); Gerber 2009 (0.44, 95% CI 0.25, 0.63; Patients in IVUS 47, and Angio 47); Yoshitomi 1999 (0.47, 95% CI 0.28, 0.66; Patients in IVUS 40, and Angio 29); Faulknier 2004 (0.38, 95% CI 0.35, 0.41; Patients in IVUS 70, and Angio 65); Fujimoto 2008 (-0.01, 95% CI -0.08, 0.06; Patients in IVUS 97, and Angio 271); Fitzgerald 2000 (0.20, 95% CI 0.12, 0.28; Patients in IVUS 290, and Angio 253). Meta-analysis of seven observational studies reporting lesion-level data (three rated as being at a medium risk of bias;(Albiero, 1997;Gerber, 2009;Sakamoto, 1999) four at a high risk (Faulknier, 2004; Fitzgerald, 2000;Fujimoto, 2008;Yoshitomi, 1999) revealed a significant difference indicating a favorable effect for IVUS-guided stent placement over angiography-guided stent placement: minimal lumen diameter summary net change = 0.29 mm (95 percent CI 0.16, 0.43; P<0.001).

In summary, for in-hospital MLD, the available RCTs and observational data showed conflicting results, and we therefore cannot draw a conclusion as to whether the use of IVUS significantly increases postprocedural MLD.

###### Medium-Term (Up to 1 Year) MLD

Meta-analysis of the net changes in MLD between IVUS-guided and angiography-guided stent placement groups, from baseline to medium-term (up to 1 year), across four RCTs23,29,31,33 found a significant favorable effect with IVUS over angiography alone (Figure 5). No sensitivity analysis by risk of bias was performed due to the small number of available studies per subgroup. Meta-analysis of the nonrandomized studies (two patient-level35,43 and four studies reporting five sets of lesion-level data34,39,45,46) revealed no significant difference between groups (Figure 6).

Figure 5 RCTs of medium-term minimal lumen diameter: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n = number

Notes: Estimates favoring IVUS are in the direction of the arrow, in contrast to Figures 7-10 on diameter stenosis.

A confidence interval that crosses 0 indicates no significant mean difference; values >0 indicate that a larger minimal lumen diameter was achieved in the IVUS group over angiography alone group.

RCTs medium-term minimal lumen diameter: forest plot Figure 5 displays a forest plot of studies reporting the medium-term (up to 1 year) duration minimal lumen diameter, IVUS-guided stent placement versus angiography-guided stent placement. The mean difference reported for individual studies, all reported by patients are: OPTICUS by Mudra 2001 (0.07, 95% CI -0.03, 0.17; Patients in IVUS 229, and Angio 228); RESIST by Schiele 1998 (0.16, 95% CI -0.02, 0.34; Patients in IVUS 79, and Angio 76); SIPS by Frey 2000 (0.04, 95% CI -0.19, 0.27; Patients in IVUS 24, and Angio 34); TULIP by Oemrawsingh 2003 (0.16, 95% CI -0.06, 0.26; Patients in IVUS 73, and Angio 71). Meta-analysis of the four RCTs (one of each rated at a low,(Mudra, 2001) medium,(Schiele, 1998;Frey, 2000;Oemrawsingh, 2003) found a significant favorable effect with IVUS-guided stent placement when compared with angiography-guided stent placement: summary mean difference 0.16 mm (95 % CI 0.06, 0.26; P = 0.002).

Figure 6 Nonrandomized comparative studies of medium-term minimal lumen diameter: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n = number

Notes: Estimates favoring IVUS are in the direction of the arrow, in contrast to Figures 7-10 on diameter stenosis.

A confidence interval that crosses 0 indicates no significant mean difference; values >0 indicate that a larger minimal lumen diameter was achieved in the IVUS group over angiography alone group.

Nonrandomized comparative studies of medium-term minimal lumen diameter: forest plot Figure 6 displays a forest plot of studies reporting the intermediate duration minimal lumen diameter, IVUS-guided stent placement versus angiography-guided stent placement. The mean difference reported for individual studies by patients are: Blasini 1998 (0.07, 95% CI -0.12, 0.26; Patients in IVUS 105, and Angio 107); Park 2001 (-0.20, 95% CI -0.51, 0.11; Patients in IVUS 77, and Angio 50). Meta-analysis of these studies revealed no significant difference between the groups (summary mean difference -0.04 mm (95 percent CI -0.30, 0.22; nonsignificant [NS]). The mean difference reported for individual studies by lesions are: Sakamoto 1999 (0.10, 95% CI -0.26, 0.46; Patients in IVUS 18, and Angio 19); Albiero (late phase patients) 1997 (-0.20, 95% CI -0.01, 0.41; Patients in IVUS 97, and Angio 97); Albiero (early phase patients) 1997 (0.56, 95% CI 0.36, 0.76; Patients in IVUS 76, and Angio 76); Fujimoto 2008 (-0.04, 95% CI -0.12, 0.04; Patients in IVUS 97, and Angio 271); Yoshitomi 1999 (0.52, 95% CI 0.18, 0.86; Patients in IVUS 40, and Angio 29). Meta-analysis of the four lesion-level observational studies (Albiero, 1997;Fujimoto, 2008;Sakamoto, 1999;Yoshitomi, 1999) two rated as being at a medium risk of bias; two at a high risk) revealed no significant difference between IVUS-guided stent placement and angiography-guided stent placement: summary mean difference 0.26 mm (95 percent CI -0.02, 0.54; NS).

In summary, the available RCTs and observational data demonstrated conflicting results in the medium term (up to 1 year), and therefore, we cannot draw a conclusion as to whether the use of IVUS significantly increases MLD during medium-term followup.

###### In-Hospital Diameter Stenosis

Among eight RCTs,23,25-29,31,33 meta-analysis of the five RCTs23,25-27,31 reporting data by patient revealed a significant difference in the net changes in percent diameter stenosis, indicating a favorable effect for IVUS-guided over angiography-guided stent placement (Figure 7). Meta-analysis of either the three RCTs that reported lesion-level data,28,29,33 or the 14 nonrandomized comparative studies that reported 16 data points (either at the patient- or lesion-level),34,35,37-42,45-48,52,55 revealed consistent small gains favoring IVUS, but there was no significant difference between groups (Figures 7 and 8).

In summary, the available studies demonstrated conflicting results, and we therefore cannot draw a conclusion as to whether the use of IVUS significantly decreases stenosis during postprocedural period.

Meta-analysis of the net changes in percent diameter stenosis between the IVUS-guided stenting group and the group receiving stenting guided by angiography alone, during medium-term followup, across four RCTs23,29,31,33 and four nonrandomized studies (reporting five sets of lesion-level data)34,39,45,46 revealed no significant difference between groups (Figures 9 and 10). The lone nonrandomized study (Blasini, 1998) analyzing data by patient reported a significant favorable effect of IVUS-guided stenting over angiography alone (Figure 10).35

In summary, the available studies demonstrated no significant difference between groups for the outcome of percent diameter stenosis in the medium term (up to 1 year).

###### In-Hospital Reference Vessel Diameter

Small nonsignificant gains favoring IVUS were found in the net changes in reference vessel diameter between the IVUS-guided and angiography guided stent placement groups, from baseline to postprocedure, in the four RCTs examined (Figure 11).26,29,31,33 No meta-analysis was performed due to the small number of RCTs per category (patient- or lesion-level). Of the nine nonrandomized comparative studies,34,35,38,39,41,45,48,50,55 the five reporting six sets of lesion-level data34,38,39,45,50 revealed a significant difference indicating a favorable effect for IVUS-guided stenting over stent procedures guided by angiography alone (Figure 12). Meta-analysis of the four patient-level nonrandomized comparative studies35,41,48,55 revealed no statistically significant difference between groups (Figure 12).

Figure 11 RCTs of in-hospital reference vessel diameter: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n = number

Notes: Estimates favoring IVUS are in the direction of the arrow, in contrast to Figures 7-10 on diameter stenosis.

A confidence interval that crosses 0 indicates no significant mean difference.

RCTs of in-hospital reference vessel diameter: forest plot Figure 11 displays a forest plot of the mean difference reported for individual studies by patients are: Oemrawsingh 2003 (0.11, 95% CI -0.06, 0.28; Patients in IVUS 73, and Angio 71; Medium risk); DIPOL (0.06, 95% CI -0.13, 0.25; Patients in IVUS 80, and Angio 83; Medium risk);The mean difference reported for individual studies by lesions are: Schiele (0.06, 95% CI -0.11, 0.23; Patients in IVUS 79, and Angio 76; Medium risk); OPTICUS by Mudra 2001 (0.01, 95% CI -0.08, 0.10; Patients in IVUS 229, and Angio 228; Low risk). No summary estimate was obtained.

Figure 12 Nonrandomized comparative studies of in-hospital reference vessel diameter: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n = number

Notes: Estimates favoring IVUS are in the direction of the arrow, in contrast to Figures 7-10 on diameter stenosis.

A confidence interval that crosses 0 indicates no significant mean difference.

Nonrandomized studies of in-hospital reference vessel diameter: forest plot Figure 12 displays a forest plot of studies reporting the in-hospital reference vessel diameter, IVUS-guided stent placement versus angiography-guided stent placement. The mean difference reported for individual studies by patients are: Blasini 1998(-0.03, 95% CI -0.18, 0.12; Patients in IVUS 105, and Angio 107); Kim 2011(0.00, 95% CI -0.06, 0.06; Patients in IVUS 487, and Angio 487); Orford 2004(0.10, 95% CI 0.05, 0.15; Patients in IVUS 731, and Angio 1434); Youn 2011(0.02, 95% CI -0.09, 0.13; Patients in IVUS 125, and Angio 216). Meta-analysis of the four patient-level observational studies (all rated as being at a medium risk of bias) revealed no statistically significant difference between IVUS-guided and angiography-guided stent placement: reference vessel diameter summary net change = 0.04 mm (95 percent CI −0.05, 0.0.12; P=0.28). The mean difference reported for individual studies are: Albiero (early phase) 1997 (0.09, 95% CI -0.01, 0.19; Patients in IVUS 76, and Angio 76); Sakamoto 1999 (0.06, 95% CI -0.27, 0.39; Patients in IVUS 18, and Angio 19); Albiero (late phase) 1997 (0.03, 95% CI -0.07, 0.13; Patients in IVUS 97, and Angio 97); Gerber 2009 (0.29, 95% CI 0.06, 0.52; Patients in IVUS 47, and Angio 47); Fitzgerald 2000 (0.10, 95% CI 0.02, 0.18; Patients in IVUS 290, and Angio 253); Fujimoto 2008 (0.00, 95% CI -0.07, 0.07; Patients in IVUS 97, and Angio 271). Meta-analysis of the five lesion-level studies (three were rated as being at a medium risk of bias;(Albiero, 1997;Gerber, 2009;Sakamoto, 1999) two at a high risk(Fitzgerald, 2000;Fujimoto, 2008) revealed a significant difference indicating a favorable effect for IVUS-guided stent placement over angiography-guided stent placement: reference vessel diameter summary net change = 0.07 mm (95 percent CI 0.01, 0.13; P=0.03).

In summary, the available studies demonstrated conflicting results, and we therefore cannot draw a conclusion as to whether the use of IVUS significantly changes reference vessel diameter during the postprocedural period.

###### Medium-Term (Up to 1 Year) Reference Vessel Diameter

Meta-analysis of the net changes in reference diameter between the IVUS-guided and angiography-guided stent placement groups, from baseline to medium-term, across three RCTs23,29,31 and three nonrandomized comparative studies (reporting four lesion-level data sets),34,39,45 revealed no significant difference between groups (Figures 13 and 14). The only nonrandomized comparative study analyzing data by patient reported no significant difference between groups.35

Figure 13 RCTs of medium-term reference vessel diameter: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n = number

Notes: Estimates favoring IVUS are in the direction of the arrow, in contrast to Figures 7-10 on diameter stenosis.

A confidence interval that crosses 0 indicates no significant mean difference.

RCTs of medium-term reference vessel diameter: forest plot Figure 13 displays a forest plot of studies reporting the intermediate duration reference vessel diameter, IVUS-guided stent placement versus angiography-guided stent placement. The mean difference reported for individual studies are: OPTICUS by Mudra 2001(-2.90, 95% CI -6.09, 0.29; Patients in IVUS 229, and Angio 228); SIPS 2000(0.13, 95% CI -0.04, 0.30; Patients in IVUS 121, and Angio 148); TULIP by Oemrawsingh 2003(0.11, 95% CI -0.06, 0.28; Patients in IVUS 73, and Angio 71). Meta-analysis of the three RCTs (one rated at a low,(Mudra, 2001) two medium,(Frey, 2000;Oemrawsingh, 2003) revealed no significant difference between IVUS-guided stent placement and angiography-guided stent placement: summary mean difference 0.11 mm (95 percent CI -0.08, 0.30; NS).

Figure 14 Nonrandomized comparative studies of medium-term reference vessel diameter: forest plot

Angio = angiography; CI = confidence interval; IVUS = intravascular ultrasound; n = number

Notes: Estimates favoring IVUS are in the direction of the arrow, in contrast to Figures 7-10 on diameter stenosis.

A confidence interval that crosses 0 indicates no significant mean difference.

Nonrandomized comparative studies of medium-term reference vessel diameter: forest plot Figure 14 displays a forest plot of studies reporting the intermediate duration percent diameter, IVUS-guided stent placement versus angiography-guided stent placement. The mean difference reported by patients for Blasini 1998 (0.03, 95% CI -0.13, 0.19; Patients in IVUS 105, and Angio 107). The mean difference reported for individual studies by lesions are: Albiero (late phase patients) 1997 (0.05, 95% CI -0.05, 0.15; Patients in IVUS 97, and Angio 97); Albiero (early phase patients) 1997 (0.22, 95% CI 0.11, 0.33; Patients in IVUS 76, and Angio 76); Sakamoto 1999 (0.06, 95% CI -0.27, 0.39; Patients in IVUS 18, and Angio 19); Fujimoto 2008 (-0.01, 95% CI -0.08, 0.06; Patients in IVUS 97, and Angio 271). Meta-analysis of the three lesion-level observational studies (Albiero, 1997;Fujimoto, 2008;Sakamoto, 1999) two rated as being at a medium risk of bias; one at a high risk) revealed no significant difference between IVUS-guided stent placement and angiography-guided stent placement: summary mean difference 0.08 mm (95 percent CI -0.04, 0.20; NS).

In summary, the available studies demonstrated no significant difference between groups for the outcome of reference vessel diameter in the medium term (up to 1 year).

###### Late Lumen Loss

Meta-analysis of three RCTs23,29,31 (summary mean difference in late lumen loss -0.001 mm [95% CI -1.13, 0.13; NS]) and one nonrandomized comparative study45 revealed no significant difference between groups in late lumen loss (figure not displayed).

Across all QCA outcomes, the available studies demonstrated either conflicting or nonsignificant results, and we therefore cannot draw a conclusion as to whether the use of IVUS significantly changes QCA outcomes at all time points.

###### Stent-Related Outcomes

###### In-Hospital and Medium-Term Restenosis

In-hospital restenosis rates were not significantly different between groups in one RCT29 and three nonrandomized comparative studies.34,43,53

Six RCTs provided data for binary restenosis at 6-month followup. Meta-analysis of six RCTs23,24,26,29-31,33 revealed a significantly lower risk (29%) of restenosis in the IVUS-guided group compared with the angiography alone group (Figure 15). Two small sample size RCTs found a statistically significant effect favoring IVUS use, while the remaining RCTs, including two of a large sample size, did not. A meta-analysis of five nonrandomized comparative studies (data by patients)35,42,43,45,46 found a 29 percent lower (though nonsignificantly so) risk of restenosis in the IVUS-guided group compared with the angiography alone group (Figure 15).

Figure 15 Medium-term restenosis: forest plot

CI = confidence interval; IVUS = intravascular ultrasound

Medium-term restenosis: forest plot Figure 15 displays a forest plot of studies reporting the relative risk of restenosis from both RCTs and nonrandomized comparative studies, IVUS-guided stent placement versus angiography-guided stent placement. The mean risk ratio reported for individual studies are: Gaster 2001 (0.62, 95% CI 0.28, 1.36; Total event in patients in IVUS 8/54, and Angio 13/54); TULIP by Oemrawsingh 2003 (0.50, 95% CI 0.31, 0.81; Total event in patients in IVUS 17/73, and Angio 33/71); DIPOL by Gil 2007 (0.37, 95% CI 0.17, 0.78; Total event in patients in IVUS 8/83, and Angio 21/80); SIPS by Frey 2000 (0.82, 95% CI 0.58, 1.17; Total event in patients in IVUS 35/121, and Angio 52/148); RESIST by Schiele 1998 (0.78, 95% CI 0.45, 1.37; Total event in patients in IVUS 16/71, and Angio 21/73); OPTICUS by Mudra 2001 (1.07, 95% CI 0.77, 1.49; Total event in patients in IVUS 56/229, and Angio 52/228). This figure is described further as follows: Six RCTs provided data for binary restenosis at 6-month followup.(Schiele, 1998;Gaster, 2001;Frey, 2000;Mudra, 2001;Gil, 2007;Oemrawsingh, 2003) Meta-analysis of these RCTs (one rated as being at a low risk of bias; five at a medium risk) revealed a significantly lower risk of restenosis in the IVUS-guided stent placement group, compared with the angiography-guided stent placement group (summary relative risk [RR] 0.71; 95 percent confidence interval [CI] 0.52, 0.96; P = 0.03). The mean risk ratio reported for individual studies are: Sakamoto 1999 (0.30, 95% CI 0.10, 0.90; Events in Patients in IVUS 3/17, and Angio 10/17); Blasini 1998 (0.70, 95% CI 0.44, 1.12; Events in Patients in IVUS 22/105, and Angio 32/107); REDUCE III 2007 (1.14, 95% CI 0.67, 1.96; Events in Patients in IVUS 25/122, and Angio 19/106); Park 2001 (0.96, 95% CI 0.42, 2.17; Events in Patients in IVUS 11/59, and Angio 8/41); Yoshitomi 1999 (0.41, 95% CI 0.15, 1.09; Events in Patients in IVUS 5/38, and Angio 9/28). Five observational studies analyzed data by patients and were included in meta-analysis.(Ozaki, 2007;Blasini, 1998;Park, 2001;Sakamoto, 1999;Yoshitomi, 1999) Meta-analysis of these five studies (three rated as being at a medium risk of bias; two at a high risk) found no significant difference in the risk of restenosis between the IVUS-guided stent placement and angiography-guided stent placement groups (summary RR 0.71; 95 percent CI 0.47, 1.09; NS).

We did not identify any studies that reported restenosis rates with greater than 1 year of followup.

In summary, the available studies demonstrated that the use of IVUS significantly decreases binary restenosis rates during medium-term followup.

###### Stent Thrombosis

No RCTs reported data on in-hospital subacute stent thrombosis. Of the three nonrandomized comparative studies that reported data on in-hospital subacute stent thrombosis, no instance of subacute stent thrombosis was reported in two,34,52 while the other reported no statistically significant difference between groups.48

Stent-related thromboses at 30 days were reported in six nonrandomized comparative studies; five studies reported either no events or no difference between groups,40,52-55 while the lone study identified a significantly higher incidence of cumulative stent thrombosis in the IVUS-guided group compared with the angiography alone group.44

Of the two RCTs that provided data for stent thrombosis in the medium duration timeframe,26,32 one reported no events in either of the groups,26 and the other reported no significant difference between groups at 1 year followup.32 No meta-analysis was performed for the RCTs due to the small number of studies. Of the five nonrandomized comparative studies that provided data on stent thrombosis,39,40,44,54,55 one reported no events in either of the groups at 8 months (lesion-level),39 one reported no difference at 6 months,40 two reported no difference at 1 year,54,55 and one reported a significant favorable effect of IVUS-guided stenting over stents placed using angiography alone, over 1 year of followup.44

One RCT27 and four nonrandomized comparative studies48,53-55 reported no significant difference in stent thrombosis between groups in the long-term followup.

A meta-analysis of nonrandomized studies found a significant decrease in the medium term (up to 1 year); however, this significance was lost after 2 years (Figure 16).

Figure 16 Medium- and long-term stent thrombosis: forest plot

CI = confidence interval; IVUS = intravascular ultrasound

Note: Long stent thrombosis indicates stent thrombosis occurring within 1 year; very long stent thrombosis indicates stent thrombosis occurring after 1 year.

Medium- and long-term stent thrombosis: forest plot Figure 16 displays a forest plot of studies reporting the relative risk of stent thrombosis, IVUS-guided stent placement versus angiography-guided stent placement. The mean risk ratio reported for individual studies for long stent thrombosis up to 1 year are: Roy 2008 (0.59, 95% CI 0.41, 0.86; Events in Patients in IVUS 41/884, and Angio 69/884); MATRIX 2011 (0.50, 95% CI 0.09, 2.72; Events in Patients in IVUS 2/548, and Angio 4/548); Youn 2011 (0.86, 95% CI 0.16, 4.65; Events in Patients in IVUS 2/125, and Angio 4/216). The summary risk ratio for long stent thrombosis was 0.60 (95 percent CI 0.42, 0.86; P = 0.04). The mean risk ratio reported for individual studies are: MATRIX 2011 (0.60, 95% CI 0.14, 2.50; Events in Patients in IVUS 3/548, and Angio 5/548); I-BIGIS 2011 (0.97, 95% CI 0.31, 3.07; Events in Patients in IVUS 3/226, and Angio 56/4088); Kim 2011 (0.33, 95% CI 0.03, 3.19; Events in Patients in IVUS 1/487, and Angio 3/487); Youn 2011 (0.86, 95% CI 0.22, 3.39; Events in Patients in IVUS 3/125, and Angio 6/126). The summary risk ratio for very long stent thrombosis was 0.75 (95 percent CI 0.37, 1.53; NS).

In summary, a small number of studies indicated a decreased risk of stent thrombosis in the medium and long terms favoring IVUS use.

###### Periprocedural Complications

Periprocedural complications (reported in three RCTs) during stent placement included: prolonged spasm after stent implantation (only in the IVUS-guided stent placement group);29 more vessel dissection requiring additional therapy in the IVUS group relative to the angiography alone group;32 and vessel dissection, intima peeling off the lumen, suboptimal stenting results, and nonQ wave MI (only in the angiography alone group).28 Among the nonrandomized studies, four reported no significant differences in dissection or abrupt closure between groups,34,44-46 though one reported a significantly lower rate of abrupt closure with IVUS compared with angiography alone.36

In summary, a small number of studies indicated no significant differences between groups with respect to periprocedural complications.

##### Patient-Centered Outcomes

###### All-Cause Mortality

Among the eight studies(3 RCTs,23,25,29 and 5 nonrandomized studies44,45,53-55) no in-hospital all-cause mortality was observed in RCTs. No in-hospital all-cause mortality was observed in one of the observational studies as well,45 while four nonrandomized comparative studies reported no statistically significant difference between groups.44,53-55 The available studies showed no significant difference for all-cause mortality during in-hospital stay.

In the medium timeframe, meta-analysis of five RCTs26,29,31-33 and eight nonrandomized comparative studies37,38,40,41,44,52,54,55 found no statistical significance in the risk of all-cause mortality between groups (Figure 17). The meta-analysis of RCTs revealed 84 percent higher risk in mortality with IVUS use as compared with angiography alone, while the meta-analysis of nonrandomized studies found 23 percent lower risk in mortality with IVUS versus angiography alone during stent deployment.

Figure 17 Medium-term all-cause mortality: forest plot

CI = confidence interval; IVUS = intravascular ultrasound

Medium-term outcome of all-cause mortality: forest plot Figure 17 displays a forest plot of studies reporting the relative risk of all-cause mortality, IVUS-guided stent placement versus angiography-guided stent placement. The mean risk ratio reported for individual studies are: AVID by Russo 2009 (1.74, 95% CI 0.69, 4.38; Events in Patients in IVUS 12/369, and Angio 7/375); OPTICUS by Mudra 2001 (4.98, 95% CI 0.59, 42.28; Events in Patients in IVUS 5/229, and Angio 1/228); RESIST by Schiele 1998 (1.03, 95% CI 0.07, 16.12; Events in Patients in IVUS 1/71, and Angio 1/73); DIPOL by Gil 2007 (0.96, 95% CI 0.06, 15.15; Events in Patients in IVUS 1/83, and Angio 1/80); TULIP by Oemrawsingh 2003 (1.95, 95% CI 0.18, 20.98; Events in Patients in IVUS 2/73, and Angio 1/71). Five RCTs provided data for all-cause mortality between 6 months and 1 year of followup.(Gil, 2007;Mudra, 2001;Oemrawsingh, 2003;Russo, 2009;Schiele, 1998) Meta-analysis of these five RCTs (two rated as being at a low risk of bias; three at a medium risk) found no significant difference in the risk of all-cause mortality between the IVUS-guided stent placement and angiography-guided stent placement groups (summary RR 1.84; 95 percent CI 0.88, 3.85; NS). The mean risk ratio reported for individual studies are: Maluenda 2010 (1.26, 95% CI 0.74, 2.17; Events in Patients in IVUS 24/382, and Angio 26/523); Faulknier 2004 (0.67, 95% CI 0.12, 3.82; Events in Patients in IVUS 2/50, and Angio 3/50); CRUISE by Fitzgerald 2000 (0.17, 95% CI 0.01, 3.52; Events in Patients in IVUS 0/270, and Angio 2/229); MATRIX 2011 (0.75, 95% CI 0.32, 1.77; Events in Patients in IVUS 9/548, and Angio 12/548); KAMIR 2011 (0.49, 95% CI 0.29, 0.83; Events in Patients in IVUS 16/1635, and Angio 121/6075); Roy 2008 (0.81, 95% CI 0.56, 1.16; Events in Patients in IVUS 50/884, and Angio 62/884); Youn 2011 (0.35, 95% CI 0.04, 2.92; Events in Patients in IVUS 1/125, and Angio 5/216); Orford 2004 (0.84, 95% CI 0.41, 1.72; Events in Patients in IVUS 8/796, and Angio 99/8274). Seven observational studies provided data for all-cause mortality between 6 months and 1 year of followup. The risk of bias was rated as medium in five studies,(Roy, 2008;Orford, 2004;Fitzgerald, 2000;MATRIX 2011;KAMIR 2011) and high in the other three studies.(Faulknier, 2004;Maluenda, 2010) Meta-analysis of these seven studies found no significant difference in the risk of all-cause mortality between the IVUS-guided stent placement and angiography-guided stent placement groups (summary RR 0.77; 95 percent CI 0.59, 1.00; NS).

With regards to long-term followup, meta-analysis of three RCTs23,25,27 found a 6 percent higher (though nonsignificantly so) risk of all-cause mortality with IVUS-guided stenting than with angiography-guided stent placement (Figure 18). The meta-analysis of three nonrandomized comparative studies48,49,53 found a statistically significant, 47 percent lower risk of all-cause mortality with IVUS-guided stenting than with angiography-guided stent placement during long-term followup (Figure 18). Of the three nonrandomized comparative studies that evaluated this outcome,48,49,53 two reported a point estimate indicating a favorable effect of IVUS-guided stent placement, but statistical significance was reached in only one.49 In summary, the available studies (across RCTs and nonrandomized studies) demonstrated either conflicting or nonsignificant results, and we therefore cannot draw a conclusion as to whether the use of IVUS significantly decreased all-cause mortality.

Figure 18 Long-term all-cause mortality: forest plot

CI = confidence interval; IVUS = intravascular ultrasound

Long-term all-cause mortality: forest plot Figure 18 displays a forest plot of studies reporting the relative risk of all-cause mortality, IVUS-guided stent placement versus angiography-guided stent placement. The mean risk ratio reported for individual studies are: SIPS by Frey 2000 (1.22, 95% CI 0.31, 4.79; Events in Patients in IVUS 4/121, and ANGIO 4/148); Gaster 2003 (0.20, 95% CI 0.01, 4.07; Events in Patients in IVUS 0/54, and ANGIO 2/54); HOME DES IVUS by Jakabcin 2010 (1.50, 95% CI 0.26, 8.79; Events in Patients in IVUS 3/105, and ANGIO 2/105). Meta-analysis of these three RCTs (Frey, 2000;Gaster, 2003;Jakabcin, 2010) found no significant difference in the risk of all-cause mortality between the IVUS-guided stent placement and angiography-guided stent placement groups (summary RR 1.06; 95 percent CI 0.38, 2.94). The mean risk ratio reported for individual studies are: Kim 2011 (0.78, 95% CI 0.29, 2.07; Events in Patients in IVUS 7/487, and ANGIO 9/487); Park 2009 (0.44, 95% CI 0.23, 0.85; Events in Patients in IVUS 12/201, and ANGIO 27/201); I-BIGIS 2011 (0.54, 95% CI 0.24, 1.20; Events in Patients in IVUS 6/226, and ANGIO 201/4088). The meta-analysis of three nonrandomized comparative studies found a statistically significant, 47 percent lower risk of all-cause mortality with IVUS-guided stenting than with angiography-guided stent placement during long-term followup (summary RR 0.53; 95 percent CI 0.34, 0.83; P<0.01).

###### Cardiac Mortality

We identified no RCT that reported cardiac mortality in the medium timeframe. Meta-analysis of five nonrandomized comparative studies36,40,44,52,54 demonstrated a 32 percent lower risk, but no statistical significance in the risk of cardiac mortality between groups (Figure 19).

Figure 19 Medium-term cardiac mortality: forest plot

CI = confidence interval; IVUS = intravascular ultrasound

Medium-term cardiac mortality: forest plot Figure 19 displays a forest plot of studies reporting the relative risk of cardiac mortality, IVUS-guided stent placement versus angiography-guided stent placement. The mean risk ratio reported for individual studies are: Roy 2008 (0.67, 95% CI 0.36, 1.25; Events in Patients in IVUS 16/884, and Angio 24/884); Choi 2001 (1.69, 95% CI 0.07, 41.17; Events in Patients in IVUS 1/178, and Angio 0/100); Maluenda 2010 (1.37, 95% CI 0.52, 3.62; Events in Patients in IVUS 8/382, and Angio 8/523); MATRIX 2011 (1.00, 95% CI 0.25, 3.98; Events in Patients in IVUS 4/548, and Angio 4/548); KAMIR 2011 (0.24, 95% CI 0.10, 0.60; Events in Patients in IVUS 5/1635, and Angio 76/6075). Five observational studies were included in meta-analysis.(Roy, 2008; Choi, 2001; Maluenda, 2010;MATRIX 2011;KAMIR 2011) Meta-analysis of these studies (five rated as being at a medium risk of bias; one at a high risk of bias) found no significant difference in the risk of cardiac mortality between the IVUS-guided stent placement and angiography-guided stent placement groups (summary RR 0.68; 95 percent CI 0.35, 1.34; NS).

None of the three RCTs reported data for cardiac mortality. One retrospective nonrandomized comparative study enrolling 975 patients reported a significantly lower rate of 3-year cardiac mortality in the IVUS-guided compared with the angiography-guided stent placement group (RR 0.32; 95% CI 0.18, 0.56; p<0.0001).49 Another study analyzing registry data of 1,504 patients reported no difference between groups at 2 years (1% vs. 1.8%; p=0.28).54

In summary, a small number of studies indicated a decrease in the risk of cardiac mortality with the use of IVUS, but without statistically significant differences between groups.

###### Myocardial Infarction

One RCT reported no instances of in-hospital acute MI25 while the other two RCTs,23,29 and two of the nonrandomized comparative studies34,45 found no statistically significant difference between groups. The remaining nonrandomized comparative study reported significantly lower rates of Q-wave MI in the IVUS than in the angiography alone group (0.1% in the IVUS group vs. 0.9% in the angiography alone group; p<0.02)44 Two additional nonrandomized studies52,53 found no statistically significant difference in acute MI between groups at 30 days. The remaining nonrandomized comparative study reported significantly lower rates of MI in the IVUS than in the angiography alone group at 30 days (adjusted hazard ratio [HR] 0.24; 95% CI 0.07, 0.77; p=0.02).54 The available studies showed no significant difference for MI during in-hospital stay.

Meta-analysis of four RCTs26,29,31,32 (34% lower risk) and nine nonrandomized comparative studies34,36-38,40,41,52,54,55 (no difference) that provided data for MI in the medium timeframe found no statistical significance in the risk of MI between groups (Figure 20).

Figure 20 Medium-term myocardial infarction: forest plot

CI = confidence interval; IVUS = intravascular ultrasound.

Medium-term myocardial infarction: forest plot Figure 20 displays a forest plot of studies reporting the relative risk of myocardial infarction, IVUS-guided stent placement versus angiography-guided stent placement. The mean risk ratio reported for individual studies are: OPTICUS by Mudra 2001 (0.60, 95% CI 0.22, 1.62; Events in Patients in IVUS 6/229, and Angio 10/228); AVID by Russo 2009 (1.34, 95% CI 0.75, 2.39; Events in Patients in IVUS 25/369, and Angio 19/375); TULIP by Oemrawsingh 2003 (0.19, 95% CI 0.02, 1.62; Events in Patients in IVUS 1/73, and Angio 5/71); DIPOL by Gil 2007 (0.24, 95% CI 0.03, 1.56; Events in Patients in IVUS 1/83, and Angio 4/80). Four RCTs provided data for MI between 6 months and 1 year of followup.(Gil, 2007;Mudra, 2001;Oemrawsingh, 2003;Russo, 2009) All but one of these RCTs recruited patients before the year 2000.(Gil, 2007) Meta-analysis of all four RCTs (two rated as being at a low risk of bias; two at a medium risk) found no significant difference in the risk of MI between the IVUS-guided stent placement and angiography-guided stent placement groups (summary RR 0.66; 95 percent CI 0.28, 1.56; NS). The mean risk ratio reported for individual studies are: CRUISE 2000 (1.15, 95% CI 0.59, 2.24; Events in Patients in IVUS 19/270, and Angio 14/229); Faulknier 2004 (2.00, 95% CI 0.19, 21.36; Events in Patients in IVUS 2/50, and Angio 1/50); Maluenda 2010 (0.87, 95% CI 0.56, 1.36; Events in Patients in IVUS 30/382, and Angio 47/523); Albiero 1997 (4.87, 95% CI 0.24, 100.71; Events in Patients in IVUS 2/158, and Angio 0/154); Choi 2001 (1.69, 95% CI 0.18, 15.99; Events in Patients in IVUS 3/178, and Angio 1/100); Orford 2004 (1.04, 95% CI 0.58, 1.87; Events in Patients in IVUS 12/796, and Angio 120/8274); MATRIX 2011 (0.38, 95% CI 0.19, 0.79; Events in Patients in IVUS 10/548, and Angio 26/548); Youn 2011 (0.58, 95% CI 0.12, 2.81; Events in Patients in IVUS 2/125, and Angio 6/216); KAMIR 2011 (1.78, 95% CI 1.09, 2.92; Events in Patients in IVUS 23/1635, and Angio 48/6075). Six observational studies analyzed data by patients, and were included in meta-analysis.(Albiero, 1997;Maluenda, 2010;Choi, 2001;Faulknier, 2004;Orford, 2004;Fitzgerald, 2000;MATRIX 2011; Youn 2011; KAMIR 2011) Meta-analysis of these nine studies (six rated as being at a medium risk of bias; three at a high risk) found no significant difference in the risk of MI between the IVUS-guided stent placement and angiography-guided stent placement groups (summary RR 1.00; 95 percent CI 0.69, 1.47; NS).

During long-term followup, meta-analysis of the three included RCTs23,25,27 found 63 percent lower risk of MI in the IVUS group compared with angiography alone group, but this did not reach statistical significance. The meta-analysis of five nonrandomized comparative studies also found no significant difference in the risk between the IVUS and angiography alone groups (Figure 21).48,49,53-55 In summary, the available studies showed no significant difference for MI during medium- and long-term followup.

Figure 21 Long-term myocardial infarction: forest plot

CI = confidence interval; IVUS = intravascular ultrasound.

Long-term myocardial infarction: forest plot Figure 21 displays a forest plot of studies reporting the relative risk of myocardial infarction, IVUS-guided stent placement versus angiography-guided stent placement. The mean risk ratio reported for individual studies are: SIPS by Frey 2000 (0.20, 95% CI 0.02, 1.67; Events in Patients in IVUS 4/121, and Angio 6/148); Gaster 2003 (3.00, 95% CI 0.12, 72.05; Events in Patients in IVUS 1/54, and Angio 0/54); HOME DES IVUS 2010 by Jakabcin (0.25, 95% CI 0.03, 2.20; Events in Patients in IVUS 1/105, and Angio 4/105). Meta-analysis of the three included RCTs (Frey, 2000;Gaster, 2003;Jakabcin, 2010) found no significant difference in the risk of MI between the IVUS-guided stent placement and angiography-guided stent placement groups (summary RR 0.37; 95 percent CI 0.09, 1.50; NS).The mean risk ratio reported for individual studies are: Park 2009 (1.31, 95% CI 0.82, 2.11; Events in Patients in IVUS 86/756, and Angio 19/219); Kim 2011 (0.38, 95% CI 0.10, 1.41; Events in Patients in IVUS 3/487, and Angio 8/487); MATRIX 2011 (0.39, 95% CI 0.20, 0.75; Events in Patients in IVUS 12/548, and Angio 31/548); I-BIGIS 2011 (1.21, 95% CI 0.64, 2.26; Events in Patients in IVUS 10/226, and Angio 150/4088); Youn 2011 (0.65, 95% CI 0.18, 2.40; Events in Patients in IVUS 3/125, and Angio 8/216). The meta-analysis of five nonrandomized comparative studies also found no significant difference in the risk between the IVUS and angiography alone groups (summary RR 0.76; 95 percent CI 0.42, 1.36; NS).

###### Repeat Revascularization

Data on repeat revascularization during in-hospital stay was reported in five RCTs23,24,26,29,31 and in five nonrandomized comparative studies.34,44,45,53,54 Meta-analysis of all five RCTs revealed a nonstatistically significant decrease in repeat revascularization during in-hospital stay in the IVUS group compared with the angiography alone group (summary RR 0.50; 95% CI 0.20, 1.27), without statistical heterogeneity (I^2^ = 0%) (figure not displayed). Among the nonrandomized comparative studies, two reported no patients undergoing repeat revascularization,34,45 two reported similar rates of repeat revascularization within 30 days,53,54 and one reported similar rates in the need for emergent CABG in both groups.44 The available studies showed no significant difference for repeat revascularization during in-hospital stay.

During medium-term followup, meta-analysis of all six RCTs24,26,29,31-33 with almost 1,800 patients revealed 30 percent significantly lower risk of clinically driven repeat revascularization among patients who received IVUS-guided stent placement compared with those who received stents guided by angiography alone (Figure 22). A meta-analysis of 11 of the nonrandomized comparative studies (data by 22,000 patients)34,36-38,40,41,44,45,52,54,55 found 19 percent lower risk, but no statistical significance in the risk of repeat revascularization between groups (Figure 22).

Figure 22 Medium-term repeat revascularization: forest plot

CI = confidence interval; IVUS = intravascular ultrasound

Medium-term repeat revascularization: forest plot Figure 22 displays a forest plot of studies reporting the relative risk of repeat revascularization, IVUS-guided stent placement versus angiography-guided stent placement. Six RCTs provided data for MI between 6 months and 1 year of followup. The mean risk ratio reported for individual studies are: OPTICUS by Mudra 2001 (1.07, 95% CI 0.72, 1.60; Events in Patients in IVUS 41/229, and Angio 38/228); AVID by Russo 2009 (0.68, 95% CI 0.44, 1.05; Events in Patients in IVUS 30/369, and Angio 45/375); TULIP by Oemrawsingh 2003 (0.40, 95% CI 0.18, 0.91; Events in Patients in IVUS 7/73, and Angio 17/71); Gaster 2001 (0.56, 95% CI 0.28, 1.09; Events in Patients in IVUS 10/54, and Angio 18/54); DIPOL by Gil 2007 (0.96, 95% CI 0.06, 15.15; Events in Patients in IVUS 1/83, and Angio 1/80); RESIST by Schiele 1998 (0.51, 95% CI 0.16, 1.63; Events in Patients in IVUS 4/71, and Angio 8/73). (Gaster, 2001;Gil, 2007;Mudra, 2001;Oemrawsingh, 2003;Russo, 2009;Schiele, 1998) Meta-analysis of these six RCTs (two rated as being at a low risk of bias; four at a medium risk) revealed a significantly lower risk of TVR among patients who received IVUS-guided stent placement compared with those who received angiography-guided stent placement (summary RR 0.70; 95 percent CI 0.51, 0.97; P = 0.03.) Eleven observational studies analyzed data by patients, and were included in meta-analysis.(Albiero, 1997;Choi, 2001;Faulknier, 2004;Fitzgerald, 2000;Maluenda, 2010;Orford, 2004;Roy, 2008;Sakamoto, 1999;MATRIX 2011; Youn 2011; KAMIR 2011). The mean risk ratio reported for individual studies are: CRUISE 2000 (0.56, 95% CI 0.34, 0.92; Events in Patients in IVUS 23/270, and Angio 35/229); Maluenda 2010 (0.92, 95% CI 0.58, 1.48; Events in Patients in IVUS 27/382, and Angio 40/523); Faulkiner 2004 (3.50, 95% CI 0.76, 16.03; Events in Patients in IVUS 7/50, and Angio 2/50); Sakamoto 1999 (0.20, 95% CI 0.05, 0.78; Events in Patients in IVUS 2/17, and Angio 10/17); Roy 2008 (0.95, 95% CI 0.70, 1.29; Events in Patients in IVUS 73/884, and Angio 7/884); Choi 2001 (0.59, 95% CI 0.33, 1.08; Events in Patients in IVUS 19/178, and Angio 18/100); Albiero 1997 (0.60, 95% CI 0.29, 1.22; Events in Patients in IVUS 11/158, and Angio 18/154); Orford 2004 (1.13, 95% CI 0.94, 1.36; Events in Patients in IVUS 110/796, and Angio 1010/8274); KAMIR 2011 (0.63, 95% CI 0.29, 1.41; Events in Patients in IVUS 7/1635, and Angio 41/6075); MATRIX 2011 (0.78, 95% CI 0.53, 1.17; Events in Patients in IVUS 40/548, and Angio 51/548); Youn 2011 (0.90, 95% CI 0.46, 1.75; Events in Patients in IVUS 12/125, and Angio 23/216). Meta-analysis of these 11 studies (eight rated as being at a medium risk of bias; three at a high risk) found no significant difference in the risk of TVR between the IVUS-guided stent placement and angiography-guided stent placement groups (summary RR 0.81; 95 percent CI 0.65, 1.01; NS).

During long-term followup, meta-analysis of the three included RCTs23,25,27 found a significantly 33 percent lower risk of repeat revascularization among patients who received IVUS-guided stent placement compared with those who received stents guided by angiography alone. The meta-analysis of five nonrandomized comparative studies that provided data for repeat revascularization, found no significant difference between groups (Figure 23).48,49,52,54,55

Figure 23 Long-term repeat revascularization: forest plot

CI = confidence interval; IVUS = intravascular ultrasound

Long-term repeat revascularization: forest plot Figure 23 displays a forest plot of studies reporting the relative risk of repeat revascularization, IVUS-guided stent placement versus angiography-guided stent placement. The mean risk ratio reported for individual studies are: SIPS by Frey 2000 (0.78, 95% CI 0.54, 1.12; Events in Patients in IVUS 33/121, and Angio 52/148); HOME DES IVUS 2010 (1.00, 95% CI 0.33, 3.00; Events in Patients in IVUS 6/105, and Angio 6/105); Gaster 2003 (0.55, 95% CI 0.39, 0.77; Events in Patients in IVUS 23/54, and Angio 42/54). Meta-analysis of the three included RCTs (Frey, 2000;Gaster, 2003;Jakabcin, 2010) found a significantly lower risk of TVR among patients who received IVUS-guided stent placement compared with those who received angiography-guided stent placement (summary RR 0.67; 95 percent CI 0.50, 0.90; P = 0.007). The mean risk ratio reported for individual studies are: Park 2009 (0.32, 95% CI 0.18, 0.56; Events in Patients in IVUS 23/756, and Angio 21/219); Youn 2011 (0.89, 95% CI 0.50, 1.60; Events in Patients in IVUS 15/125, and Angio 29/216); MATRIX 2011 (0.92, 95% CI 0.67, 1.28; Events in Patients in IVUS 61/548, and Angio 66/548); I-BIGLIS 2011 (1.23, 95% CI 0.89, 1.69; Events in Patients in IVUS 34/226, and Angio 501/4088); Kim 2011 (1.09, 95% CI 0.69, 1.72; Events in Patients in IVUS 36/487, and Angio 33/487). Meta-analysis of the five nonrandomized studies found no significant difference in the risk of MACE between IVUS-guided stenting and stent placement guided by angiography alone (summary RR 0.84; 95 percent CI 0.57, 1.25; NS).

In summary, the available studies demonstrated a significant reduction in repeat revascularization (defined heterogeneously across studies) with IVUS over angiography alone during medium- and long-term followup.

###### MACE

The overall rates of in-hospital MACE and its individual components of death, MI, and repeat revascularization were reported as similar between groups in two RCTs.29,31 Three nonrandomized comparative study reported similar findings,40,53,55 while one other identified a significantly lower incidence of MACE in the IVUS group compared with the angiography alone group.44 The available studies showed no significant difference for MACE during in-hospital stay.

Meta-analysis of five RCTs26,29,31-33 revealed a nonsignificantly lower risk (21%) of MACE during medium-term followup (up to 1 year), and eight nonrandomized studies36,37,40,41,44,52,54,55 found no significant difference in the risk of MACE between IVUS-guided stenting and stent placement guided by angiography alone (Figure 24). The definition of MACE varied considerably among studies (see Appendix C).

Figure 24 Medium-term MACE: forest plot

CI = confidence interval; IVUS = intravascular ultrasound; MACE = major adverse cardiac event

Medium-term MACE: forest plot Figure 24 displays a forest plot of studies reporting the relative risk of major adverse cardiovascular events, IVUS-guided stent placement versus angiography-guided stent placement. ). Five RCTs provided data for a composite of major adverse cardiovascular events (MACE) between 6 months and 1 year of followup.(Gil, 2007;Mudra, 2001;Oemrawsingh, 2003;Russo, 2009;Schiele, 1998). The mean risk ratio reported for individual studies are: OPTICUS by Mudra 2001 (1.06, 95% CI 0.75, 1.49; Events in Patients in IVUS 52/229, and Angio 49/228); AVID 2009 (0.99, 95% CI 0.73, 1.33; Events in Patients in IVUS 68/369, and Angio 70/375); TULIP 2003 (0.46, 95% CI 0.22, 0.95; Events in Patients in IVUS 9/73, and Angio 19/71); RESIST 1998 (0.57, 95% CI 0.20, 1.62; Events in Patients in IVUS 5/71, and Angio 9/73); DIPOL 2007 (0.44, 95% CI 0.18, 1.11; Events in Patients in IVUS 6/83, and Angio 13/80). Meta-analysis of all five RCTs (two rated as being at a low risk of bias; three at a medium risk) found no significant difference between groups (summary RR 0.79; 95 percent CI 0.57, 1.11; NS). The mean risk ratio reported for individual studies are: Maluenda 2010 (1.02, 95% CI 0.74, 1.41; Events in Patients in IVUS 55/382, and Angio 74/523); Faulkiner 2004 (2.20, 95% CI 0.82, 5.87; Events in Patients in IVUS 11/50, and Angio 5/50); KAMIR 2011 (1.07, 95% CI 0.87, 1.32; Events in Patients in IVUS 108/1635, and Angio 374/6075); Roy 2008 (0.90, 95% CI 0.72, 1.11; Events in Patients in IVUS 128/884, and Angio 143/884); MATRIX 2011 (0.68, 95% CI 0.48, 0.95; Events in Patients in IVUS 50/548, and Angio 74/548); Orford 2004 (1.12, 95% CI 0.94, 1.33; Events in Patients in IVUS 121/796, and Angio 1122/8274); Youn 2011 (0.69, 95% CI 0.37, 1.30; Events in Patients in IVUS 12/125, and Angio 30/216); Choi 2001 (0.62, 95% CI 0.35, 1.12; Events in Patients in IVUS 20/178, and Angio 18/100). Seven observational studies provided data for MACE between 6 months and 1 year of followup.(Choi, 2001;Faulknier, 2004;Maluenda, 2010;Orford, 2004;Roy, 2008;MATRIX 2011; Youn 2011; KAMIR 2011) Meta-analysis of these studies (three rated as being at a medium risk of bias; two at a high risk) found no significant difference in the risk of MACE between groups (summary RR 0.94; 95 percent CI 0.80, 1.11; NS).

Meta-analysis of all included studies with long-term followup (>1 year) found a lower risk of MACE (23% lower risk in three RCTs25,27,30 and 9% lower risk in six nonrandomized studies47-49,53-55) with IVUS over angiography alone; however, the results were not statistically significant (Figure 25).

Figure 25 Long-term MACE: forest plot

CI = confidence interval; IVUS = intravascular ultrasound; MACE = major adverse cardiac event

Long-term MACE: forest plot Figure 25 displays a forest plot of studies reporting the relative risk of MACE, IVUS-guided stent placement versus angiography-guided stent placement. The mean risk ratio reported for individual studies are: HOME DES IVUS 2010 (0.92, 95% CI 0.44, 1.93; Events in Patients in IVUS 12/105, and Angio 13/105); SIPS 2000 (0.82, 95% CI 0.59, 1.16; Events in Patients in IVUS 37/121, and Angio 54/148); Gaster 2003 (0.55, 95% CI 0.30, 0.99; Events in Patients in IVUS 12/54, and Angio 22/54). Meta-analysis of the three included RCTs (Frey, 2000;Gaster, 2003;Jakabcin, 2010) found no significant difference in the risk of MACE between the IVUS and angiography alone (summary RR 0.77; 95 percent CI 0.58, 1.01; NS). The mean risk ratio reported for individual studies are: Agostoni 2005 (0.40, 95% CI 0.09, 1.78; Events in Patients in IVUS 2/24, and Angio 7/34); Park 2009 (1.33, 95% CI 0.75, 2.38; Events in Patients in IVUS 24/201, and Angio 18/201); MATRIX 2011 (0.77, 95% CI 0.58, 1.03; Events in Patients in IVUS 71/548, and Angio 92/548); Youn 2011 (0.71, 95% CI 0.41, 1.21; Events in Patients in IVUS 16/125, and Angio 39/216); I-BIGILIS 2011 (1.08, 95% CI 0.81, 1.44; Events in Patients in IVUS 40/226, and Angio 670/4088); Kim 2011 (0.90, 95% CI 0.63, 1.27; Events in Patients in IVUS 53/487, and Angio 59/487). Meta-analysis of five observational studies (Agostoni, 2005;Kim, 2011;Park, 2009; MATRIX 2011; Youn 2011; I-BIGIS 2011) found no significant difference in the risk of MACE between groups (summary RR 0.91; 95 percent CI 0.75, 1.09; NS).

In summary, across all time points, the available studies indicated no significant difference for the outcome of MACE (defined heterogeneously across studies) between groups.

#### Other Intravascular Diagnostic Techniques Compared With Angiography Alone

One high risk of bias prospective nonrandomized study (with a historical comparator) compared FFR-guided additional therapy (dilation) during stent deployment with angiography-guided stenting. No firm conclusions could be drawn from this single high-risk-of-bias study.19 There were no comparative studies evaluating any other techniques.

## Key Question 3 For patients having just undergone a PCI, what is the impact of using an intravascular diagnostic technique and angiography to evaluate the success of stent placement immediately after the procedure—when compared with angiography alone—on therapeutic decisionmaking, intermediate, and patient-centered outcomes?

### Key Points

- There is insufficient evidence regarding the adjunctive use of intravascular diagnostic techniques immediately post-procedure, to evaluate the success of stent placement.
- Two studies, both evaluating IVUS were rated as being at a high risk of bias.
- No studies evaluated FFR or any other intravascular diagnostic technique on the success of stenting immediately after the procedure.

### Summary of Evidence

There is insufficient evidence regarding the comparisons of interest in this Key Question, as data were drawn from two studies, both evaluating IVUS and rated as being at a high risk of bias, with each reporting on two different types of outcomes at different time points. There is insufficient evidence for any intravascular diagnostic technique, as none of the reviewed studies evaluated the effect of FFR or any other intravascular diagnostic technique on the success of stent placement immediately post- procedure.

### Available Evidence

Two retrospective studies addressed this Key Question.57,58 Neither of these studies adjusted for potential confounders.

Nasu 2004 compared the use of IVUS with angiography in patients with either de novo or restenotic lesions who had a stand-alone directional coronary atherectomy (DCA) without angioplasty.57 The study did not provide baseline characteristics for the two groups separately. IVUS assessments were obtained for 38 patients with 38 lesions. This was compared with 53 patients (inferred from paper, not explicitly reported) with 63 lesions without IVUS assessments. No significant differences in postprocedure angiographic results were observed between the two groups: reference diameter (mm) (3.31 ± 0.17 [SD] vs. 3.36 ± 0.56 [SD], p=0.69); minimal luminal diameter (mm) (2.91 ± 0.35 [SD] vs. 2.79 ± 0.50 [SD], p=0.23); diameter stenosis (%) (12.6 ± 8.3 [SD] vs. 16.5 ± 10.5 [SD], p=0.07)). In addition, no significant differences in these parameters were observed at short- (4 to 10 months) or long-term (5 to 9 years) followup. No clinical outcomes were reported.

Seo 1996 evaluated the use of IVUS after stent placement in 83 patients with angina and classified them into sufficient and insufficient dilatation groups defined as luminal area <5 mm^2^ or luminal stenosis >60 percent by IVUS, respectively. Patients in the insufficient dilatation group consequently received additional treatments, including larger balloon, longer dilatation time, DCA, or stenting (35 of 83 patients; 42%). The IVUS after stenting (83 patients) was compared with no IVUS after stenting (192 patients). The observed incidence of restenosis at 3 to 6 months of followup was 17 percent in the IVUS versus 42 percent in the no IVUS after stent placement, respectively (statistical significance not reported).58

## Key Question 4 How do different intravascular diagnostic techniques compare to each other in their effects on therapeutic decisionmaking, intermediate outcomes, and patient-centered outcomes?

### Key Points

- There is insufficient evidence comparing different intravascular diagnostic techniques and their effects on outcomes
- Only one study rated as being at a high risk of bias provided relevant data for the comparison of FFR versus IVUS.

### Summary of Evidence

There is insufficient evidence regarding the comparison of FFR versus IVUS, as only one study rated as being at a high risk of bias provided relevant data. There is insufficient evidence for all other comparisons, as none of the studies reviewed examining other intravascular diagnostic techniques addressed this Key Question.

### Available Evidence

One retrospective study rated as being at a high risk of bias due to the potential for selection bias and lack of adjusted analyses addressed this Key Question.59 Nam 2010 compared the use of FFR-guided with IVUS-guided stent placement in patients with intermediate coronary lesions (40% to 70% diameter stenosis by visual assessment).59 The study included 167 consecutive patients (83 in the FFR group and 94 in the IVUS group). The use of FFR or IVUS was based on operator preference. The cutoff value for the use of PCI in the FFR group was 0.80 and 4 mm^2^ derived minimal lumen area in the IVUS group. Of 83 patients in the FFR group, 28 received stenting (34%), while 86 of 94 patients in the IVUS group received stenting (92%; p<0.001). The 1 year composite outcome of death/myocardial infarction/ischemia-driven target vessel revascularization was not significantly different between FFR and IVUS (3.6% vs. 3.2%; p=1.00). There were no significant differences between groups in postintervention MLD and percent diameter stenosis.

## Key Question 5 What factors (e.g., patient/physician characteristics, availability of prior noninvasive testing, type of PCI performed) influence the effect of intravascular diagnostic techniques and angiography—when compared with angiography alone (or among different intravascular diagnostic techniques)—on therapeutic decisionmaking, intermediate outcomes, and patient-centered outcomes?

### Key Points

- There is a moderate strength of evidence from one large sample size (9,070 patients) prospective study with a medium risk of bias that the effect of IVUS on outcomes did not vary by modifying factors including left main disease, sex, diabetes mellitus status, lesion length, and reference diameter.
- No studies addressed this Key Question for any technique other than IVUS.
- No studies addressed additional factors of interest, including chronic inflammation (e.g., systemic lupus erythematosus), and atherosclerosis following heart transplantation.

### Summary of Evidence

There is a moderate strength of evidence that the effect of IVUS on outcomes did not vary by factors such as left main disease, sex, diabetes mellitus status, lesion length, and reference diameter. There were no studies to address this Key Question for any technique other than IVUS.

### Available Evidence

Two studies, one multicenter prospective study (a post hoc RCT),41 and one single center retrospective study47 evaluated various factors that influenced the effect of IVUS-guided stenting on outcomes, compared with stent placement guided by angiography alone. The multicenter prospective study (a post hoc RCT), Orford 2004 was rated as being at a medium risk of bias due to potential for selection bias by excluding of subjects who refused to undergo followup angiography. The single center retrospective study, Agostoni 2005 was rated as being at a high risk of bias due to the potential for selection bias and lack of adjusted analyses. Both studies enrolled CAD patients with angina, silent ischemia or patients with left main coronary artery disease who were undergoing a PCI procedure with or without stenting.

The multicenter prospective study (post hoc RCT) included 9,070 patients with an average age of 60 years.41 The majority included were men (79%). The proportion of patients with diabetes was 24 percent, hypertension was 59 percent, and dyslipidemia was 67 percent. Smokers accounted for 24 percent, and the average ejection fraction was not reported in this study.47 The average followup period was 9 months.41

The single center retrospective study included 58 patients with an average age 63 years.47 The proportions of men included 68 percent. The proportions of patients with diabetes were 33 percent, hypertension was 59 percent, and dyslipidemia was 65 percent. Smokers accounted for 19 percent, and the average ejection fraction was 47 percent. The followup period for this study was 1 year.47

The multicenter prospective study (post hoc RCT), Orford 2004 evaluated various patient- and lesion-related factors—such as sex, diabetes mellitus status, lesion length, and reference vessel diameter—for their influence on the effect of IVUS-guided stent placement versus stenting guided by angiography alone, through interaction tests. These tests for interaction did not reach statistical significance for the composite clinical end point (any event), or any of their three individual components (death, myocardial infarction, or target-vessel revascularization; p>05).41

The retrospective study, Agostoni 2005 stratified patients on the basis of left main disease (nondistal vs. distal) and evaluated the effect of IVUS-guided PCI among patients with different anatomic left main disease.47 In multivariate analysis, patients with distal left main disease were significantly more likely to experience more adverse outcomes compared with those with nondistal left main disease (HR 7.7; 95% CI 1, 62.6, p=0.05).The stratification on the basis of left main disease (nondistal vs. distal) revealed that IVUS-guided PCI was performed less often in patients with distal left main disease (31%, 10 of 32) than in patients with nondistal left main disease (54%, 14 of 26) However, regardless of the differences in anatomic left main disease, the rate of events was not significantly different between the IVUS-guided PCI group and the non-IVUS-guided PCI group.

Other than these two studies of IVUS, we found no studies of other intravascular diagnostic techniques that evaluated factors influencing the effect of intravascular diagnostic techniques compared with angiography alone or different intravascular diagnostic techniques on outcomes.

We found no studies evaluating additional subgroups of interest, including patients with and without diabetes, patients with chronic inflammation (e.g., systemic lupus erythematosus), and patients with atherosclerosis following heart transplantation.