# References

1 Faxon DP, Fuster V, Libby P, et al. Atherosclerotic Vascular Disease Conference: Writing Group III: pathophysiology. Circulation. Jun. 1. 2004;109(21):2617-25. [pmid: 15173044].
2 Thygesen K, Alpert JS, White HD, et al. Universal definition of myocardial infarction. Circulation. Nov. 27. 2007;116(22):2634-53. [pmid: 17951284].
3 World Health Organization. Cardiovascular diseases fact sheet. 2011. www.who.int/mediacentre/factsheets/fs317/en/print.html. November 7, 2012.
4 Ford ES, Ajani UA, Croft JB, et al. Explaining the decrease in U.S. deaths from coronary disease, 1980-2000. N Engl J Med. Jun. 7. 2007;356(23):2388-98. [pmid: 17554120].
5 Odden MC, Coxson PG, Moran A, et al. The impact of the aging population on coronary heart disease in the United States. Am J Med. Sep. 2011;124(9):827-33. [pmid: 21722862].
6 Prevalence of Coronary Heart Disease-United States, 2006-2010. Centers for Disease Control and Prevention. MMWR Morb Mortal Wkly Rep. Oct. 14. 2011;60(40):1377-81. [pmid: 21993341].
7 Hillis LD, Smith PK, Anderson JL, et al. 2011 ACCF/AHA guideline for coronary artery bypass graft surgery: executive summary: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. J Thorac Cardiovasc Surg. Jan. 2012;143(1):4-34. [pmid: 22172748].
8 Levine GN, Bates ER, Blankenship JC, et al. 2011 ACCF/AHA/SCAI Guideline for Percutaneous Coronary Intervention: executive summary: a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines and the Society for Cardiovascular Angiography and Interventions. Catheter Cardiovasc Interv. Feb. 15. 2012;79(3):453-95. [pmid: 22328235].
9 Waxman S, Ishibashi F, Muller JE. Detection and treatment of vulnerable plaques and vulnerable patients: novel approaches to prevention of coronary events. Circulation. Nov. 28. 2006;114(22):2390-411. [pmid: 17130356].
10 Tobis J, Azarbal B, Slavin L. Assessment of intermediate severity coronary lesions in the catheterization laboratory. J Am Coll Cardiol. Feb. 27. 2007;49(8):839-48. [pmid: 17320741].
11 Maehara A, Mintz GS, Weissman NJ. Advances in intravascular imaging. Circ Cardiovasc Interv. Oct. 2009;2(5):482-90. [pmid: 20031760].
12 De BB, Pijls NH, Kalesan B, et al. Fractional flow reserve-guided PCI versus medical therapy in stable coronary disease. N Engl J Med. Sep. 13. 2012;367(11):991-1001. [pmid: 22924638].
13 Pijls NH, van SP, Manoharan G, et al. Percutaneous coronary intervention of functionally nonsignificant stenosis: 5-year follow-up of the DEFER Study. J Am Coll Cardiol. May. 29. 2007;49(21):2105-11. [pmid: 17531660].
14 ECRI Institute. Horizon Scanning Existing Technology Reports Coronary Intravascular Ultrasound - Draft Report. 2011.
15 Casella G, Klauss V, Ottani F, et al. Impact of intravascular ultrasound-guided stenting on long-term clinical outcome: a meta-analysis of available studies comparing intravascular ultrasound-guided and angiographically guided stenting. atheter Cardiovasc Interv. Jul. 2003;59(3):314-21.
16 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(12)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. April. 2012. www.effectivehealthcare.ahrq.gov.
17 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions. Agency for Healthcare Research and Quality. Methods Guide for Comparative Effectiveness Reviews. [posted July 2009]. Rockville, MD. www.effectivehealthcare.ahrq.gov.
18 Fearon WF, Bornschein B, Tonino PA, et al. Economic evaluation of fractional flow reserve-guided percutaneous coronary intervention in patients with multivessel disease. Circulation. Dec. 14. 2010;122(24):2545-50. [pmid: 21126973].
19 Muramatsu T, Tsukahara R, Ho M, et al. Usefulness of fractional flow reserve guidance for PCI in acute myocardial infarction. J Invasive Cardiol. Nov. 2002;14(11):657-62. [pmid: 12403892].
20 Pijls NH, Fearon WF, Tonino PA, et al. Fractional flow reserve versus angiography for guiding percutaneous coronary intervention in patients with multivessel coronary artery disease: 2-year follow-up of the FAME (Fractional Flow Reserve Versus Angiography for Multivessel Evaluation) study. J Am Coll Cardiol. Jul. 13. 2010;56(3):177-84. [pmid: 20537493].
21 Tonino PA, De BB, Pijls NH, et al. Fractional flow reserve versus angiography for guiding percutaneous coronary intervention. N Engl J Med. Jan. 15. 2009;360(3):213-24. [pmid: 19144937].
22 Wongpraparut N, Yalamanchili V, Pasnoori V, et al. Thirty-month outcome after fractional flow reserve-guided versus conventional multivessel percutaneous coronary intervention. Am J Cardiol. Oct. 1. 2005;96(7):877-84. [pmid: 16188509].
23 Frey AW, Hodgson JM, Muller C, et al. Ultrasound-guided strategy for provisional stenting with focal balloon combination catheter: results from the randomized Strategy for Intracoronary Ultrasound-guided PTCA and Stenting (SIPS) trial. Circulation. Nov. 14. 2000;102(20):2497-502. [pmid: 11076823].
24 Gaster AL, Slothuus U, Larsen J, et al. Cost-effectiveness analysis of intravascular ultrasound guided percutaneous coronary intervention versus conventional percutaneous coronary intervention. Scand Cardiovasc J. Mar. 2001;35(2):80-5. [pmid: 11405501].
25 Gaster AL, Slothuus SU, Larsen J, et al. Continued improvement of clinical outcome and cost effectiveness following intravascular ultrasound guided PCI: insights from a prospective, randomised study. Heart. Sep. 2003;89(9):1043-49. [pmid: 12923023].
26 Gil RJ, Pawlowski T, Dudek D, et al. Comparison of angiographically guided direct stenting technique with direct stenting and optimal balloon angioplasty guided with intravascular ultrasound. The multicenter, randomized trial results. Am Heart J. Oct. 2007;154(4):669-75. [pmid: 17892989].
27 Jakabcin J, Spacek R, Bystron M, et al. Long-term health outcome and mortality evaluation after invasive coronary treatment using drug eluting stents with or without the IVUS guidance. Randomized control trial. HOME DES IVUS. Catheter Cardiovasc Inter. Mar. 1. 2010;75(4):578-83. [pmid: 19902491].
28 Kawata M, Okada T, Igarashi N, et al. Assessment of intravascular ultrasound-bearing balloon catheter-guided percutaneous transluminal coronary angioplasty and stenting. Heart Vessels. Suppl 12. 1997:185-7. [pmid: 9476578].
29 Mudra H, Di MC, de JP, et al. Randomized comparison of coronary stent implantation under ultrasound or angiographic guidance to reduce stent restenosis (OPTICUS Study). Circulation. Sep. 18. 2001;104(12):1343-49. [pmid: 11560848].
30 Mueller C, Mc Hodgson JB, Brutsche M, et al. Impact of intracoronary ultrasound guidance on long-term outcome of percutaneous coronary interventions in diabetics--insights from the randomized SIPS trial. Swiss Med Wkly. Jun. 1. 2002;132(21-22):279-84. [pmid: 12362285].
31 Oemrawsingh PV, Mintz GS, Schalij MJ, et al. Intravascular ultrasound guidance improves angiographic and clinical outcome of stent implantation for long coronary artery stenoses: final results of a randomized comparison with angiographic guidance (TULIP Study). Circulation. Jan. 7. 2003;107(1):62-67. [pmid: 12515744].
32 Russo RJ, Silva PD, Teirstein PS, et al. A randomized controlled trial of angiography versus intravascular ultrasound-directed bare-metal coronary stent placement (the AVID Trial). Circ Cardiovasc Interv. Apr. 2009;2(2):113-23. [pmid: 20031704].
33 Schiele F, Meneveau N, Vuillemenot A, et al. Impact of intravascular ultrasound guidance in stent deployment on 6-month restenosis rate: a multicenter, randomized study comparing two strategies--with and without intravascular ultrasound guidance. RESIST Study Group. REStenosis after Ivus guided STenting. J Am Coll Cardiol. Aug. 1998;32(2):320-8. [pmid: 9708456].
34 Albiero R, Rau T, Schluter M, et al. Comparison of immediate and intermediate-term results of intravascular ultrasound versus angiography-guided Palmaz-Schatz stent implantation in matched lesions. Circulation. Nov. 4. 1997;96(9):2997-3005. [pmid: 9386168].
35 Blasini R, Neumann FJ, Schmitt C, et al. Restenosis rate after intravascular ultrasound-guided coronary stent implantation. Cathet Cardiovasc Diagn. Aug. 1998;44(4):380-6. [pmid: 9716200].
36 Choi JW, Goodreau LM, Davidson CJ. Resource utilization and clinical outcomes of coronary stenting: a comparison of intravascular ultrasound and angiographical guided stent implantation. Am Heart J. Jul. 2001;142(1):112-8. [pmid: 11431666].
37 Faulknier BA, Broce M, Baskerville S, et al. Clinical outcomes following IVUS-guided stent deployment in a community hospital. J Invasive Cardiol. Jun. 2004;16(6):311-5. [pmid: 15156000].
38 Fitzgerald PJ, Oshima A, Hayase M, et al. Final results of the Can Routine Ultrasound Influence Stent Expansion (CRUISE) study. Circulation. Aug. 1. 2000;102(5):523-30. [pmid: 10920064].
39 Fujimoto H, Tao S, Dohi T, et al. Primary and mid-term outcome of sirolimus-eluting stent implantation with angiographic guidance alone. J Cardiol. Feb. 2008;51(1):18-24. [pmid: 18522771].
40 Maluenda G, Lemesle G, Ben-Dor I, et al. Impact of intravascular ultrasound guidance in patients with acute myocardial infarction undergoing percutaneous coronary intervention. Catheter Cardiovascular Inter. Jan. 1. 2010;75(1):86-92. [pmid: 19670305].
41 Orford JL, Denktas AE, Williams BA, et al. Routine intravascular ultrasound scanning guidance of coronary stenting is not associated with improved clinical outcomes. Am Heart J. Sep. 2004;148(3):501-06. [pmid: 15389239].
42 Ozaki Y, Yamaguchi T, Suzuki T, et al. Impact of cutting balloon angioplasty (CBA) prior to bare metal stenting on restenosis. Circ J. Jan. 2007;71(1):1-8. [pmid: 17186970].
43 Park SJ, Hong MK, Lee CW, et al. Elective stenting of unprotected left main coronary artery stenosis: effect of debulking before stenting and intravascular ultrasound guidance. J Am College of Cardiol. Oct. 2001;38(4):1054-60. [pmid: 11583882].
44 Roy P, Steinberg DH, Sushinsky SJ, et al. The potential clinical utility of intravascular ultrasound guidance in patients undergoing percutaneous coronary intervention with drug-eluting stents. Eur Heart J. Aug. 2008;29(15):1851-7. [pmid: 18550555].
45 Sakamoto T, Kawarabayashi T, Taguchi H, et al. Intravascular ultrasound-guided balloon angioplasty for treatment of in-stent restenosis. Catheter Cardiovascular Interv. Jul. 1999;47(3):298-303. [pmid: 10402282].
46 Yoshitomi Y, Kojima S, Yano M, et al. Benefit of intravascular ultrasound in Wiktor stent implantation. Catheter Cardiovascular Inter. May. 1999;47(1):28-35. [pmid: 10385154].
47 Agostoni P, Valgimigli M, Van Mieghem CA, et al. Comparison of early outcome of percutaneous coronary intervention for unprotected left main coronary artery disease in the drug-eluting stent era with versus without intravascular ultrasonic guidance. Am J Cardiol. Mar. 1. 2005;95(5):644-7. [pmid: 15721110].
48 Kim JS, Hong MK, Ko YG, et al. Impact of intravascular ultrasound guidance on long-term clinical outcomes in patients treated with drug-eluting stent for bifurcation lesions: data from a Korean multicenter bifurcation registry. Am Heart J. Jan. 2011;161(1):180-7. [pmid: 21167352].
49 Park SJ, Kim YH, Park DW, et al. Impact of intravascular ultrasound guidance on long-term mortality in stenting for unprotected left main coronary artery stenosis. Circ Cardiovasc Interv. Jun. 2009;2(3):167-77. [pmid: 20031713].
50 Gerber RT, Latib A, Ielasi A, et al. Defining a new standard for IVUS optimized drug eluting stent implantation: the PRAVIO study. Catheter Cardiovascular Interv. Aug. 1. 2009;74(2):348-56. [pmid: 19213067].
51 Talley JD, Mauldin PD, Becker ER, et al. Cost and therapeutic modification of intracoronary ultrasound-assisted coronary angioplasty. Am J Cardiol. Jun. 15. 1996;77(15):1278-82. [pmid: 8677866].
52 Ahmed K, Jeong MH, Chakraborty R, et al. Role of intravascular ultrasound in patients with acute myocardial infarction undergoing percutaneous coronary intervention. Am J Cardiol. Jul. 1. 2011;108(1):8-14. [pmid: 21529735].
53 Biondi-Zoccai G, Sheiban I, Romagnoli E, et al. Is intravascular ultrasound beneficial for percutaneous coronary intervention of bifurcation lesions? Evidence from a 4,314-patient registry. Clin Res Cardiol. Nov. 2011;100(11):1021-8. [pmid: 21701872].
54 Claessen BE, Mehran R, Mintz GS, et al. Impact of intravascular ultrasound imaging on early and late clinical outcomes following percutaneous coronary intervention with drug-eluting stents. JACC Cardiovasc Interv. Sep. 2011;4(9):974-81. [pmid: 21939937].
55 Youn YJ, Yoon J, Lee JW, et al. Intravascular ultrasound-guided primary percutaneous coronary intervention with drug-eluting stent implantation in patients with ST-segment elevation myocardial infarction. Clin Cardiol. Nov. 2011;34(11):706-13. [pmid: 22057856].
56 Schiele F, Meneveau N, Seronde MF, et al. Medical costs of intravascular ultrasound optimization of stent deployment. Results of the multicenter randomized ‘REStenosis after Intravascular ultrasound Stenting’ (RESIST) study. Int J Cardiovasc Intervent. Dec. 2000;3(4):207-13. [pmid: 12431345].
57 Nasu K, Tsuchikane E, Awata N, et al. Quantitative angiographic and intravascular ultrasound study >5 years after directional coronary atherectomy. Am J Cardiol. Mar. 1. 2004;93(5):543-8. [pmid: 14996576].
58 Seo T, Yamao K, Hayashi T, et al. Intravascular ultrasound in determining the end point of percutaneous transluminal coronary angioplasty. J Cardiol. Oct. 1996;28(4):183-9. [pmid: 8934333].
59 Nam CW, Yoon HJ, Cho YK, et al. Outcomes of percutaneous coronary intervention in intermediate coronary artery disease: fractional flow reserve-guided versus intravascular ultrasound-guided. JACC Cardiovasc Inter. Aug. 2010;3(8):812-7. [pmid: 20723852].
60 Berry E, Kelly S, Hutton J, et al. Intravascular ultrasound-guided interventions in coronary artery disease: a systematic literature review, with decision-analytic modelling, of outcomes and cost-effectiveness. Health Tech Assess. 2000;4(35):1-117. [pmid: 11109031].
61 Parise H, Maehara A, Stone GW, et al. Meta-analysis of randomized studies comparing intravascular ultrasound versus angiographic guidance of percutaneous coronary intervention in pre-drug-eluting stent era. Am J Cardiol. Feb. 1. 2011;107(3):374-82. [pmid: 21257001].
62 Fiscella K, Tancredi D, Franks P. Adding socioeconomic status to Framingham scoring to reduce disparities in coronary risk assessment. Am Heart J. Jun. 2009;157(6):988-94. [pmid: 19464408].
63 Ioannidis JP, Ntzani EE, Trikalinos TA, et al. Replication validity of genetic association studies. Nat Genet. Nov. 2001;29(3):306-9. [pmid: 11600885].
64 Bech GJ, Pijls NH, De BB, et al. Usefulness of fractional flow reserve to predict clinical outcome after balloon angioplasty. Circulation. Feb. 23. 1999;99(7):883-8. [pmid: 10027810].
65 Hanekamp CE, Koolen JJ, Pijls NH, et al. Comparison of quantitative coronary angiography, intravascular ultrasound, and coronary pressure measurement to assess optimum stent deployment. Circulation. Mar. 2. 1999;99(8):1015-21. [pmid: 10051294].
66 Pijls NH, Klauss V, Siebert U, et al. Coronary pressure measurement after stenting predicts adverse events at follow-up: a multicenter registry. Circulation. Jun. 25. 2002;105(25):2950-4. [pmid: 12081986].
67 Lowe HC, Narula J, Fujimoto JG, et al. Intracoronary Optical Diagnostics: Current Status, Limitations, and Potential. JACC: Cardiovasc Inter. 2011;4:1257-70. [pmid: 22192367].
68 Stone GW, Maehara A, Lansky AJ, et al. A prospective natural-history study of coronary atherosclerosis. N Engl J Med. Jan. 20. 2011;364(3):226-35. [pmid: 21247313].