# Methods

The Tufts Evidence-based Practice Center (EPC) reviewed the existing body of evidence on the comparative effectiveness of intravascular diagnostic techniques versus angiography alone in therapeutic decisionmaking, intermediate outcomes, and patient-centered outcomes in the management of patients with coronary artery disease (CAD) who are undergoing coronary artery stenting. This report is based on a systematic review of the published scientific literature using established methodologies as outlined in the Agency for Healthcare Research and Quality's (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”16

## AHRQ Task Order Officer

The AHRQ Task Order Officer (TOO) assigned to this project was responsible for overseeing all aspects of this report. The TOO facilitated a common understanding among all parties involved in the project, resolved ambiguities, and fielded all EPC queries regarding the scope and processes of the project. The TOO and other staff at AHRQ reviewed the report for consistency, clarity, and to ensure that it conforms to AHRQ standards. Input from the TOO and other staff at AHRQ was incorporated during preparation of the draft and final report.

## External Expert Input

During topic refinement, the initial questions that had previously been nominated for this report were refined with input from a panel of Key Informants who included experts in interventional cardiology, interventional radiology, and noninterventional cardiology; representatives from relevant specialty societies; payers; and a patient representative. After a public review of the proposed Key Questions, the clinical experts were reconvened to form the Technical Expert Panel (TEP), which served in an advisory capacity to help translating the Key Questions into a research protocol, identify important issues, and define parameters for the review of evidence. Discussions among the EPC, TOO, and Key Informants (and subsequently, the TEP) occurred during a series of teleconferences and via email.

## Key Questions

Five Key Questions were posed. Four pertained to outcomes in patients with CAD on the use of intravascular diagnostic applications when compared with angiography (Key Questions 1–3), or different intravascular diagnostic techniques (Key Questions 4), and one (Key Question 5) addressed associations between factors (e.g., patient/physician characteristics, availability of prior noninvasive testing, type of PCI performed) that could influence the effect of intravascular diagnostic techniques compared with angiography (or among different intravascular diagnostic techniques) on outcomes. The exact wording of the Key Questions has been described in the Introduction.

## Analytic Framework

We developed an analytic framework (Figure 1) that maps the Key Questions within the context of the populations of interest, the interventions, comparator, and the outcomes of interest, and the chain of logic that evidence must support to link the interventions to improved health outcomes. The figure illustrates how intravascular diagnostic techniques—compared with angiography alone—may aid in decisions to stent coronary lesions (A in Figure 1), allow optimization of stent placement during PCI (B in Figure 1), and assessment of immediate results in patients after stent deployment to decide the need for additional procedures (C in Figure 1), and improve short-term (in hospital or discharge to 30 days), medium-term (>30 days to 1 year), and long-term (>1 year) outcomes. Angiography alone is the comparator for Key Questions 1–3. For Key Question 4, the comparator is a different intravascular diagnostic technique from the index intravascular diagnostic technique of interest (head-to-head comparisons of intravascular diagnostic techniques). For Key Question 5, the modifiers of treatment effect included patient/physician characteristics, availability of prior noninvasive testing, and the type of PCI performed.

Figure 1 Analytic framework

CAD = coronary artery disease; KQ = Key Question; MACE = major adverse cardiac events; MI = myocardial infarction; QoL = quality of life; TVR = target vessel revascularization

Analytic Framework: Figure 1 is an analytic framework that depicts the events that individuals experience while undergoing evaluation of coronary artery disease and treatment with revascularization, including medical therapy, coronary artery bypass grafting, and percutaneous coronary intervention with stenting. The framework includes the following: Patient Population of Interest, Treatment, Imaging and diagnostic techniques, Therapeutic decisionmaking, Intermediate-outcomes, and Patient-centered outcomes. Our patient population of interest is patients with coronary artery disease. The treatment is percutaneous coronary intervention with stent placement. Imaging and diagnostic techniques are intravascular diagnostic techniques and angiography. The outcomes are categorized first by therapeutic decisionmaking, intermediate-outcomes and patient-centered outcomes and further categorized by time points of short-term (in-hospital or up to 30 days), medium-term (more than 30 day to 1 year), and long-term (more than 1 year). The intermediate outcome measures are utilized to determine if the treatment is effective and include resource utilization, outcomes assessed by quantitative coronary angiogram, and stent-related outcomes. Patient-centered outcomes include death (any cause or cardiac), myocardial infarction, repeat revascularization, major adverse cardiac event, quality of life/satisfaction with treatment, and survival.

## Literature Search

We conducted literature searches for studies in MEDLINE^®^ (from inception to August 31, 2012) and the Cochrane Central Trials Registry^®^ (through the second quarter of 2012) without any language restriction. All studies conducted in adult human subjects were screened to identify articles relevant to each Key Question. Our search included terms for intravascular diagnostic techniques, myocardial ischemia, revascularization, stents, and relevant research designs (see Appendix A for complete search strings). We also reviewed the reference lists from recently published systematic reviews on intravascular diagnostic techniques for potentially eligible studies. We excluded narrative reviews, editorials, and letters to the editor.

With input from the TEP, we compiled a list of professional organization meetings that published oral presentations and poster abstracts on intravascular diagnostic techniques addressing our Key Questions. We retrieved and screened relevant abstracts from professional and summit conference meetings that were available online through the following resources: Transcatheter Cardiovascular Therapeutics (www.tctmd.com) indexed until June 2012, the American Heart Association (www.aha.org) indexed from 2009 through June 2012, and the American College of Cardiology (www.cardiosource.com) indexed from 2009 through June 2012. We also searched the ClinicalTrials.gov Web site to identify ongoing trials.

## Study Selection and Eligibility Criteria

We screened titles and abstracts of citations identified from our literature search using the predefined eligibility criteria. The titles and abstracts were initially screened by one investigator; rejected abstracts were rescreened by a second investigator. Abstracts equivocal for inclusion would trigger an automatic full-text review. Full-text articles of abstracts that met screening criteria were retrieved and examined by two investigators to confirm their eligibility. All disagreements were resolved in consultation with a senior investigator. Full-text articles published in non-English languages were translated using Google™ Translate (translate.google.com). We focused only on direct comparative studies for this review. We excluded studies of indirect comparisons or that lacked a distinct comparator group. We did not include studies that solely compared stenting versus medical therapy. We also excluded studies that compared different thresholds within a single intravascular diagnostic technique. Eligibility criteria for inclusion were as follows.

### Populations and Conditions of Interest

We included studies conducted in adults (≥18 years) with CAD who were undergoing coronary artery stenting. We included the following conditions of interest, if reported in individual studies: CAD due to intermediate coronary stenoses (40% to 70%), either ischemic or nonischemic; left main artery lesions; any type of complex coronary lesions (e.g., long diffuse lesions, tandem lesions, bypass conduit vessel lesions, bifurcation lesions, total occlusions, ostial lesions, stent thromboses, thrombotic and nonthrombotic lesions); types of acute coronary syndrome (ST segment elevation myocardial infarction [STEMI] and non-STEMI); unstable and stable angina; in-stent restenosis; and stent fractures.

Additional subgroups of interest for all Key Questions included: patients with and without diabetes; patients with chronic inflammation (e.g., systemic lupus erythematosus); patients with atherosclerosis following heart transplantation.

### Interventions

For all Key Questions, we included intravascular diagnostic techniques that evaluate morphological or physiological parameters of coronary lesions and are presently employed in clinical care. The most commonly employed intravascular diagnostic techniques included FFR and IVUS. If available, also included were interventions that are primarily investigational at present, such as IVUS-virtual histology, OCT, elastography, NIRS, thermography, angioscopy, and IMRI), and techniques measuring stenosis index and index of microcirculatory resistance.

For Key Question 5, the modifiers of treatment effect of interest included patient and physician characteristics, availability of prior noninvasive testing, and the type of PCI performed.

### Comparators

Coronary angiography was the comparison of interest for Key Questions 1, 2, 3, and 5. For Key Questions 4 and 5, head-to-head comparisons of two or more intravascular diagnostic techniques were included.

We did not include studies that solely compared stenting versus medical therapy. We also excluded studies that compared different thresholds within a single intravascular diagnostic technique.

### Outcomes

The outcomes of interest were categorized as therapeutic decisionmaking, intermediate outcomes, or patient-centered outcomes. Outcomes were measured at three time points: short-term (up to 30 days after the procedure), medium-term (>30 days to 1 year), and long-term (>1 year).

#### Therapeutic Decisionmaking

- Key Question 1: In patients with CAD, the change in the number of hemodynamically significant lesions after the application of intravascular diagnostic techniques, and the change in the decision about an interventional therapy (e.g., if stenting is needed) after the application of the intravascular diagnostic techniques
- Key Question 2: During PCI, the change in the type of stent or number of stents or length of stent after the application of intravascular diagnostic
- Key Question 3: Immediately after PCI, the change in the decision about the need for additional interventions or modifications to stent placement

#### Intermediate Outcomes

- Process outcomes (technical success rates assessed by QCA, such as proportion of successful completion of attempted procedures or proportion of interpretable results in completed procedures, total procedural time required, fluoroscopy time, and volume of contrast medium used)
- Periprocedural complications (e.g., vessel dissection, bleeding, repeat PCI, or emergency coronary bypass surgery)
- Resource utilization (e.g., number of guide catheters, wires, balloons, and stents)
- Stent-related complications (e.g., restenosis, acute stent thrombosis, and dissection)
- Other measures (e.g., cardiac imaging findings [such as ventricular function or myocardial perfusion], electrocardiographic ischemia, biochemical markers, noninvasive assessment using magnetic resonance imaging, and a high-intensity signal on Doppler flow wire during PCI)

#### Patient-Centered Outcomes

- Clinical outcomes that directly affect patient well-being or clinical status (e.g., death, MI, repeat revascularizations or composites of major adverse cardiac events [MACE], freedom from angina, quality of life, and quality-adjusted survival)

### Sample Size and Timing

We did not specify a minimum sample-size threshold. We included studies of any duration of followup.

### Eligible Study Designs

We included all comparative studies, including randomized controlled trials (RCTs) and nonrandomized comparative studies that provide data directly comparing intravascular diagnostic technique and angiography with angiography alone or one intravascular diagnostic technique with another. We excluded narrative reviews and case reports.

### Settings

Application of intravascular diagnostic techniques and use in the following settings were considered: tertiary care centers or community hospitals; in-hospital or stand-alone catheterization laboratories; and emergency or nonemergency catheterizations.

## Data Extraction

Each study extraction was conducted by one investigator and reviewed by at least one other. Any disagreements were resolved by discussion in team meetings. Data were extracted into standard forms in Microsoft^®^ Word. The basic elements included fields that addressed population characteristics, sample size, study design, analytic details, and outcomes.

We extracted data including basic demographics (such as age, sex, race); comorbidities (such as diabetes, hypertension); clinical characteristics (such as percent ejection fraction, location of stenosis, lesion type); and modifying factors associated with the application of intravascular diagnostic and outcomes. We tested the extraction form on several studies and revised the form as necessary before commencing full data extraction of all articles.

### Data Synthesis

To evaluate the effect of an intervention on outcomes, we performed DerSimonian and Laird random effects model meta-analyses of the risk ratio of binary data or mean differences of continuous outcomes between interventions where studies had sufficiently similar population and had the same comparison of interventions and the same outcomes. For each specific outcome of interest, we performed separate meta-analyses at specific time points (i.e., in-hospital, ≤1 year, and >1 year), chosen based on available relevant data. We sought input from the clinical expert (cardiologist) on our team to assess whether studies were too clinically heterogeneous for meta-analysis to be appropriate. For example, if target vessel revascularization was not reported, we used target lesion revascularization.

When possible, we preferentially evaluated the net change of continuous outcomes (the difference between the intervention of interest and the control intervention in the changes between final and baseline values). However, a large number of studies did not report full statistical analyses of the net change. Where sufficient data were reported, we calculated the net change values and estimated their standard error from reported standard deviations (or standard errors) of baseline and/or final values. For outcomes that were reported as final measurements, we conducted the weighted mean difference meta-analyses between final measurements. For each meta-analysis the statistical heterogeneity was assessed with the I^2^ statistic, which describes the percentage of variation across studies that is due to heterogeneity rather than chance. We performed sensitivity meta-analyses by excluding studies that were rated to have high risk of bias (see assessment of risk of bias) to see if these studies impacted inferences drawn from syntheses of studies with low and medium risk of biases only.

The findings of the report were presented according to the order of the Key Questions. Within each Key Question, findings were presented separately for therapeutic decisionmaking, intermediate, and patient-centered outcomes. They were further categorized by specific time periods: short term (in hospital, discharge to 30 days), medium-term (>30 days to 1 year), and long-term (>1 year). Outcome data were presented in evidence tables and were summarized in the full text and the Executive Summary of the report. All included studies were summarized in narrative form and in summary tables, which tabulated the important features of the study populations, design, intervention, outcomes, and results. We did not conduct statistical analyses to assess publication bias, as most of the statistical methods for detecting or correcting for publication bias have specific drawbacks. We attempted to mitigate the issue by searching grey literature sources available online (through June 2012) from www.tctmd.com, www.aha.org, and www.CardioSource.org.

### Summary Tables

Summary tables succinctly report measures of the main outcomes evaluated. We included information regarding study design, intravascular diagnostic technique, country, age data, gender data, sample size, study duration, patients' medical characteristics, and study quality. For continuous outcomes, we included the mean outcome values, their 95% confidence intervals (CI), standard deviations (SD) or other measures of variability, and when available, the mean difference (between groups) and its corresponding P value or CI, as appropriate. For categorical (dichotomous) outcomes, we reported the number of events and total number of patients for each intervention and relative risk metrics (odds ratios, risk ratios or hazard ratios) with their corresponding 95% CI and associated P value. We created separate summary tables based on the type of interventions and the type of outcomes.

### Risk of Bias (Overall Methodological Quality) of Individual Studies

We assessed the risk of biases (methodological quality) for each individual study using the assessment instrument detailed by the Agency for Healthcare Research and Quality in its “Methods Guide for Effectiveness and Comparative Effectiveness Reviews,” hereafter referred to as “the Methods Guide.”16 Briefly, we rated each study as being of high, medium, or low risk of bias on the basis of their adherence to well-accepted standard methodologies for studies including the Cochrane risk of bias tool for intervention studies, and assessed and reported each methodological quality item for all qualifying studies (Yes, No, or Unclear/Not reported). The overall judgment of risk of bias was based on the overall study conduct, specifically relating to selection, performance, attrition, detection, and selective outcome reporting biases. Two independent reviewers evaluated the risk of bias for each study, and all disagreements were resolved in consensus with a third reviewer.

### Grading the Body of Evidence

We graded the strength of the body of evidence for each analysis within the Key Questions as per the Methods Guide16 and an updated methods paper,17 with modifications as described below. The appraisal of the strength of evidence relied on studies rated as being at a low-or medium risk of bias. We assessed the consistency of the data as either “no inconsistency” or “inconsistency present” (or “not applicable” if only one study). The direction, magnitude, and statistical significance of all studies were evaluated in assessing consistency. We also assessed the precision and sparseness of the evidence. We considered evidence to be sparse if only one study of a small sample size addressed the analysis. Because this review assessed many outcomes within the categories of therapeutic decisionmaking, intermediate, and patient-centered clinical outcomes, we assessed the strength of evidence based on these three broad categories. However, the overall strength of evidence evaluation was based on patient-centered clinical outcomes, which we broadly define here as any outcomes that affect the patient's well-being.

We rated the strength of evidence with one of the following four strengths (as per the Methods Guide): High, Moderate, Low, and Insufficient. Ratings were assigned based on our level of confidence that the evidence reflected the true effect for the major comparisons of interest. Ratings were defined as follows:

High: There is high confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect. No important scientific disagreement exists across studies.

Moderate: There is moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate. Little disagreement exists across studies.

Low: There is low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate. Underlying studies may report conflicting results.

Insufficient: Evidence is either unavailable or does not permit a conclusion. There are sparse or no data. In general, the evidence is considered insufficient when only one study has been published, unless the study was particularly large, robust, and of good quality.

These ratings provide a shorthand description of the strength of evidence supporting the major questions we addressed. However, by necessity they may oversimplify the many complex issues involved in the appraisal of a body of evidence. It is important to remember that the individual studies evaluated in formulating the composite rating differed in their design, reporting, and quality. The strengths and weaknesses of the individual reports, as described in detail in the text and tables, should also be taken into consideration.

### Assessing Applicability

We assessed applicability of studies using the individual study eligibility criteria and baseline characteristics of the included population. Characteristics that could affect applicability to a wide population included narrow study eligibility criteria (e.g., narrow range of demographics) and dated studies using practices that are no longer applicable to contemporary practices. We also summarized how well the evidence applies to clinical practice. We provided an overall summary table describing key conclusions about applicability of bodies of evidence, and also provided comments on specific issues that affected applicability.

### Protocol Registration

A Comparative Effectiveness Review protocol was submitted and published on the AHRQ Effective Health Care Program Web site on August 29, 2011 (www.effectivehealthcare.ahrq.gov). Some minor amendments to the posted protocol were made at the time of preparation of this draft. These included a slight rewording of the Key Questions (e.g., PCI replaced by stenting), and a restructuring of the outcome categories (short-, intermediate-, and long-term outcomes were changed to therapeutic decisionmaking, intermediate outcomes, and patient-centered outcomes).