# Introduction

Coronary artery disease (CAD) involves narrowing (stenosis) of one or more of the epicardial coronary arteries. It is most commonly due to a buildup of plaque (atherosclerosis), which impedes the ability of these blood vessels to deliver oxygenated blood to the heart muscle (myocardium). This form of arteriosclerosis is characterized by a hardening of the arterial walls, cholesterol deposition, local inflammation, fibrosis, and progressive narrowing (stenosis) of the lumen of these vessels.1 It is a long-term health condition that affects populations with untreated or ineffectively treated risk factors, such as high blood pressure, high levels of cholesterol, diabetes, and smoking. Coronary atherosclerosis is a chronic disease with stable and unstable periods. Patients with stable angina usually experience effort-related symptoms. These symptoms arise because of an inability to augment myocardial blood flow in response to exertion, due to a fixed stenosis. During unstable periods, activated inflammation in the vascular wall may lead to atheromatous plaque rupture and thrombus formation, resulting in chest pain (unstable angina) or a heart attack (myocardial infarction [MI]).2

## Burden of Disease

Cardiovascular disease is a leading cause of morbidity and mortality worldwide, accounting for 17.3 million (30%) of all deaths globally in 2005; of these, 7.3 million were due CAD.3 Although, there has been a steady decline in the age-adjusted mortality rates for CAD,4 it is still the leading cause of death in the United States of both men and women.CAD is a major cause of disability and comprises a significant portion of the consumption of health care resources. In the United States alone, health care costs for management of CAD are projected to increase by 41 percent from $126.2 billion to $177.5 billion in 2040.^5^ In the United States in 2010, the prevalence of CAD among men was 7.8 percent and among women was 4.6 percent. Elderly (≥65 years of age), American Indians/Alaska natives and people with less than a high school education had the greatest prevalence of CAD that were 19.8 percent, 11.6 percent, and 9.2 percent, respectively.6

## Challenges of Diagnosing Coronary Stenoses

Treatment options for CAD vary according to the disease presentation (i.e., acute or chronic). The management of acute coronary syndrome may include the use of thrombolytics (“clot busting” medications), urgent or emergent percutaneous coronary intervention (PCI), or coronary artery bypass graft surgery (CABG) depending on clinical factors and the specific subtype (ST segment elevation and certain non-ST segment elevation syndromes, as defined by electrocardiogram). Adjunctive medical therapies in acute coronary syndromes include the use of antiplatelet and anticoagulant medications (blood thinners). For patients with stable CAD, mechanical revascularization (i.e., PCI or CABG) are indicated: 1) to improve survival in patients with high risk coronary anatomy (e.g., ≥50% left main coronary artery stenosis, or ≥70% stenoses in three major coronary arteries); 2) to improve symptoms in patients with unacceptable lifestyle limiting angina despite aggressive medical therapy, and with one or more significant (≥70% diameter) coronary artery stenoses amenable to revascularization. There are a number of details and variations of these revascularization guidelines, which are beyond the scope of the present review.7,8

PCI with stent deployment is currently the most commonly performed revascularization procedure for CAD. In determining the proper treatment course for patients with CAD, a number of treatment decisions must be made, including whether a particular lesion can be treated with medical therapy alone or whether it requires PCI or bypass grafting. If PCI is prescribed, the particulars of how to stent the lesion (stent size, length, material, and positioning) and, following the procedure, whether stenting was successful, must also be determined. PCI with stent deployment has traditionally been based on coronary angiography, an imaging technique for visualizing the interior of blood vessels that can be analyzed either qualitatively (visual inspection of the radiocontrast luminogram) or quantitatively (computer-based quantitation). While angiography is the standard technique for anatomic visualization of coronary arteries, it only visualizes an outline of the luminal wall and, generally, has limited ability in determining the functional severity of stenoses. Because the outer wall of the artery enlarges to accommodate the growing plaque (positive remodeling),9 angiographic evidence of stenosis is usually not detected until the plaque approaches 40 to 50 percent of the total cross-sectional area of the coronary artery. For intermediate ranges of coronary stenoses (40% to 70%), there is considerable variability between angiographic and physiologic assessments of stenoses severity, making it difficult to determine whether stenting will be needed, as angiography often under- or overestimates lumen dimensions.10 The use of angiography alone could lead to an underestimate of stenosis severity, possibly deferring a clinically indicated revascularization procedure, or to an overestimate of stenosis severity, possibly leading to unnecessary stenting procedures. In addition, angiography may not reveal the detailed morphology of complex lesions (e.g., ostial, graft, or bifurcation lesions) and lesions in left main coronary artery. Angiography also cannot provide information on the composition of the coronary plaque, which could be important in determining therapeutic choices.9 In addition, it is difficult to assess by angiography alone whether a stent is fully expanded and apposed to the intraluminal border, after stent implantation.

In order to address these limitations, several adjunctive intravascular diagnostic procedures and imaging techniques (collectively referred to as intravascular diagnostic techniques in this report) have been developed for the purpose of providing more detailed anatomic and hemodynamic information in coronary stenoses. Intravascular diagnostic techniques do not preclude the use of angiography; rather, they are complementary in nature by assisting treatment decisionmaking.11

One such intravascular diagnostic technique, fractional flow reserve (FFR), defined as the ratio of maximal blood flow in a stenotic coronary artery to normal maximal flow is used during coronary angiography to determine the physiological (functional) severity of coronary stenoses as opposed to simply visualizing anatomy with angiography. In this way, FFR may aid in deciding whether a lesion needs to be stented or whether stenting can be deferred.12,13 Other less commonly used techniques to determine the physiological severity of coronary stenosis include coronary flow reserve (CFR) and tests that measure the stenosis index and the index of microcirculatory resistance.

Among the intravascular diagnostic techniques used to visualize coronary anatomy, intravascular ultrasound (IVUS) is the most common. IVUS augments angiography by providing precise lesion characteristics, such as minimal and maximal lumen diameters, cross-sectional area, and plaque area. Other intravascular diagnostic techniques to visualize coronary anatomy that are less commonly used or are still evolving include IVUS-virtual histology, integrated backscatter IVUS, optical coherence tomography (OCT), near-infrared spectroscopy (NIRS), angioscopy, thermography, and intravascular magnetic resonance imaging (IMRI).

## Proposed Advantages of Intravascular Diagnostic Techniques

Intravascular diagnostic techniques are potentially valuable in a number of clinical scenarios. For example, IVUS provides precise visualization of intracoronary anatomy, atherosclerotic plaque composition, and changes in vessel dimensions. It could be used in stent deployment and optimization, thereby improving long-term clinical outcomes. Conversely, FFR might help identify patients whose stenoses are not really impeding flow and thereby reduce the number of stents used and limit patient exposure to the risks of the initial or repeat revascularization procedures and antiplatelet agents.12,13

While intravascular diagnostic techniques do provide additional anatomic and hemodynamic information during PCI, they are invasive techniques, and their application can potentially result in procedure-related complications or increased procedural times and high initial costs. The use of these adjunctive invasive procedures themselves could lead to additional invasive tests or treatments that can adversely impact long-term clinical outcomes. Therefore, it is important to assess whether the additional diagnostic information produced actually translates into benefits to patients that outweigh the risks. These decisions are not always straightforward. Invasive intravascular diagnostic modalities have emerged as potentially important complementary tools to angiography, as other available noninvasive imaging techniques for evaluating stenoses are inferior in a number of respects, such as having much lower resolutions than invasive techniques (e.g., cardiac computed tomography compared with IVUS).

## Current Uncertainties About Intravascular Diagnostic Techniques

Recent clinical practice guidelines have indicated that FFR and IVUS can be useful in certain clinical contexts—specifically, FFR in determining the necessity of stenting in angiographically borderline-significant lesions, and IVUS for providing technical guidance during PCI and optimizing stent deployment results.7,8 The systematic reviews currently available do not comprehensively examine the role of intravascular diagnostic techniques in relation to the settings of interest (tertiary care and other hospital settings), and are not generally applicable to contemporary practice, as recent literature has not yet been thoroughly reviewed (e.g., application of intravascular diagnostic techniques during PCI and deployment of the newer drug-eluting stents). Furthermore, variation in how intravascular diagnostic techniques are adopted in clinical practice across catheterization laboratories reflects considerable uncertainty regarding the utility and role of these techniques.14 Thus, a Comparative Effectiveness Review on the use of intravascular diagnostic applications in patients with CAD is timely and necessary to assess the clinical impact of incorporating such techniques into coronary revascularization procedures.

## Narrative Description of Intravascular Diagnostic Techniques

### Reference Diagnostic Technique: Angiography

Angiography is the current reference standard for identifying coronary artery lesions. It provides 2-dimensional silhouette image information about the luminal diameter and enables visualization of the luminal surface to diagnose atherosclerotic disease. The stenosis severity by angiography is reported as a ratio of the stenosis' minimal lumen diameter (MLD) to the adjacent “normal” reference segment. Computer-assisted, automated, edge-detection algorithm systems are often used to quantify coronary stenoses more accurately (e.g., quantitative coronary angiography [QCA]). Angiography may underestimate the degree of stenosis or atheroma burden, particularly in the setting of diffuse CAD, or because of the positive remodeling phenomenon with outward displacement of the external vessel wall that prevents plaque from encroaching into the lumen. The use of angiography alone could also lead to an underestimate of stenosis severity, possibly deferring a clinically indicated revascularization procedure, or could lead to an overestimate of stenosis severity, possibly leading to unnecessary stenting procedures.

### Index Diagnostic Techniques

A description of intravascular diagnostic-manufacturers and regulatory status is provided in Appendix D.

### Intravascular Physiologic Testing Techniques

#### Coronary Flow Reserve

CFR utilizes invasive physiologic testing to assess the functional significance of a coronary stenosis. Measurements of CFR are obtained utilizing a Doppler-sensor-tipped intravascular wire to determine the ratio of hyperemia to basal mean flow velocity just distal to the coronary stenosis in question. This ratio is obtained from flow measurements before and immediately after the administration of a vasodilator, such as adenosine. The CFR decreases with increased lesion severity. A CFR <2.0 is typically used as a threshold to determine if an intermediate coronary lesion is physiologically significant (Table 1); however, CFR measurements have not been standardized for guiding stent placement during PCI.

Table 1 Catheter-based anatomic and physiologic criteria associated with clinical outcomes

Application | IVUS | CFR | FFR
Ischemia detection | <3-4 mm^2^ | <2 | <0.8
Deferred angioplasty | NA | >2 | >0.8
Endpoint of stenting | >9 mm^2^; >80% reference area; full apposition (depending on vessel size and volume plus morphology of plaque and target vessel segment) | | >0.94 (depending on diffuse disease in persistent segment)

CFR = coronary flow reserve; FFR = fractional flow reserve; IVUS = intravascular ultrasound; NA = not applicable

The major limitation in assessing a coronary stenosis with CFR is the influence of microvascular impairment on CFR values. When microvascular circulation is compromised by ventricular hypertrophy or diabetes mellitus, then the CFR may be less than 2.0 (abnormal). An abnormal CFR does not differentiate whether an abnormality exists in the epicardial coronary artery or in the microcirculation. To overcome this limitation, the measurement of an adjacent “normal” coronary vessel has been proposed to provide values for a relative CFR. However, this requires interrogation of an additional vessel, which extends the procedural time and may result in additional complications. Because of these limitations, CFR has not gained wide-spread acceptance.

#### Fractional Flow Reserve

Coronary pressure wire-derived FFR is defined as the ratio of maximal blood flow achievable in a stenotic coronary artery relative to the maximal flow in the same vessel if it were normal. This index represents the fraction of the normal maximal myocardial flow that can be achieved despite coronary stenosis. Flow measurements are obtained readily by advancing a pressure sensor-tipped coronary angioplasty guide wire across a stenosis and recording the distal pressure at rest and at maximal hyperemia induced with intracoronary or intravenous infusion of the vasodilator adenosine. The ratio between the mean distal pressure at maximal hyperemia and the mean aortic pressure is the FFR. Unlike CFR, FFR is independent of changes in heart rate, blood pressure, or prior infarction, and takes into account the contribution of collateral blood flow. The normal FFR for all vessels under all hemodynamic conditions is 1.0, regardless of the status of microcirculation. An FFR value >0.80 generally excludes ischemia related to a specific stenosis.8 The presence of conditions that limit achievement of maximal hyperemia, such as small vessel, diffuse disease, infarcted myocardium, or left ventricular hypertrophy, diminish the reliability of FFR.

FFR can also accurately determine the hemodynamic significance of serial coronary lesions when performed via a slow “pull back method” during continuous intravenous infusion of adenosine, with avoidance of unnecessary procedures that may not provide additional hemodynamic benefit. The long-term followup of the DEFER trial evaluated the appropriateness of stenting a functionally nonsignificant stenosis, and demonstrated that stenting nonsignificant lesions does not improve patient outcome.13 Five-year outcome after deferral of PCI based on an FFR ≥ 0.75 indicated a low risk of cardiac death or myocardial infarction related to such a stenosis of approximately 1 percent per year (a rate not decreased by stenting).Once a PCI is performed, adequacy of the PCI result can be assessed by FFR with established criterion for a successful stent placement an FFR value of >0.94 (Table 1).

Clinical adoption of FFR varies widely, influenced by geographic factors, physician preferences, provider settings (hospital-employed vs. private practice interventionists) and insurance coverage. FFR is currently covered by the Centers for Medicare and Medicaid (CMS) for reimbursement.

### Intravascular Imaging Techniques

#### Intravascular Ultrasound

IVUS is a catheter-based technique that provides tomographic images perpendicular to the length of the coronary arteries. During PCI, IVUS provides high-resolution images of the vessel and lumen geometry, and enables analysis of plaque composition and distribution, as well as guidance of coronary artery stent implantation. IVUS can also be used to quantitatively assess revascularization success or diagnose stent-related complications.15 However, it does not directly measure the hemodynamic effects of a stenosis. Limitations of the technique include the inability to discriminate between fibrous and lipid-rich plaques and the fact that thrombus formation cannot be easily detected. Modifications of IVUS using analysis of integrated backscatter and the radiofrequency envelope have been reported to improve resolution and sensitivity for the detection of lipid-rich plaques. IVUS elastography that combines ultrasound images with radiofrequency measurements may be able to better detect regions of increased strain prone to rupture. In an effort to improve plaque characterization, IVUS-virtual histology was developed, which combined frequency and amplitude analysis and used an algorithm developed from known tissue types to detect plaques with vulnerability features.

IVUS has been used to guide and optimize stent implantation. It allows the operator to visualize how well the stent is deployed, quantify the residual luminal diameter, and detect complications of stent implantation that require immediate management, such as stent-edge dissections. IVUS offers optimal stent deployment with only minimal residual luminal stenosis. Attainment of a large luminal diameter minimizes the risk of both stent thrombosis and restenosis. IVUS may have potential value for the stenting of long lesions, bifurcation, ostial and undilatable lesions and for saphenous vein grafts. IVUS is currently covered by CMS for reimbursement.

#### Optical Coherence Tomography

OCT measures the echo time delay and intensity of backscattered light due to internal microstructure in the tissue in order to create high-resolution (10 μm) cross-sectional images. Because of the short wavelength of OCT, it will reflect (and detect) very small objects, including blood cells. Therefore, in order for OCT to image the vessel wall, it requires a blood-free field. The original time-domain OCT technique requires continuous flushing with proximal balloon occlusion to displace the blood. Recently, faster data and image acquisition with optical frequency domain imaging has enabled rapid (i.e., 15 to 30 mm/s) imaging with only a 3 to 5 second contrast or saline injection through the guiding catheter (without the need for proximal balloon occlusion). The proposed advantages of OCT are that it provides a clearer picture of plaque structures than IVUS. The potential disadvantage of OCT is limited tissue penetration and, therefore, its inability to consistently image the adventitia and assess plaque burden. The diagnostic information provided by OCT pertains to the very detailed anatomic imaging of plaques, thus making the technique potentially useful for the detection and treatment plaques that are at risk of rupture and also for the assessment of stent apposition. No potential role of OCT in helping to make treatment decisions for intermediate lesions has been described. Recent data suggest that OCT imaging can be performed with similar safety profile as IVUS. The United States Food and Drug Administration (FDA) has recently cleared an OCT device (LightLab Imaging, Inc., Westford, MA) for high resolution vessel and lumen morphology, but CMS does not currently reimburse OCT imaging.

#### Angioscopy

Intracoronary angioscopy facilitates direct visualization of the plaque surface, color of the luminal surface, presence of thrombus, and macroscopic features of the arterial wall. Angioscopy can assess plaque color and detect red and white thrombus and surface characteristics, such as ulcerations, fissures and flaps. Angioscopy visualizes the luminal surface but is insensitive to subtle differences in plaque. Therefore, the major role of angioscopy is limited to the assessment of the lumen structure before and after interventions. However, angioscopy is rarely used in clinical practice, because it requires a blood-free field of view. The technique, nevertheless, remains valuable for research purposes, with most use occurring in Japan. This imaging modality is not currently covered by CMS.

#### Near Infrared Spectroscopy

NIRS employs a catheter containing an optic fiber that is used to measure diffuse reflectance signals with near infrared light as an energy source. NIRS yields information about the plaque chemical composition via the pattern of absorption of the light in relation to the wavelength. This pattern is unique for lipid and each of the other plaque elements. A NIRS device (Lipiscan) has been recently cleared by the FDA for the detection of lipid-rich plaque. The clinical premise of NIRS is that lipid-rich plaques could be detected before performing PCI and thus therapeutic decisions could be tailored to the chemical composition of the plaque (e.g., use of embolic protection devices, selection of stent type). The major limitation of NIRS is that it provides compositional but not structural information. This imaging modality is not currently covered by CMS.

#### Thermography

Thermography is a catheter-based technique to detect heat released by activated inflammatory cells of atherosclerotic plaques. Temperature differences correlate positively with cell (macrophage) density, which may predict plaque disruption and thrombosis. However, there is no clear evidence that temperature differentials correlate with specific plaques that are at risk of rupture, and without the structural definition obtained from high-resolution imaging techniques, the role of thermography is limited. This imaging modality is not currently covered by CMS.

#### Intravascular Magnetic Resonance Imaging

Plaque characterization by IMRI may be useful in the detection of plaques with necrotic core and intraplaque hemorrhage. In this technique, an intravascular coil is inserted into the artery or the adjacent vein. IMRI yields adequate resolution to discriminate plaque components, including lipid, collagen, thrombus, and calcium on the basis of biochemical properties. Technical limitations exist in the IMRI coil designs, however, requiring multiple catheter manipulations and repeated imaging. Image quality is also reduced significantly as the intravascular coil moves off axis from the external magnet field. This imaging modality is not currently covered by CMS.

## Scope of the Review

This review systematically evaluates the comparative effectiveness of intravascular diagnostic techniques versus angiography alone, as well as among different intravascular diagnostic techniques, in patients with CAD who are undergoing coronary artery stenting. This review evaluates the factors influencing the effect of intravascular diagnostic techniques on outcomes, as compared with angiography alone (or different intravascular diagnostic techniques).

## Key Questions

Our review focused on five Key Questions.

Key Question 1: In patients with CAD, what is the impact of using an intravascular diagnostic technique and angiography in deciding whether a coronary lesion requires intervention—when compared with angiography alone—on therapeutic decisionmaking, intermediate outcomes, and patient-centered outcomes?

Key Question 2: For patients undergoing PCI, what is the impact of using an intravascular diagnostic technique and angiography to guide the stent placement (either immediately prior to or during the procedure)—when compared with angiography alone—on therapeutic decisionmaking, intermediate outcomes, and patient-centered outcomes?

Key Question 3: For patients having just undergone a PCI, what is the impact of using an intravascular diagnostic technique and angiography to evaluate the success of stent placement immediately after the procedure—when compared with angiography alone—on therapeutic decisionmaking, intermediate outcomes, and patient-centered outcomes?

Key Question 4: How do different intravascular diagnostic techniques compare to each other in their effects on therapeutic decisionmaking, intermediate outcomes, and patient-centered outcomes?

a. During evaluation of the presence/extent of CAD and the potential necessity of coronary intervention?
b. During PCI to guide stent placement?
c. Immediately after PCI to evaluate the success of stent placement?

Key Question 5: What factors (e.g., patient/physician characteristics, availability of prior noninvasive testing, type of PCI performed) influence the effect of intravascular diagnostic techniques and angiography—when compared with angiography alone (or among different intravascular diagnostic techniques)—on therapeutic decisionmaking, intermediate outcomes, and patient-centered outcomes?

a. During evaluation of the presence/extent of CAD and the potential need for coronary intervention?
b. During PCI to guide stent placement?
c. Immediately after PCI to evaluate the success of stent placement?