# Peer Reviewers

- Matthew Brennan, M.D., M.P.H.
  Assistant Professor of Medicine
  Duke University School of Medicine
  Durham, NC
- Michael Farkouh, M.D., M.Sc.
  Associate Clinical Professor of Medicine, Cardiology
  Mount Sinai School of Medicine
  New York, NY
- Michael J. Lim, M.D., FACC, FSCAI
  Associate Professor, Internal Medicine
  Director, Division of Cardiology
  Saint Louis University School of Medicine
  Saint Louis, MO