# Technical Expert Panel

- Brett E. Bouma, Ph.D., M.S.
  Associate Professor, Dermatology
  Associate Professor, Health Sciences and Technology
  Harvard Medical School
  Boston, MA
- John M. Hodgson, M.D.
  Chairman, Department of Cardiology, Geisinger Health System
  Co-Director, Geisinger Heart Institute
  Wilkes-Barre, PA
- Massound Lessar, M.D.
  Professor of Medicine
  Associate Chief, Division of Cardiology
  Director, Cardiac and Vascular Invasive Services
  University of Cincinnati
  Cincinnati, OH
- Roxana Mehran, M.D., FACC, FACP, FCCP, FESC, FSCAI
  Professor of Medicine, Mount Sinai School of Medicine
  Representative, Society for Cardiovascular Angiography and Interventions
  New York, NY
- Gary Mintz, M.D.
  Chief Medical Officer, Cardiovascular Research Foundation
  Representative, American College of Cardiology
  Washington, DC
- Deeb Salem, M.D., FACC, FACP
  Professor and Chairman, Department of Medicine
  Tufts University School of Medicine
  Chief of Medicine
  Tufts Medical Center
  Boston, MA
- Monvadi Barbara Srichai-Parsia, M.D., M.S.C.I.
  Assistant Professor of Radiology & Medicine
  New York University School of Medicine
  New York, NY