# Key Informants

- Wael Al-Husami, M.D., FACC, FACP
  Director, International Health-Middle East
  Interventional Cardiology, Vascular Medicine & Endovascular Intervention
  Lahey Clinic Medical Center
  Tufts University School of Medicine
  Boston, MA
- Leon Axel, M.D., Ph.D.
  Professor, Department of Radiology
  New York University Langone Medical Center
  New York, NY
- Edgar R. Black, M.D.
  Medical Director, Policy Resources
  Technology Evaluation Center
  BlueCross BlueShield Association
  Adjunct Associate Professor, Northwestern University
  Chicago, IL
- Brian Downey, M.D.
  Cardiologist, Saint Vincent Hospital
  Worcester, MA
- Joel C. Harder, M.B.A.
  Director, Quality Initiatives and Clinical Documents
  Society for Cardiovascular Angiography and Interventions
  Washington, DC
- Margaret D. Hawkins, M.S.
  Director, Health Promotion
  American Association of Retired Persons
  Washington, DC
- Glenn Levine, M.D.
  Professor of Medicine, Baylor College of Medicine
  Director, Cardiac Care Unit, Michael E. DeBakey Medical Center
  Representative, American Heart Association
  Houston, TX
- James Lincoln, RCIS
  Chair, Legislative/Advocacy Committee
  Society of Invasive Cardiovascular Professionals
  Cranston, RI
- Neil J. Weissman, M.D., FACC, FAHA, FASE
  Professor of Medicine, Georgetown University
  President, MedStar Health Research Institute
  Washington, DC