# Acknowledgements

The authors thank the Associate Editor of this report, Karen Schoelles, M.D., S.M., FACP, Director, ECRI Institute-Penn Medicine Evidence-based Practice Center, for helpful suggestions on the draft and final versions of this report.