# Description of Intravascular Diagnostic Techniques

Intravascular diagnostic Techniques | Device Names | Manufacturers | FDA Clearance | Date of FDA Clearance
Fractional Flow Reserve (FFR) | PressureWire™ Aeris Wireless FFR Measurement System | St. Jude Medical | Yes | April 24 1998
| PressureWire® Certus with RADIAnalyzer® Xpress monitor | St. Jude Medical | Yes | July 1 2008 (Pressure wire) Oct 9 2009 (RadiAnalyzer Xpress)
| Horizon Cardiology™ | McKesson | Yes | Nov 8 2006
| OptoWire | Opsens Inc. | No
| ComboMap® Pressure and Flow System | Volcano Corporation | Yes | June 2 2004
Coronary Flow Reserve (CFR) | FloWire® Doppler Guide Wire | Volcano Corporation | Yes | Nov 24 2004
Intravascular Ultrasound (IVUS) | Volcano s5i™ Imaging System | Volcano Corporation | Yes | Oct 8 2008
| iCross™ Coronary Imaging Catheter | Boston Scientific | No (Recalled on March 28 2011)
Intravascular Ultrasound (VH-IVUS) with Virtual Histology | VH® IVUS Imaging System | Volcano Corporation | Yes | Aug 18 2005
| Volcano imaging system with a 20-MHz Eagle Eye Gold IVUS imaging catheter | Volcano Therapeutics Inc, Rancho Cordova, Calif | Yes | Aug 18 2005
Optical Coherent Tomography (OCT) | C7-XR™ OCT Intravascular Imaging System | LightLab Imaging Inc./St. Jude Medical | Yes | Apr 30 2010
| C7 Dragonfly™ Intravascular Imaging Catheter | St. Jude medical | Yes | Apr 30 2010
Near-Infrared Spectroscopy (NIR) | LipiScan | InfraReDx, Inc | Yes | April 25 2008
| NIR spectrometer model 6500 | FOSS NIRSystems, Inc. | No
Angioscopy | A5000 | Applied Medical Resources Corporation | Yes | July 11 1995
Intravascular Magnetic Resonance Imaging (MRI) | Cathamaran™ IVMRI System | TopSpin Medical Inc. | No
Elastrography | Galaxy IVUS scanners | Boston Scientific | Yes | April 22 1998
| LOGIQ E9 ultrasound platform | GE Healthcare | Yes | August 15 2008
| Atlantis® SR Pro Imaging Catheter | Boston Scientific | Yes | Nov 30 2006
Thermography | Epiphany Coronary Thermography Catheters | Rontis | No