# Summary Tables

Appendix C. Table 1 Study design and patient characteristics of FFR-guided stenting versus angiography-guided stenting (Key Question 1)

Appendix C. Table 2 Study design and patient characteristics of IVUS-guided PCI versus angiography-guided PCI (Key Question 2)

Appendix C. Table 3 Study design and patient characteristics of IVUS-guided PCI versus angiography-guided PCI in evaluating success of stent implantation (Key Question 3)

Appendix C. Table 4 Study design and patient characteristics of FFR-guided PCI versus IVUS-guided PCI (Key Question 4)

Appendix C. Table 5 Study design and patient characteristics of IVUS-guided PCI versus angiography-guided PCI (Key Question 5)

Appendix C. Table 6 Definition of MACE or composite outcomes among included studies

Appendix C. Table 7 Inclusion and exclusion criteria