# List of Excluded Studies

The 438 references (of the 519 total) that were excluded for reasons other than being a narrative review or case report are listed below.

Aarnoudse W, Fearon WF, Manoharan G, Geven M, van de V, Rutten M, De Bruyne B, Pijls NH. Epicardial stenosis severity does not affect minimal microcirculatory resistance. Circulation. 10. 12. 2004;110(15):2137-42. UI - 15466646. Reject Reason: No direct comparison between techniques. [pmid: 15466646].
Abaci A, Oguzhan A, Topsakal R, Seyfeli E, Yilmaz Y, Eryol NK, Basar E, Ergin A. Intracoronary electrocardiogram and angina pectoris during percutaneous coronary interventions as an assessment of myocardial viability: comparison with low-dose dobutamine echocardiography. Catheterization & Cardiovascular Interventions. 2003;60(4):469-76. UI - 14624423. Reject Reason: No comparator of interest. [pmid: 14624423].
Abizaid A, Pichard AD, Mintz GS, Abizaid AS, Klutstein MW, Satler LF, Mehran R, Leiboff B, Kent KM, Leon MB. Acute and long-term results of an intravascular ultrasound-guided percutaneous transluminal coronary angioplasty/provisional stent implantation strategy. American Journal of Cardiology. 12. 1. 1999;84(11):1298-303. UI - 10614794. Reject Reason: No direct comparison between techniques. [pmid: 10614794].
Abizaid A, Albertal M, Ormiston J, Londero H, Ruygrok P, Seixas AC, Feres F, Mattos LA, Staico R, Silva RL, Webster M, Stewart J, Paoletti F, Kataoka T, Fitzgerald P, Sousa A, Sousa JE. IMPACT Trial: angiographic and intravascular ultrasound observations of the first human experience with mycophenolic acid-eluting polymer stent system. Catheterization & Cardiovascular Interventions. 2005;66(4):491-5. UI - 16283680. Reject Reason: No direct comparison between techniques. [pmid: 16283680].
Agostoni P, Vermeersch P, Semeraro O, Verheye S, Van Langenhove G, Van den Heuvel P, Convens C, Van den Branden F, Bruining N. Intravascular ultrasound comparison of sirolimus-eluting stent versus bare metal stent implantation in diseased saphenous vein grafts (from the RRISC [Reduction of Restenosis In Saphenous Vein Grafts With Cypher Sirolimus-Eluting Stent] trial). American Journal of Cardiology. 7. 1. 2007;100(1):52-8. UI - 17599440. Reject Reason: Not relevant to KQs. [pmid: 17599440].
Ahmed JM, Mintz GS, Waksman R, Lansky AJ, Mehran R, Wu H, Weissman NJ, Pichard AD, Satler LF, Kent KM, Leon MB. Serial intravascular ultrasound analysis of edge recurrence after intracoronary gamma radiation treatment of native artery in-stent restenosis lesions. American Journal of Cardiology. 5. 15. 2001;87(10):1145-9. UI - 11356387. Reject Reason: No direct comparison between techniques. [pmid: 11356387].
Al Suwaidi J, Higano ST, Holmes DR Jr., Rihal CS, Lerman A. Measuring maximal percent area stenosis poststent placement with intracoronary Doppler and the continuity equation and correlation with intracoronary ultrasound and angiography. American Journal of Cardiology. 9. 15. 1999;84(6):650-4. UI - 10498133. Reject Reason: No outcome of interest. [pmid: 10498133].
Albertal M, Van Langenhove G, Kay IP, Costa MA, Kozuma K, Serruys PW. Angiographic and clinical outcome of mild to moderate nonocclusive unstented coronary artery dissection and the influence on coronary flow velocity reserve. The Debate I Study Group. American Journal of Cardiology. 8. 15. 2000;86(4):375-8. UI - 10946027. Reject Reason: No comparator of interest. [pmid: 10946027].
Albertal M, Van Langenhove G, Regar E, Kay IP, Foley D, Sianos G, Kozuma K, Beijsterveldt T, Carlier SG, Belardi JA, Boersma E, Sousa JE, De Bruyne B, Serruys PW, DEBATE II Study Group. Uncomplicated moderate coronary artery dissections after balloon angioplasty: good outcome without stenting. Heart. 2001;86(2):193-8. UI - 11454840. Reject Reason: No direct comparison between techniques. [pmid: 11454840].
Albiero R, Hall P, Itoh A, Blengino S, Nakamura S, Martini G, Ferraro M, Colombo A. Results of a consecutive series of patients receiving only antiplatelet therapy after optimized stent implantation. Comparison of aspirin alone versus combined ticlopidine and aspirin therapy. Circulation. 3. 4. 1997;95(5):1145-56. UI - 9054843. Reject Reason: No direct comparison between techniques. [pmid: 9054843].
Alfonso F, Macaya C, Goicolea J, Iniguez A, Hernandez R, Banuelos C, Castillo JA, Zarco P. Angiographic changes induced by intracoronary ultrasound imaging before and after coronary angioplasty. American Heart Journal. 1993;125(3):877-80. UI - 8438718. Reject Reason: Case report. [pmid: 8438718].
Alfonso F, Suarez A, Angiolillo DJ, Sabate M, Escaned J, Moreno R, Hernandez R, Banuelos C, Macaya C. Findings of intravascular ultrasound during acute stent thrombosis. Heart. 2004;90(12):1455-9. UI - 15547028. Reject Reason: No direct comparison between techniques. [pmid: 15547028].
Alfonso F, Garcia P, Fleites H, Pimentel G, Sabate M, Hernandez R, Escaned J, Banuelos C, Perez-Vizcayno MJ, Moreno R, Macaya C. Repeat stenting for the prevention of the early lumen loss phenomenon in patients with in-stent restenosis. Angiographic and intravascular ultrasound findings of a randomized study. American Heart Journal. 2005;149(2):e1-8. UI - 15846250. Reject Reason: No direct comparison between techniques. [pmid: 15846250].
Algowhary M, Matsumura A, Hashimoto Y, Isobe M. Poststenting axial redistribution of atherosclerotic plaque into the reference segments and lumen reduction at the stent edge: a volumetric intravascular ultrasound study. International Heart Journal. 2006;47(2):159-71. UI - 16607044. Reject Reason: No direct comparison between techniques. [pmid: 16607044].
Altstidl R, Regenfus M, Lehmkuhl H, Dill H, Bachmann K. Evaluation of successful PTCA by transstenotic flow velocity ratios. Angiology. 1997;48(9):775-82. UI - 9313627. Reject Reason: No direct comparison between techniques. [pmid: 9313627].
Andreini D, Pontone G, Bartorelli AL, Trabattoni D, Mushtaq S, Bertella E, Annoni A, Formenti A, Cortinovis S, Montorsi P, Veglia F, Ballerini G, Pepi M. Comparison of feasibility and diagnostic accuracy of 64-slice multidetector computed tomographic coronary angiography versus invasive coronary angiography versus intravascular ultrasound for evaluation of in-stent restenosis. American Journal of Cardiology. 5. 15. 2009;103(10):1349-58. UI - 19427427. Reject Reason: No direct comparison between techniques. [pmid: 19427427].
Arakawa K, Isoda K, Sugiyabu Y, Fukuda M, Nishizawa K, Shibuya T, Nakamura H. Intimal proliferation after stenting reflected by increased stent-to-vessel cross-sectional area ratio: serial intravascular ultrasound study. Journal of Cardiology. 1998;32(6):379-89. UI - 9914955. Reject Reason: No direct comparison between techniques. [pmid: 9914955].
Athanasiadis A, Haase KK, Wullen B, Treusch AW, Mahrholdt H, Voelker W, Baumbach A, Oberhoff M, Karsch KR. Lesion morphology assessed by preinterventional intravascular ultrasound does not predict the incidence of severe coronary artery dissections. European Heart Journal. 1919;(6):870-878. UI - 9651710. Reject Reason: No direct comparison between techniques.
az-Sandoval LJ, Bouma BE, Tearney GJ, Jang IK. Optical coherence tomography as a tool for percutaneous coronary interventions. Catheterization & Cardiovascular Interventions. 2005;65(4):492-6. UI - 15920721. Reject Reason: No direct comparison between techniques. [pmid: 15920721].
Bach RG, Donohue TJ, Caracciolo EA, Wolford T, Aguirre FV, Kern MJ. Quantification of collateral blood flow during PTCA by intravascular Doppler. European Heart Journal. Suppl J. 1995;16:74-7. UI - 8746942. Reject Reason: No direct comparison between techniques. [pmid: 8746942].
Bachmann R, Sechtem U, Voth E, Schroder J, Hopp HW, Schicha H. Dipyridamole scintigraphy and intravascular ultrasound after successful coronary intervention. Journal of Nuclear Medicine. 1997;38(4):553-8. UI - 9139119. Reject Reason: No outcome of interest. [pmid: 9139119].
Bae JH, Kwon TG, Hyun DW, Rihal CS, Lerman A. Predictors of slow flow during primary percutaneous coronary intervention: an intravascular ultrasound-virtual histology study. Heart. 2008;94(12):1559-64. UI - 18381376. Reject Reason: No outcome of interest. [pmid: 18381376].
Balian V, Galli M, Repetto S, Luvini M, Galdangelo F, Castiglioni B, Boscarini M, Petrucci E, Filippini G, Marcassa C. Intracoronary ST segment evolution during primary coronary stenting predicts infarct zone recovery. Catheterization & Cardiovascular Interventions. 2005;64(1):53-60. UI - 15619303. Reject Reason: No IVDx technique used. [pmid: 15619303].
Baptista J, Di Mario C, Ozaki Y, Escaned J, Gil R, de Feyter P, Roelandt JR, Serruys PW. Impact of plaque morphology and composition on the mechanisms of lumen enlargement using intracoronary ultrasound and quantitative angiography after balloon angioplasty. American Journal of Cardiology. 1. 15. 1996;77(2):115-21. UI - 8546076. Reject Reason: No direct comparison between techniques. [pmid: 8546076].
Batkoff BW, Linker DT. Safety of intracoronary ultrasound: data from a Multicenter European Registry. Catheterization & Cardiovascular Diagnosis. 1996;38(3):238-41. UI - 8804778. Reject Reason: No comparison of interest. [pmid: 8804778].
Bech GJ, Pijls NH, De Bruyne B, Peels KH, Michels HR, Bonnier HJ, Koolen JJ. Usefulness of fractional flow reserve to predict clinical outcome after balloon angioplasty. Circulation. 2. 23. 1999;99(7):883-8. UI - 10027810. Reject Reason: No comparison of interest. [pmid: 10027810].
Bech GJ, De Bruyne B, Pijls NH, de Muinck ED, Hoorntje JC, Escaned J, Stella PR, Boersma E, Bartunek J, Koolen JJ, Wijns W. Fractional flow reserve to determine the appropriateness of angioplasty in moderate coronary stenosis: a randomized trial. Circulation. 2001;103(24):2928-34. UI - 11413082. Reject Reason: No direct comparison between techniques. [pmid: 11413082].
Bech GJ, Droste H, Pijls NH, De Bruyne B, Bonnier JJ, Michels HR, Peels KH, Koolen JJ. Value of fractional flow reserve in making decisions about bypass surgery for equivocal left main coronary artery disease. Heart. 2001;86(5):547-52. UI - 11602550. Reject Reason: No direct comparison between techniques. [pmid: 11602550].
Beleslin B, Ostojic M, Djordjevic-Dikic A, Vukcevic V, Stojkovic S, Nedeljkovic M, Stankovic G, Orlic D, Milic N, Stepanovic J, Giga V, Saponjski J. The value of fractional and coronary flow reserve in predicting myocardial recovery in patients with previous myocardial infarction. European Heart Journal. 2008;29(21):2617-24. UI - 18826987. Reject Reason: No direct comparison between techniques. [pmid: 18826987].
Beleslin B, Dobric M, Sobic-Saranovic D, Giga V, Stepanovic J, Djordjevic-Dikic A, Nedeljkovic M, Stojkovic S, Vukcevic V, Stankovic G, Orlic D, Petrasinovic Z, Pavlovic S, Obradovic V, Ostojic M. Fractional flow reserve and myocardial viability as assessed by SPECT perfusion scintigraphy in patients with prior myocardial infarction. Journal of Nuclear Cardiology. 2010;17(5):817-24. UI - 20524100. Reject Reason: No direct comparison between techniques. [pmid: 20524100].
Bermejo J, Botas J, Garcia E, Elizaga J, Osende J, Soriano J, Abeytua M, Delcan JL. Mechanisms of residual lumen stenosis after high-pressure stent implantation: a quantitative coronary angiography and intravascular ultrasound study. Circulation. 7. 14. 1998;98(2):112-8. UI - 9679716. Reject Reason: No comparison of interest. [pmid: 9679716].
Bertrand OF, De Larochelliere R, Joyal M, Bonan R, Mongrain R, Tardif JC. Incidence of stent under-deployment as a cause of in-stent restenosis in long stents. The International Journal of Cardiovascular Imaging. 1920;(4):279-284. UI - 15529909. Reject Reason: No direct comparison between techniques.
Bertrand OF, Poirier P, Rodes-Cabau J, Rinfret S, Title L, Dzavik V, Natarajan M, Angel J, Batalla N, Almeras N, Costerousse O, De Larochelliere R, Roy L, Despres JP, VICTORY, trial investigators. A multicentre, randomized, double-blind placebo-controlled trial evaluating rosiglitazone for the prevention of atherosclerosis progression after coronary artery bypass graft surgery in patients with type 2 diabetes. Design and rationale of the VeIn-Coronary aTherOsclerosis and Rosiglitazone after bypass surgerY (VICTORY) trial. Canadian Journal of Cardiology. 2009;25(9):509-15. UI - 19746240. Reject Reason: Measurement timepoint not of interest. [pmid: 19746240].
Bertrand OF, Rodes-Cabau J, Larose E, Rinfret S, Gaudreault V, Proulx G, Barbeau G, Dery JP, Gleeton O, Manh-Nguyen C, Noel B, Roy L, Costerousse O, De Larochelliere R, EArly Discharge after Transradial Stenting of CoronarY Arteries in Acute Myocardial Infarction (EASY-MI) Study Investigators. Intracoronary compared to intravenous Abciximab and high-dose bolus compared to standard dose in patients with ST-segment elevation myocardial infarction undergoing transradial primary percutaneous coronary intervention: a two-by-two factorial placebo-controlled randomized study. American Journal of Cardiology. 6. 1. 2010;105(11):1520-7. UI - 20494655. Reject Reason: No direct comparison between techniques. [pmid: 20494655].
Blasini R, Neumann FJ, Richardt G, Schmitt C, Paloncy R, Schomig A. Intravascular ultrasound-guided emergency coronary Palmaz-Schatz stent placement without post-procedural systemic anticoagulation. Heart. 1996;76(4):344-9. UI - 8983682. Reject Reason: No direct comparison between techniques. [pmid: 8983682].
Blasini R, Neumann FJ, Schmitt C, Bokenkamp J, Schomig A. Comparison of angiography and intravascular ultrasound for the assessment of lumen size after coronary stent placement: impact of dilation pressures. Catheterization & Cardiovascular Diagnosis. 1997;42(2):113-9. UI - 9328688. Reject Reason: No direct comparison between techniques. [pmid: 9328688].
Blessing E, Hausmann D, Sturm M, Wolpers HG, Amende I, Mugge A. Intravascular ultrasound and stent implantation: intraobserver and interobserver variability. American Heart Journal. 1999;137(2):368-71. UI - 9924173. Reject Reason: No direct comparison between techniques. [pmid: 9924173].
Blessing E, Hausmann D, Sturm M, Wolpers HG, Amende I, Mugge A. Incomplete expansion of Palmaz-Schatz stents despite high-pressure implantation technique: impact on target lesion revascularization. Cardiology. 1999;91(2):102-8. UI - 10449881. Reject Reason: No direct comparison between techniques. [pmid: 10449881].
Bodanese LC, Perin EC, Gottschall CA. Evaluation of post-intracoronary stent implant. Intravascular ultrasound versus quantitative angiography. [Portuguese]. Arquivos Brasileiros de Cardiologia. 1995;64(5):439-46. UI - 8526774. Reject Reason: No outcome of interest. [pmid: 8526774].
Bonello L, De Labriolle A, Lemesle G, Roy P, Steinberg DH, Slottow TL, Xue Z, Torguson R, Kaneshige K, Suddath WO, Satler LF, Kent KM, Lindsay J, Pichard AD, Waksman R. Comparison of outcomes of drug-eluting stents versus bare-metal stents in nonostial proximal left anterior descending coronary arteries. American Journal of Cardiology. 2. 15. 2009;103(4):496-500. UI - 19195509. Reject Reason: No direct comparison between techniques. [pmid: 19195509].
Boschat J, Matteodo K, Gilard M, Larlet JM, Provost K, Jobic Y, Guillo P, Etienne Y, Mansourati J, Blanc JJ. Endocoronary ultrasonography and quantitative coronary angiography. Correlations before and after transluminal coronary angioplasty. [French]. Archives des Maladies du Coeur et des Vaisseaux. 1997;90(3):353-60. UI - 9232073. Reject Reason: No outcome of interest. [pmid: 9232073].
Boschat J, Le Breton H, Commeau P, Huret B, Bedossa M, Gilard M, Stent Without BAlloon Predilatation (SWIBAP) Study Group. Is coronary stent deployment and remodeling affected by predilatation? An intravascular ultrasound randomized study Stenting with or without predilation: an IVUS study. The International Journal of Cardiovascular Imaging. 2002;18(6):399-404. UI - 12537406. Reject Reason: No comparison of interest. [pmid: 12537406].
Botas J, Clark DA, Pinto F, Chenzbraun A, Fischell TA. Balloon angioplasty results in increased segmental coronary distensibility: a likely mechanism of percutaneous transluminal coronary angioplasty. Journal of the American College of Cardiology. 1994;23(5):1043-52. UI - 8144766. Reject Reason: Not relevant to KQs. [pmid: 8144766].
Botman CJ, Schonberger J, Koolen S, Penn O, Botman H, Dib N, Eeckhout E, Pijls N. Does stenosis severity of native vessels influence bypass graft patency? A prospective fractional flow reserve-guided study. Annals of Thoracic Surgery. 2007;83(6):2093-7. UI - 17532405. Reject Reason: Not relevant to KQs. [pmid: 17532405].
Bouma BE, Tearney GJ, Yabushita H, Shishkov M, Kauffman CR, DeJoseph Gauthier D, MacNeill BD, Houser SL, Aretz HT, Halpern EF, Jang IK. Evaluation of intracoronary stenting by intravascular optical coherence tomography. Heart. 2003;89(3):317-20. UI - 12591841. Reject Reason: No outcome of interest. [pmid: 12591841].
Britten MB, Zeiher AM, Schachinger V. Microvascular dysfunction in angiographically normal or mildly diseased coronary arteries predicts adverse cardiovascular long-term outcome. Coronary Artery Disease. 2004;15(5):259-64. UI - 15238822. Reject Reason: No direct comparison between techniques. [pmid: 15238822].
Bruchhauser J, Sechtem U, Hopp HW, Erdmann E. Intracoronary ultrasound changes the therapeutic approach in ambivalent angiography findings. [German]. Zeitschrift fur Kardiologie. 1997;86(2):138-47. UI - 9173698. Reject Reason: Not relevant to KQs. [pmid: 9173698].
Bruining N, Sabate M, de Feyter PJ, Kay IP, Ligthart J, Disco C, Kutryk MJ, Roelandt JR, Serruys PW. Quantitative measurements of in-stent restenosis: A comparison between quantitative coronary ultrasound and quantitative coronary angiography. Catheterization & Cardiovascular Interventions. 1999;48(2):133-42. UI - 10506766. Reject Reason: No outcome of interest. [pmid: 10506766].
Bruining N, Tanimoto S, Otsuka M, Weustink A, Ligthart J, de Winter S, van Mieghem C, Nieman K, de Feyter PJ, van Domburg RT, Serruys PW. Quantitative multi-modality imaging analysis of a bioabsorbable poly-L-lactic acid stent design in the acute phase: a comparison between 2- and 3D-QCA, QCU and QMSCT-CA. Eurointervention. 2008;4(2):285-91. UI - 19110796. Reject Reason: Not relevant to KQs. [pmid: 19110796].
Bryniarski L, Dragan J, Zabojszcz M, Klecha A, Jankowski P, Krolikowski T, Rajzer M, Dudek D, Kawecka-Jaszcz K. Intracoronary ultrasound-guided angioplasty for coronary chronic total occlusion. Kardiologia Polska. 2009;67(8A):992-1003. UI - 19784904. Reject Reason: Not relevant to KQs. [pmid: 19784904].
Caiati C, Montaldo C, Zedda N, Montisci R, Ruscazio M, Lai G, Cadeddu M, Meloni L, Iliceto S. Validation of a new noninvasive method (contrast-enhanced transthoracic second harmonic echo Doppler) for the evaluation of coronary flow reserve: comparison with intracoronary Doppler flow wire. Journal of the American College of Cardiology. 1999;34(4):1193-200. UI - 10520812. Reject Reason: No comparator of interest. [pmid: 10520812].
Capodanno D, Prati F, Pawlowsky T, Cera M, La Manna A, Albertucci M, Tamburino C. Comparison of optical coherence tomography and intravascular ultrasound for the assessment of in-stent tissue coverage after stent implantation. Eurointervention. 2009;5(5):538-43. UI - 20142173. Reject Reason: No direct comparison between techniques. [pmid: 20142173].
Carrozza JP Jr., Hermiller JB Jr., Linnemeier TJ, Popma JJ, Yock PG, Roubin GS, Dean LS, Kuntz RE, Robertson L, Ho KK, Cutlip DE, Baim DS. Quantitative coronary angiographic and intravascular ultrasound assessment of a new nonarticulated stent: report from the Advanced Cardiovascular Systems MultiLink stent pilot study. Journal of the American College of Cardiology. 1998;31(1):50-6. UI - 9426017. Reject Reason: No direct comparison between techniques. [pmid: 9426017].
Casserly IP, Aronow HD, Schoenhagen P, Tsutsui H, Popovich J, Goormastic M, Popma JJ, Nissen SE, Tuzcu EM. Relationship between residual atheroma burden and neointimal growth in patients undergoing stenting: analysis of the atherectomy before MULTI-LINK improves lumen gain and clinical outcomes trial intravascular ultrasound substudy. Journal of the American College of Cardiology. 11. 6. 2002;40(9):1573-8. UI - 12427408. Reject Reason: No outcome of interest. [pmid: 12427408].
Catalano G, Tamburini V, Colombo A, Nishida T, Parisi G, Mazzetta C, Orecchia R. Intravascular ultrasound based dose assessment in endovascular brachytherapy. Radiotherapy & Oncology. 2003;68(2):199-206. UI - 12972316. Reject Reason: No direct comparison between techniques. [pmid: 12972316].
Caymaz O, Tezcan H, Fak AS, Toprak A, Tokay S, Oktay A. Measurement of myocardial fractional flow reserve during coronary angioplasty in infarct-related and non-infarct related coronary artery lesions. Journal of Invasive Cardiology. 2000;12(5):236-41. UI - 10825764. Reject Reason: Not relevant to KQs. [pmid: 10825764].
Cervinka P, Stasek J, Costa MA, Stursa J, Fiser M, Vodnansky P, Kocisova M, Veselka J, Pleskot M, Maly J. Intravascular ultrasound study of the effect of beta-emitting ((55)Co) stents on vascular remodeling and intimal proliferation. Catheterization & Cardiovascular Interventions. 2004;61(3):320-5. UI - 14988888. Reject Reason: No direct comparison between techniques. [pmid: 14988888].
Cheneau E, Mintz GS, Leborgne L, Kotani J, Satler LF, Ajani AE, Weissman NJ, Waksman R, Pichard AD. Intravascular ultrasound predictors of subacute vessel closure after balloon angioplasty or atherectomy. Journal of Invasive Cardiology. 2004;16(10):572-4. UI - 15505353. Reject Reason: No direct comparison between techniques. [pmid: 15505353].
Cheneau E, Leborgne L, Canos D, Pichard AD, Satler LF, Suddath WO, Kent KM, Lindsay J, Weissman N, Waksman R. Impact of intravascular ultrasound-guided direct stenting on clinical outcome of patients treated for native coronary disease. Cardiovascular Radiation Medicine. Mar. 2004;5(1):15-9. UI - 15275627. Reject Reason: No direct comparison between techniques. [pmid: 15275627].
Cheneau E, Satler LF, Escolar E, Suddath WO, Kent KM, Weissman NJ, Waksman R, Pichard AD. Underexpansion of sirolimus-eluting stents: incidence and relationship to delivery pressure. Catheterization & Cardiovascular Interventions. 2005;65(2):222-6. UI - 15900554. Reject Reason: No direct comparison between techniques. [pmid: 15900554].
Chevalier B, Silber S, Park SJ, Garcia E, Schuler G, Suryapranata H, Koolen J, Hauptmann KE, Wijns W, Morice MC, Carrie D, van Es GA, Nagai H, Detiege D, Paunovic D, Serruys PW, Clinical, Investigators. Randomized comparison of the Nobori Biolimus A9-eluting coronary stent with the Taxus Liberte paclitaxel-eluting coronary stent in patients with stenosis in native coronary arteries: the NOBORI 1 trial--Phase 2. Circulation: Cardiovascular Interventions. 2009;2(3):188-95. UI - 20031715. Reject Reason: No direct comparison between techniques. [pmid: 20031715].
Choi JW, Vardi GM, Meyers SN, Parker MA, Goodreau LM, Davidson CJ. Role of intracoronary ultrasound after high-pressure stent implantation. American Heart Journal. 2000;139(4):643-8. UI - 10740146. Reject Reason: No direct comparison between techniques. [pmid: 10740146].
Chugh SK, Koppel J, Scott M, Shewchuk L, Goodhart D, Bonan R, Tardif JC, Worthley SG, DiMario C, Curtis MJ, Meredith IT, Anderson TJ. Coronary flow velocity reserve does not correlate with TIMI frame count in patients undergoing non-emergency percutaneous coronary intervention. Journal of the American College of Cardiology. 8. 18. 2004;44(4):778-82. UI - 15312858. Reject Reason: No outcome of interest. [pmid: 15312858].
Chung WS, Park CS, Seung KB, Kim PJ, Lee JM, Koo BK, Jang YS, Yang JY, Yoon JH, Kim DI, Yoon YW, Park JS, Cho YH, Park SJ. The incidence and clinical impact of stent strut fractures developed after drug-eluting stent implantation. International Journal of Cardiology. 4. 25. 2008;125(3):325-31. UI - 17434616. Reject Reason: Not relevant to KQs. [pmid: 17434616].
Citro R, Voci P, Pizzuto F, Maione AG, Patella MM, Bossone E, Provenza G, Gregorio G, Mariano E, Feinstein M, Athanassopoulos G, Puddu PE. Clinical value of echocardiographic assessment of coronary flow reserve after left anterior descending coronary artery stenting in an unselected population. Journal of Cardiovascular Medicine. 2008;9(12):1254-9. UI - 19001933. Reject Reason: No direct comparison between techniques. [pmid: 19001933].
Colombo A, Hall P, Nakamura S, Almagor Y, Maiello L, Martini G, Gaglione A, Goldberg SL, Tobis JM. Intracoronary stenting without anticoagulation accomplished with intravascular ultrasound guidance. Circulation. 3. 15. 1995;91(6):1676-88. UI - 7882474. Reject Reason: No comparator of interest. [pmid: 7882474].
Costa JR Jr., Abizaid A, Feres F, Costa R, Seixas AC, Maia F, Abizaid A, Tanajura LF, Staico R, Siqueira D, Meredith L, Bhat V, Yan J, Ormiston J, Sousa AG, Fitzgerald P, Sousa JE. EXCELLA First-in-Man (FIM) study: safety and efficacy of novolimus-eluting stent in de novo coronary lesions. Eurointervention. 2008;4(1):53-8. UI - 19112779. Reject Reason: No direct comparison between techniques. [pmid: 19112779].
Costa JR Jr., Abizaid A, Costa R, Feres F, Tanajura LF, Abizaid A, Mattos LA, Staico R, Siqueira D, Sousa AG, Bonan R, Sousa JE. Preliminary results of the hydroxyapatite nonpolymer-based sirolimus-eluting stent for the treatment of single de novo coronary lesions a first-in-human analysis of a third-generation drug-eluting stent system. Jacc: Cardiovascular Interventions. 2008;1(5):545-51. UI - 19463357. Reject Reason: Measurement timepoint not of interest. [pmid: 19463357].
Costa MA, Sabate M, Staico R, Alfonso F, Seixas AC, Albertal M, Crossman A, Angiolillo DJ, Zenni M, Sousa JE, Macaya C, Bass TA. Anatomical and physiologic assessments in patients with small coronary artery disease: final results of the Physiologic and Anatomical Evaluation Prior to and After Stent Implantation in Small Coronary Vessels (PHANTOM) trial. American Heart Journal. 2007;153(2):296.e1-7. UI - 17239692. Reject Reason: No comparison of interest. [pmid: 17239692].
Costa RA, Mintz GS, Carlier SG, Lansky AJ, Moussa I, Fujii K, Takebayashi H, Yasuda T, Costa JR Jr., Tsuchiya Y, Jensen LO, Cristea E, Mehran R, Dangas GD, Iyer S, Collins M, Kreps EM, Colombo A, Stone GW, Leon MB, Moses JW. Bifurcation coronary lesions treated with the “crush” technique: an intravascular ultrasound analysis. [Erratum appears in J Am Coll Cardiol. 2005 Sep 20;46(6):1115].[Erratum appears in J Am Coll Cardiol. 2005 Sep 6;46(5):936]. Journal of the American College of Cardiology. 8. 16. 2005;46(4):599-605. UI - 16098422. Reject Reason: No direct comparison between techniques. [pmid: 16098422].
Courtis J, Rodes-Cabau J, Larose E, Dery JP, Nguyen CM, Proulx G, Gleeton O, Roy L, Barbeau G, Noel B, Delarochelliere R, Bertrand OF. Comparison of medical treatment and coronary revascularization in patients with moderate coronary lesions and borderline fractional flow reserve measurements. Catheterization & Cardiovascular Interventions. 3. 1. 2008;71(4):541-8. UI - 18307236. Reject Reason: No direct comparison between techniques. [pmid: 18307236].
Courtis J, Rodes-Cabau J, Larose E, Potvin JM, Dery JP, Larochelliere RD, Cote M, Cousterousse O, Nguyen CM, Proulx G, Rinfret S, Bertrand OF. Usefulness of coronary fractional flow reserve measurements in guiding clinical decisions in intermediate or equivocal left main coronary stenoses. American Journal of Cardiology. 4. 1. 2009;103(7):943-9. UI - 19327420. Reject Reason: Intra-diagnostic comparison. [pmid: 19327420].
Cubeddu RJ, Wood FO, Saylors EK, Mann T. Isolated disease of the ostium left anterior descending or circumflex artery: management using a left main stenting technique. Clinical outcome at 2 years. Journal of Invasive Cardiology. 1919;(11):457-461. UI - 17986719. Reject Reason: No direct comparison between techniques.
Dangas G, Mintz GS, Mehran R, Lansky AJ, Kornowski R, Pichard AD, Satler LF, Kent KM, Stone GW, Leon MB. Preintervention arterial remodeling as an independent predictor of target-lesion revascularization after nonstent coronary intervention: an analysis of 777 lesions with intravascular ultrasound imaging. Circulation. 6. 22. 1999;99(24):3149-54. UI - 10377078. Reject Reason: No comparison of interest. [pmid: 10377078].
Davidavicius G, Van Praet F, Mansour S, Casselman F, Bartunek J, Degrieck I, Wellens F, De Geest R, Vanermen H, Wijns W, De Bruyne B. Hybrid revascularization strategy: a pilot study on the association of robotically enhanced minimally invasive direct coronary artery bypass surgery and fractional-flow-reserve-guided percutaneous coronary intervention. Circulation. 8. 30. 2005;112(9 Suppl):I317-22. UI - 16159838. Reject Reason: No direct comparison between techniques. [pmid: 16159838].
Davidson CJ, Sheikh KH, Kisslo KB, Phillips HR, Peter RH, Behar VS, Kong YH, Krucoff M, Ohman EM, Tcheng JE. Intracoronary ultrasound evaluation of interventional technologies. American Journal of Cardiology. 11. 15. 1991;68(13):1305-9. UI - 1951117. Reject Reason: No outcome of interest. [pmid: 1951117].
de Feyter PJ, Kay P, Disco C, Serruys PW. Reference chart derived from post-stent-implantation intravascular ultrasound predictors of 6-month expected restenosis on quantitative coronary angiography. Circulation. 10. 26. 1999;100(17):1777-83. UI - 10534464. Reject Reason: No comparison of interest. [pmid: 10534464].
de Lezo JS, Pavlovic D, Medina A, Pan M, Cabrera JA, Romero M, Segura J, Hernandez E, Gallardo A, Melian F. Angiographic predictors of neointimal thickening after successful coronary wall healing following percutaneous revascularization. American Heart Journal. 1997;133(2):210-20. UI - 9023168. Reject Reason: No direct comparison between techniques. [pmid: 9023168].
de Vrey EA, Mintz GS, von Birgelen C, Kimura T, Noboyoshi M, Popma JJ, Serruys PW, Leon MB. Serial volumetric (three-dimensional) intravascular ultrasound analysis of restenosis after directional coronary atherectomy. Journal of the American College of Cardiology. 1998;32(7):1874-80. UI - 9857866. Reject Reason: No direct comparison between techniques. [pmid: 9857866].
De Bruyne B, Hersbach F, Pijls NH, Bartunek J, Bech JW, Heyndrickx GR, Gould KL, Wijns W. Abnormal epicardial coronary resistance in patients with diffuse atherosclerosis but “Normal” coronary angiography. Circulation. 11. 13. 2001;104(20):2401-6. UI - 11705815. Reject Reason: No direct comparison between techniques. [pmid: 11705815].
De BB, Pijls NH, Kalesan B, et al. Fractional Flow Reserve-Guided PCI versus Medical Therapy in Stable Coronary Disease. N Engl J Med. 2012. Aug. 27. UI - 22924638. Reject reason: Comparison not of interest.
de Jaegere P, Mudra H, Figulla H, Almagor Y, Doucet S, Penn I, Colombo A, Hamm C, Bartorelli A, Rothman M, Nobuyoshi M, Yamaguchi T, Voudris V, DiMario C, Makovski S, Hausmann D, Rowe S, Rabinovich S, Sunamura M, van Es GA. Intravascular ultrasound-guided optimized stent deployment. Immediate and 6 months clinical and angiographic results from the Multicenter Ultrasound Stenting in Coronaries Study (MUSIC Study). European Heart Journal. 1919;(8):1214-1223. UI - 9740343. Reject Reason: No direct comparison between techniques.
De Servi S, Arbustini E, Marsico F, Bramucci E, Angoli L, Porcu E, Costante AM, Kubica J, Boschetti E, Valentini P, Specchia G. Correlation between clinical and morphologic findings in unstable angina. American Journal of Cardiology. 1. 15. 1996;77(2):128-32. UI - 8546078. Reject Reason: No direct comparison between techniques. [pmid: 8546078].
Di Mario C, Meneveau N, Gil R, de Jaegere P, de Feyter PJ, Slager CJ, Roelandt JR, Serruys PW. Maximal blood flow velocity in severe coronary stenoses measured with a Doppler guidewire. Limitations for the application of the continuity equation in the assessment of stenosis severity. American Journal of Cardiology. 1993;71(14):54D-61D. UI - 8488776. Reject Reason: No direct comparison between techniques.
Di Mario C, Gil R, Camenzind E, Ozaki Y, von Birgelen C, Umans V, de Jaegere P, de Feyter PJ, Roelandt JR, Serruys PW. Quantitative assessment with intracoronary ultrasound of the mechanisms of restenosis after percutaneous transluminal coronary angioplasty and directional coronary atherectomy. American Journal of Cardiology. 4. 15. 1995;75(12):772-7. UI - 7717277. Reject Reason: No direct comparison between techniques. [pmid: 7717277].
Di Mario C, Reimers B, Almagor Y, Moussa I, Di Francesco L, Ferraro M, Leon MB, Richter K, Colombo A. Procedural and follow up results with a new balloon expandable stent in unselected lesions. Heart. 1998;79(3):234-41. UI - 9602655. Reject Reason: No direct comparison between techniques. [pmid: 9602655].
Diletti R, Garcia-Garcia HM, Gomez-Lara J, et al. Assessment of coronary atherosclerosis progression and regression at bifurcations using combined IVUS and OCT. Jacc: Cardiovascular Imaging. 2011;4(7):774-80. Jul. UI - 21757169. Reject reason: No direct comparison between techniques. [pmid: 21757169].
Doi H, Maehara A, Mintz GS, Weissman NJ, Yu A, Wang H, Mandinov L, Popma JJ, Ellis SG, Grube E, Dawkins KD, Stone GW. Impact of in-stent minimal lumen area at 9 months poststent implantation on 3-year target lesion revascularization-free survival: a serial intravascular ultrasound analysis from the TAXUS IV, V, and VI trials. Circulation: Cardiovascular Interventions. 2008;1(2):111-8. UI - 20031665. Reject Reason: No direct comparison between techniques. [pmid: 20031665].
Doi H, Maehara A, Mintz GS, Tsujita K, Kubo T, Castellanos C, Liu J, Yang J, Oviedo C, Aoki J, Franklin-Bond T, Dasgupta N, Lansky AJ, Dangas GD, Stone GW, Moses JW, Mehran R, Leon MB. Classification and potential mechanisms of intravascular ultrasound patterns of stent fracture. American Journal of Cardiology. 3. 2009;103(6):818-23. UI - 19268738. Reject Reason: No comparator of interest. [pmid: 19268738].
Dominguez-Franco AJ, Jimenez-Navarro MF, Munoz-Garcia AJ, onso-Briales JH, Hernandez-Garcia JM, de Teresa Galvan E. Long-term prognosis in diabetic patients in whom revascularization is deferred following fractional flow reserve assessment. [Spanish]. Revista Espanola de Cardiologia. 2008;61(4):352-9. UI - 18405515. Reject Reason: No direct comparison between techniques. [pmid: 18405515].
Dudek D, Legutko J, Turek P, Zmudka K, Dubiel JS. Improvement of coronary flow reserve during intravascular ultrasound guided percutaneous coronary intervention (PCI). [Polish]. Przeglad Lekarski. 2003;60(8):504-7. UI - 14974340. Reject Reason: No direct comparison between techniques. [pmid: 14974340].
Dussaillant GR, Mintz GS, Pichard AD, Kent KM, Satler LF, Popma JJ, Bucher TA, Griffin J, Leon MB. Mechanisms and immediate and long-term results of adjunct directional coronary atherectomy after rotational atherectomy. Journal of the American College of Cardiology. 1996;27(6):1390-7. UI - 8626949. Reject Reason: No direct comparison between techniques. [pmid: 8626949].
Edris A, Patel PM, Kern MJ. Early recognition of catheter-induced left main coronary artery vasospasm: implications for revascularization. Catheterization & Cardiovascular Interventions. 8. 1. 2010;76(2):304-7. UI - 20665882. Reject Reason: No direct comparison between techniques. [pmid: 20665882].
Escolar E, Mintz GS, Popma J, Michalek A, Kim SW, Mandinov L, Koglin J, Stone G, Ellis SG, Grube E, Dawkins KD, Weissman NJ. Meta-analysis of angiographic versus intravascular ultrasound parameters of drug-eluting stent efficacy (from TAXUS IV, V, and VI). [Review] [12 refs]. American Journal of Cardiology. 8. 15. 2007;100(4):621-6. UI - 17697817. Reject Reason: Not relevant to KQs. [pmid: 17697817].
Fassa AA, Wagatsuma K, Higano ST, Mathew V, Barsness GW, Lennon RJ, Holmes DR Jr., Lerman A. Intravascular ultrasound-guided treatment for angiographically indeterminate left main coronary artery disease: a long-term follow-up study. Journal of the American College of Cardiology. 1. 18. 2005;45(2):204-11. UI - 15653016. Reject Reason: Intra-diagnostic comparison. [pmid: 15653016].
Fearon WF, Luna J, Samady H, Powers ER, Feldman T, Dib N, Tuzcu EM, Cleman MW, Chou TM, Cohen DJ, Ragosta M, Takagi A, Jeremias A, Fitzgerald PJ, Yeung AC, Kern MJ, Yock PG. Fractional flow reserve compared with intravascular ultrasound guidance for optimizing stent deployment. Circulation. 10. 16. 2001;104(16):1917-22. UI - 11602494. Reject Reason: No outcome of interest. [pmid: 11602494].
Feld S, Ganim M, Carell ES, Kjellgren O, Kirkeeide RL, Vaughn WK, Kelly R, McGhie AI, Kramer N, Loyd D, Anderson HV, Schroth G, Smalling RW. Comparison of angioscopy, intravascular ultrasound imaging and quantitative coronary angiography in predicting clinical outcome after coronary intervention in high risk patients. Journal of the American College of Cardiology. 1996;28(1):97-105. UI - 8752800. Reject Reason: No direct comparison between techniques. [pmid: 8752800].
Feres F, Andrade PB, Costa RA, de Ribamar Costa J Jr., Abizaid A, Staico R, Tanajura LF, Siqueira D, Maia JP, Lasave L, Sousa AG, Sousa JE. Angiographic and intravascular ultrasound findings following implantation of the Endeavor zotarolimus-eluting stents in patients from the real-world clinical practice. Eurointervention. 2009;5(3):355-62. UI - 19736161. Reject Reason: No direct comparison between techniques. [pmid: 19736161].
Ferrari M, Andreas S, Werner GS, Wicke J, Kreuzer H, Figulla HR. Evaluation of an active coronary perfusion balloon device using Doppler flow wire during PTCA. Catheterization & Cardiovascular Diagnosis. 1997;42(1):84-9. UI - 9286550. Reject Reason: No direct comparison between techniques. [pmid: 9286550].
Ferrari M, Schnell B, Werner GS, Figulla HR. Safety of deferring angioplasty in patients with normal coronary flow velocity reserve. Journal of the American College of Cardiology. 1999;33(1):82-7. UI - 9935013. Reject Reason: No comparison of interest. [pmid: 9935013].
Ferrari M, Mudra H, Grip L, Voudris V, Schachinger V, de Jaegere P, Rieber J, Hausmann D, Rothman M, Koschyk DH, Figulla HR, OPTICUS, ACE Substudy. Angiotensin-converting enzyme insertion/deletion polymorphism does not influence the restenosis rate after coronary stent implantation. Cardiology. 2002;97(1):29-36. UI - 11893827. Reject Reason: No outcome of interest. [pmid: 11893827].
Filho JG, Leitao MC, Forte AJ, Filho HG, Silva AA, Bastos ES, Murad H. Flow analysis of left internal thoracic artery in myocardial revascularization surgery using y graft. Texas Heart Institute Journal. 2006;33(4):430-6. UI - 17215965. Reject Reason: Not relevant to KQs. [pmid: 17215965].
Finci L, Ferraro M, Nishida T, Albiero R, Corvaja N, Vaghetti M, Stankovic G, Recchia M, Di Mario C, Colombo A. Coronary stenting beyond standard indications. Immediate and follow-up results. Italian Heart Journal: Official Journal of the Italian Federation of Cardiology. 2000;1(11):739-48. UI - 11110516. Reject Reason: No direct comparison between techniques. [pmid: 11110516].
Finocchiaro ML, Buffon A, Beltrame JF, Lupi A, Conti E, Lanza GA, Cianflone D, Crea F, Maseri A. Differences in vasodilatory response to dipyridamole between patients with angina and normal coronary arteries and patients with successful coronary angioplasty. Coronary Artery Disease. 1995;6(6):479-87. UI - 7551269. Reject Reason: No comparison of interest. [pmid: 7551269].
Fischer JJ, Wang XQ, Samady H, Sarembock IJ, Powers ER, Gimple LW, Ragosta M. Outcome of patients with acute coronary syndromes and moderate coronary lesions undergoing deferral of revascularization based on fractional flow reserve assessment. Catheterization & Cardiovascular Interventions. 2006;68(4):544-8. UI - 16969847. Reject Reason: No direct comparison between techniques. [pmid: 16969847].
Fitzgerald PJ, Yock PG. Mechanisms and outcomes of angioplasty and atherectomy assessed by intravascular ultrasound imaging. [Review] [39 refs]. Journal of Clinical Ultrasound. Dec. 1993;21(9):579-88. UI - 8227388. Reject Reason: No direct comparison between techniques. [pmid: 8227388].
Forster S, Rieber J, Ubleis C, Weiss M, Bartenstein P, Cumming P, Klauss V, Hacker M. Tc-99m sestamibi single photon emission computed tomography for guiding percutaneous coronary intervention in patients with multivessel disease: a comparison with quantitative coronary angiography and fractional flow reserve. The International Journal of Cardiovascular Imaging. 2010;26(2):203-13. UI - 19760091. Reject Reason: Not relevant to KQs. [pmid: 19760091].
Fujii K, Mintz GS, Kobayashi Y, Carlier SG, Takebayashi H, Yasuda T, Moussa I, Dangas G, Mehran R, Lansky AJ, Reyes A, Kreps E, Collins M, Colombo A, Stone GW, Teirstein PS, Leon MB, Moses JW. Contribution of stent underexpansion to recurrence after sirolimus-eluting stent implantation for in-stent restenosis. Circulation. 3. 9. 2004;109(9):1085-8. UI - 14993129. Reject Reason: No direct comparison between techniques. [pmid: 14993129].
Fujita H, Inoue N, Matsuo Y, Tokura T, Tanaka T, Ohta B, Matsumuro AM, Kuriyama T, Kitamura M, Miyao K. Fractional myocardial flow reserve (FFRmyo) after coronary intervention as a predictor of chronic restenosis. Journal of Invasive Cardiology. 1999;11(9):527-32. UI - 10745591. Reject Reason: Not relevant to KQs. [pmid: 10745591].
Fukuda D, Tanaka A, Shimada K, Nishida Y, Kawarabayashi T, Yoshikawa J. Predicting angiographic distal embolization following percutaneous coronary intervention in patients with acute myocardial infarction. American Journal of Cardiology. 2. 15. 2003;91(4):403-7. UI - 12586252. Reject Reason: No direct comparison between techniques. [pmid: 12586252].
Fukuda Y, Shirai K, Miura S, Ike A, Takamiya Y, Kuwano T, Yanagi D, Mori K, Kubota K, Miller N, Nishikawa H, Zhang B, Saku K. Impact of angulated lesions on angiographic late loss in patients with drug-eluting stent implantation. Journal of Cardiology. 2009;53(3):396-401. UI - 19477382. Reject Reason: No direct comparison between techniques. [pmid: 19477382].
Fusazaki T, Itoh T, Koeda T, Kimura T, Ogino Y, Matsui H, Sugawara S, Nakamura M. Angioscopy and OCT in repeated in-stent restenosis in saphenous vein graft. Jacc: Cardiovascular Imaging. 2010;3(7):785-6. UI - 20633859. Reject Reason: Case report. [pmid: 20633859].
Ge J, Erbel R, Zamorano J, Haude M, Kearney P, Gorge G, Meyer J. Improvement of coronary morphology and blood flow after stenting. Assessment by intravascular ultrasound and intracoronary Doppler. International Journal of Cardiac Imaging. 1995;11(2):81-7. UI - 7673762. Reject Reason: No direct comparison between techniques. [pmid: 7673762].
Ge J, Liu F, Kearney P, Gorge G, Haude M, Baumgart D, Ashry M, Erbel R. Intravascular ultrasound approach to the diagnosis of coronary artery aneurysms. American Heart Journal. 1995;130(4):765-71. UI - 7572584. Reject Reason: No direct comparison between techniques. [pmid: 7572584].
Gercken U, Lansky AJ, Buellesfeld L, Desai K, Badereldin M, Mueller R, Selbach G, Leon MB, Grube E. Results of the Jostent coronary stent graft implantation in various clinical settings: procedural and follow-up results. Catheterization & Cardiovascular Interventions. 2002;56(3):353-60. UI - 12112888. Reject Reason: No direct comparison between techniques. [pmid: 12112888].
Gil R, von Birgelen C, Prati F, Di Mario C, Ligthart J, Serruys PW. Usefulness of three-dimensional reconstruction for interpretation and quantitative analysis of intracoronary ultrasound during stent deployment. American Journal of Cardiology. 4. 1. 1996;77(9):761-4. UI - 8651131. Reject Reason: No comparison of interest. [pmid: 8651131].
Gil RJ, Gziut AI, Prati F, Witkowski A, Kubica J. Threshold parameters of left main coronary artery stem stenosis based on intracoronary ultrasound examination. Kardiologia Polska. discussion 232-3. 2005;63(3):223-31. UI - 16180175. Reject Reason: Not relevant to KQs. [pmid: 16180175].
Gilutz H, Russo RJ, Tsameret I, Fitzgerald PJ, Yock PG. Comparison of coronary stent expansion by intravascular ultrasonic imaging in younger versus older patients with diabetes mellitus. American Journal of Cardiology. 3. 1. 2000;85(5):559-62. UI - 11078267. Reject Reason: No direct comparison between techniques. [pmid: 11078267].
Goldberg SL, Colombo A, Nakamura S, Almagor Y, Maiello L, Tobis JM. Benefit of intracoronary ultrasound in the deployment of Palmaz-Schatz stents. Journal of the American College of Cardiology. 1994;24(4):996-1003. UI - 7930236. Reject Reason: No direct comparison between techniques. [pmid: 7930236].
Gonzalo N, Serruys PW, Garcia-Garcia HM, van Soest G, Okamura T, Ligthart J, Knaapen M, Verheye S, Bruining N, Regar E. Quantitative ex vivo and in vivo comparison of lumen dimensions measured by optical coherence tomography and intravascular ultrasound in human coronary arteries. Revista Espanola de Cardiologia. 2009;62(6):615-24. UI - 19480757. Reject Reason: No direct comparison between techniques. [pmid: 19480757].
Grube E, Sievert H, Hauptmann KE, Mueller R, Gerckens U, Buellesfeld L, Ako J, Shimohama T, Costa M, Fitzgerald P. Novel drug eluting stent system for customised treatment of coronary lesions: CUSTOM I feasibility trial 24 month results. Eurointervention. 2008;4(1):71-6. UI - 19112782. Reject Reason: Measurement timepoint not of interest. [pmid: 19112782].
Guarda E, Marchant E, Fajuri A, Martinez A, Moran S, Mendez M, Uriarte P, Valenzuela E, Lazen R. Oral rapamycin to prevent human coronary stent restenosis: a pilot study. American Heart Journal. 2004;148(2):e9. UI - 15309012. Reject Reason: No direct comparison between techniques. [pmid: 15309012].
Guédès A, Keller PF, L'Allier PL, Lespérance J, Grégoire J, Tardif JC. Long-term safety of intravascular ultrasound in nontransplant, nonintervened, atherosclerotic coronary arteries. J Am Coll Cardiol. Feb. 15. 2005;45(4):559-64. UI – 15708704. Reject reason: Population not of interest. [pmid: 15708704].
Guo N, Maehara A, Mintz GS, He Y, Xu K, Wu X, Lansky AJ, Witzenbichler B, Guagliumi G, Brodie B, Kellett MA Jr., Dressler O, Parise H, Mehran R, Stone GW. Incidence, mechanisms, predictors, and clinical impact of acute and late stent malapposition after primary intervention in patients with acute myocardial infarction: an intravascular ultrasound substudy of the Harmonizing Outcomes with Revascularization and Stents in Acute Myocardial Infarction (HORIZONS-AMI) trial. Circulation. 9. 14. 2010;122(11):1077-84. UI - 20805433. Reject Reason: No direct comparison between techniques. [pmid: 20805433].
Gutierrez H, Arnold R, Gimeno F, Ramos B, Lopez J, del Amo E, Vazquez E, San Roman JA. Optical coherence tomography. Initial experience in patients undergoing percutaneous coronary intervention. Revista Espanola de Cardiologia. 2008;61(9):976-9. UI - 18775241. Reject Reason: No direct comparison between techniques. [pmid: 18775241].
Haase J, Ozaki Y, Di Mario C, Escaned J, de Feyter PJ, Roelandt JR, Serruys PW. Can intracoronary ultrasound correctly assess the luminal dimensions of coronary artery lesions? A comparison with quantitative angiography. European Heart Journal. 1995;16(1):112-9. UI - 7737207. Reject Reason: No outcome of interest. [pmid: 7737207].
Haase KK, Athanasiadis A, Mahrholdt H, Treusch A, Wullen B, Jaramillo C, Baumbach A, Voelker W, Meisner C, Karsch KR. Acute and one year follow-up results after vessel size adapted PTCA using intracoronary ultrasound. European Heart Journal. 1919;(2):263-272. UI - 9519320. Reject Reason: No direct comparison between techniques.
Hagiwara H, Shirakawa M, Nakayama T, Asai T, Nakayama M, Ito T, Yano Y. The correlation between flow pattern during cardiopulmonary bypass and patency of the coronary artery bypass grafts. [Japanese]. Kyobu Geka - Japanese Journal of Thoracic Surgery. discussion 524-6. 2005;58(7):519-23. UI - 16004331. Reject Reason: Not relevant to KQs. [pmid: 16004331].
Haldis TA, Fenster B, Gavlick K, Singh KD, Iliadis E, Blankenship JC. The angiographic step-up and step-down: a surrogate for optimal stent expansion by intravascular ultrasound. Journal of Invasive Cardiology. 1919;(3):101-105. UI - 17341775. Reject Reason: No direct comparison between techniques.
Hall P, Colombo A, Almagor Y, Maiello L, Nakamura S, Martini G, Tobis JM. Preliminary experience with intravascular ultrasound guided Palmaz-Schatz coronary stenting: the acute and short-term results on a consecutive series of patients. Journal of Interventional Cardiology. 1994;7(2):141-59. UI - 10151041. Reject Reason: No direct comparison between techniques. [pmid: 10151041].
Hall P, Nakamura S, Maiello L, Almagor Y, Gaglione A, Goldberg SL, Tobis JM, Martini G, Tucci G, Di Maggio M. Clinical and angiographic outcome after Palmaz-Schatz stent implantation guided by intravascular ultrasound. Journal of Invasive Cardiology. Suppl A. 1995;7:12A-22A. UI - 10155111. Reject Reason: Not relevant to KQs.
Hamilos M, Muller O, Cuisset T, Ntalianis A, Chlouverakis G, Sarno G, Nelis O, Bartunek J, Vanderheyden M, Wyffels E, Barbato E, Heyndrickx GR, Wijns W, De Bruyne B. Long-term clinical outcome after fractional flow reserve-guided treatment in patients with angiographically equivocal left main coronary artery stenosis. Circulation. 10. 13. 2009;120(15):1505-12. UI - 19786633. Reject Reason: No comparison of interest. [pmid: 19786633].
Hanekamp CE, Koolen JJ, Pijls NH, Michels HR, Bonnier HJ. Comparison of quantitative coronary angiography, intravascular ultrasound, and coronary pressure measurement to assess optimum stent deployment. Circulation. 3. 2. 1999;99(8):1015-21. UI - 10051294. Reject Reason: No outcome of interest. [pmid: 10051294].
Hardt SE, Bekeredjian R, Brachmann J, Kuecherer HF, Hansen A, Kubler W, Katus HA. Intravascular ultrasound for evaluation of initial vessel patency and early outcome following directional coronary atherectomy. Catheterization & Cardiovascular Interventions. 1999;47(1):14-22. UI - 10385152. Reject Reason: No comparison of interest. [pmid: 10385152].
Hartmann A, Reuss W, Burger W, Kneissl GD, Rothe W, Beyersdorf F. Endothelium-dependent and endothelium-independent flow reserve in vascular regions supplied by the internal mammary artery before and after bypass grafting. European Journal of Cardio-Thoracic Surgery. 1998;13(4):410-5. UI - 9641340. Reject Reason: No comparator of interest. [pmid: 9641340].
Hassan AK, Bergheanu SC, Stijnen T, van der Hoeven BL, Snoep JD, Plevier JW, Schalij MJ, Wouter Jukema J. Late stent malapposition risk is higher after drug-eluting stent compared with bare-metal stent implantation and associates with late stent thrombosis. [Review]. European Heart Journal. 2010;31(10):1172-80. UI - 19158118. Reject Reason: No outcome of interest. [pmid: 19158118].
Haude M, Baumgart D, Verna E, Piek JJ, Vrints C, Probst P, Erbel R. Intracoronary Doppler- and quantitative coronary angiography-derived predictors of major adverse cardiac events after stent implantation. Circulation. 3. 6. 2001;103(9):1212-7. UI - 11238263. Reject Reason: No direct comparison between techniques. [pmid: 11238263].
Hermiller JB, Buller CE, Tenaglia AN, Kisslo KB, Phillips HR, Bashore TM, Stack RS, Davidson CJ. Unrecognized left main coronary artery disease in patients undergoing interventional procedures. American Journal of Cardiology. 1. 15. 1993;71(2):173-6. UI - 8421979. Reject Reason: No direct comparison between techniques. [pmid: 8421979].
Herregods MC, de Scheerder I, de Geest H, van der Werf F. Usefulness of echocardiography and Doppler in the detection of segmental myocardial ischemia. International Journal of Cardiac Imaging. 1993;9(4):241-7. UI - 8133121. Reject Reason: No direct comparison between techniques. [pmid: 8133121].
Herrmann J, Haude M, Lerman A, Schulz R, Volbracht L, Ge J, Schmermund A, Wieneke H, von Birgelen C, Eggebrecht H, Baumgart D, Heusch G, Erbel R. Abnormal coronary flow velocity reserve after coronary intervention is associated with cardiac marker elevation. Circulation. 5. 15. 2001;103(19):2339-45. UI - 11352881. Reject Reason: No direct comparison between techniques. [pmid: 11352881].
Hodgson JM, Reddy KG, Suneja R, Nair RN, Lesnefsky EJ, Sheehan HM. Intracoronary ultrasound imaging: correlation of plaque morphology with angiography, clinical syndrome and procedural results in patients undergoing coronary angioplasty. Journal of the American College of Cardiology. 1993;21(1):35-44. UI - 8417074. Reject Reason: No outcome of interest. [pmid: 8417074].
Hoffmann R, Mintz GS, Popma JJ, Satler LF, Kent KM, Pichard AD, Leon MB. Overestimation of acute lumen gain and late lumen loss by quantitative coronary angiography (compared with intravascular ultrasound) in stented lesions. American Journal of Cardiology. 11. 15. 1997;80(10):1277-81. UI - 9388098. Reject Reason: No direct comparison between techniques. [pmid: 9388098].
Hoffmann R, Mintz GS, Pichard AD, Kent KM, Satler LF, Leon MB. Intimal hyperplasia thickness at follow-up is independent of stent size: a serial intravascular ultrasound study. American Journal of Cardiology. 11. 15. 1998;82(10):1168-72. UI - 9832088. Reject Reason: No direct comparison between techniques. [pmid: 9832088].
Hoffmann R, Haager P, Mintz GS, Kerckhoff G, Schwarz R, Franke A, vom Dahl J, Hanrath P. The impact of high pressure vs low pressure stent implantation on intimal hyperplasia and follow-up lumen dimensions; results of a randomized trial. European Heart Journal. 2001;22(21):2015-24. UI - 11603909. Reject Reason: No direct comparison between techniques. [pmid: 11603909].
Hoffmann R, Jansen C, Konig A, Haager PK, Kerckhoff G, vom Dahl J, Klauss V, Hanrath P, Mudra H. Stent design related neointimal tissue proliferation in human coronary arteries; an intravascular ultrasound study. European Heart Journal. 2001;22(21):2007-14. UI - 11603908. Reject Reason: Measurement timepoint not of interest. [pmid: 11603908].
Hoffmann R, Mintz GS, Haager PK, Bozoglu T, Grube E, Gross M, Beythien C, Mudra H, vom Dahl J, Hanrath P. Relation of stent design and stent surface material to subsequent in-stent intimal hyperplasia in coronary arteries determined by intravascular ultrasound. American Journal of Cardiology. 6. 15. 2002;89(12):1360-4. UI - 12062728. Reject Reason: No direct comparison between techniques. [pmid: 12062728].
Hoffmann R, Morice MC, Moses JW, Fitzgerald PJ, Mauri L, Breithardt G, Schofer J, Serruys PW, Stoll HP, Leon MB. Impact of late incomplete stent apposition after sirolimus-eluting stent implantation on 4-year clinical events: intravascular ultrasound analysis from the multicentre, randomised, RAVEL, E-SIRIUS and SIRIUS trials. Heart. 2008;94(3):322-8. UI - 17761505. Reject Reason: Not relevant to KQs. [pmid: 17761505].
Hofma SH, van Dalen BM, Lemos PA, Ligthart JM, Aoki J, McFadden EP, Sianos G, van Essen D, de Feijter PJ, Serruys PW, van der Giessen WJ. No change in endothelial-dependent vasomotion late after coronary irradiation. Cardiovascular Radiation Medicine. Dec. 2004;5(4):156-61. UI - 16237983. Reject Reason: No direct comparison between techniques. [pmid: 16237983].
Hoher M, Hombach V, Wohrle J. Angioscopic predictors of restenosis following coronary angioplasty--the impact of yellow smooth plaques. Zeitschrift fur Kardiologie. 2001;90(2):111-9. UI - 11263000. Reject Reason: Not relevant to KQs. [pmid: 11263000].
Hong MK, Mintz GS, Hong MK, Pichard AD, Satler LF, Kent KM, Popma JJ, Leon MB. Intravascular ultrasound predictors of target lesion revascularization after stenting of protected left main coronary artery stenoses. American Journal of Cardiology. 1. 15. 1999;83(2):175-9. UI - 10073817. Reject Reason: No comparison of interest. [pmid: 10073817].
Hong MK, Park SW, Mintz GS, Lee NH, Lee CW, Kim JJ, Park SJ. Intravascular ultrasonic predictors of angiographic restenosis after long coronary stenting. American Journal of Cardiology. 2. 15. 2000;85(4):441-5. UI - 10728947. Reject Reason: No direct comparison between techniques. [pmid: 10728947].
Hong MK, Park SW, Lee NH, Nah DY, Lee CW, Kang DH, Song JK, Kim JJ, Park SJ. Long-term outcomes of minor dissection at the edge of stents detected with intravascular ultrasound. American Journal of Cardiology. A9. 10. 1. 2000;86(7):791-5. UI - 11018205. Reject Reason: No direct comparison between techniques. [pmid: 11018205].
Hong MK, Park SW, Lee CW, Rhee KS, Song JM, Kang DH, Song JK, Kim JJ, Park SJ. Six-month angiographic follow-up after intravascular ultrasound-guided stenting of infarct-related artery: comparison with non-infarct-related artery. American Heart Journal. 2001;141(5):832-6. UI - 11320374. Reject Reason: No direct comparison between techniques. [pmid: 11320374].
Hong MK, Park SW, Moon DH, Oh SJ, Kim EH, Lee CW, Song JM, Kang DH, Song JK, Kim JJ, Park SJ. Impact of geographic miss on adjacent coronary artery segments in diffuse in-stent restenosis with beta-radiation therapy: angiographic and intravascular ultrasound analysis. American Heart Journal. 2002;143(2):327-33. UI - 11835039. Reject Reason: Measurement timepoint not of interest. [pmid: 11835039].
Hong MK, Park SW, Lee CW, Kim YH, Song JM, Kang DH, Song JK, Kim JJ, Park SJ. Relation between residual plaque burden after stenting and six-month angiographic restenosis. American Journal of Cardiology. 2. 15. 2002;89(4):368-71. UI - 11835912. Reject Reason: No direct comparison between techniques. [pmid: 11835912].
Hong MK, Lee CW, Kim JH, Kim YH, Song JM, Kang DH, Song JK, Kim JJ, Park SW, Park SJ. Impact of various intravascular ultrasound criteria for stent optimization on the six-month angiographic restenosis. Catheterization & Cardiovascular Interventions. 2002;56(2):178-83. UI - 12112909. Reject Reason: No direct comparison between techniques. [pmid: 12112909].
Hong MK, Mintz GS, Lee CW, Song JM, Han KH, Kang DH, Song JK, Kim JJ, Weissman NJ, Fearnot NE, Park SW, Park SJ, ASian Paclitaxel-Eluting Stent Clinical Trial. Paclitaxel coating reduces in-stent intimal hyperplasia in human coronary arteries: a serial volumetric intravascular ultrasound analysis from the Asian Paclitaxel-Eluting Stent Clinical Trial (ASPECT). Circulation. 2. 4. 2003;107(4):517-20. UI - 12566359. Reject Reason: No comparison of interest. [pmid: 12566359].
Hong MK, Mintz GS, Lee CW, Kim YH, Lee SW, Moon DH, Oh SJ, Song JM, Han KH, Kang DH, Song JK, Kim JJ, Park SW, Park SJ. Late intravascular ultrasound findings of patients treated with brachytherapy for diffuse in-stent restenosis. Catheterization & Cardiovascular Interventions. 2004;63(2):208-14. UI - 15390251. Reject Reason: No direct comparison between techniques. [pmid: 15390251].
Hong MK, Mintz GS, Lee CW, Park DW, Choi BR, Park KH, Kim YH, Cheong SS, Song JK, Kim JJ, Park SW, Park SJ. Intravascular ultrasound predictors of angiographic restenosis after sirolimus-eluting stent implantation. European Heart Journal. 2006;27(11):1305-10. UI - 16682378. Reject Reason: No direct comparison between techniques. [pmid: 16682378].
Hong YJ, Jeong MH, Lim SY, Lee SR, Kim KH, Sohn IS, Park HW, Kim JH, Kim W, Ahn Y, Cho JG, Park JC, Kang JC. Preinterventional peak monocyte count and in-stent intimal hyperplasia after coronary stent implantation in human coronary arteries. Clinical Cardiology. 2005;28(11):512-8. UI - 16450794. Reject Reason: No direct comparison between techniques. [pmid: 16450794].
Hong YJ, Mintz GS, Kim SW, Lee SY, Kim SY, Okabe T, Pichard AD, Satler LF, Waksman R, Kent KM, Suddath WO, Weissman NJ. Disease progression in nonintervened saphenous vein graft segments a serial intravascular ultrasound analysis. Journal of the American College of Cardiology. 4. 14. 2009;53(15):1257-64. UI - 19358938. Reject Reason: No direct comparison between techniques. [pmid: 19358938].
Hong YJ, Pichard AD, Mintz GS, Kim SW, Lee SY, Kim SY, Ahn Y, Jeong MH, Satler LF, Kent KM, Suddath WO, Weissman NJ, Kang JC, Waksman R. Outcome of undersized drug-eluting stents for percutaneous coronary intervention of saphenous vein graft lesions. [Erratum appears in Am J Cardiol. 2010 Jul 1;106(1):142]. American Journal of Cardiology. 1. 15. 2010;105(2):179-85. UI - 20102915. Reject Reason: No direct comparison between techniques. [pmid: 20102915].
Hur SH, Hassan AH, Rekhi R, Ako J, Shimada Y, Nakamura M, Yamasaki M, Bonneau HN, Sudhir K, Yock PG, Honda Y, Fitzgerald PJ. Serial intravascular ultrasonic study of outcomes of coronary culprit lesions with plaque rupture following bare metal stent implantation in patients with angina pectoris. American Journal of Cardiology. 5. 15. 2007;99(10):1394-8. UI - 17493467. Reject Reason: Not relevant to KQs. [pmid: 17493467].
Imola F, Mallus MT, Ramazzotti V, Manzoli A, Pappalardo A, Di Giorgio A, Albertucci M, Prati F. Safety and feasibility of frequency domain optical coherence tomography to guide decision making in percutaneous coronary intervention. Eurointervention. 2010;6(5):575-81. UI - 21044910. Reject Reason: No direct comparison between techniques. [pmid: 21044910].
Iofina E, Langenberg R, Blindt R, Kuhl H, Kelm M, Hoffmann R. Polymer-based paclitaxel-eluting stents are superior to nonpolymer-based paclitaxel-eluting stents in the treatment of de novo coronary lesions. American Journal of Cardiology. 10. 15. 2006;98(8):1022-7. UI - 17027564. Reject Reason: No comparison of interest. [pmid: 17027564].
Isaaz K, Bruntz JF, Ethevenot G, Courtalon T, Aliot E. Noninvasive assessment of coronary flow dynamics before and after coronary angioplasty using transesophageal Doppler. American Journal of Cardiology. 12. 1. 1993;72(17):1238-42. UI - 8256698. Reject Reason: No direct comparison between techniques. [pmid: 8256698].
Ishikawa S, Asakura Y, Okabe T, Sakamoto M, Shibata M, Asakura K, Mitamura H, Ogawa S. Repeat intervention for in-stent restenosis: re-expansion of the initial stent is a predictor of recurrence of restenosis. Coronary Artery Disease. 2000;11(6):451-7. UI - 10966130. Reject Reason: No direct comparison between techniques. [pmid: 10966130].
Ito S, Suzuki T, Katoh O, Ojio S, Sato H, Ehara M, Ito T, Myoishi M, Kawase Y, Kurokawa R, Suzuki Y, Sato K, Toyama J, Fukutomi T, Itoh M. The influence of diabetes mellitus on plaque volume and vessel size in patients undergoing percutaneous coronary intervention. Japanese Heart Journal. 2004;45(4):573-80. UI - 15353868. Reject Reason: No direct comparison between techniques. [pmid: 15353868].
Jain SP, Jain A, Collins TJ, Ramee SR, White CJ. Predictors of restenosis: a morphometric and quantitative evaluation by intravascular ultrasound. American Heart Journal. 1994;128(4):664-73. UI - 7942436. [pmid: 7942436].
Jang IK, Tearney G, Bouma B. Visualization of tissue prolapse between coronary stent struts by optical coherence tomography: comparison with intravascular ultrasound. Circulation. 11. 27. 2001;104(22):2754. UI - 11723031. Reject Reason: Case report. [pmid: 11723031].
Jasti V, Ivan E, Yalamanchili V, Wongpraparut N, Leesar MA. Correlations between fractional flow reserve and intravascular ultrasound in patients with an ambiguous left main coronary artery stenosis. Circulation. 11. 2. 2004;110(18):2831-6. UI - 15492302. Reject Reason: No outcome of interest. [pmid: 15492302].
Jensen LO, Maeng M, Mintz GS, Christiansen EH, Hansen KN, Galloe A, Kelbaek H, Hansen HS, Joergensen E, Lassen JF, Thuesen L, Thayssen P. Intravascular ultrasound assessment of expansion of the sirolimus-eluting (cypher select) and paclitaxel-eluting (Taxus Express-2) stent in patients with diabetes mellitus. American Journal of Cardiology. 7. 1. 2008;102(1):19-26. UI - 18572030. Reject Reason: No direct comparison between techniques. [pmid: 18572030].
Jeremias A, Gorge G, Konorza T, Haude M, von Birgelen C, Ge J, Simon H, Erbel R. Stepwise intravascular ultrasound (IVUS) guidance of high-pressure coronary stenting does not result in an improved acute or long-term outcome: a randomized comparison to “final-look” IVUS assessment. Catheterization & Cardiovascular Interventions. 1999;46(2):135-41. UI - 10348530. Reject Reason: Measurement timepoint not of interest. [pmid: 10348530].
Jimenez-Navarro MF, onso-Briales J, Hernandez-Garcia JM, Curiel E, Kuhlmorgen B, Gomez-Doblas JJ, Garcia-Pinilla JM, Robledo J, De Teresa E. Usefulness of fractional flow reserve in multivessel coronary artery disease with intermediate lesions. Journal of Interventional Cardiology. 1919;(2):148-152. UI - 16650243. Reject Reason: No direct comparison between techniques.
Johansson B, Olsson H, Wennerblom B. Angiography-guided routine coronary stent implantation results in suboptimal dilatation. Angiology. Feb. 2002;53(1):69-75. UI - 11863311. Reject Reason: No direct comparison between techniques. [pmid: 11863311].
Johansson B, Allared M, Borgencrantz B, Brorson L, Geijer H, Kellerth T, Olsson H, Ragnarsson A, Skoglund H, Wennerblom B. Standardized angiographically guided over-dilatation of stents using high pressure technique optimize results without increasing risks. Journal of Invasive Cardiology. 2002;14(5):221-6. UI - 11983940. Reject Reason: Not relevant to KQs. [pmid: 11983940].
Kang SJ, Mintz GS, Kim WJ, Lee JY, Park DW, Yun SC, Lee SW, Kim YH, Lee CW, Han KH, Kim JJ, Park SW, Park SJ. Effect of intravascular ultrasound findings on long-term repeat revascularization in patients undergoing drug-eluting stent implantation for severe unprotected left main bifurcation narrowing. American Journal of Cardiology. 2. 1. 2011;107(3):367-73. UI - 21257000. Reject Reason: No direct comparison between techniques. [pmid: 21257000].
Kang WC, Oh KJ, Han SH, Ahn TH, Chung WJ, Shin MS, Koh KK, Choi IS, Shin EK. Angiographic and intravascular ultrasound study of the effects of overlapping sirolimus- and paclitaxel-eluting stents: comparison with same drug-eluting overlapping stents. International Journal of Cardiology. 12. 15. 2007;123(1):12-7. UI - 17289176. Reject Reason: No comparison of interest. [pmid: 17289176].
Kang WC, Ahn T, Moon CI, Lee K, Han SH, Shin EK, Kim JS, Ko YG, Choi D, Jang Y, Kim BK, Oh SJ, Jeon DW, Yang JY. Comparison of the effect of preinterventional arterial remodeling on intimal hyperplasia after implantation of a sirolimus- or paclitaxel-eluting stent. Cardiology. 2010;116(2):117-22. UI - 20588020. Reject Reason: No direct comparison between techniques. [pmid: 20588020].
Kasaoka S, Tobis JM, Akiyama T, Reimers B, Di Mario C, Wong ND, Colombo A. Angiographic and intravascular ultrasound predictors of in-stent restenosis. Journal of the American College of Cardiology. 11. 15. 1998;32(6):1630-5. UI - 9822089. Reject Reason: No direct comparison between techniques. [pmid: 9822089].
Kass M, Glover CA, Labinaz M, So DY, Chen L, Yam Y, Chow BJ. Lesion characteristics and coronary stent selection with computed tomographic coronary angiography: a pilot investigation comparing CTA, QCA and IVUS. Journal of Invasive Cardiology. 2010;22(7):328-34. UI - 20603505. Reject Reason: No direct comparison between techniques. [pmid: 20603505].
Katayama T, Kubo N, Takagi Y, Funayama H, Ikeda N, Ishida T, Hirahara T, Sugawara Y, Yasu T, Kawakami M, Saito M. Relation of atherothrombosis burden and volume detected by intravascular ultrasound to angiographic no-reflow phenomenon during stent implantation in patients with acute myocardial infarction. American Journal of Cardiology. 2. 1. 2006;97(3):301-4. UI - 16442385. Reject Reason: No direct comparison between techniques. [pmid: 16442385].
Katritsis DG, Ioannidis JP, Korovesis S, Giazitzoglou E, Parissis J, Kalivas P, Webb-Peploe MM. Comparison of myocardial fractional flow reserve and intravascular ultrasound for the assessment of slotted-tube stents. Catheterization & Cardiovascular Interventions. discussion 327. 2001;52(3):322-6. UI - 11246245. Reject Reason: No direct comparison between techniques. [pmid: 11246245].
Kawamoto T, Okura H, Koyama Y, Toda I, Taguchi H, Tamita K, Yamamuro A, Yoshimura Y, Neishi Y, Toyota E, Yoshida K. The relationship between coronary plaque characteristics and small embolic particles during coronary stent implantation. Journal of the American College of Cardiology. 10. 23. 2007;50(17):1635-40. UI - 17950143. Reject Reason: No direct comparison between techniques. [pmid: 17950143].
Kay IP, Sabate M, Van Langenhove G, Costa MA, Wardeh AJ, Gijzel AL, Deshpande NV, Carlier SG, Coen VL, Levendag PC, van der Giessen W, de Feyter PJ, Serruys PW. Outcome from balloon induced coronary artery dissection after intracoronary beta radiation. Heart. 2000;83(3):332-7. UI - 10677416. Reject Reason: No direct comparison between techniques. [pmid: 10677416].
Kern MJ, Moore JA, Aguirre FV, Bach RG, Caracciolo EA, Wolford T, Khoury AF, Mechem C, Donohue TJ. Determination of angiographic (TIMI grade) blood flow by intracoronary Doppler flow velocity during acute myocardial infarction. Circulation. 10. 1. 1996;94(7):1545-52. UI - 8840842. Reject Reason: No direct comparison between techniques. [pmid: 8840842].
Kern MJ, Dupouy P, Drury JH, Aguirre FV, Aptecar E, Bach RG, Caracciolo EA, Donohue TJ, Rande JL, Geschwind HJ, Mechem CJ, Kane G, Teiger E, Wolford TL. Role of coronary artery lumen enlargement in improving coronary blood flow after balloon angioplasty and stenting: a combined intravascular ultrasound Doppler flow and imaging study. Journal of the American College of Cardiology. 1997;29(7):1520-7. UI - 9180114. Reject Reason: No direct comparison between techniques. [pmid: 9180114].
Kiemeneij F, Laarman GJ. Transradial artery Palmaz-Schatz coronary stent implantation: results of a single-center feasibility study. American Heart Journal. 1995;130(1):14-21. UI - 7611104. Reject Reason: No IVDx technique used. [pmid: 7611104].
Kiemeneij F, Laarman GJ, Slagboom T. Percutaneous transradial coronary Palmaz-Schatz stent implantation, guided by intravascular ultrasound. Catheterization & Cardiovascular Diagnosis. 1995;34(2):133-6. UI - 7788691. Reject Reason: No direct comparison between techniques. [pmid: 7788691].
Kiemeneij F, Laarman G, Slagboom T. Mode of deployment of coronary Palmaz-Schatz stents after implantation with the stent delivery system: an intravascular ultrasound study. American Heart Journal. 1995;129(4):638-44. UI - 7900610. Reject Reason: No direct comparison between techniques. [pmid: 7900610].
Kim HS, Kim YH, Lee SW, Park DW, Lee CW, Hong MK, Kim JJ, Park SW, Park SJ. Safety and effectiveness of sirolimus-eluting stent implantation for in-stent restenosis of the unprotected left main coronary artery. International Journal of Cardiology. 2. 20. 2008;124(1):118-20. UI - 17383034. Reject Reason: Not relevant to KQs. [pmid: 17383034].
Kim SW, Mintz GS, Ohlmann P, Hassani SE, Fernandez S, Lu L, Chu WW, Escolar E, Kuchulakanti PK, Weigold G, Pichard AD, Satler LF, Kent KM, Suddath WO, Waksman R, Weissman NJ. Frequency and severity of plaque prolapse within Cypher and Taxus stents as determined by sequential intravascular ultrasound analysis. American Journal of Cardiology. 11. 1. 2006;98(9):1206-11. UI - 17056329. Reject Reason: No comparison of interest. [pmid: 17056329].
Kim U, Kim JS, Kim JS, Lee JM, Son JW, Kim J, Ko YG, Choi D, Jang Y. The initial extent of malapposition in ST-elevation myocardial infarction treated with drug-eluting stent: the usefulness of optical coherence tomography. Yonsei Medical Journal. 2010;51(3):332-8. UI - 20376884. Reject Reason: No direct comparison between techniques. [pmid: 20376884].
Kim WH, Lee BK, Lee S, Shim JM, Kim JS, Kim BK, Ko YG, Choi D, Jang Y, Hong MK. Serial changes of minimal stent malapposition not detected by intravascular ultrasound: follow-up optical coherence tomography study. Clinical Research in Cardiology. 2010;99(10):639-44. UI - 20407905. Reject Reason: No direct comparison between techniques. [pmid: 20407905].
Kim YH, Dangas GD, Solinas E, Aoki J, Parise H, Kimura M, Franklin-Bond T, Dasgupta NK, Kirtane AJ, Moussa I, Lansky AJ, Collins M, Stone GW, Leon MB, Moses JW, Mehran R. Effectiveness of drug-eluting stent implantation for patients with unprotected left main coronary artery stenosis. American Journal of Cardiology. 3. 15. 2008;101(6):801-6. UI - 18328844. Reject Reason: No direct comparison between techniques. [pmid: 18328844].
Kim YS, Koo BK, Seo JB, Park KW, Suh JW, Lee HY, Park JS, Kang HJ, Cho YS, Chung WY, Chae IH, Choi DJ, Kim HS, Oh BH, Park YB. The incidence and predictors of postprocedural incomplete stent apposition after angiographically successful drug-eluting stent implantation. Catheterization & Cardiovascular Interventions. 7. 1. 2009;74(1):58-63. UI - 19360868. Reject Reason: No direct comparison between techniques. [pmid: 19360868].
Kini AS, Kim MC, Moreno PR, Krishnan P, Ivan OC, Sharma SK. Comparison of coronary flow reserve and fractional flow reserve in patients with versus without diabetes mellitus and having elective percutaneous coronary intervention and abciximab therapy (from the PREDICT Trial). American Journal of Cardiology. 3. 15. 2008;101(6):796-800. UI - 18328843. Reject Reason: No direct comparison between techniques. [pmid: 18328843].
Kinoshita Y, Katoh O, Matsubara T, Ehara M, Nasu K, Habara M, Suzuki T. First clinical experience of “flower petal stenting”: a novel technique for the treatment of coronary bifurcation lesions. Jacc: Cardiovascular Interventions. 2010;3(1):58-65. UI - 20129570. Reject Reason: No comparison of interest. [pmid: 20129570].
Kobori Y, Tanaka N, Takazawa K, Yamashina A. Usefulness of fractional flow reserve in determining the indication of target lesion revascularization. Catheterization & Cardiovascular Interventions. 2005;65(3):355-60. UI - 15926183. Reject Reason: Intra-diagnostic comparison. [pmid: 15926183].
Kok WE, Peters RJ, Pasterkamp G, Di Mario C, Serruys PW, Prins M, Visser CA. Greater late lumen loss after successful coronary balloon angioplasty in the proximal left anterior descending coronary artery is not explained by extent of vessel wall damage or plaque burden. Journal of the American College of Cardiology. 2000;35(2):382-8. UI - 10676685. Reject Reason: No direct comparison between techniques. [pmid: 10676685].
Kok WE, Peters RJ, Pasterkamp G, van Liebergen RA, Piek JJ, Koch KT, Visser CA. Early lumen diameter loss after percutaneous transluminal coronary angioplasty is related to coronary plaque burden: a role for viscous plaque properties in early lumen diameter loss. The International Journal of Cardiovascular Imaging. 2001;17(2):111-21. UI - 11558970. Reject Reason: No direct comparison between techniques. [pmid: 11558970].
Komiyama N, Nakanishi S, Nishiyama S, Seki A. Intravascular imaging of serial changes of disease in saphenous vein grafts after coronary artery bypass grafting. American Heart Journal. 1996;132(1 Pt 1):30-40. UI - 8701873. Reject Reason: No direct comparison between techniques. [pmid: 8701873].
Koschyk DH, Nienaber CA, Schaps KP, Twisselmann T, Hofmann T, Lund GK, Langes K, Meinertz T. Impact of intravascular ultrasound guidance on directional coronary atherectomy. Zeitschrift fur Kardiologie. 2000;89(4):301-6. UI - 10868004. Reject Reason: Not relevant to KQs. [pmid: 10868004].
Kotani J, Mintz GS, Pregowski J, Kalinczuk L, Pichard AD, Satler LF, Suddath WO, Waksman R, Weissman NJ. Volumetric intravascular ultrasound evidence that distal embolization during acute infarct intervention contributes to inadequate myocardial perfusion grade. American Journal of Cardiology. 9. 15. 2003;92(6):728-32. UI - 12972120. Reject Reason: No direct comparison between techniques. [pmid: 12972120].
Kozuma K, Regar E, Bruining N, van der Giessen W, Boersma E, Foley DP, de Feyter PJ, Levendag PC, Serruys PW. Sensitivity and specificity of QCA in detecting coronary arterial remodeling after intracoronary brachytherapy: a comparison to serial volumetric three-dimensional intravascular ultrasound analysis. Can we detect positive remodeling by luminography?. Journal of Invasive Cardiology. 2003;15(11):636-40. UI - 14608135. Reject Reason: Not relevant to KQs. [pmid: 14608135].
Kruger S, Koch KC, Kaumanns I, Merx MW, Hanrath P, Hoffmann R. Clinical significance of fractional flow reserve for evaluation of functional lesion severity in stent restenosis and native coronary arteries. Chest. 2005;128(3):1645-9. UI - 16162770. Reject Reason: No direct comparison between techniques. [pmid: 16162770].
Kubo T, Imanishi T, Kitabata H, Kuroi A, Ueno S, Yamano T, Tanimoto T, Matsuo Y, Masho T, Takarada S, Tanaka A, Nakamura N, Mizukoshi M, Tomobuchi Y, Akasaka T. Comparison of vascular response after sirolimus-eluting stent implantation between patients with unstable and stable angina pectoris: a serial optical coherence tomography study. Jacc: Cardiovascular Imaging. 2008;1(4):475-84. UI - 19356470. Reject Reason: No direct comparison between techniques. [pmid: 19356470].
Kulik A, Le May MR, Voisine P, Tardif JC, Delarochelliere R, Naidoo S, Wells GA, Mesana TG, Ruel M. Aspirin plus clopidogrel versus aspirin alone after coronary artery bypass grafting: the clopidogrel after surgery for coronary artery disease (CASCADE) Trial. Circulation. 12. 21. 2010;122(25):2680-7. UI - 21135365. Reject Reason: No direct comparison between techniques. [pmid: 21135365].
Lachance P, Dery JP, Rodes-Cabau J, Potvin JM, Barbeau G, Bertrand OF, Gleeton O, Larose E, Nguyen CM, Noel B, Proulx G, Roy L, De Larochelliere R. Impact of fractional flow reserve measurement on the clinical management of patients with coronary artery disease evaluated with noninvasive stress tests prior to cardiac catheterization. Cardiovascular Revascularization Medicine. Dec. 2008;9(4):229-34. UI - 18928947. Reject Reason: No direct comparison between techniques. [pmid: 18928947].
Lamm C, Albertsson P, Dohnal M, Tylen U, Emanuelsson H. Assessment of coronary artery stenosis during PTCA by measurement of the trans-stenotic pressure gradient. Comparison with quantitative coronary angiography. European Heart Journal. 1995;16(10):1367-74. UI - 8746905. Reject Reason: No direct comparison between techniques. [pmid: 8746905].
Larsen AI, Basran R, Anderson T, Goodhart D, FICS study group. Large and small vessel vasoconstriction following coronary artery stenting. Effect of intra coronary nitroglycerine and relation to LDL cholesterol. International Journal of Cardiology. 10. 26. 2006;113(1):61-5. UI - 16337702. Reject Reason: No direct comparison between techniques. [pmid: 16337702].
Lasave LI, Costa Jde R Jr., Abizaid AA, Feres F, Tanajura LF, Staico R, Abizaid AA, Beraldo P, Sousa AM, Sousa JE. A three-dimensional intravascular ultrasound comparison between the new zotarolimus-eluting stent (ZoMaxx) and the non-drug-eluting TriMaxx stent. Journal of Invasive Cardiology. 1919;(7):303-308. UI - 17620675. Reject Reason: No direct comparison between techniques.
Laskey WK, Brady ST, Kussmaul WG, Waxler AR, Krol J, Herrmann HC, Hirshfeld JW Jr., Sehgal C. Intravascular ultrasonographic assessment of the results of coronary artery stenting. American Heart Journal. 1993;125(6):1576-83. UI - 8498296. Reject Reason: No outcome of interest. [pmid: 8498296].
Lavoie AJ, Bayturan O, Uno K, Hsu A, Wolski K, Schoenhagen P, Kapadia S, Tuzcu EM, Nissen SE, Nicholls SJ. Plaque progression in coronary arteries with minimal luminal obstruction in intravascular ultrasound atherosclerosis trials. American Journal of Cardiology. 6. 15. 2010;105(12):1679-83. UI - 20538114. Reject Reason: No direct comparison between techniques. [pmid: 20538114].
Lee CH, Zhang J, Kailasam A, Tai BC, Ye F, Low AF, Hou X, Hay ET, Teo SG, Lim YT, Chen S, Tan HC. An intravascular ultrasound study of Cypher, Taxus, and endeavor stents on relation between neointimal proliferation and residual plaque burden. Journal of Interventional Cardiology. 2008;21(6):519-27. UI - 18973509. Reject Reason: No direct comparison between techniques. [pmid: 18973509].
Lee DY, Eigler N, Luo H, Nishioka T, Tabak SW, Forrester JS, Siegel RJ. Effect of intracoronary ultrasound imaging on clinical decision making. American Heart Journal. 1995;129(6):1084-93. UI - 7754937. Reject Reason: No direct comparison between techniques. [pmid: 7754937].
Lee TM, Chu CC, Hsu YM, Chen MF, Liau CS, Lee YT. Exaggerated luminal loss a few minutes after successful percutaneous transluminal coronary angioplasty in patients with recent myocardial infarction compared with stable angina: an intracoronary ultrasound study. Catheterization & Cardiovascular Diagnosis. 1997;41(1):32-9. UI - 9143764. Reject Reason: No direct comparison between techniques. [pmid: 9143764].
Legalery P, Schiele F, Seronde MF, Meneveau N, Wei H, Didier K, Blonde MC, Caulfield F, Bassand JP. One-year outcome of patients submitted to routine fractional flow reserve assessment to determine the need for angioplasty. European Heart Journal. 2005;26(24):2623-9. UI - 16141256. Reject Reason: Intra-diagnostic comparison. [pmid: 16141256].
Legutko J, Dudek D, Dubiel JS. Intracoronary ultrasound assessment of balloon angioplasty with “stent-like' angiographic result. [Polish]. Przeglad Lekarski. 2001;58(7-8):755-8. UI - 11769381. Reject Reason: No direct comparison between techniques. [pmid: 11769381].
Legutko J, Dudek D, Rzeszutko L, Wizimirski M, Dubiel JS. Fractional flow reserve assessment to determine the indications for myocardial revascularisation in patients with borderline stenosis of the left main coronary artery. Kardiologia Polska. discussion 507-8. 2005;63(5):499-506. UI - 16362855. Reject Reason: Not relevant to KQs. [pmid: 16362855].
Lemos PA, Saia F, Ligthart JM, Arampatzis CA, Sianos G, Tanabe K, Hoye A, Degertekin M, Daemen J, McFadden E, Hofma S, Smits PC, de Feyter P, van der Giessen WJ, van Domburg RT, Serruys PW. Coronary restenosis after sirolimus-eluting stent implantation: morphological description and mechanistic analysis from a consecutive series of cases. Circulation. 7. 22. 2003;108(3):257-60. UI - 12860901. Reject Reason: Not relevant to KQs. [pmid: 12860901].
Lima-Filho MO, Figueiredo GL, Foss-Freitas MC, Foss MC, Marin-Neto JA. Predictors of restenosis after percutaneous coronary intervention using bare-metal stents: a comparison between patients with and without dysglycemia. Brazilian Journal of Medical & Biological Research. 2010;43(6):572-9. UI - 20521015. Reject Reason: No comparison of interest. [pmid: 20521015].
Lindstaedt M, Fritz MK, Yazar A, Perrey C, Germing A, Grewe PH, Laczkovics AM, Mugge A, Bojara W. Optimizing revascularization strategies in patients with multivessel coronary disease: impact of intracoronary pressure measurements. Journal of Thoracic & Cardiovascular Surgery. 2005;129(4):897-903. UI - 15821661. Reject Reason: No direct comparison between techniques. [pmid: 15821661].
Lindstaedt M, Yazar A, Germing A, Fritz MK, Holland-Letz T, Mugge A, Bojara W. Clinical outcome in patients with intermediate or equivocal left main coronary artery disease after deferral of surgical revascularization on the basis of fractional flow reserve measurements. American Heart Journal. 2006;152(1):156.e1-9. UI - 16824848. Reject Reason: No direct comparison between techniques. [pmid: 16824848].
Lindstaedt M, Halilcavusogullari Y, Yazar A, Holland-Letz T, Bojara W, Mugge A, Germing A. Clinical outcome following conservative vs revascularization therapy in patients with stable coronary artery disease and borderline fractional flow reserve measurements. Clinical Cardiology. 2010;33(2):77-83. UI - 20186987. Reject Reason: No comparison of interest. [pmid: 20186987].
Liu J, Maehara A, Mintz GS, Weissman NJ, Yu A, Wang H, Mandinov L, Popma JJ, Ellis SG, Grube E, Dawkins KD, Stone GW. An integrated TAXUS IV, V, and VI intravascular ultrasound analysis of the predictors of edge restenosis after bare metal or paclitaxel-eluting stents. American Journal of Cardiology. 2. 15. 2009;103(4):501-6. UI - 19195510. Reject Reason: No direct comparison between techniques. [pmid: 19195510].
Lopez-Palop R, Pinar E, Lozano I, Saura D, Pico F, Valdes M. Utility of the fractional flow reserve in the evaluation of angiographically moderate in-stent restenosis. European Heart Journal. 2004;25(22):2040-7. UI - 15541841. Reject Reason: Intra-diagnostic comparison. [pmid: 15541841].
Madaric J, Mistrik A, Riecansky I, Vulev I, Pacak J, Verhamme K, De Bruyne B, Fridrich V, Bartunek J. Left internal mammary artery bypass dysfunction after revascularization of moderately narrowed coronary lesions. Colour-duplex ultrasound versus angiography study. European Journal of Echocardiography. 2008;9(2):273-7. UI - 17588499. Reject Reason: Not relevant to KQs. [pmid: 17588499].
Maddux JT, Carroll JD, Groves BM, Messenger JC, Tseng A, Falcone E, Burchenal JE. Optimal deployment of third-generation stents: an intravascular ultrasound assessment. Catheterization & Cardiovascular Interventions. 2002;57(2):142-7. UI - 12357508. Reject Reason: No direct comparison between techniques. [pmid: 12357508].
Maehara A, Takagi A, Okura H, Hassan AH, Bonneau HN, Honda Y, Yock PG, Fitzgerald PJ. Longitudinal plaque redistribution during stent expansion. American Journal of Cardiology. 11. 15. 2000;86(10):1069-72. UI - 11074201. Reject Reason: No comparator of interest. [pmid: 11074201].
Maehara A, Mintz GS, Lansky AJ, Witzenbichler B, Guagliumi G, Brodie B, Kellett MA Jr., Parise H, Mehran R, Stone GW. Volumetric intravascular ultrasound analysis of Paclitaxel-eluting and bare metal stents in acute myocardial infarction: the harmonizing outcomes with revascularization and stents in acute myocardial infarction intravascular ultrasound substudy. Circulation. 11. 10. 2009;120(19):1875-82. UI - 19858413. Reject Reason: No direct comparison between techniques. [pmid: 19858413].
Mandinov L, Kaufmann P, Staub D, Buckingham TA, Amann FW, Hess OM. Coronary vasomotion after percutaneous transluminal coronary angioplasty depends on the severity of the culprit lesion. Journal of the American College of Cardiology. 1997;30(3):682-8. UI - 9283526. Reject Reason: No outcome of interest. [pmid: 9283526].
Markwirth T, Hennen B, Scheller B, Schafers HJ, Wendler O. Complete arterial revascularization using T-graft technique in diabetics with coronary three-vessel disease. Thoracic & Cardiovascular Surgeon. 2000;48(5):269-73. UI - 11100758. Reject Reason: Not relevant to KQs. [pmid: 11100758].
Matar FA, Mintz GS, Pinnow E, Javier SP, Popma JJ, Kent KM, Satler LF, Pichard AD, Leon MB. Multivariate predictors of intravascular ultrasound end points after directional coronary atherectomy. Journal of the American College of Cardiology. 1995;25(2):318-24. UI - 7829783. Reject Reason: No direct comparison between techniques. [pmid: 7829783].
Mates M, Hrabos V, Hajek P, Maly M, Horak D, Fiedler J, Durdil V, Vojacek J. Deferral of coronary intervention based on measurement of myocardial fractional flow reserve. [Czech]. Vnitrni Lekarstvi. 2004;50(8):600-5. UI - 15521203. Reject Reason: No comparator of interest. [pmid: 15521203].
Matsumoto D, Shite J, Shinke T, Otake H, Tanino Y, Ogasawara D, Sawada T, Paredes OL, Hirata K, Yokoyama M. Neointimal coverage of sirolimus-eluting stents at 6-month follow-up: evaluated by optical coherence tomography. European Heart Journal. 2007;28(8):961-7. UI - 17135281. Reject Reason: Not relevant to KQs. [pmid: 17135281].
Matthys K, Carlier S, Segers P, Ligthart J, Sianos G, Serrano P, Verdonck PR, Serruys PW. In vitro study of FFR, QCA, and IVUS for the assessment of optimal stent deployment. Catheterization & Cardiovascular Interventions. 2001;54(3):363-75. UI - 11747166. Reject Reason: Population not met. [pmid: 11747166].
Mazur W, Bitar JN, Lechin M, Grinstead WC, Khalil AA, Khan MM, Sekili S, Zoghbi WA, Raizner AE, Kleiman NS. Coronary flow reserve may predict myocardial recovery after myocardial infarction in patients with TIMI grade 3 flow. American Heart Journal. 1998;136(2):335-44. UI - 9704699. Reject Reason: No direct comparison between techniques. [pmid: 9704699].
Mehran R, Dangas G, Mintz GS, Waksman R, Abizaid A, Satler LF, Pichard AD, Kent KM, Lansky AJ, Stone GW, Leon MB. Treatment of in-stent restenosis with excimer laser coronary angioplasty versus rotational atherectomy: comparative mechanisms and results. Circulation. 5. 30. 2000;101(21):2484-9. UI - 10831522. Reject Reason: No direct comparison between techniques. [pmid: 10831522].
Meneveau N, Schiele F, Grollier G, Farah B, Lablanche JM, Khalife K, Machecourt J, Danchin N, Wolf JE, Simpson M, Hak JB, Bassand JP. Local delivery of nadroparin for the prevention of neointimal hyperplasia following stent implantation: results of the IMPRESS trial. A multicentre, randomized, clinical, angiographic and intravascular ultrasound study. European Heart Journal. 2000;21(21):1767-75. UI - 11052841. Reject Reason: No comparator of interest. [pmid: 11052841].
Meuwissen M, de Winter RJ, Chamuleau SA, Heijne M, Koch KT, van den Berg A, van Straalen JP, Bax M, Schorborgh CE, Kearney D, Sanders GT, Tijssen JG, Piek JJ. Value of C-reactive protein in patients with stable angina pectoris, coronary narrowing (30% to 70%), and normal fractional flow reserve. American Journal of Cardiology. 9. 15. 2003;92(6):702-5. UI - 12972111. Reject Reason: No direct comparison between techniques. [pmid: 12972111].
Meuwissen M, Chamuleau SA, Siebes M, de Winter RJ, Koch KT, Dijksman LM, van den Berg AJ, Tijssen JG, Spaan JA, Piek JJ. The prognostic value of combined intracoronary pressure and blood flow velocity measurements after deferral of percutaneous coronary intervention. Catheterization & Cardiovascular Interventions. 2. 15. 2008;71(3):291-7. UI - 18288725. Reject Reason: No direct comparison between techniques. [pmid: 18288725].
Min PK, Jung JH, Ko YG, Choi D, Jang Y, Shim WH. Effect of cilostazol on in-stent neointimal hyperplasia after coronary artery stenting: a quantative coronary angiography and volumetric intravascular ultrasound study. Circulation Journal. 2007;71(11):1685-90. UI - 17965485. Reject Reason: No direct comparison between techniques. [pmid: 17965485].
Mintz GS, Pichard AD, Kovach JA, Kent KM, Satler LF, Javier SP, Popma JJ, Leon MB. Impact of preintervention intravascular ultrasound imaging on transcatheter treatment strategies in coronary artery disease. American Journal of Cardiology. 3. 1. 1994;73(7):423-30. UI - 8141081. Reject Reason: No direct comparison between techniques. [pmid: 8141081].
Mintz GS, Hong MK, Raizner AE, Lee CW, Kim JJ, Escolar E, Fearnot NE, Park SW, Park SJ, Weissman NJ. Comparison of quantitative angiographic parameters with the magnitude of neointimal hyperplasia measured by volumetric intravascular ultrasound in patients treated with bare metal and nonpolymeric paclitaxel-coated stents. American Journal of Cardiology. 1. 1. 2005;95(1):105-7. UI - 15619403. Reject Reason: No outcome of interest. [pmid: 15619403].
Mishell JM, Vakharia KT, Ports TA, Yeghiazarians Y, Michaels AD. Determination of adequate coronary stent expansion using StentBoost, a novel fluoroscopic image processing technique. Catheterization & Cardiovascular Interventions. 2007;69(1):84-93. UI - 17139686. Reject Reason: Not relevant to KQs. [pmid: 17139686].
Montorsi P, Galli S, Fabbiocchi F, Loaldi A, Trabattoni D, Grancini L, Cozzi S, Ravagnani P, Parodi O, Bartorelli AL. Mechanism of cutting balloon angioplasty for in-stent restenosis: an intravascular ultrasound study. Catheterization & Cardiovascular Interventions. 2002;56(2):166-73. UI - 12112907. Reject Reason: No direct comparison between techniques. [pmid: 12112907].
Moore P, Barlis P, Spiro J, Ghimire G, Roughton M, Di Mario C, Wallis W, Ilsley C, Mitchell A, Mason M, Kharbanda R, Vincent P, Sherwin S, Dalby M. A randomized optical coherence tomography study of coronary stent strut coverage and luminal protrusion with rapamycin-eluting stents. Jacc: Cardiovascular Interventions. 2009;2(5):437-44. UI - 19463468. Reject Reason: Measurement timepoint not of interest. [pmid: 19463468].
Moussa I, Moses J, Di Mario C, Busi G, Reimers B, Kobayashi Y, Albiero R, Ferraro M, Colombo A. Stenting after optimal lesion debulking (sold) registry. Angiographic and clinical outcome. Circulation. 1998;98(16):1604-9. UI - 9778324. Reject Reason: No direct comparison between techniques. [pmid: 9778324].
Moussa I, Di Mario C, Moses J, Reimers B, Di Francesco L, Blengino S, Colombo A. Comparison of angiographic and clinical outcomes of coronary stenting of chronic total occlusions versus subtotal occlusions. American Journal of Cardiology. 1. 1. 1998;81(1):1-6. UI - 9462596. Reject Reason: No direct comparison between techniques. [pmid: 9462596].
Moussa I, Moses J, Di Mario C, Albiero R, De Gregorio J, Adamian M, Di Francesco L, Colombo A. Does the specific intravascular ultrasound criterion used to optimize stent expansion have an impact on the probability of stent restenosis?. American Journal of Cardiology. 4. 1. 1999;83(7):1012-7. UI - 10190511. Reject Reason: No comparison of interest. [pmid: 10190511].
Mudra H, Klauss V, Blasini R, Kroetz M, Rieber J, Regar E, Theisen K. Ultrasound guidance of Palmaz-Schatz intracoronary stenting with a combined intravascular ultrasound balloon catheter. Circulation. 1994;90(3):1252-61. UI - 8087934. Reject Reason: No outcome of interest. [pmid: 8087934].
Mudra H, Werner F, Regar E, Klauss V, Henneke KH, Rothman M, Di Mario C. One balloon approach for optimized Palmaz-Schatz stent implantation: the MUSCAT trial. Catheterization & Cardiovascular Diagnosis. 1997;42(2):130-6. UI - 9328693. Reject Reason: No direct comparison between techniques. [pmid: 9328693].
Mudra H, Regar E, Klauss V, Werner F, Henneke KH, Sbarouni E, Theisen K. Serial follow-up after optimized ultrasound-guided deployment of Palmaz-Schatz stents. In-stent neointimal proliferation without significant reference segment response. Circulation. 1. 21. 1997;95(2):363-70. UI - 9008450. Reject Reason: No direct comparison between techniques. [pmid: 9008450].
Muller C, Frey AW, Roskamm H, Hodgson JM. Single device approach to ultrasound-guided percutaneous transluminal coronary angioplasty and stenting: initial experience with a combined intracoronary ultrasound/variable diameter balloon. Catheterization & Cardiovascular Diagnosis. 1997;40(4):393-9. UI - 9096944. Reject Reason: No direct comparison between techniques. [pmid: 9096944].
Murata T, Hiro T, Fujii T, Yasumoto K, Murashige A, Kohno M, Yamada J, Miura T, Matsuzaki M. Impact of the cross-sectional geometry of the post-deployment coronary stent on in-stent neointimal hyperplasia: an intravascular ultrasound study. Circulation Journal. 2002;66(5):489-93. UI - 12030346. Reject Reason: No comparison of interest. [pmid: 12030346].
Musci M, Loebe M, Wellnhofer E, Meyer R, Pasic M, Hummel M, Bocksch W, Grauhan O, Weng Y, Hetzer R. Coronary angioplasty, bypass surgery, and retransplantation in cardiac transplant patients with graft coronary disease. Thoracic & Cardiovascular Surgeon. 1998;46(5):268-74. UI - 9885117. Reject Reason: Not relevant to KQs. [pmid: 9885117].
Nageh T, De Belder AJ, Thomas MR, Williams IL, Wainwright RJ. A randomised trial of endoluminal reconstruction comparing the NIR stent and the Wallstent in angioplasty of long segment coronary disease: results of the RENEWAL Study. American Heart Journal. 2001;141(6):971-6. UI - 11376312. Reject Reason: No direct comparison between techniques. [pmid: 11376312].
Nageh T, De Belder AJ, Thomas MR, Wainwright RJ. Intravascular ultrasound-guided stenting in long lesions: an insight into possible mechanisms of restenosis and comparison of angiographic and intravascular ultrasound data from the MUSIC and RENEWAL trials. Journal of Interventional Cardiology. 2001;14(4):397-405. UI - 12053493. Reject Reason: No direct comparison between techniques. [pmid: 12053493].
Nakamura M, Yock PG, Bonneau HN, Kitamura K, Aizawa T, Tamai H, Fitzgerald PJ, Honda Y. Impact of peri-stent remodeling on restenosis: a volumetric intravascular ultrasound study. Circulation. 5. 1. 2001;103(17):2130-2. UI - 11331251. Reject Reason: No direct comparison between techniques. [pmid: 11331251].
Nakamura M, Kataoka T, Honda Y, Bonneau HN, Hibi K, Kitamura K, Tamai H, Aizawa T, Yock PG, Fitzgerald PJ. Late incomplete stent apposition and focal vessel expansion after bare metal stenting. American Journal of Cardiology. 11. 15. 2003;92(10):1217-9. UI - 14609603. Reject Reason: No direct comparison between techniques. [pmid: 14609603].
Nakamura S, Colombo A, Gaglione A, Almagor Y, Goldberg SL, Maiello L, Finci L, Tobis JM. Intracoronary ultrasound observations during stent implantation. Circulation. 1994;89(5):2026-34. UI - 8181126. Reject Reason: No direct comparison between techniques. [pmid: 8181126].
Nakamura S, Mahon DJ, Leung CY, Maheswaran B, Gutfinger DE, Yang J, Zelman R, Tobis JM. Intracoronary ultrasound imaging before and after directional coronary atherectomy: in vitro and clinical observations. American Heart Journal. 1995;129(5):841-51. UI - 7732971. Reject Reason: No direct comparison between techniques. [pmid: 7732971].
Nakamura S, Di Francesco L, Finci L, Reimers B, Adamian M, Di Mario C, Colombo A. Focal wall overstretching after high-pressure coronary stent implantation does not influence restenosis. Catheterization & Cardiovascular Interventions. 1999;48(1):24-30. UI - 10467067. Reject Reason: No comparison of interest. [pmid: 10467067].
Nakatogawa T, Hibi K, Furukawa E, Sugano T, Kosuge M, Takamura T, Toda N, Tsukahara K, Okuda J, Kimura K, Umemura S. Impact of peri-stent remodeling on in-stent neointimal proliferation in acute myocardial infarction. American Journal of Cardiology. 9. 15. 2004;94(6):769-71. UI - 15374784. Reject Reason: No comparison of interest. [pmid: 15374784].
Nicholls SJ, Tuzcu EM, Crowe T, Sipahi I, Schoenhagen P, Kapadia S, Hazen SL, Wun CC, Norton M, Ntanios F, Nissen SE. Relationship between cardiovascular risk factors and atherosclerotic disease burden measured by intravascular ultrasound. Journal of the American College of Cardiology. 5. 16. 2006;47(10):1967-75. UI - 16697312. Reject Reason: No direct comparison between techniques. [pmid: 16697312].
Nishino M, Tanouchi J, Kawabata M, Tanaka K, Ito T, Kato J, Yamada Y, Kamada T. Evaluation of contrast agents for delineation of vessel wall boundary by intracoronary ultrasound after coronary angioplasty in human. Catheterization & Cardiovascular Interventions. 1999;47(1):6-13. UI - 10385151. Reject Reason: No direct comparison between techniques. [pmid: 10385151].
Nitenberg A, Durand E, Delatour B, Sdiri W, Raha S, Lafont A. Postocclusion hyperemia provides a better estimate of coronary reserve than intracoronary adenosine in patients with coronary artery stenosis. Journal of Invasive Cardiology. 1919;(9):390-394. UI - 17827509. Reject Reason: No direct comparison between techniques.
Ntalianis A, Sels JW, Davidavicius G, Tanaka N, Muller O, Trana C, Barbato E, Hamilos M, Mangiacapra F, Heyndrickx GR, Wijns W, Pijls NH, De Bruyne B. Fractional flow reserve for the assessment of nonculprit coronary artery stenoses in patients with acute myocardial infarction. Jacc: Cardiovascular Interventions. 2010;3(12):1274-81. UI - 21232721. Reject Reason: No direct comparison between techniques. [pmid: 21232721].
Nunez BD, Keelan ET, Higano ST, Lerman A, Garratt KN, Holmes DR Jr. Coronary hemodynamics before and after rotational atherectomy with adjunctive balloon angioplasty. Catheterization & Cardiovascular Diagnosis. Suppl 3. 1996:40-9. UI - 8874927. Reject Reason: No direct comparison between techniques. [pmid: 8874927].
Ochiai K, Shimada T, Murakami Y, Ishibashi Y, Sano K, Kitamura J, Inoue S, Murakami R, Kawamitsu H, Sugimura K. Hemorrhagic myocardial infarction after coronary reperfusion detected in vivo by magnetic resonance imaging in humans: prevalence and clinical implications. Journal of Cardiovascular Magnetic Resonance. 1999;1(3):247-56. UI - 11550358. Reject Reason: No direct comparison between techniques. [pmid: 11550358].
Ogawa S, Ohkubo T, Fukazawa R, Kamisago M, Kuramochi Y, Uchikoba Y, Ikegami E, Watanabe M, Katsube Y. Estimation of myocardial hemodynamics before and after intervention in children with Kawasaki disease. Journal of the American College of Cardiology. 2. 18. 2004;43(4):653-61. UI - 14975478. Reject Reason: No outcome of interest. [pmid: 14975478].
Ohashi T, Shibata R, Morimoto T, Kanashiro M, Ishii H, Ichimiya S, Hiro T, Miyauchi K, Nakagawa Y, Yamagishi M, Ozaki Y, Kimura T, Daida H, Murohara T, Matsuzaki M. Correlation between circulating adiponectin levels and coronary plaque regression during aggressive lipid-lowering therapy in patients with acute coronary syndrome: subgroup analysis of JAPAN-ACS study. Atherosclerosis. 2010;212(1):237-42. UI - 20684825. Reject Reason: No comparison of interest. [pmid: 20684825].
Ohsawa H, Noike H, Kanai M, Hitsumoto T, Aoyagi K, Sakurai T, Sugiyama Y, Yoshinaga K, Kaku M, Matsumoto J, Iizuka T, Shimizu K, Takahashi M, Tomaru T, Sakuragawa H, Tokuhiro K. Preventive effect of an antiallergic drug, pemirolast potassium, on restenosis after stent placement: quantitative coronary angiography and intravascular ultrasound studies. Journal of Cardiology. 2003;42(1):13-22. UI - 12892037. Reject Reason: No direct comparison between techniques. [pmid: 12892037].
Oikawa Y, Yajima J, Costa MA, Matsuno S, Akabane M, Funada R, Inaba T, Nakagawa Y, Nakamura M, Nagashima K, Kirigaya H, Ogasawara K, Sawada H, Aizawa T. Intravascular ultrasound, angioscopic and histopathological characterisation of heterogeneous patterns of restenosis after sirolimus-eluting stent implantation: insights into potential “thromborestenosis” phenomenon. Eurointervention. 2010;6(3):380-7. UI - 20884418. Reject Reason: No direct comparison between techniques. [pmid: 20884418].
Okabe T, Mintz GS, Lee SY, Lee B, Roy P, Steinberg DH, Pinto-Slottow T, Smith KA, Xue Z, Satler LF, Kent KM, Pichard AD, Lindsay J, Waksman R, Weissman NJ. Five-year outcomes of moderate or ambiguous left main coronary artery disease and the intravascular ultrasound predictors of events. Journal of Invasive Cardiology. 1920;(12):635-639. UI - 19057025. Reject Reason: No direct comparison between techniques.
Okabe T, Asakura Y, Ishikawa S, Asakura K, Mitamura H, Ogawa S. Evaluation of scaffolding effects of five different types of stents by intravascular ultrasound analysis. American Journal of Cardiology. 11. 1. 1999;84(9):981-6. UI - 10569650. Reject Reason: No comparator of interest. [pmid: 10569650].
Okabe T, Asakura Y, Ishikawa S, Asakura K, Mitamura H, Ogawa S. Determining appropriate small vessels for stenting by intravascular ultrasound. Journal of Invasive Cardiology. 2000;12(12):625-30. UI - 11103031. Reject Reason: Not relevant to KQs. [pmid: 11103031].
Okabe T, Asakura Y, Asakura K, Kawamura A, Ogawa S. Usefulness of residual percent plaque area after percutaneous coronary intervention in predicting peristent positive remodeling. American Journal of Cardiology. 12. 15. 2003;92(12):1399-403. UI - 14675573. Reject Reason: No direct comparison between techniques. [pmid: 14675573].
Opolski MP, Pracon R, Mintz GS, Okabe T, Pregowski J, Lee SY, van der Waal EC, Kalinczuk L, Roy P, Smith KA, Torguson R, Xue Z, Satler LF, Kent KM, Pichard AD, Waksman R, Weissman NJ. Relation of drug-eluting stent strut distribution to stent thrombosis in coronary arteries. American Journal of Cardiology. 8. 1. 2009;104(3):343-8. UI - 19616665. Reject Reason: No direct comparison between techniques. [pmid: 19616665].
Ormiston JA, Serruys PW, Regar E, Dudek D, Thuesen L, Webster MW, Onuma Y, Garcia-Garcia HM, McGreevy R, Veldhof S. A bioabsorbable everolimus-eluting coronary stent system for patients with single de-novo coronary artery lesions (ABSORB): a prospective open-label trial. Lancet. 3. 15. 2008;371(9616):899-907. UI - 18342684. Reject Reason: No direct comparison between techniques. [pmid: 18342684].
Osman A, Otero J, Brizolara A, Waxman S, Stouffer G, Fitzgerald P, Uretsky BF. Effect of rosiglitazone on restenosis after coronary stenting in patients with type 2 diabetes. American Heart Journal. 2004;147(5):e23. UI - 15131558. Reject Reason: No direct comparison between techniques. [pmid: 15131558].
Ozaki Y, Keane D, Nobuyoshi M, Hamasaki N, Popma JJ, Serruys PW. Coronary lumen at six-month follow-up of a new radiopaque Cordis tantalum stent using quantitative angiography and intracoronary ultrasound. American Journal of Cardiology. 12. 1. 1995;76(16):1135-43. UI - 7484898. Reject Reason: No outcome of interest. [pmid: 7484898].
Ozaki Y, Lemos PA, Yamaguchi T, Suzuki T, Nakamura M, Ismail TF, Kitayama M, Nishikawa H, Kato O, Serruys PW. A quantitative coronary angiography-matched comparison between a prospective randomised multicentre cutting balloon angioplasty and bare metal stent trial (REDUCE III) and the Rapamycin-Eluting Stent Evaluation At Rotterdam Cardiology Hospital (RESEARCH) study. Eurointervention. 2010;6(3):400-6. UI - 20884421. Reject Reason: No direct comparison between techniques. [pmid: 20884421].
Palmer ND, Lessells A, Northridge DB, Fox KA. Evaluation of vascular injury following percutaneous transluminal coronary angioplasty: a comparison of the accuracy of two- and three-dimensional intracoronary ultrasound imaging. Coronary Artery Disease. 2003;14(3):255-62. UI - 12702930. Reject Reason: No direct comparison between techniques. [pmid: 12702930].
Pan M, Suarez de Lezo J, Medina A, Romero M, Segura J, Pavlovic D, Hernandez E, Munoz J, Rodriguez M, Rus C, Delgado M, Ojeda S. Late recovery of coronary flow reserve in patients successfully treated with a percutaneous procedure. [Spanish]. Revista Espanola de Cardiologia. 2003;56(5):459-64. UI - 12737783. Reject Reason: No comparison of interest. [pmid: 12737783].
Park DW, Hong MK, Mintz GS, Lee CW, Song JM, Han KH, Kang DH, Cheong SS, Song JK, Kim JJ, Weissman NJ, Park SW, Park SJ. Two-year follow-up of the quantitative angiographic and volumetric intravascular ultrasound analysis after nonpolymeric paclitaxel-eluting stent implantation: late “catch-up” phenomenon from ASPECT Study. Journal of the American College of Cardiology. 2006;48(12):2432-9. UI - 17174179. Reject Reason: No comparison of interest. [pmid: 17174179].
Park SJ, Park SW, Hong MK, Cheong SS, Lee CW, Kim JJ, Mintz GS, Leon MB. Late clinical outcomes of cordis tantalum coronary stenting without anticoagulation. American Journal of Cardiology. 10. 1. 1997;80(7):943-7. UI - 9382014. Reject Reason: No direct comparison between techniques. [pmid: 9382014].
Park SM, Kim JS, Ko YG, Choi D, Hong MK, Jang Y, Kang WC, Ahn T, Kim BK, Oh SJ, Jeon DW, Yang JY. Angiographic and intravascular ultrasound follow up of paclitaxel- and sirolimus-eluting stent after poststent high-pressure balloon dilation: from the poststent optimal stent expansion trial. Catheterization & Cardiovascular Interventions. 1. 1. 2011;77(1):15-21. UI - 20928842. Reject Reason: No direct comparison between techniques. [pmid: 20928842].
Perera D, Postema P, Rashid R, Patel S, Blows L, Marber M, Redwood S. Does a well developed collateral circulation predispose to restenosis after percutaneous coronary intervention? An intravascular ultrasound study. Heart. 2006;92(6):763-7. UI - 16216859. [pmid: 16216859].
Pesenti-Rossi D, Chouli M, Gharbi M, Ghostine S, Habib Y, Brenot P, Angel CY, Paul JF, Capderou A, Lancelin B, Caussin C. Coronary aorto-ostial stenosis analysed by multislice computed tomography: a new tool for percutaneous coronary intervention?. Eurointervention. 2011;6(6):717-21. UI - 21205594. Reject Reason: Population not met. [pmid: 21205594].
Peters RJ, Kok WE, Di Mario C, Serruys PW, Bar FW, Pasterkamp G, Borst C, Kamp O, Bronzwaer JG, Visser CA, Piek JJ, Panday RN, Jaarsma W, Savalle L, Bom N. Prediction of restenosis after coronary balloon angioplasty. Results of PICTURE (Post-IntraCoronary Treatment Ultrasound Result Evaluation), a prospective multicenter intracoronary ultrasound imaging study. Circulation. 5. 6. 1997;95(9):2254-61. UI - 9142002. Reject Reason: Not relevant to KQs. [pmid: 9142002].
Peters RJ, Kok WE, Pasterkamp G, von Birgelen C, Prins M, Serruys PW. Videodensitometric quantitative angiography after coronary balloon angioplasty, compared to edge-detection quantitative angiography and intracoronary ultrasound imaging. European Heart Journal. 2000;21(8):654-61. UI - 10731403. Reject Reason: No outcome of interest. [pmid: 10731403].
Philipp S, Bose D, Wijns W, Marso SP, Schwartz RS, Konig A, Lerman A, Garcia-Garcia HM, Serruys PW, Erbel R. Do systemic risk factors impact invasive findings from virtual histology? Insights from the international virtual histology registry. European Heart Journal. 2010;31(2):196-202. UI - 19854730. Reject Reason: No direct comparison between techniques. [pmid: 19854730].
Piek JJ, Boersma E, Di Mario C, Schroeder E, Vrints C, Probst P, De Bruyne B, Hanet C, Fleck E, Haude M, Verna E, Voudris V, Geschwind H, Emanuelsson H, Muhlberger V, Peels HO, Serruys PW. Angiographical and Doppler flow-derived parameters for assessment of coronary lesion severity and its relation to the result of exercise electrocardiography. DEBATE study group. Doppler Endpoints Balloon Angioplasty Trial Europe. European Heart Journal. 2000;21(6):466-74. UI - 10681487. Reject Reason: No direct comparison between techniques. [pmid: 10681487].
Pijls NH, Van Gelder B, Van der V, Peels K, Bracke FA, Bonnier HJ, el Gamal MI. Fractional flow reserve. A useful index to evaluate the influence of an epicardial coronary stenosis on myocardial blood flow. Circulation. 12. 1. 1995;92(11):3183-93. UI - 7586302. Reject Reason: Not relevant to KQs. [pmid: 7586302].
Pijls NH, Klauss V, Siebert U, Powers E, Takazawa K, Fearon WF, Escaned J, Tsurumi Y, Akasaka T, Samady H, De Bruyne B, Fractional Flow Reserve (FFR) Post-Stent Registry Investigators. Coronary pressure measurement after stenting predicts adverse events at follow-up: a multicenter registry. Circulation. 6. 25. 2002;105(25):2950-4. UI - 12081986. Reject Reason: No direct comparison between techniques. [pmid: 12081986].
Pijls NH, van Schaardenburgh P, Manoharan G, Boersma E, Bech JW, Van't Veer M, Bar F, Hoorntje J, Koolen J, Wijns W, De Bruyne B. Percutaneous coronary intervention of functionally nonsignificant stenosis: 5-year follow-up of the DEFER Study. Journal of the American College of Cardiology. 5. 29. 2007;49(21):2105-11. UI - 17531660. Reject Reason: Not relevant to KQs. [pmid: 17531660].
Pinto IM, Sousa AG, Ishikama W, Mattos LA, Abizaid A, Feres F, Tanajura LF, Sousa LC, Sousa JE, Jatene A. Late outcome of sirolimus-eluting stents: comparison of multidetector computed tomography with quantitative coronary angiography and intravascular ultrasound. Arquivos Brasileiros de Cardiologia. 2006;87(5):575-82. UI - 17221032. Reject Reason: No comparison of interest. [pmid: 17221032].
Pirolo JS, Fredi JL, Shuman TA. Intracoronary ultrasound-guided CABG in patients with angiographically noncritical lesions. Cardiovascular Surgery Associates. Annals of Thoracic Surgery. 1997;64(2):375-9. UI - 9262578. Reject Reason: No direct comparison between techniques. [pmid: 9262578].
Pizzuto F, Voci P, Mariano E, Puddu PE, Chiavari PA, Romeo F. Noninvasive coronary flow reserve assessed by transthoracic coronary Doppler ultrasound in patients with left anterior descending coronary artery stents. American Journal of Cardiology. 3. 1. 2003;91(5):522-6. UI - 12615253. Reject Reason: No IVDx technique used. [pmid: 12615253].
Pohl T, Seiler C, Billinger M, Herren E, Wustmann K, Mehta H, Windecker S, Eberli FR, Meier B. Frequency distribution of collateral flow and factors influencing collateral channel development. Functional collateral channel measurement in 450 patients with coronary artery disease. Journal of the American College of Cardiology. 2001;38(7):1872-8. UI - 11738287. Reject Reason: No comparator of interest. [pmid: 11738287].
Pomerantsev EV, Kobayashi Y, Fitzgerald PJ, Grube E, Sanders WJ, Alderman EL, Oesterle SN, Yock PG, Stertzer SH. Coronary stents: In vitro aspects of an angiographic and ultrasound quantification with in vivo correlation. Circulation. 10. 13. 1998;98(15):1495-503. UI - 9769302. Reject Reason: No comparator of interest. [pmid: 9769302].
Popma JJ, Mintz GS, Satler LF, Pichard AD, Kent KM, Chuang YC, Matar F, Bucher TA, Merritt AJ, Leon MB. Clinical and angiographic outcome after directional coronary atherectomy. A qualitative and quantitative analysis using coronary arteriography and intravascular ultrasound. American Journal of Cardiology. 10. 18. 1993;72(13):55E-64E. UI - 8213571. Reject Reason: No direct comparison between techniques.
Potvin JM, Rodes-Cabau J, Bertrand OF, Gleeton O, Nguyen CN, Barbeau G, Proulx G, De Larochelliere R, Dery JP, Batalla N, Dana A, Facta A, Roy L. Usefulness of fractional flow reserve measurements to defer revascularization in patients with stable or unstable angina pectoris, non-ST-elevation and ST-elevation acute myocardial infarction, or atypical chest pain. American Journal of Cardiology. 8. 1. 2006;98(3):289-97. UI - 16860011. Reject Reason: No direct comparison between techniques. [pmid: 16860011].
Prasad A, Cipher DJ, Prasad A, Mohandas A, Roesle M, Brilakis ES, Banerjee S. Reproducibility of intravascular ultrasound virtual histology analysis. Cardiovascular Revascularization Medicine. Jun. 2008;9(2):71-7. UI - 18486080. Reject Reason: No direct comparison between techniques. [pmid: 18486080].
Prati F, Di Mario C, Gil R, von Birgelen C, Camenzind E, Montauban van Swijndregt WJ, de Feyter PJ, Serruys PW, Roelandt JR. Usefulness of on-line three-dimensional reconstruction of intracoronary ultrasound for guidance of stent deployment. American Journal of Cardiology. 3. 1. 1996;77(7):455-61. UI - 8629584. Reject Reason: No direct comparison between techniques. [pmid: 8629584].
Prati F, Morocutti G, Bernardi G, Sommariva L, Tomai F, Pagano A, Parma A, Boccanelli A, Fioretti P. The extent of late in-stent neointima formation is modified by treatment with pravastatin: a preliminary study with intravascular ultrasound. Italian Heart Journal: Official Journal of the Italian Federation of Cardiology. 2002;3(8):455-61. UI - 12407821. Reject Reason: No direct comparison between techniques. [pmid: 12407821].
Prati F, Pawlowski T, Gil R, Labellarte A, Gziut A, Caradonna E, Manzoli A, Pappalardo A, Burzotta F, Boccanelli A. Stenting of culprit lesions in unstable angina leads to a marked reduction in plaque burden: a major role of plaque embolization? A serial intravascular ultrasound study. Circulation. 5. 13. 2003;107(18):2320-5. UI - 12707236. Reject Reason: No comparison of interest. [pmid: 12707236].
Pregowski J, Tyczynski P, Mintz GS, Kim SW, Witkowski A, Waksman R, Pichard A, Satler L, Kent K, Kruk M, Bieganski S, Ohlmann P, Weissman NJ. Incidence and clinical correlates of ruptured plaques in saphenous vein grafts: an intravascular ultrasound study. Journal of the American College of Cardiology. 6. 21. 2005;45(12):1974-9. UI - 15963395. Reject Reason: No direct comparison between techniques. [pmid: 15963395].
Puymirat E, Peace A, Mangiacapra F, et al. Long-term clinical outcome after fractional flow reserve-guided percutaneous coronary revascularization in patients with small-vessel disease. Circ Cardiovasc Interv. 2012;5:62-68. Feb. UI – 22319067. Reject reason: No distinct FFR-guided stenting group. [pmid: 22319067].
Radu M, Jorgensen E, Kelbaek H, Helqvist S, Skovgaard L, Saunamaki K. Strut apposition after coronary stent implantation visualised with optical coherence tomography. Eurointervention. 2010;6(1):86-93. UI - 20542802. Reject Reason: No direct comparison between techniques. [pmid: 20542802].
Rathore S, Terashima M, Katoh O, Matsuo H, Tanaka N, Kinoshita Y, Kimura M, Tuschikane E, Nasu K, Ehara M, Asakura K, Asakura Y, Suzuki T. Predictors of angiographic restenosis after drug eluting stents in the coronary arteries: contemporary practice in real world patients. Eurointervention. 2009;5(3):349-54. UI - 19736160. Reject Reason: No direct comparison between techniques. [pmid: 19736160].
Reczuch K, Jankowska E, Telichowski A, Porada A, Banasiak W, Ponikowski P. Measurement of fractional flow reserve in patients with multi-vessel coronary artery disease and borderline lesions prevents unnecessary revascularisation procedures. Kardiologia Polska. discussion 320-1. 2004;60(4):311-19. UI - 15226780. Reject Reason: Not relevant to KQs. [pmid: 15226780].
Reczuch K, Jankowska E, Porada A, Telichowski A, Derkacz A, Banasiak W, Ponikowski P. Long-term outcome of conservatively treated patients with borderline coronary lesions--role of the fractional flow reserve measurement. Kardiologia Polska. discussion 12-3. 2005;62(1):6-11. UI - 15815774. Reject Reason: Not relevant to KQs. [pmid: 15815774].
Regenfus M, Alstidl R, Lehmkuhl H, Dill H, Bachmann K. Poststenotic coronary blood flow following percutaneous transluminal coronary angioplasty. Physiological Measurement. 1919;(3):345-351. UI - 9735885. Reject Reason: No direct comparison between techniques.
Rensing BJ, Vos J, Smits PC, Foley DP, van den Brand MJ, van der Giessen WJ, de Feijter PJ, Serruys PW. Coronary restenosis elimination with a sirolimus eluting stent: first European human experience with 6-month angiographic and intravascular ultrasonic follow-up. European Heart Journal. 2001;22(22):2125-30. UI - 11686669. Reject Reason: No direct comparison between techniques. [pmid: 11686669].
Ricciardi MJ, Meyers S, Choi K, Pang JL, Goodreau L, Davidson CJ. Angiographically silent left main disease detected by intravascular ultrasound: a marker for future adverse cardiac events. American Heart Journal. 2003;146(3):507-12. UI - 12947371. Reject Reason: No comparison of interest. [pmid: 12947371].
Rieber J, Schiele TM, Koenig A, Erhard I, Segmiller T, Stempfle HU, Theisen K, Jung P, Siebert U, Klauss V. Long-term safety of therapy stratification in patients with intermediate coronary lesions based on intracoronary pressure measurements. American Journal of Cardiology. 11. 15. 2002;90(10):1160-4. UI - 12423726. Reject Reason: Intra-diagnostic comparison. [pmid: 12423726].
Rieber J, Gockel K, Koschyk D, Erhard I, Koenig A, Schiele TM, Theisen K, Siebert U, Klauss V. Application, feasibility, and efficacy of a combined intravascular ultrasound and stent delivery system: results from a prospective multicenter trial. Journal of Interventional Cardiology. 2005;18(5):367-74. UI - 16202113. Reject Reason: No comparison of interest. [pmid: 16202113].
Rieber J, Jung P, Koenig A, Schiele T, Shapiro M, Hoffmann U, Klauss V. Five-year follow-up in patients after therapy stratification based on intracoronary pressure measurement. American Heart Journal. 2007;153(3):403-9. UI - 17307420. Reject Reason: Not relevant to KQs. [pmid: 17307420].
Rother T, Neugebauer A, Mende M, Kolb HJ, Hagendorff A, Pfeiffer D. Fractional flow reserve as a deciding criterion for intervention in patients with 50% coronary stenoses and impaired myocardial perfusion. [German]. Zeitschrift fur Kardiologie. 2000;89(4):307-15. UI - 10868005. Reject Reason: Not relevant to KQs. [pmid: 10868005].
Roy P, Torguson R, Okabe T, Pinto Slottow TL, Steinberg DH, Smith K, Xue Z, Satler LF, Pichard AD, Waksman R. Angiographic and procedural correlates of stent thrombosis after intracoronary implantation of drug-eluting stents. Journal of Interventional Cardiology. 1920;(5):M307-313. UI - 17880326. Reject Reason: No direct comparison between techniques.
Sahara M, Kirigaya H, Oikawa Y, Yajima J, Ogasawara K, Satoh H, Nagashima K, Hara H, Nakatsu Y, Aizawa T. Arterial remodeling patterns before intervention predict diffuse in-stent restenosis: an intravascular ultrasound study. Journal of the American College of Cardiology. 2003;42(10):1731-8. UI - 14642680. Reject Reason: No direct comparison between techniques. [pmid: 14642680].
Sahara M, Kirigaya H, Oikawa Y, Yajima J, Nagashima K, Hara H, Ogasawara K, Aizawa T. Soft plaque detected on intravascular ultrasound is the strongest predictor of in-stent restenosis: an intravascular ultrasound study. European Heart Journal. 2004;25(22):2026-33. UI - 15541839. Reject Reason: No direct comparison between techniques. [pmid: 15541839].
Sakurai R, Ako J, Morino Y, Sonoda S, Kaneda H, Terashima M, Hassan AH, Leon MB, Moses JW, Popma JJ, Bonneau HN, Yock PG, Fitzgerald PJ, Honda Y, SIRIUS, Trial, I. Predictors of edge stenosis following sirolimus-eluting stent deployment (a quantitative intravascular ultrasound analysis from the SIRIUS trial). American Journal of Cardiology. 11. 1. 2005;96(9):1251-3. UI - 16253592. Reject Reason: No direct comparison between techniques. [pmid: 16253592].
Samady H, McDaniel M, Veledar E, De Bruyne B, Pijls NH, Fearon WF, Vaccarino V. Baseline fractional flow reserve and stent diameter predict optimal post-stent fractional flow reserve and major adverse cardiac events after bare-metal stent deployment. Jacc: Cardiovascular Interventions. 2009;2(4):357-63. UI - 19463450. Reject Reason: Intra-diagnostic comparison. [pmid: 19463450].
Sanchez-Recalde A, Gonzalez-Obeso E, Martin Reyes R, Jimenez-Valero S, Galeote G, Calvo L, Moreno R, Lopez Sendon JL. Intravascular ultrasound and histology findings in very late bare-metal stent thrombosis. Revista Espanola de Cardiologia. 2010;63(12):1492-6. UI - 21144414. Reject Reason: No direct comparison between techniques. [pmid: 21144414].
Sant'Anna FM, Silva EE, Batista LA, Ventura FM, Barrozo CA, Pijls NH. Influence of routine assessment of fractional flow reserve on decision making during coronary interventions. American Journal of Cardiology. 2. 15. 2007;99(4):504-8. UI - 17293194. Reject Reason: No comparison of interest. [pmid: 17293194].
Sant'Anna FM, da Silva ER, Batista LA, Brito MB, Ventura FM, Ferraz HA, Buczynski L, Barrozo CA, Pijls N. What is the angiography error when defining myocardial ischemia during percutaneous coronary interventions?. Arquivos Brasileiros de Cardiologia. 179. 84. 2008;91(3):162-7. UI - 18853058. Reject Reason: No outcome of interest. [pmid: 18853058].
Sapra R, Kaul U, Singh B, Sudan D, Isser HS, Ghose T, Kachru R. Coronary stent implantation without lesion predilatation (direct stenting): our experience with this evolving technique. Indian Heart Journal. Jun. 2001;53(3):308-13. UI - 11516029. Reject Reason: No direct comparison between techniques. [pmid: 11516029].
Sarno G, Onuma Y, Garcia Garcia HM, Garg S, Regar E, Thuesen L, Dudek D, Veldhof S, Dorange C, Ormiston JA, Serruys PW. IVUS radiofrequency analysis in the evaluation of the polymeric struts of the bioabsorbable everolimus-eluting device during the bioabsorption process. Catheterization & Cardiovascular Interventions. 5. 1. 2010;75(6):914-8. UI - 20091822. Reject Reason: No direct comparison between techniques. [pmid: 20091822].
Schiele F, Meneveau N, Vuillemenot A, Gupta S, Bassand JP. Treatment of in-stent restenosis with high speed rotational atherectomy and IVUS guidance in small <3.0 mm vessels. Catheterization & Cardiovascular Diagnosis. 1998;44(1):77-82. UI - 9600530. Reject Reason: No direct comparison between techniques. [pmid: 9600530].
Schiele F, Meneveau N, Seronde MF, Deforet MF, Gupta S, Bassand JP. Predictors of event-free survival after repeat intracoronary procedure for in-stent restenosis; study with angiographic and intravascular ultrasound imaging. European Heart Journal. 2000;21(9):754-62. UI - 10739731. Reject Reason: No direct comparison between techniques. [pmid: 10739731].
Schroeder S, Baumbach A, Mahrholdt H, Haase KK, Oberhoff M, Herdeg C, Athanasiadis A, Karsch KR. The impact of untreated coronary dissections on acute and long-term outcome after intravascular ultrasound guided PTCA. European Heart Journal. 2000;21(2):137-45. UI - 10637087. Reject Reason: No direct comparison between techniques. [pmid: 10637087].
Schroeder S, Kopp AF, Baumbach A, Kuettner A, Herdeg C, Rosenberger A, Selbmann HK, Claussen CD, Oberhoff M, Karsch KR. Noninvasive detection of coronary lesions by multislice computed tomography: results of the New Age pilot trial. Catheterization & Cardiovascular Interventions. 2001;53(3):352-8. UI - 11458413. Reject Reason: No comparison of interest. [pmid: 11458413].
Schuijf JD, Bax JJ, Salm LP, Jukema JW, Lamb HJ, van der Wall EE, de Roos A. Noninvasive coronary imaging and assessment of left ventricular function using 16-slice computed tomography. American Journal of Cardiology. 3. 1. 2005;95(5):571-4. UI - 15721093. Reject Reason: No IVDx technique used. [pmid: 15721093].
Schukro C, Syeda B, Yahya N, Gessl A, Holy EW, Pichler P, Derntl M, Glogar D. Volumetric intravascular ultrasound imaging to illustrate the extent of coronary plaque burden in type 2 diabetic patients. Journal of Diabetes & its Complications. Dec. 2007;21(6):381-6. UI - 17967711. Reject Reason: No outcome of interest. [pmid: 17967711].
Schwarzacher SP, Metz JA, Yock PG, Fitzgerald PJ. Vessel tearing at the edge of intracoronary stents detected with intravascular ultrasound imaging. Catheterization & Cardiovascular Diagnosis. 1997;40(2):152-5. UI - 9047054. Reject Reason: No direct comparison between techniques. [pmid: 9047054].
Segal J, Kern MJ, Scott NA, King SB III, Doucette JW, Heuser RR, Ofili E, Siegel R. Alterations of phasic coronary artery flow velocity in humans during percutaneous coronary angioplasty. Journal of the American College of Cardiology. 1920;(2):276-286. UI - 1386088. Reject Reason: Not relevant to KQs.
Semeraro O, Agostoni P, Verheye S, Van Langenhove G, Van den Heuvel P, Convens C, Van den Branden F, Bruining N, Vermeersch P, Reduction of Restenosis in Saphenous Vein Grafts with Cypher Stent Trial Investigators. Re-examining minimal luminal diameter relocation and quantitative coronary angiography--intravascular ultrasound correlations in stented saphenous vein grafts: methodological insights from the randomised RRISC trial. Eurointervention. 2009;4(5):633-40. UI - 19378685. Reject Reason: Measurement timepoint not of interest. [pmid: 19378685].
Sera F, Awata M, Uematsu M, Kotani J, Nanto S, Nagata S. Optimal stent-sizing with intravascular ultrasound contributes to complete neointimal coverage after sirolimus-eluting stent implantation assessed by angioscopy. Jacc: Cardiovascular Interventions. 2009;2(10):989-94. UI - 19850260. Reject Reason: No direct comparison between techniques. [pmid: 19850260].
Serruys PW, Foley DP, Pieper M, Kleijne JA, de Feyter PJ, TRAPIST, investigators. The TRAPIST Study. A multicentre randomized placebo controlled clinical trial of trapidil for prevention of restenosis after coronary stenting, measured by 3-D intravascular ultrasound. [Erratum appears in Eur Heart J 2002 Jul;23(13):1066]. European Heart Journal. 2001;22(20):1938-47. UI - 11601838. Reject Reason: No direct comparison between techniques. [pmid: 11601838].
Serruys PW, Hoye A, Grollier G, Colombo A, Symons J, Mudra H. A European multi-center trial investigating the anti-restenotic effect of intravascular sonotherapy after stenting of de novo lesions (EUROSPAH: EUROpean Sonotherapy Prevention of Arterial Hyperplasia). International Journal of Cardiovascular Interventions. 2004;6(2):53-60. UI - 15385204. Reject Reason: No direct comparison between techniques. [pmid: 15385204].
Serruys PW, Ormiston JA, Sianos G, Sousa JE, Grube E, den Heijer P, de Feyter P, Buszman P, Schomig A, Marco J, Polonski L, Thuesen L, Zeiher AM, Bett JH, Suttorp MJ, Glogar HD, Pitney M, Wilkins GT, Whitbourn R, Veldhof S, Miquel K, Johnson R, Coleman L, Virmani R, ACTION, investigators. Actinomycin-eluting stent for coronary revascularization: a randomized feasibility and safety study: the ACTION trial. Journal of the American College of Cardiology. 10. 6. 2004;44(7):1363-7. UI - 15464314. Reject Reason: No direct comparison between techniques. [pmid: 15464314].
Serruys PW, Wijns W, Sianos G, de Scheerder I, van den Heuvel PA, Rutsch W, Glogar HD, Macaya C, Materne PH, Veldhof S, Vonhausen H, Otto-Terlouw PC, van der Giessen WJ. Direct stenting versus direct stenting followed by centered beta-radiation with intravascular ultrasound-guided dosimetry and long-term anti-platelet treatment: results of a randomized trial: Beta-Radiation Investigation with Direct Stenting and Galileo in Europe (BRIDGE). Journal of the American College of Cardiology. 8. 4. 2004;44(3):528-37. UI - 15358015. Reject Reason: No direct comparison between techniques. [pmid: 15358015].
Serruys PW, Onuma Y, Ormiston JA, De Bruyne B, Regar E, Dudek D, Thuesen L, Smits PC, Chevalier B, McClean D, Koolen J, Windecker S, Whitbourn R, Meredith I, Dorange C, Veldhof S, Miquel-Hebert K, Rapoza R, Garcia-Garcia HM. Evaluation of the second generation of a bioresorbable everolimus drug-eluting vascular scaffold for treatment of de novo coronary artery stenosis: six-month clinical and imaging outcomes. Circulation. 11. 30. 2010;122(22):2301-12. UI - 21098436. Reject Reason: No direct comparison between techniques. [pmid: 21098436].
Seung KB, Kim YH, Park DW, Lee BK, Lee CW, Hong MK, Kim PJ, Chung WS, Tahk SJ, Park SW, Park SJ. Effectiveness of sirolimus-eluting stent implantation for the treatment of ostial left anterior descending artery stenosis with intravascular ultrasound guidance. Journal of the American College of Cardiology. 9. 6. 2005;46(5):787-92. UI - 16139126. Reject Reason: No direct comparison between techniques. [pmid: 16139126].
Sezer M, Nisanci Y, Umman B, Yilmaz E, Mercanoglu F, Umman S, Oflaz H, Ozsaruhan O. Can thrombolytic therapy provide beneficial effects additional to epicardial coronary artery recanalization? A study based on coronary pressure measurement. Coronary Artery Disease. 2002;13(2):125-30. UI - 12004265. Reject Reason: No direct comparison between techniques. [pmid: 12004265].
Sezer M, Cimen A, Aslanger E, Elitok A, Umman B, Bugra Z, Yormaz E, Turkmen C, Adalet IS, Nisanci Y, Umman S. Effect of intracoronary streptokinase administered immediately after primary percutaneous coronary intervention on long-term left ventricular infarct size, volumes, and function. Journal of the American College of Cardiology. 9. 15. 2009;54(12):1065-71. UI - 19744615. Reject Reason: No IVDx technique used. [pmid: 19744615].
Sharma SK, Kini A, Mehran R, Lansky A, Kobayashi Y, Marmur JD. Randomized trial of Rotational Atherectomy Versus Balloon Angioplasty for Diffuse In-stent Restenosis (ROSTER). American Heart Journal. 2004;147(1):16-22. UI - 14691413. Reject Reason: No direct comparison between techniques. [pmid: 14691413].
Sheris SJ, Canos MR, Weissman NJ. Natural history of intravascular ultrasound-detected edge dissections from coronary stent deployment. American Heart Journal. 2000;139(1 Pt 1):59-63. UI - 10618563. Reject Reason: No direct comparison between techniques. [pmid: 10618563].
Shiran A, Mintz GS, Waksman R, Mehran R, Abizaid A, Kent KM, Pichard AD, Satler LF, Popma JJ, Leon MB. Early lumen loss after treatment of in-stent restenosis: an intravascular ultrasound study. Circulation. 7. 21. 1998;98(3):200-3. UI - 9697818. Reject Reason: No direct comparison between techniques. [pmid: 9697818].
Sigwart U, Grbic M, Goy JJ, Kappenberger L. Left atrial function in acute transient left ventricular ischemia produced during percutaneous transluminal coronary angioplasty of the left anterior descending coronary artery. American Journal of Cardiology. 2. 1. 1990;65(5):282-6. UI - 2301255. Reject Reason: No IVDx technique used. [pmid: 2301255].
Sousa JE, Costa MA, Abizaid A, Abizaid AS, Feres F, Pinto IM, Seixas AC, Staico R, Mattos LA, Sousa AG, Falotico R, Jaeger J, Popma JJ, Serruys PW. Lack of neointimal proliferation after implantation of sirolimus-coated stents in human coronary arteries: a quantitative coronary angiography and three-dimensional intravascular ultrasound study. Circulation. 1. 16. 2001;103(2):192-5. UI - 11208675. Reject Reason: No direct comparison between techniques. [pmid: 11208675].
Sousa JE, Sousa AG, Costa MA, Abizaid AC, Feres F. Use of rapamycin-impregnated stents in coronary arteries. Transplantation Proceedings. 2003;35(3 Suppl):165S-170S. UI - 12742491. Reject Reason: No direct comparison between techniques. [pmid: 12742491].
Sousa JE, Costa MA, Abizaid A, Sousa AG, Feres F, Mattos LA, Centemero M, Maldonado G, Abizaid AS, Pinto I, Falotico R, Jaeger J, Popma JJ, Serruys PW. Sirolimus-eluting stent for the treatment of in-stent restenosis: a quantitative coronary angiography and three-dimensional intravascular ultrasound study. Circulation. 1. 7. 2003;107(1):24-7. UI - 12515737. Reject Reason: No direct comparison between techniques. [pmid: 12515737].
Stempfle HU, Konig A, Drescher E, Siebert U, Klauss V. Discrepancy between morphologic and functional criteria of optimal stent deployment using intravascular ultrasound and pressure derived myocardial fractional flow reserve. International Journal of Cardiovascular Interventions. 2005;7(2):101-7. UI - 16093220. Reject Reason: No direct comparison between techniques. [pmid: 16093220].
Stone GW, Hodgson JM, St Goar FG, Frey A, Mudra H, Sheehan H, Linnemeier TJ. Improved procedural results of coronary angioplasty with intravascular ultrasound-guided balloon sizing: the CLOUT Pilot Trial. Clinical Outcomes With Ultrasound Trial (CLOUT) Investigators. Circulation. 4. 15. 1997;95(8):2044-52. UI - 9133514. Reject Reason: No direct comparison between techniques. [pmid: 9133514].
Stone GW, St Goar FG, Hodgson JM, Fitzgerald PJ, Alderman EL, Yock PG, Coverdale J, Sheehan H, Linnemeier TJ. Analysis of the relation between stent implantation pressure and expansion. Optimal Stent Implantation (OSTI) Investigators. American Journal of Cardiology. A8. 5. 1. 1999;83(9):1397-400. UI - 10235100. Reject Reason: No direct comparison between techniques. [pmid: 10235100].
Suemaru S, Iwasaki K, Yamamoto K, Kusachi S, Hina K, Hirohata S, Hirota M, Murakami M, Kamikawa S, Murakami T, Shiratori Y. Coronary pressure measurement to determine treatment strategy for equivocal left main coronary artery lesions. Heart & Vessels. 1920;(6):271-277. UI - 16314909. Reject Reason: No direct comparison between techniques.
Sunamura M, Di Mario C, Piek JJ, Schroeder E, Vrints C, Probst P, Heyndrickx GR, Fleck E, Serruys PW. Cyclic flow variations after angioplasty: a rare phenomenon predictive of immediate complications. DEBATE Investigator's Group. American Heart Journal. 1996;131(5):843-8. UI - 8615299. Reject Reason: No direct comparison between techniques. [pmid: 8615299].
Suneja R, Nair RN, Reddy KG, Rasheed Q, Sheehan HM, Hodgson JM. Mechanisms of angiographically successful directional coronary atherectomy: evaluation by intracoronary ultrasound and comparison with transluminal coronary angioplasty. American Heart Journal. 1993;126(3 Pt 1):507-14. UI - 8362702. Reject Reason: No direct comparison between techniques. [pmid: 8362702].
Suryapranata H, Zijlstra F, MacLeod DC, van den Brand M, de Feyter PJ, Serruys PW. Predictive value of reactive hyperemic response on reperfusion on recovery of regional myocardial function after coronary angioplasty in acute myocardial infarction. Circulation. 1994;89(3):1109-17. UI - 8124797. Reject Reason: No outcome of interest. [pmid: 8124797].
Suzuki K, Tsurumi Y, Fuda Y, Ishii Y, Takagi A, Hagiwara N, Kasanuki H. Postprocedural resistance of the target lesion is a strong predictor of subsequent revascularization: assessment by a novel lesion-specific physiological parameter, the epicardial resistance index. Heart & Vessels. 2007;22(3):139-45. UI - 17533516. Reject Reason: No comparison of interest. [pmid: 17533516].
Suzuki N, Nanda H, Angiolillo DJ, Bezerra H, Sabate M, Jimenez-Quevedo P, Alfonso F, Macaya C, Bass TA, Ilegbusi OJ, Costa MA. Assessment of potential relationship between wall shear stress and arterial wall response after bare metal stent and sirolimus-eluting stent implantation in patients with diabetes mellitus. The International Journal of Cardiovascular Imaging. 2008;24(4):357-64. UI - 17972162. Reject Reason: No direct comparison between techniques. [pmid: 17972162].
Suzuki T, Hosokawa H, Katoh O, Fujita T, Ueno K, Takase S, Fujii K, Tamai H, Aizawa T, Yamaguchi T, Kurogane H, Kijima M, Oda H, Tsuchikane E, Hinohara T, Fitzgerald PJ. Effects of adjunctive balloon angioplasty after intravascular ultrasound-guided optimal directional coronary atherectomy: the result of Adjunctive Balloon Angioplasty After Coronary Atherectomy Study (ABACAS). Journal of the American College of Cardiology. 1999;34(4):1028-35. UI - 10520785. Reject Reason: No direct comparison between techniques. [pmid: 10520785].
Suzuki T, Hayase M, Hibi K, Hosokawa H, Yokoya K, Fitzgerald PJ, Yock PG, Cooke JP, Suzuki T, Yeung AC. Effect of local delivery of L-arginine on in-stent restenosis in humans. American Journal of Cardiology. 2. 15. 2002;89(4):363-7. UI - 11835911. Reject Reason: No direct comparison between techniques. [pmid: 11835911].
Suzumura H, Hosokawa H, Suzuki T, Fukutomi T, Ito S, Itoh M. Comparison of dilatation mechanism and long-term vessel remodeling between directional coronary atherectomy and balloon angioplasty assessed by volumetric intravascular ultrasound. Journal of Invasive Cardiology. 2002;14(6):315-20. UI - 12042623. Reject Reason: Not relevant to KQs. [pmid: 12042623].
Tahara S, Bezerra HG, Sirbu V, Kyono H, Musumeci G, Rosenthal N, Guagliumi G, Costa MA. Angiographic, IVUS and OCT evaluation of the long-term impact of coronary disease severity at the site of overlapping drug-eluting and bare metal stents: a substudy of the ODESSA trial. Heart. 2010;96(19):1574-8. UI - 20736206. Reject Reason: No direct comparison between techniques. [pmid: 20736206].
Takano M, Yamamoto M, Murakami D, Inami S, Okamatsu K, Seimiya K, Ohba T, Seino Y, Mizuno K. Lack of association between large angiographic late loss and low risk of in-stent thrombus: angioscopic comparison between paclitaxel- and sirolimus-eluting stents. Circulation: Cardiovascular Interventions. 2008;1(1):20-7. UI - 20031651. Reject Reason: No direct comparison between techniques. [pmid: 20031651].
Takazawa K, Fujita M, Tanaka N, Takeda K, Ishimaru M, Kowaguchi H, Matsuoka O, Kurosu F, Tamura S, Ibukiyama C. Comparison of lumen area after PTCA by IVUS and QCA. Heart & Vessels. Suppl 12. 1997:217-20. UI - 9476587. Reject Reason: No direct comparison between techniques. [pmid: 9476587].
Takeda Y, Tsuchikane E, Kobayashi T, Yachiku K, Nasu K, Awata N, Kobayashi T. Effect of preintervention remodeling type on subsequent coronary artery behavior after directional atherectomy. American Journal of Cardiology. 2. 1. 2004;93(3):339-43. UI - 14759386. Reject Reason: No direct comparison between techniques. [pmid: 14759386].
Takeuchi I, Moriguchi M, Imaki R, Fukaya H, Shinagawa H, Shimohama T, Tojo T, Fukuda N, Inomata T, Aoyama N, Soma K, Izumi T. Hemodialysis is an independent predictor of coronary in-stent restenosis after paclitaxel eluting stent implantation. Internal Medicine. 2010;49(22):2379-84. UI - 21088337. Reject Reason: No direct comparison between techniques. [pmid: 21088337].
Takeuchi M, Himeno E, Sonoda S, Nakashima Y, Kuroiwa A. Measurement of myocardial fractional flow reserve during coronary angioplasty in patients with old myocardial infarction. Catheterization & Cardiovascular Diagnosis. 1997;42(1):19-25. UI - 9286532. Reject Reason: No direct comparison between techniques. [pmid: 9286532].
Takeuchi M, Himeno E. Does coronary stenting following balloon angioplasty improve myocardial fractional flow reserve?. Cardiovascular & Interventional Radiology. Dec. 1998;21(6):459-63. UI - 9853162. Reject Reason: No outcome of interest. [pmid: 9853162].
Tamita K, Akasaka T, Takagi T, Yamamuro A, Yamabe K, Katayama M, Morioka S, Yoshida K. Effects of microvascular dysfunction on myocardial fractional flow reserve after percutaneous coronary intervention in patients with acute myocardial infarction. Catheterization & Cardiovascular Interventions. 2002;57(4):452-9. UI - 12455078. Reject Reason: No direct comparison between techniques. [pmid: 12455078].
Tanaka A, Kawarabayashi T, Nishibori Y, Sano T, Nishida Y, Fukuda D, Shimada K, Yoshikawa J. No-reflow phenomenon and lesion morphology in patients with acute myocardial infarction. Circulation. 5. 7. 2002;105(18):2148-52. UI - 11994247. Reject Reason: No direct comparison between techniques. [pmid: 11994247].
Tanaka A, Kawarabayashi T, Nishibori Y, Oe H, Namba M, Nishida Y, Fukuda D, Shimada K, Yoshikawa J. In-stent restenosis and lesion morphology in patients with acute myocardial infarction. American Journal of Cardiology. 11. 15. 2003;92(10):1208-11. UI - 14609600. Reject Reason: No direct comparison between techniques. [pmid: 14609600].
Tanaka A, Shimada K, Sano T, Namba M, Sakamoto T, Nishida Y, Kawarabayashi T, Fukuda D, Yoshikawa J. Multiple plaque rupture and C-reactive protein in acute myocardial infarction. Journal of the American College of Cardiology. 5. 17. 2005;45(10):1594-9. UI - 15893172. Reject Reason: No direct comparison between techniques. [pmid: 15893172].
Tanaka A, Imanishi T, Kitabata H, Kubo T, Takarada S, Tanimoto T, Kuroi A, Tsujioka H, Ikejima H, Komukai K, Kataiwa H, Okouchi K, Kashiwaghi M, Ishibashi K, Matsumoto H, Takemoto K, Nakamura N, Hirata K, Mizukoshi M, Akasaka T. Lipid-rich plaque and myocardial perfusion after successful stenting in patients with non-ST-segment elevation acute coronary syndrome: an optical coherence tomography study. European Heart Journal. 2009;30(11):1348-55. UI - 19383736. Reject Reason: No outcome of interest. [pmid: 19383736].
Teirstein PS, Schatz RA, DeNardo SJ, Jensen EE, Johnson AD. Angioscopic versus angiographic detection of thrombus during coronary interventional procedures. American Journal of Cardiology. 6. 1. 1995;75(16):1083-7. UI - 7762489. Reject Reason: No IVDx technique used. [pmid: 7762489].
Tenaglia AN, Buller CE, Kisslo KB, Stack RS, Davidson CJ. Mechanisms of balloon angioplasty and directional coronary atherectomy as assessed by intracoronary ultrasound. Journal of the American College of Cardiology. 1920;(3):685-691. UI - 1512349. Reject Reason: No direct comparison between techniques.
Tenaglia AN, Buller CE, Kisslo KB, Phillips HR, Stack RS, Davidson CJ. Intracoronary ultrasound predictors of adverse outcomes after coronary artery interventions. Journal of the American College of Cardiology. 1920;(6):1385-1390. UI - 1430689. Reject Reason: No direct comparison between techniques.
Terashima M, Ohashi Y, Azumi H, Otsui K, Kaneda H, Awano K, Kobayashi S, Honjo T, Suzuki T, Maeda K, Yokoyama M, Inoue N. Impact of NAD(P)H oxidase-derived reactive oxygen species on coronary arterial remodeling: a comparative intravascular ultrasound and histochemical analysis of atherosclerotic lesions. Circulation: Cardiovascular Interventions. 2009;2(3):196-204. UI - 20031716. Reject Reason: Not relevant to KQs. [pmid: 20031716].
Timmis SB, Hermiller JB, Burns WH, Meyers SN, Davidson CJ. Comparison of immediate and in-hospital results of conventional balloon and perfusion balloon angioplasty using intracoronary ultrasound. American Journal of Cardiology. 2. 1. 1999;83(3):311-6. UI - 10072214. Reject Reason: No direct comparison between techniques. [pmid: 10072214].
Tobis JM, Mahon D, Mallery JA, Lehmann K, Griffith J, Gessert J, Zalesky P, McRae M, Huwe S, Paynter J. Intravascular ultrasound imaging during balloon angioplasty. American Journal of Cardiac Imaging. 1991;5(1):78-86. UI - 10147589. Reject Reason: No direct comparison between techniques. [pmid: 10147589].
Tobis JM, Mallery J, Mahon D, Lehmann K, Zalesky P, Griffith J, Gessert J, Moriuchi M, McRae M, Dwyer ML. Intravascular ultrasound imaging of human coronary arteries in vivo. Analysis of tissue characterizations with comparison to in vitro histological specimens. Circulation. 1991;83(3):913-26. UI - 1999040. Reject Reason: No outcome of interest. [pmid: 1999040].
Toda I, Teragaki M, Nishida Y, Kobayashi Y, Shimada K, Yoshiyama M, Akioka K, Takeuchi K, Yoshikawa J. Prediction of restenosis after percutaneous transluminal coronary angioplasty using coronary flow reserve. Kansai Doppler Guide Wire Study Group. [Japanese]. Journal of Cardiology. 2000;35(3):165-73. UI - 10808423. Reject Reason: No direct comparison between techniques. [pmid: 10808423].
Tonino PA, Fearon WF, De Bruyne B, Oldroyd KG, Leesar MA, Ver Lee PN, Maccarthy PA, Van't Veer M, Pijls NH. Angiographic versus functional severity of coronary artery stenoses in the FAME study fractional flow reserve versus angiography in multivessel evaluation. Journal of the American College of Cardiology. 6. 22. 2010;55(25):2816-21. UI - 20579537. Reject Reason: No direct comparison between techniques. [pmid: 20579537].
Trabattoni D, Fabbiocchi F, Montorsi P, Ravagnani P, Galli S, Teruzzi G, Calligaris G, De Martini S, Bartorelli AL. Stent thrombosis after sirolimus- and paclitaxel-eluting stent implantation in daily clinical practice: analysis of a single center registry. Catheterization & Cardiovascular Interventions. 2007;70(3):415-21. UI - 17722020. Reject Reason: Not relevant to KQs. [pmid: 17722020].
Tron C, Donohue TJ, Bach RG, Wolford T, Caracciolo EA, Aguirre FV, Khoury A, Kern MJ. Differential characterization of human coronary collateral blood flow velocity. American Heart Journal. 1996;132(3):508-15. UI - 8800019. Reject Reason: No outcome of interest. [pmid: 8800019].
Tsuchida K, Serruys PW, Bruining N, Dudek D, Drzewiecki J, Banning AP, Zmudka K, Schiele F, Zhou Z, Rademaker TA, van Es GA, Koglin J, Russell ME, Colombo A. Two-year serial coronary angiographic and intravascular ultrasound analysis of in-stent angiographic late lumen loss and ultrasonic neointimal volume from the TAXUS II trial. American Journal of Cardiology. 3. 1. 2007;99(5):607-15. UI - 17317358. Reject Reason: No comparison of interest. [pmid: 17317358].
Tsuchikane E, Sumitsuji S, Awata N, Nakamura T, Kobayashi T, Izumi M, Otsuji S, Tateyama H, Sakurai M, Kobayashi T. Final results of the STent versus directional coronary Atherectomy Randomized Trial (START). Journal of the American College of Cardiology. 1999;34(4):1050-7. UI - 10520789. Reject Reason: No direct comparison between techniques. [pmid: 10520789].
Tsuchikane E, Kobayashi T, Kobayashi T, Takeda Y, Otsuji S, Sakurai M, Awata N. Debulking and stenting versus debulking only of coronary artery disease in patients treated with cilostazol (final results of ESPRIT). American Journal of Cardiology. 9. 15. 2002;90(6):573-8. UI - 12231079. Reject Reason: No direct comparison between techniques. [pmid: 12231079].
Tsujita K, Maehara A, Mintz GS, Doi H, Kubo T, Castellanos C, Liu J, Yang J, Oviedo C, Franklin-Bond T, Sugirtharaj DD, Dangas GD, Lansky AJ, Stone GW, Moses JW, Leon MB, Mehran R. Impact of myocardial bridge on clinical outcome after coronary stent placement. American Journal of Cardiology. 5. 15. 2009;103(10):1344-8. UI - 19427426. Reject Reason: No direct comparison between techniques. [pmid: 19427426].
Tsujita K, Maehara A, Mintz GS, Lansky AJ, Kubo T, Doi H, Yang J, Bharaj H, Witzenbichler B, Guagliumi G, Brodie BR, Kellett MA Jr., Parise H, Mehran R, Stone GW. Serial intravascular ultrasound analysis of the impact of myocardial bridge on neointimal proliferation after coronary stenting in patients with acute myocardial infarction. Journal of Interventional Cardiology. 2010;23(2):114-22. UI - 20236216. Reject Reason: No direct comparison between techniques. [pmid: 20236216].
Tsunoda T, Nakamura M, Wada M, Ito N, Kitagawa Y, Shiba M, Yajima S, Iijima R, Nakajima R, Yamamoto M, Takagi T, Yoshitama T, Anzai H, Nishida T, Yamaguchi T. Chronic stent recoil plays an important role in restenosis of the right coronary ostium. Coronary Artery Disease. 2004;15(1):39-44. UI - 15201619. Reject Reason: No direct comparison between techniques. [pmid: 15201619].
Umans VA, Baptista J, Di Mario C, von Birgelen C, Quaedvlieg P, de Feyter PJ, Serruys PW. Angiographic, ultrasonic, and angioscopic assessment of the coronary artery wall and lumen area configuration after directional atherectomy: the mechanism revisited. American Heart Journal. 1995;130(2):217-27. UI - 7631599. Reject Reason: No direct comparison between techniques. [pmid: 7631599].
van der Hoeven BL, Liem SS, Jukema JW, Suraphakdee N, Putter H, Dijkstra J, Atsma DE, Bootsma M, Zeppenfeld K, Oemrawsingh PV, van der Wall EE, Schalij MJ. Sirolimus-eluting stents versus bare-metal stents in patients with ST-segment elevation myocardial infarction: 9-month angiographic and intravascular ultrasound results and 12-month clinical outcome results from the MISSION! Intervention Study. Journal of the American College of Cardiology. 2. 12. 2008;51(6):618-26. UI - 18261680. Reject Reason: No direct comparison between techniques. [pmid: 18261680].
van Liebergen RA, Piek JJ, Koch KT, Peters RJ, de Winter RJ, Schotborgh CE, Lie KI. Hyperemic coronary flow after optimized intravascular ultrasound-guided balloon angioplasty and stent implantation. Journal of the American College of Cardiology. 1999;34(7):1899-906. UI - 10588201. Reject Reason: No direct comparison between techniques. [pmid: 10588201].
Van Mieghem CA, Cademartiri F, Mollet NR, Malagutti P, Valgimigli M, Meijboom WB, Pugliese F, McFadden EP, Ligthart J, Runza G, Bruining N, Smits PC, Regar E, van der Giessen WJ, Sianos G, van Domburg R, de Jaegere P, Krestin GP, Serruys PW, de Feyter PJ. Multislice spiral computed tomography for the evaluation of stent patency after left main coronary artery stenting: a comparison with conventional coronary angiography and intravascular ultrasound. Circulation. 8. 15. 2006;114(7):645-53. UI - 16894038. Reject Reason: Population not met. [pmid: 16894038].
Vavuranakis M, Toutouzas K, Stefanadis C, Chrisohou C, Markou D, Toutouzas P. Stent deployment in calcified lesions: can we overcome calcific restraint with high-pressure balloon inflations?. Catheterization & Cardiovascular Interventions. 2001;52(2):164-72. UI - 11170322. Reject Reason: No direct comparison between techniques. [pmid: 11170322].
Vaz VD, Abizaid A, Chaves A, Feres F, Ferreira E, Mattos L, Staico R, Abizaid A, Tanajura L, Centemero M, Mintz G, Sousa A, Sousa JE. Long-term follow up of diabetic patients treated with sirolimus-eluting stents. An angiographic and three-dimensional intravascular ultrasound study. Journal of Invasive Cardiology. 2006;18(4):142-6. UI - 16729398. Reject Reason: No direct comparison between techniques. [pmid: 16729398].
Vaz VD, Abizaid AC, Abizaid AA, Feres F, Staico R, Mattos LA, Pinto I, Tanajura LF, Sousa AG, Sousa JE. The usefulness of intracoronary ultrasound in the treatment decision-making of patients with ambiguous lesions in the left main coronary artery. Arquivos Brasileiros de Cardiologia. 2006;87(6):681-7. UI - 17262103. Reject Reason: No comparison of interest. [pmid: 17262103].
Verheye S, Agostoni P, Dubois CL, Dens J, Ormiston J, Worthley S, Trauthen B, Hasegawa T, Koo BK, Fitzgerald PJ, Mehran R, Lansky AJ. 9-month clinical, angiographic, and intravascular ultrasound results of a prospective evaluation of the Axxess self-expanding biolimus A9-eluting stent in coronary bifurcation lesions: the DIVERGE (Drug-Eluting Stent Intervention for Treating Side Branches Effectively) study. Journal of the American College of Cardiology. 3. 24. 2009;53(12):1031-9. UI - 19298915. Reject Reason: Measurement timepoint not of interest. [pmid: 19298915].
Verheye S, Grube E, Ramcharitar S, Schofer JJ, Witzenbichler B, Kovac J, Hauptmann KE, Agostoni P, Wiemer M, Lefevre T, Serruys PW, van Geuns RJ. First-in-man (FIM) study of the Stentys bifurcation stent--30 days results. Eurointervention. 2009;4(5):566-71. UI - 19378675. Reject Reason: No direct comparison between techniques. [pmid: 19378675].
Vermeersch P, Agostoni P, Verheye S, Van den Heuvel P, Convens C, Bruining N, Van den Branden F, Van Langenhove G. Randomized double-blind comparison of sirolimus-eluting stent versus bare-metal stent implantation in diseased saphenous vein grafts: six-month angiographic, intravascular ultrasound, and clinical follow-up of the RRISC Trial. Journal of the American College of Cardiology. 2006;48(12):2423-31. UI - 17174178. Reject Reason: No comparison of interest. [pmid: 17174178].
Verna E, Lattanzio M, Ghiringhelli S, Provasoli S, Caico SI. Performing versus deferring coronary angioplasty based on functional evaluation of vessel stenosis by pressure measurements: a clinical outcome study. Journal of Cardiovascular Medicine. 2006;7(3):169-75. UI - 16645381. Reject Reason: No direct comparison between techniques. [pmid: 16645381].
Violaris AG, Linnemeier TJ, Campbell S, Rothbaum DA, Cumberland DC. Intravascular ultrasound imaging combined with coronary angioplasty. Lancet. 6. 27. 1992;339(8809):1571-2. UI - 1351552. Reject Reason: Not relevant to KQs. [pmid: 1351552].
vom Dahl J, Dietz U, Haager PK, Silber S, Niccoli L, Buettner HJ, Schiele F, Thomas M, Commeau P, Ramsdale DR, Garcia E, Hamm CW, Hoffmann R, Reineke T, Klues HG. Rotational atherectomy does not reduce recurrent in-stent restenosis: results of the angioplasty versus rotational atherectomy for treatment of diffuse in-stent restenosis trial (ARTIST). Circulation. 2. 5. 2002;105(5):583-8. UI - 11827923. Reject Reason: No direct comparison between techniques. [pmid: 11827923].
von Birgelen C, Mintz GS, Eggebrecht H, Herrmann J, Jasper M, Brinkhoff J, Neumann T, Bose D, Baumgart D, Schmermund A, Wieneke H, Haude M, Erbel R. Preintervention arterial remodeling affects vessel stretch and plaque extrusion during coronary stent deployment as demonstrated by three-dimensional intravascular ultrasound. American Journal of Cardiology. 7. 15. 2003;92(2):130-5. UI - 12860212. Reject Reason: No comparison of interest. [pmid: 12860212].
Waksman R, White RL, Chan RC, Bass BG, Geirlach L, Mintz GS, Satler LF, Mehran R, Serruys PW, Lansky AJ, Fitzgerald P, Bhargava B, Kent KM, Pichard AD, Leon MB. Intracoronary gamma-radiation therapy after angioplasty inhibits recurrence in patients with in-stent restenosis. Circulation. 5. 9. 2000;101(18):2165-71. UI - 10801757. Reject Reason: No direct comparison between techniques. [pmid: 10801757].
Waksman R, Ajani AE, Pichard AD, Torguson R, Pinnow E, Canos D, Satler LF, Kent KM, Kuchulakanti P, Pappas C, Gambone L, Weissman N, Abbott MC, Lindsay J. Oral Rapamune to Inhibit Restenosis study. Oral rapamycin to inhibit restenosis after stenting of de novo coronary lesions: the Oral Rapamune to Inhibit Restenosis (ORBIT) study. Journal of the American College of Cardiology. 10. 6. 2004;44(7):1386-92. UI - 15464317. Reject Reason: No direct comparison between techniques. [pmid: 15464317].
Watanabe T, Nanto S, Uematsu M, Ohara T, Morozumi T, Kotani J, Nishio M, Awata M, Nagata S, Hori M. Prediction of no-reflow phenomenon after successful percutaneous coronary intervention in patients with acute myocardial infarction: intravascular ultrasound findings. Circulation Journal. 2003;67(8):667-71. UI - 12890907. Reject Reason: No comparison of interest. [pmid: 12890907].
Weissman NJ, Koglin J, Cox DA, Hermiller J, O'Shaughnessy C, Mann JT, Turco M, Caputo R, Bergin P, Greenberg J, Kutcher M, Wong SC, Strickland W, Mooney M, Russell ME, Ellis SG, Stone GW. Polymer-based paclitaxel-eluting stents reduce in-stent neointimal tissue proliferation: a serial volumetric intravascular ultrasound analysis from the TAXUS-IV trial. Journal of the American College of Cardiology. 2005;45(8):1201-5. UI - 15837249. Reject Reason: No direct comparison between techniques. [pmid: 15837249].
Werner GS, Sold G, Buchwald A, Kreuzer H, Wiegand V. Intravascular ultrasound imaging of human coronary arteries after percutaneous transluminal angioplasty: morphologic and quantitative assessment. American Heart Journal. 1991;122(1 Pt 1):212-20. UI - 2063739. Reject Reason: No direct comparison between techniques. [pmid: 2063739].
Werner GS, Diedrich J, Morguet AJ, Buchwald AB, Kreuzer H. Morphology of chronic coronary occlusions and response to interventional therapy--a study by intracoronary ultrasound. International Journal of Cardiac Imaging. 1997;13(6):475-84. UI - 9415849. Reject Reason: No direct comparison between techniques. [pmid: 9415849].
Werner GS, Diedrich J, Schunemann S, Gastmann O, Ferrari M, Buchwald AB, Figulla HR, Kreuzer H. Additional luminal area gain by intravascular ultrasound guidance after coronary stent implantation with high inflation pressure. International Journal of Cardiac Imaging. 1997;13(4):311-21. UI - 9306145. Reject Reason: No direct comparison between techniques. [pmid: 9306145].
Werner GS, Gastmann O, Ferrari M, Schuenemann S, Knies A, Diedrich J, Kreuzer H. Risk factors for acute and subacute stent thrombosis after high-pressure stent implantation: a study by intracoronary ultrasound. American Heart Journal. 1998;135(2 Pt 1):300-9. UI - 9489980. Reject Reason: No direct comparison between techniques. [pmid: 9489980].
Werner GS, Ferrari M, Richartz BM, Gastmann O, Figulla HR. Microvascular dysfunction in chronic total coronary occlusions. Circulation. 9. 4. 2001;104(10):1129-34. UI - 11535568. Reject Reason: No direct comparison between techniques. [pmid: 11535568].
Werner GS. Simultaneous Doppler pressure recordings to assess microvascular dysfunction in chronic total coronary occlusions--potential for recovery during follow-up. Zeitschrift fur Kardiologie. Suppl 3. 2002;91:120-5. UI - 12641026. Reject Reason: Not relevant to KQs. [pmid: 12641026].
Werner GS, Richartz BM, Heinke S, Ferrari M, Figulla HR. Impaired acute collateral recruitment as a possible mechanism for increased cardiac adverse events in patients with diabetes mellitus. European Heart Journal. 2003;24(12):1134-42. UI - 12804928. Reject Reason: Not relevant to KQs. [pmid: 12804928].
Werner GS, Bahrmann P, Mutschke O, Emig U, Betge S, Ferrari M, Figulla HR. Determinants of target vessel failure in chronic total coronary occlusions after stent implantation. The influence of collateral function and coronary hemodynamics. Journal of the American College of Cardiology. 7. 16. 2003;42(2):219-25. UI - 12875755. Reject Reason: Not relevant to KQs. [pmid: 12875755].
Wexberg P, Gyongyosi M, Sperker W, Kiss K, Yang P, Hassan A, Pasterkamp G, Glogar D. Pre-existing arterial remodeling is associated with in-hospital and late adverse cardiac events after coronary interventions in patients with stable angina pectoris. Journal of the American College of Cardiology. 11. 15. 2000;36(6):1860-9. UI - 11092657. Reject Reason: No direct comparison between techniques. [pmid: 11092657].
Whitbourn RJ, Sethi R, Pomerantsev EV, Fitzgerald PJ. High-speed rotational atherectomy and coronary stenting: QCA and QCU analysis. Catheterization & Cardiovascular Interventions. 2003;60(2):167-71. UI - 14517919. Reject Reason: No direct comparison between techniques. [pmid: 14517919].
White CJ, Ramee SR, Collins TJ, Mesa JE, Jain A. Percutaneous angioscopy of saphenous vein coronary bypass grafts. Journal of the American College of Cardiology. 1993;21(5):1181-5. UI - 8459074. Reject Reason: No IVDx technique used. [pmid: 8459074].
White CJ, Ramee SR, Collins TJ, Jain SP, Escobar A. Coronary angioscopy of abrupt occlusion after angioplasty. Journal of the American College of Cardiology. 1995;25(7):1681-4. UI - 7759723. Reject Reason: No IVDx technique used. [pmid: 7759723].
Wiemer M, Konig A, Rieber J, Sohn HY, Leibig M, Theisen K, Klauss V, Langer C, Lindner O, Horstkotte D, Schiele TM. Sirolimus-eluting stent implantation versus beta-irradiation for the treatment of in-stent restenotic lesions: clinical and ultrasound results from a randomised trial. Eurointervention. 2011;6(6):687-94. UI - 21205590. Reject Reason: No direct comparison between techniques. [pmid: 21205590].
Wolfe CL, Klette MA, Trask RV, Rothbaum DA, Landin RJ, Ball MW, Hodes ZI, Linnemeier TJ. Assessment of the results of percutaneous transluminal coronary angioplasty using an integrated ultrasound imaging-angioplasty catheter. Catheterization & Cardiovascular Diagnosis. 1994;32(2):108-12. UI - 8062363. Reject Reason: No outcome of interest. [pmid: 8062363].
Wolfhard U, Gorge G, Konorza T, Haude M, Ge J, Piotrowski JA, Splittgerber FH, Sadony V, Erbel R. Intravascular ultrasound (IVUS) examination reverses therapeutic decision from percutaneous intervention to a surgical approach in patients with alterations of the left main stem. Thoracic & Cardiovascular Surgeon. 1998;46(5):281-4. UI - 9885119. Reject Reason: Not relevant to KQs. [pmid: 9885119].
Wong P. Two years experience of a simple technique of precise ostial coronary stenting. Catheterization & Cardiovascular Interventions. 9. 1. 2008;72(3):331-4. UI - 18412234. Reject Reason: No direct comparison between techniques. [pmid: 18412234].
Yamada R, Okura H, Kume T, Neishi Y, Kawamoto T, Miyamoto Y, Imai K, Saito K, Tsuchiya T, Hayashida A, Yoshida K. Target lesion thin-cap fibroatheroma defined by virtual histology intravascular ultrasound affects microvascular injury during percutaneous coronary intervention in patients with angina pectoris. Circulation Journal. 2010;74(8):1658-62. UI - 20595776. Reject Reason: No comparison of interest. [pmid: 20595776].
Yamada T, Okamoto M, Sueda T, Hashimoto M, Kajiyama G. Relation between collateral flow assessed by Doppler guide wire and angiographic collateral grades. American Heart Journal. 1995;130(1):32-7. UI - 7611120. Reject Reason: No outcome of interest. [pmid: 7611120].
Yamaguchi T, Hamasaki S, Arima S, Biro S, Kihara K, Fukumoto N, Kamekou M, Nakano F, Yoshitama T, Kiyonaga K, Nakajima H, Nakao S, Tei C. Morphological effects on in-stent restenosis assessed by intravascular ultrasound imaging. Japanese Heart Journal. 1999;40(2):109-18. UI - 10420872. Reject Reason: No comparison of interest. [pmid: 10420872].
Yoon MH, Tahk SJ, Yang HM, Woo SI, Lim HS, Kang SJ, Choi BJ, Choi SY, Hwang GS, Shin JH. Comparison of accuracy in the prediction of left ventricular wall motion changes between invasively assessed microvascular integrity indexes and fluorine-18 fluorodeoxyglucose positron emission tomography in patients with ST-elevation myocardial infarction. American Journal of Cardiology. 7. 15. 2008;102(2):129-34. UI - 18602508. Reject Reason: No outcome of interest. [pmid: 18602508].
Yoon SC, Laskey WK, Assadourian A, Kelly D, Gellman J, Herzog W, Stafford JL. Assessment of contemporary stent deployment using intravascular ultrasound. Catheterization & Cardiovascular Interventions. 2002;57(2):150-4. UI - 12357510. Reject Reason: No direct comparison between techniques. [pmid: 12357510].
Yoshitomi Y, Kojima S, Yano M, Matsumoto Y, Sugi T, Saotome M, Tanaka K, Endo M, Kuramochi M. Relation between stent expansion and arterial remodeling: a serial intravascular ultrasound study. Catheterization & Cardiovascular Interventions. 2000;50(3):282-9. UI - 10878623. Reject Reason: No direct comparison between techniques. [pmid: 10878623].
Zhang D, Cai X, Shen W, Schiele F, Bassand JP. Intracoronary stent implantation under intracoronary ultrasound guidance with aspirin and ticlopidine therapy. Chinese Medical Journal. 2001;114(3):262-5. UI - 11780310. Reject Reason: No direct comparison between techniques. [pmid: 11780310].
Zhang JJ, Chen SL, Ye F, Yang S, Kan J, Liu YQ, Zhou Y, Sun XW, Zhang AP, Wang X, Chen J. Mechanisms and clinical significance of quality of final kissing balloon inflation in patients with true bifurcation lesions treated by crush stenting technique. Chinese Medical Journal. 9. 20. 2009;122(18):2086-91. UI - 19781289. Reject Reason: No direct comparison between techniques. [pmid: 19781289].
Zhang RY, DU R, Zhu ZB, Zhang Q, Hu J, Lu AK, Zhang JS, Shen WF. Acute coronary syndrome is an independent risk factor for late incomplete stent apposition after sirolimus-eluting stent implantation. Chinese Medical Journal. 12. 20. 2008;121(24):2504-8. UI - 19187586. Reject Reason: No direct comparison between techniques. [pmid: 19187586].
Zhou W, Hoffmann R, Franke A, Yang H, Kuhl H, Hanrath P. Intravascular ultrasound evaluating coronary stents for patients with coronary artery disease: compared old with new multilink stents. Chinese Medical Sciences Journal. 2002;17(2):95-100. UI - 12906162. Reject Reason: No direct comparison between techniques. [pmid: 12906162].
Ziada KM, Tuzcu EM, De Franco AC, Kim MH, Raymond RE, Franco I, Whitlow PL, Ellis SG, Nissen SE. Intravascular ultrasound assessment of the prevalence and causes of angiographic “haziness” following high-pressure coronary stenting. American Journal of Cardiology. 7. 15. 1997;80(2):116-21. UI - 9230144. Reject Reason: No direct comparison between techniques. [pmid: 9230144].
Ziada KM, Kapadia SR, Belli G, Houghtaling PL, De Franco AC, Ellis SG, Whitlow PL, Franco I, Nissen SE, Tuzcu EM. Prognostic value of absolute versus relative measures of the procedural result after successful coronary stenting: importance of vessel size in predicting long-term freedom from target vessel revascularization. American Heart Journal. 2001;141(5):823-31. UI - 11320373. Reject Reason: No direct comparison between techniques. [pmid: 11320373].
Ziaee A, Herrmann SC, Lim MJ, Kern MJ. Intravascular ultrasound and fractional flow reserve of equivocal left main stenosis in patients with Takayasu's arteritis: impact on surgical decision-making. Catheterization & Cardiovascular Interventions. 2005;65(3):381-5. UI - 15937934. Reject Reason: Case report. [pmid: 15937934].
Zimarino M, Ausiello A, Contegiacomo G, Riccardi I, Renda G, Di Iorio C, De Caterina R. Rapid decline of collateral circulation increases susceptibility to myocardial ischemia: the trade-off of successful percutaneous recanalization of chronic total occlusions. Journal of the American College of Cardiology. 7. 4. 2006;48(1):59-65. UI - 16814649. Reject Reason: No direct comparison between techniques. [pmid: 16814649].