# Search Strategy

Databases include: MEDLINE^®^ and Cochrane Central Register of Controlled Trials

# | Searches
1 | intravascular.af.
2 | intra-vascular.af.
3 | endovascular.af.
4 | endo-vascular.af.
5 | endocoronary.af.
6 | endo-coronary.af.
7 | intra-coronary.af.
8 | intracoronary.af.
9 | endoluminal.af.
10 | endo-luminal.af.
11 | transluminal.af.
12 | trans-luminal.af.
13 | intraluminal.af.
14 | intra-luminal.af.
15 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14
16 | magnetic resonance imaging.af.
17 | magnetic resonance angiography.af.
18 | exp magnetic resonance imaging/
19 | exp magnetic resonance angiography/
20 | elastography.af.
21 | thermography.af.
22 | microcirculatory resistance.af.
23 | vascular resistance.af.
24 | thermodilution.af.
25 | exp Thermodilution/
26 | hemodynamics.af.
27 | exp Hemodynamics/
28 | exp endosonography/
29 | physiologic measurement*.af.
30 | doppler ultrasound.af.
31 | coronary pressure.af.
32 | doppler velocimetry.af.
33 | ultraso*.af.
34 | 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 39 or 31 or 32 or 33
35 | 15 and 34
36 | exp coronary angiography/
37 | ultraso$.af.
38 | ffr.af.
39 | fractional flow reserve.af.
40 | coronary flow reserve.af.
41 | coronary flow velocity reserve.af.
42 | angioscop$.af.
43 | optical coherence tomography.af.
44 | exp Tomography, Optical Coherence/
45 | blood flow velocity.af.
46 | exp Blood Flow Velocity/
47 | doppler flow wire.af.
48 | pressure wire.af.
49 | coronary pressure measurement.af.
50 | exp endosonography/
51 | 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50
52 | 36 and 51
53 | exp Ultrasonography, Interventional/
54 | exp Fractional Flow Reserve, Myocardial/
55 | fractional flow reserve.af.
56 | intravascular ultrasound.af.
57 | IVUS.af.
58 | 53 or 54 or 55 or 56 or 57
59 | 35 or 52 or 58
60 | exp myocardial ischemia/
61 | exp Angioplasty, Transluminal, Percutaneous Coronary/
62 | exp stents/
63 | exp Angioplasty, Balloon, Coronary/
64 | exp Myocardial Revascularization/
65 | exp drug-eluting stents/
66 | 61 or 62 or 63 or 64 or 65
67 | 60 and 66
68 | 59 and 67
69 | remove duplicates from 68
70 | exp animals/ not humans.sh.
71 | 69 not 70