# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
CABG: Coronary artery bypass graft surgery
CAD: Coronary artery disease
CER: Comparative Effectiveness Review
CFR: Coronary flow reserve
CI: Confidence interval
CMS: Centers for Medicare and Medicaid Services
DCA: Directional coronary atherectomy
EPC: Evidence-based Practice Center
EQ-5D: European Quality of Life-5 Dimensions
FAME: Fractional Flow Reserve versus Angiography for Multivessel Evaluation (trial)
FDA: Food and Drug Administration (U.S.)
FFR: Fractional flow reserve
IMRI: Intravascular magnetic resonance imaging
IVUS: Intravascular ultrasound
MACE: Major adverse cardiac event
MLD: Minimal lumen diameter
MRI: Magnetic resonance imaging
MI: Myocardial infarction
NIRS: Near-infrared spectroscopy
NS: Not significant
OCT: Optical coherence tomography
PCI: Percutaneous coronary intervention
QCA: Quantitative coronary angiography
RCT: Randomized controlled trial
RR: Relative risk
SD: Standard deviation
STEMI: ST-segment elevation myocardial infarction
TEP: Technical Expert Panel
TOO: Task Order Officer