# Results

Of 5,244 identified references, we included 245 references of RCTs and 76 nonrandomized studies (Figure 2). All excluded references are presented in Appendix C.

Figure 2 Study flow

This figure depicts the study flow that contains the number of retrieved, included, and excluded studies. The investigators retrieved a total of 5,244 references from Medline, the Cochrane library, the website of the Federal Drug Administration, manual searches of reference lists, and other sources. They included 321 references and excluded the rest of the references because excluded studies examined target populations, treatments, or outcomes not eligible for the report. The review authors synthesized the evidence from 245 publications of randomized controlled clinical trials and 76 publications of non randomized studies.

## Publication Bias

By analyzing the NIH-funded and registered studies, we found that the results are available from only a small proportion of migraine prevention studies. However, we could not determine exact reasons for low availability of results based on available data. Both, posting of results and publication rates, varied by individual sponsors.

We found 18 NIH funded grants that aimed to examine migraine prevention. Six grant projects funded three RCTs. Two of those three RCTs were registered in ClinicalTrials.gov (Table 2). Overall publication rate was 44 percent (eight of 18 funded projects). The National Institute of Neurological Disorders and Stroke funded nine studies (the largest number among the agencies), and published the results from four of these projects (Table 2). We could not explain why the studies have not been published because the NIH grant database does not allow the analysis of the exact reasons for the low publication rates of the projects. Results from the NIH-funded projects were published after 1.9 to 3 years from the end dates of the projects (Table 3). Time intervals between project end dates and publication did not differ among the funding agencies.

Table 2 Registration, publication, and cost of the NIH-funded grants aimed at migraine prevention (as of May 2012)

Agency | Not Registered | Registered | Total | % Registered | Unpublished | Published | Total | % Published | Sum/Cost of Studies With No Results Available | Minimum Cost | Maximum Cost
NCCAM | 1 | 2 | 3 | 67 | 1 | 2 | 3 | 67 | $675,532/$222,925 | $100,000 | $292,000
NCI | 2 | 0 | 2 | 0 | 2 | 0 | 2 | 0 | $176,000/$176,000 | $88,000 | $88,000
NIDA | 2 | 0 | 2 | 0 | 0 | 2 | 2 | 100 | $791,080 | $283,941 | $507,139
NIMH | 1 | 0 | 1 | 0 | 1 | 0 | 1 | 0 | Not reported
NINDS | 7 | 2 | 9 | 22 | 5 | 4 | 9 | 44 | $1,159,146/$649,121 | $155,568 | $210,668
NINR | 1 | 0 | 1 | 0 | 1 | 0 | 1 | 0 | $159,480/$159,480 | $159,480 | $159,480

NCCAM = National Center for Complementary and Alternative Medicine; NCI = National Cancer Institute; NIDA = National Institute on Drug Abuse; NIMH = National Institute of Mental Health; NINDS = National Institute of Neurological Disorders and Stroke; NINR= National Institute of Nursing Research

Table 3 Years between the NIH-funded project end dates and the publication dates of the results

NIH Agency | Interval Time Point | Mean | Minimum | Maximum | Standard Deviation
NCCAM | Project End Date | 1.9 | 1.4 | 2.4 | 0.7
NCCAM | Budget End Date | 2.4 | 1.4 | 3.4 | 1.4
NIDA | Project End Date | 2.3 | 1.8 | 2.8 | 0.7
NIDA | Budget End Date | 2.8 | 1.8 | 3.8 | 1.4
NINDS | Project End Date | 2.3 | 0.6 | 3.7 | 1.6
NINDS | Budget End Date | 3.0 | 1.6 | 4.7 | 1.6

NCCAM = National Center for Complementary and Alternative Medicine; NIDA = National Institute on Drug Abuse; NIMH = National Institute of Mental Health; NINDS = National Institute of Neurological Disorders and Stroke

Searching trial registries, we found 67 studies in ClinicalTrials.gov and 24 studies in other registries. Publication rates of study results were slightly lower for the studies registered in ClinicalTrials.gov (21 percent; 14/67) than in other registries (33 percent; 8/24). Among the studies registered in ClinicalTrials.gov most studies examined drugs (61/67). A placebo control was used by 64 percent (43/67). Most studies were completed (70 percent; 47/67) and four studies were terminated. Termination due to harms with treatments was clearly indicated in two terminated studies. The results were posted for nine studies (13 percent).

Publication rates varied depending on subjects and study characteristics (Table 4). Only 28 percent of all completed studies, 50 percent of biologics studies, and 18 percent of drug studies were published. Only 33 percent of Phase III and 50 percent of Phase IV studies were published. No terminated studies were published. Publications occurred an average of 2 years after study completion (0.5 to 6.6 years). Publication time varied among individual sponsors. Odds of publication did not reach statistical significance, probably due to the small number of studies (Table 5).

Table 4 Publication and posting of the results of migraine prevention studies registered in ClinicalTrials.gov

| | Published | Not Published | Total | % Published | Has Results | No Results Available | Total | % Posted
Category | Total | 14 | 53 | 67 | 20.9 | 9 | 58 | 67 | 13.4
Age | Adult | 8 | 29 | 37 | 21.6 | 6 | 31 | 37 | 16.2
Age | Adult\| Senior | 3 | 18 | 21 | 14.3 | 3 | 18 | 21 | 14.3
Age | Child | 0 | 6 | 6 | 0.0 | 0 | 6 | 6 | 0.0
Age | Child\| Adult | 3 | 0 | 3 | 100.0 | 0 | 3 | 3 | 0.0
Gender | Both | 13 | 46 | 59 | 22.0 | 9 | 50 | 59 | 15.3
Gender | Female | 0 | 1 | 1 | 0.0 | 0 | 1 | 1 | 0.0
Type | Interventional | 14 | 51 | 65 | 21.5 | 9 | 56 | 65 | 13.8
Type | Observational | 0 | 2 | 2 | 0.0 | 0 | 2 | 2 | 0.0
Intervention | Behavioral | 0 | 1 | 1 | 0.0 | 0 | 1 | 1 | 0.0
Intervention | Biological | 2 | 2 | 4 | 50.0 | 2 | 2 | 4 | 50.0
Intervention | Drug | 11 | 50 | 61 | 18.0 | 7 | 54 | 61 | 11.5
Intervention | Procedure | 1 | 0 | 1 | 100.0 | 0 | 1 | 1 | 0.0
Phases | Phase 1\|Phase 2 | 0 | 1 | 1 | 0.0 | 0 | 1 | 1 | 0.0
Phases | Phase 2 | 2 | 17 | 19 | 10.5 | 2 | 17 | 19 | 10.5
Phases | Phase 2\|Phase 3 | 0 | 1 | 1 | 0.0 | 0 | 1 | 1 | 0.0
Phases | Phase 3 | 8 | 16 | 24 | 33.3 | 3 | 21 | 24 | 12.5
Phases | Phase 4 | 2 | 5 | 7 | 28.6 | 2 | 5 | 7 | 28.6
Phases | Phase 1 | 0 | 1 | 1 | 0.0 | 0 | 1 | 1 | 0.0
Phases | Phase 2I | 0 | 3 | 3 | 0.0 | 0 | 3 | 3 | 0.0
Phases | Phase 4 | 1 | 1 | 2 | 50.0 | 0 | 2 | 2 | 0.0
Placebo | No | 3 | 21 | 24 | 12.5 | 2 | 22 | 24 | 8.3
Placebo | Yes | 11 | 32 | 43 | 25.6 | 7 | 36 | 43 | 16.3
Recruitment | Active, not recruiting | 0 | 2 | 2 | 0.0 | 0 | 2 | 2 | 0.0
Recruitment | Completed | 13 | 34 | 47 | 27.7 | 8 | 39 | 47 | 17.0
Recruitment | Not yet recruiting | 0 | 2 | 2 | 0.0 | 0 | 2 | 2 | 0.0
Recruitment | Recruiting | 1 | 9 | 10 | 10.0 | 0 | 10 | 10 | 0.0
Recruitment | Terminated | 0 | 4 | 4 | 0.0 | 1 | 3 | 4 | 25.0
Recruitment | Withdrawn | 0 | 2 | 2 | 0.0 | 0 | 2 | 2 | 0.0
Reason for termination | Administrative | 0 | 1 | 1 | 0.0 | 1 | 0 | 1 | 100.0
Reason for termination | Other | 0 | 1 | 1 | 0.0 | 0 | 1 | 1 | 0.0
Reason for termination | Safety related | 0 | 2 | 2 | 0.0 | 0 | 2 | 2 | 0.0
Funding | Industry | 9 | 34 | 43 | 20.9 | 4 | 39 | 43 | 9.3
Funding | Industry\|NIH | 0 | 1 | 1 | 0.0 | 1 | 0 | 1 | 100.0
Funding | Industry\|Other | 1 | 1 | 2 | 50.0 | 0 | 2 | 2 | 0.0
Funding | Other | 1 | 8 | 9 | 11.1 | 0 | 9 | 9 | 0.0
Funding | Other\|Industry | 2 | 6 | 8 | 25.0 | 3 | 5 | 8 | 37.5
Funding | Other\|NIH | 0 | 1 | 1 | 0.0 | 0 | 1 | 1 | 0.0
Funding | Other\|NIH\|Industry | 1 | 0 | 1 | 100.0 | 1 | 0 | 1 | 100.0
Funding | Other\|U.S. Fed\|Industry | 0 | 1 | 1 | 0.0 | 0 | 1 | 1 | 0.0
Funding | U.S. Fed\|Other | 0 | 1 | 1 | 0.0 | 0 | 1 | 1 | 0.0

Table 5 Odds of publication and posting of results in ClinicalTrials.gov among all studies registered in ClinicalTrials.gov

Outcome | Active | Control | Active With Outcome | Active Without Outcome | Control With Outcome | Control Without Outcome | Odds Ratio | Lower 95% CI | Upper 95% CI
Publication | Interventional | Observational | 14 | 51 | 0 | 2 | 1.41 | 0.06 | 30.99
Publication | Drug studies | All other studies | 11 | 50 | 3 | 3 | 0.22 | 0.04 | 1.24
Publication | Placebo control | No placebo control (active treatments comparison) | 11 | 32 | 3 | 21 | 2.41 | 0.60 | 9.66
Publication | Has results | No results available | 4 | 5 | 10 | 48 | 3.84 | 0.87 | 16.88
Publication | Funded by industry | Funded by other sources | 9 | 34 | 1 | 10 | 2.65 | 0.30 | 23.49
Posting results | Drug studies | All other studies | 7 | 54 | 2 | 4 | 0.26 | 0.04 | 1.68
Posting results | Phase 3–4 trials | Phase 1–2 trials | 5 | 28 | 2 | 23 | 2.05 | 0.36 | 11.58
Posting results | Placebo control | No placebo control (active treatments comparison) | 7 | 36 | 2 | 22 | 2.14 | 0.41 | 11.23
Posting results | Terminated for safety reasons | Terminated for other reasons | 0 | 2 | 1 | 1 | 0.20 | 0.00 | 8.82
Posting results | Funded by Industry | Funded by other sources | 9 | 47 | 0 | 11 | 4.60 | 0.25 | 84.94

The rates of the posting of the results also varied depending on subjects and study characteristics (Table 4). Half of biologics studies and 12 percent of drug studies posted the result in ClinicalTrials.gov. Only 13 percent of Phase III and 29 percent of Phase IV trials posted the results in ClinicalTrials.gov. Trials that were terminated for safety reasons did not post the results. Results were posted an average of 2.6 years after study completion dates (0.9 to 5.2 years). Biologic studies posted the results an average of 3 years after completion dates, and drug studies posted results an average of 2.6 years after completion dates. Placebo-controlled studies posted results an average of 2.5 years after completion dates, and comparative effectiveness studies 3.4 years after completion dates. Terminated studies posted the results an average of 5 years after study termination. Odds of posting the results did not reach statistical significance, probably due to the small number of studies (Table 5).

Abstracted data are available in Appendix D with evidence tables (available at https://netfiles.umn.edu/xythoswfs/webui/_xy-21041343_1-t_zdhvSpvy). Randomized trials examined 59 drugs from 14 pharmacologic drug classes (Appendix Table D1).

Most trials were funded by industry but did not disclose conflict of interest by study investigators (Appendix Table D2). Proportions of industry sponsorship and disclosed conflict of interest varied among drugs (Appendix Table D2).

## Applicability

The results from eligible studies were applicable to the target population. Most RCTs were conducted in the United States and Western countries and used the International Headache Society’s definition (Appendix Table D3). Older publications used the definition of migraine developed by the Ad Hoc Committee on Classification of Headache, and about 34 RCTs did not specify a migraine definition.

Investigators recruited patients in clinics in almost half of RCTs. Half did not report this information, and eight RCTS clearly indicated community-based recruitment. RCTs enrolled an average of 210 adults, measured the outcomes at 2 to 3 months of followup, and reported about 14 percent loss of followup (Table 6 and Appendix Table D4).

Table 6 Total number randomized, weeks of followup, and loss of followup in randomized controlled clinical trials of migraine prevention in adults

| Total Sample | # RCTs That Reported Sample | Sample Assigned to Treatment Mean [Min to Max] | # RCTs That Reported Length of Followup | Total Length of Followup, Weeks Mean [Min to Max] | # RCTs That Reported % Loss of Followup | % Loss of Followup Mean [Min to Max]
Antiepileptics | 7656 | 42 | 182.3 [23 to 818] | 43 | 17.6 [8.0 to 28.0] | 28 | 5.5 [0.0 to 36.0]
Antidepressants | 1701 | 21 | 83.0 [17 to 391] | 21 | 13.5 [4.0 to 27.0] | 19 | 22.6 [0.0 to 48.0]
Beta blockers | 6006 | 62 | 96.9 [14 to 810] | 65 | 18.1 [4.0 to 60.0] | 36 | 12.3 [0.0 to 37.5]
ACE inhibitors | 72 | 2 | 36.0 [12 to 60] | 2 | 37.8 [7.5 to 68.0] | 1 | 22.0
Angiotensin II receptor blockers | 144 | 2 | 72.0 [60 to 84] | 2 | 22.0 [12.0 to 32.0] | 2 | 11.0 [5.0 to 17.0]
Calcium channel blockers | 2602 | 33 | 78.8 [20 to 521] | 33 | 18.8 [8.0 to 36.0] | 30 | 15.4 [0.0 to 48.3]
Antiadrenergics | 711 | 15 | 47.4 [20 to 133] | 15 | 21.6 [8.0 to 48.0] | 11 | 21.2 [6.0 to 38.0]
Dopaminergic agents | 172 | 3 | 57.3 [30 to 102] | 3 | 28.0 [16.0 to 40.0] | | Not reported
Ergot alkaloids | 1040 | 9 | 115.6 [18 to 384] | 9 | 13.6 [6.0 to 24.0] | 8 | 11.6 [0.0 to 32.4]
NSAIDs | 23993 | 16 | 1499.6 [26 to 22071] | 16 | 26.0 [4.0 to 144.0] | 6 | 15.2 [0.0 to 29.6]
Magnesium | 174 | 3 | 58.0 [24 to 81] | 3 | 17.3 [12.0 to 24.0] | 3 | 23.0 [11.0 to 42.0]
Nondrugs vs. drugs | 632 | 4 | 158.0 [114 to 218] | 4 | 20.0 [16.0 to 24.0] | | Not reported
Cortical spreading depression inhibitor | 124 | 1 | 124.0 | 1 | 13.0 | 1 | 5.1
Muscle relaxants | 136 | 1 | 136.0 | 1 | 12.0 | | Not reported
Montelukast | 177 | 1 | 177.0 | 1 | 20.0 | 1 | 2.2
Total | 45340 | 215 | 210.9 [12 to 22071] | 219 | 18.6 [4.0 to 144.0] | 146 | 13.9 [0.0 to 48.3]
% RCTs that did not report the variable | | 2.3 | | 0.5 | | 33.6

ACE = angiotensin converting enzyme; NSAID = nonsteroidal anti-inflammatory drug; RCT = randomized clinical trial

Studies enrolled mostly adults (average age, 38 years) and adolescents (Table 7). Women made up the majority of enrolled subjects (Appendix Table D5). Few trials reported a proportion of obese subjects, but many participants were overweight according to the average body mass index. Most trials included patients with and without aura (Appendix Table D5). Enrolled patients had an average of five monthly migraine attacks. Almost half of the enrolled subjects were naïve to migraine preventive drugs (Table 7). Patient age and baseline migraine characteristics were similar in most trials (Appendix Table D6).

Table 7 Reporting of patient baseline characteristics in randomized controlled clinical trials of migraine prevention drugs in adults

Drugs | # RCTs | Age Mean [Min to Max] | # RCTs | % Female, Mean [Min to Max] | # RCTs | Obesity, BMI Mean [Min to Max] | # RCTs | Baseline Frequency of Migraine/Month Mean [Min to Max] | # RCTs | Duration of Migraine, Years Mean [Min to Max] | # RCTs | % With Aura Mean [Min to Max] | # RCTs | % Naïve to Treatment Mean [Min to Max]
Anti-epileptics | 39 | 39.2 [29.4 to 46.0] | 41 | 76.3 [10.9 to 100.0] | 8 | 27.1 [23.0 to 30.3] | 40 | 6.5 [1.0 to 26.6] | 14 | 13.2 [3.0 to 25.0] | 18 | 24.0 [0.0 to 86.3] | 7 | 43.0 [0.0 to 100.0]
Antidepressants | 17 | 36.6 [31.0 to 44.4] | 19 | 80.0 [63.5 to 92.3] | | Not reported | 2 | 6.0 [5.0 to 7.0] | 2 | 18.4 [16.0 to 20.8] | 8 | 19.2 [0.0 to 45.2] | 2 | 66.7 [0.0 to 100.0]
Beta blockers | 50 | 37.8 [28.6 to 43.5] | 61 | 78.5 [52.0 to 94.5] | 2 | 23.1 [22.8 to 23.4] | 44 | 4.5 [2.0 to 8.4] | 27 | 16.8 [9.0 to 26.0] | 46 | 39.8 [0.0 to 100.0] | 7 | 53.8 [0.0 to 93.2]
ACE inhibitors | 2 | 45.0 [41.0 to 49.0] | 2 | 69.5 [58.0 to 81.0] | | Not reported | 1 | 2.3 | | Not reported | | Not reported | | Not reported
Angiotensin II receptor blockers | 2 | 40.9 [39.8 to 42.0] | 2 | 81.8 [79.0 to 84.5] | 1 | 24.0 | 1 | 6.2 | | 0.0 | | Not reported | | Not reported
Calcium channel blockers | 28 | 35.5 [29.0 to 44.0] | 32 | 73.8 [41.0 to 91.1] | 2 | 23.4 [23.0 to 23.7] | 22 | 5.2 [2.0 to 10.0] | 18 | 14.1 [5.0 to 20.0] | 29 | 25.3 [0.0 to 100.0] | 6 | 54.5 [25.0 to 100.0]
Antiadrenergics | 12 | 37.8 [32.0 to 48.0] | 14 | 77.4 [30.0 to 92.0] | | Not reported | 5 | 5.1 [4.0 to 6.5] | 3 | 16.0 [12.0 to 22.0] | | Not reported | | Not reported
Dopaminergic agents | 2 | 34.3 [33.9 to 34.6] | 3 | 74.4 [71.6 to 76.7] | | Not reported | 3 | 5.3 [4.3 to 6.0] | | Not reported | 3 | 0.0 [0.0 to 0.0] | | Not reported
Ergot alkaloids | 7 | 35.9 [30.0 to 42.0] | 8 | 76.3 [60.0 to 95.0] | 2 | 23.7 [23.1 to 24.2] | 6 | 4.8 [3.0 to 8.5] | 5 | 16.2 [14.2 to 20.0] | 7 | 23.1 [0.0 to 67.5] | 2 | 63.3 [60.0 to 66.7]
NSAIDs | 15 | 39.5 [35.0 to 53.2] | 15 | 73.9 [0.0 to 100.0] | 2 | 25.6 [25.0 to 26.1] | 6 | 4.7 [1.3 to 8.2] | 4 | 17.2 [15.0 to 20.0] | 2 | 4.4 [0.0 to 8.7] | | Not reported
Magnesium | 2 | 42.4 [41.0 to 43.8] | 2 | 89.5 [86.0 to 93.0] | | Not reported | 2 | 5.0 [4.0 to 6.0] | 1 | 4.2 | 2 | 50.0 [0.0 to 100.0] | | Not reported
Nondrug vs. drugs | 4 | 38.9 [37.8 to 40.1] | 4 | 87.9 [78.9 to 100.0] | 1 | 23.5 | 3 | 4.7 [2.0 to 6.3] | 1 | 15.9 | 3 | 38.9 [0.0 to 100.0] | 1 | 46.5 [0.0 to 0.0]
Cortical spreading depression inhibitor | 1 | 36.0 | 1 | 92.3 | | Not reported | | Not reported | | Not reported | | Not reported | 1 | 100.0
Muscle relaxants | 1 | 40.3 | 1 | 79.0 | | Not reported | | Not reported | | Not reported | | Not reported | | Not reported
Montelukast | 1 | 40.0 | 1 | 88.0 | | Not reported | 1 | 5.1 [0.0 to 0.0] | | Not reported | | Not reported | | Not reported
Total | 183 | 37.9 [28.6 to 53.2] | 206 | 77.2 [0.0 to 100.0] | 18 | 25.3 [22.8 to 30.3] | 136 | 5.3 [1.0 to 26.6] | 75 | 15.3 [3.0 to 26.0] | 118 | 30.0 [0.0 to 100.0] | 26 | 53.0 [0.0 to 100.0]
%RCTs that did not report the variable | 17 | | 6 | | 92 | | 38 | | 66 | | 46 | | 88

ACE = angiotensin converting enzyme; BMI = body mass index; NSAID = nonsteroidal anti-inflammatory drug; RCT = randomized clinical trial

Substantial variability in reporting comorbidities prevented us from using this information in quantitative synthesis of evidence. Most trials, however, excluded patients with severe medical comorbidities or psychiatric illnesses, stroke, and vascular migraine. RCTs rarely reported important patient characteristics that could modify drug effects, including family history of migraine, socioeconomic status, or response to prior preventive treatments

## Risk of Bias

More than half of the RCTs had medium risk of bias and about 21 percent had low risk of bias (Table 8). Proportions of RCTs with low risk of bias varied among drugs (Appendix Table D7). Among approved drugs, the percent of low-risk-of-bias RCTs was as follows: topiramate, 45 percent; divalproex, 67 percent; and propranolol, 13 percent (Appendix Table D7). Most RCTs (86 percent) were double blind. Timolol was examined in two RCTs of medium risk of bias. We concluded unclear adequacy of allocation concealment in 94 percent of RCTs and adequacy of randomization in 51 percent of RCTs (Table 8). Planned intention to treat was reported in 24 percent of RCTs.

Table 8 Number of randomized controlled clinical trials of migraine prevention in adults that met risk of bias criteria

Drug Classes | Double Blind | Open Label | Single Blind | Adequate Allocation Concealment | Unclear Allocation Concealment | Adequate Randomization | Not Adequate Randomization | Unclear Adequacy of Randomization | Planned Intention to Treat Analysis | Low Risk of Bias | Medium Risk of Bias | High Risk of Bias | Unclear Risk of Bias | Total
Anti-epileptics | 40 | 3 | 0 | 9 | 34 | 23 | 6 | 14 | 23 | 19 | 22 | 2 | 0 | 43
Antidepressants | 19 | 3 | 0 | 0 | 22 | 14 | 3 | 5 | 3 | 1 | 18 | 3 | 0 | 22
Beta blockers | 59 | 4 | 2 | 1 | 64 | 18 | 2 | 45 | 11 | 8 | 52 | 5 | 0 | 65
ACE inhibitors | 2 | 0 | 0 | 1 | 1 | 0 | 0 | 2 | 1 | 2 | 0 | 0 | 0 | 2
Angiotensin II receptor blockers | 2 | 0 | 0 | 1 | 1 | 0 | 1 | 1 | 1 | 1 | 0 | 1 | 0 | 2
Calcium channel blockers | 29 | 3 | 2 | 0 | 34 | 15 | 4 | 15 | 3 | 2 | 24 | 8 | 0 | 34
Antiadrenergics | 14 | 1 | 0 | 0 | 15 | 1 | 0 | 14 | 1 | 4 | 9 | 1 | 1 | 15
Dopaminergic agents | 3 | 0 | 0 | 0 | 3 | 0 | 1 | 2 | 0 | 0 | 2 | 1 | 0 | 3
Ergot alkaloids | 8 | 1 | 0 | 0 | 9 | 4 | 0 | 5 | 1 | 1 | 8 | 0 | 0 | 9
Muscle relaxants | 1 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1
Montelukast | 1 | 0 | 0 | 0 | 1 | 1 | 0 | 0 | 1 | 1 | 0 | 0 | 0 | 1
NSAIDs | 7 | 9 | 0 | 0 | 16 | 5 | 3 | 8 | 3 | 3 | 10 | 2 | 1 | 16
Magnesium | 3 | 0 | 0 | 0 | 3 | 2 | 1 | 0 | 2 | 2 | 0 | 1 | 0 | 3
Nondrugs compared with drugs | 0 | 3 | 1 | 2 | 2 | 3 | 1 | 0 | 3 | 1 | 2 | 1 | 0 | 4
Total | 188 | 27 | 5 | 14 | 206 | 87 | 22 | 111 | 53 | 45 | 148 | 25 | 2 | 220
Percent | 85.5 | 12.3 | 2.3 | 6.4 | 93.6 | 39.5 | 10.0 | 50.5 | 24.1 | 20.5 | 67.3 | 11.4 | 0.9

ACE = angiotensin converting enzyme; NSAID = nonsteroidal anti-inflammatory drug

Published RCTs rarely presented subject flows. Nor did RCTs report why some eligible subjects were not randomized and therefore excluded from the trials. Proportions of eligible subjects excluded from randomization varied among trials. Investigators excluded an average of 5 percent of randomized subjects from the analyses, with substantial variability among the drugs.

## Key Question 1 What is the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in adults?

Results from RCTs were available in 245 references. RCTs examined four approved drugs for episodic migraine (topiramate, divalproex, propranolol, and timolol), one approved drug for chronic migraine (onabotulinumtoxin A), and various off-label preventive drugs. Most trials examined a monotherapy with one active agent compared with placebo or to another drug. RCTs rarely reported exact drugs and doses of concomitant treatments. However, we surmise there were no concomitant treatments because most trials disallowed concomitant drugs during the run-in period and after randomization. Strength of evidence was low due to medium or high risk of bias and imprecise estimates from individual or meta-analyzed RCTs.

### KQ1a How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared with placebo or no active treatment?

All approved drugs were better than placebo in reducing monthly migraine frequency by ≥50 percent in patients with episodic migraine and baseline <15 migraine days per month (clinical response). The relative effect of drugs was moderate: drugs resulted in clinical response in 200 to 400 patients per 1,000 treated. Clinicians need to treat three to five patients with episodic migraine to prevent half or more migraine attacks in one patient.

Strength of evidence was lowered due to medium risk of bias and imprecise estimates. Low-strength evidence from individual RCTs suggested a dose-responsive increase in migraine prevention with higher doses of onabotulinumtoxin A and topiramate (from 50–100 mg/day with no additional benefits with 200 mg/day).

Among off-label drugs, pooled analyses offered low-strength evidence that antiepileptic gabapentin, beta-blocker metoprolol, and calcium channel blocker nimodipine were better than placebo in reducing monthly migraine attacks by ≥50 percent. Individual RCTs offered low-strength evidence that off-label beta blockers, acebutolol atenolol and nadolol, were better than placebo in reducing monthly migraine attacks by ≥50 percent. Individual RCTs demonstrated that the angiotensin converting enzyme inhibitors captopril and lisinopril and the angiotensin II antagonist candesartan were better than placebo in reducing monthly migraine attacks by ≥50 percent.

We present strength of evidence for patient-centered outcomes, including complete migraine cessation (Table 9) and migraine prevention with approved (Table 10) and off-label drugs (Tables 11 and 12).

Table 9 100% reduction in monthly migraine frequency with pharmacologic preventive treatments versus placebo in adults with episodic migraine, results from randomized controlled clinical trials

Active Drug, Weeks From Randomization to Time to Measure Outcome | References | Sample | % With Outcome in Active [Placebo] | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed to Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Risk of Bias | Directness | Consistency | Precision | Strength of Evidence
Topiramate, 16–26 weeks | Pooled Bussone, 2005^84^ Silberstein 2006^85^ Silberstein, 2009^86^ | 1299 | 5.1 [2.6] | 1.9 (1.0 to 3.4) | 0.02 (−0.01 to 0.05) | NS | NS | Medium | Yes | No | No | Low
Topiramate, 16–26 weeks | p value | | | 0.499 | 0.067
Topiramate, 16–26 weeks | I squared | | | 0.00% | 63.00%
Gabapentin 17 weeks of treatment | NCT00742209, 2010^87^ | 82 | 25.8 [20.9] | 1.3 (0.5 to 3.4) | 0.06 (−0.15 to 0.26) | NS | NS | Low | Yes | Not applicable | Imprecise | Low
Captopril 32 weeks of treatment | Minervini, 1987 88 | 24 | 66.7 [0.0] | 17.0 (1.1 to 265.0) | 0.67 (0.39 to 0.95) | 1 (1 to 3) | 667 (388 to 946) | Low | Yes | Not applicable | Imprecise | Low
Nimodipine 12 weeks of treatment | Gelmers, 1983 89 | 60 | 50.0 [6.7] | 7.5 (1.9 to 30.0) | 0.43 (0.23 to 0.63) | 2 (2 to 4) | 433 (233 to 633) | Medium | Yes | Not applicable | Imprecise | Low
Dihydroergotamine 20 weeks of treatment | Pradalier, 2004^90^ | 384 | 37.5 [30.0] | 1.3 (0.9 to 1.7) | 0.08 (−0.02 to 0.17) | NS | NS | Low | Yes | Not applicable | Imprecise | Low
Indomethacin 4 weeks of treatment | Anthony, 1968^91^ | 38 | 5.3 [10.5] | 0.5 (0.0 to 5.1) | −0.05 (−0.22 to 0.12) | NS | NS | Medium | Yes | Not applicable | Imprecise | Low

Bold = significant differences when 95% CI of absolute risk differences do not include 0; CI = confidence interval; NS = not significant;

Number needed to treat and number of attributable events were calculated for statistically significant differences

Table 10 Migraine prevention with approved pharmacologic treatments versus placebo in adults, results from randomized controlled clinical trials (pooled with random effects models)

Active Drug | References | Sample | % With Outcome With Active Drug [Placebo] | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed to Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Risk of Bias | Direct | Consistency | Precision | Strength of Evidence
Chronic Migraine
Onabotulinumtoxin A ≥50% decrease in migraine frequency | Pooled92–94 | 459 | 50.6 [34.4] | 1.5 (1.2 to 1.8) | 0.17 (0.08 to 0.26) | 6 (4 to 12) | 170 (82 to 258) | Medium | Yes | Yes | No | Low
Onabotulinumtoxin A ≥50% decrease in migraine frequency | p value | | | 0.7 | 0.9
Onabotulinumtoxin A ≥50% decrease in migraine frequency | I squared | | | 0.00% | 0.00%
Episodic Migraine
Topiramate 100% reduction in migraine frequency | Pooled84–86 | 1299 | 5.1 [2.6] | 1.9 (1.0 to 3.4) | 0.02 (−0.01 to 0.05) | NS | NS | Medium | Yes | No | No | Low
Topiramate 100% reduction in migraine frequency | p value | | | 0.499 | 0.067
Topiramate 100% reduction in migraine frequency | I squared | | | 0.00 | 0.63
Topiramate on >50% reduction on migraine frequency | Pooled84,85, 95–99 | 1422 | 49.6 [25.1] | 2.0 (1.5 to 2.7) | 0.29 (0.18 to 0.40) | 3 (3 to 6) | 288 (176 to 400) | Medium | Yes | Yes | Yes | Moderate
Topiramate on >50% reduction on migraine frequency | P value | | | 0.036 | 0.001
Topiramate on >50% reduction on migraine frequency | I squared | | | 0.555 | 0.736
Topiramate on >50% reduction on migraine days | Pooled84,86, 100 | 1145 | 42.2 [23.3] | 1.7 (1.0 to 2.9) | 0.18 (0.08 to 0.28) | 6 (4 to 13) | 179 (75 to 284) | Low | Yes | Yes | No | Moderate
Topiramate on >50% reduction on migraine days | P value | | | 0.012 | 0.042
Topiramate on >50% reduction on migraine days | I squared | | | 0.772 | 0.684
Topiramate on ≥75% reduction in migraine days | Pooled84,86 | 1086 | 22.3 [11.0] | 1.9 (1.1 to 3.1) | 0.10 (−0.01 to 0.20) | NS | NS | Low | Yes | Yes | No | Moderate
Topiramate on ≥75% reduction in migraine days | P value | | | 0.123 | 0.026
Topiramate on ≥75% reduction in migraine days | I squared | | | 0.58 | 0.797
Divalproex | Pooled101–103 | 405 | 43.0 [23.3] | 2.2 (1.1 to 4.2) | 0.24 (0.10 to 0.38) | 4 (3 to 10) | 241 97 to 384) | Medium | Yes | Yes | No | Low
Divalproex | P value | | | 0.123 | 0.098
Divalproex | I squared | | | 0.523 | 0.569
Propranolol | Pooled104–107 | 541 | 45.1 [22.3] | 2.0 (1.5 to 2.7) | 0.22 (0.14 to 0.30) | 4 (3 to 7) | 223 (142 to 304) | Medium | Yes | Yes | No | Low
Propranolol | P value | | | 0.995 | 0.936
Propranolol | I squared | | | 0 | 0
Timolol 100% reduction in migraine frequency | Single RCT108 | 28 | 14.3 [0.0] | 5.0 (0.3 to 95.6) | 0.14 (−0.07 to 0.35) | NS | NS | Medium | Yes | Not applicable | No | Low
Timolol ≥50% reduction in migraine frequency | Pooled104, 107,109 | 276 | 49.4 [23.3] | 2.1 (1.5 to 3.1) | 0.27 (0.15 to 0.38) | 4 (3 to 6) | 265 (154 to 377) | Medium | Yes | Yes | No | Low
Timolol ≥50% reduction in migraine frequency | P value | | | 0.732 | 0.606
Timolol ≥50% reduction in migraine frequency | I squared | | | 0 | 0

Bold = significant differences when 95% CI of absolute risk difference do not include 0; CI = confidence interval; RCT = randomized controlled trial; NS = not significant;

Number needed to treat and number of attributable events were calculated for statistically significant differences

Table 11 Migraine prevention with pharmacologic treatments versus placebo in adults with episodic migraine (pooled with random effects model results from randomized controlled clinical trials)

Active Drug | References | Sample | % With Outcome With Active Drug [Placebo] | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed to Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Risk of Bias | Direct | Consistency | Precision | Strength of Evidence
Gabapentin | Pooled87,110,111 | 270 | 45.9 [31.0] | 1.5 (1.1 to 2.0) | 0.17 (0.06 to 0.27) | 6 (4 to 16) | 165 (61 to 269) | Medium | Yes | Yes | No | Low
Gabapentin | P value | | | 0.487 | 0.847
Gabapentin | I squared | | | 0 | 0
Metoprolol | Pooled89,112–114 | 225 | 39.9 [19.4] | 2.0 (1.3 to 3.2) | 0.20 (0.09 to 0.3) | 5 (3 to 11) | 204 (88 to 321) | Medium | Yes | Yes | No | Low
Metoprolol | P value | | | 0.415 | 0.385
Metoprolol | I squared | | | 0 | 0
Nimodipine | Pooled89,112 | 126 | 28.6 [6.3] | 4.5 (0.5 to 40.1) | 0.23 (0.06 to 0.39) | 4 (3 to 16) | 229 (64 to 394) | Medium | Yes | No | No | Low
Nimodipine | P value | | | 0.125 | 0.194
Nimodipine | I squared | | | 0.576 | 0.407
Magnesium | Pooled115,116 | 137 | 33.8 [25.8] | 1.3 (0.7 to 2.3) | 0.08 (−0.09 to 0.26) | NS | NS | Low | Yes | No | No | Low
Magnesium | P value | | | 0.268 | 0.248
Magnesium | I squared | | | 0.186 | 0.251

CI = confidence interval; NS= not significant

Number needed to treat and number of attributable events were calculated for statistically significant differences

Bold = significant differences when 95% CI of absolute risk difference do not include 0.

Table 12 Migraine prevention (50% or more reduction) with off-label pharmacologic treatments versus placebo in adults with episodic migraine, results from individual randomized controlled clinical trials

Active Drug, Weeks From Randomization to Time to Measure Outcome | Reference | Sample | % With Outcome With Active Drug [Placebo] | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed to Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Risk of Bias | Direct | Consistency | Precision | Strength of Evidence
Acetazolamide 12 weeks | Vahedi, 2002^117^ | 53 | 30.8 [33.3] | 0.9 (0.4 to 2.0) | −0.03 (−0.28 to 0.23) | NS | NS | Low | Yes | NA | Imprecise | Low
Carbamazepin 6 weeks | Rompel, 1970 118 | 96 | 54.2 [10.4] | 5.2 (2.2 to 12.4) | 0.44 (0.27 to 0.60) | 2 (2 to 4) | 438 (272 to 603) | Medium | Yes | NA | Imprecise | Low
Lamotrigine 20 weeks | Gupta, 2007^99^ | 120 | 46.0 [34.0] | 1.4 (0.9 to 2.2) | 0.13 (−0.04 to 0.31) | NS | NS | Low | Yes | NA | Imprecise | Low
Oxcarbazepine 15 weeks | Silberstein, 2008^119^ | 170 | 32.9 [36.5] | 0.9 (0.6 to 1.4) | −0.04 (−0.18 to 0.11) | NS | NS | Low | Yes | NA | Imprecise | Low
Valproate 12 weeks | Jensen, 1994 120 | 86 | 39.5 [14.0] | 2.8 (1.2 to 6.5) | 0.26 (0.08 to 0.43) | 4 (2 to 13) | 256 (77 to 435) | Medium | Yes | NA | Imprecise | Low
Acebutolol 12 weeks | Nanda, 1978 121 | 86 | 30.2 [4.7] | 6.5 (1.6 to 27.1) | 0.26 (0.10 to 0.41) | 4 (2 to 10) | 256 (105 to 407) | Medium | Yes | NA | Imprecise | Low
Alprenolol 6 weeks | Ekbom, 1975^122^ | 66 | 33.3 [36.4] | 0.9 (0.5 to 1.8) | −0.03 (−0.26 to 0.20) | NS | NS | Medium | Yes | NA | Imprecise | Low
Atenolol 12 weeks | Forssman, 1983 123 | 48 | 33.3 [0.0] | 17.0 (1.0 to 278.9) | 0.33 (0.14 to 0.53) | 3 (2 to 7) | 333 (140 to 527) | Medium | Yes | NA | Imprecise | Low
Nadolol 12 weeks | Freitag, 1984 124 | 32 | 25.0 [0.0] | 4.7 (0.3 to 75.0) | 0.25 (0.02 to 0.48) | 4 (2 to 45) | 250 (22 to 478) | Low | Yes | NA | Imprecise | Low
Amitriptyline 16 weeks | Couch, 2011^125^ | 391 | 24.2 [24.4] | 1.0 (0.7 to 1.4) | 0.00 (−0.09 to 0.08) | NS | NS | Medium | Yes | NA | Imprecise | Low
Amitriptyline 4 weeks (≥75% improvement in headache) | Couch, 1976 126 | 73 | 43.2 [19.4] | 2.2 (1.0 to 4.8) | 0.24 (0.03 to 0.44) | 4 (2 to 31) | 238 (33 to 443) | Medium | Yes | NA | Imprecise | Low
Tonabersat 12 weeks | Goadsby, 2009^127^ | 124 | 40.7 [36.9] | 1.1 (0.7 to 1.7) | 0.04 (−0.13 to 0.21) | NS | NS | Low | Yes | NA | Imprecise | Low
Lisinopril 12 weeks | Schrader, 2001^128^ | 120 | 23.3 [0.0] | 29.0 (1.8 to 475.4) | 0.23 (0.12 to 0.34) | 4 (3 to 8) | 233 (124 to 343) | Low | Yes | NA | Imprecise | Low
Candesartan 12 weeks | Tronvik, 2003^129^ | 120 | 38.3 [3.3] | 11.5 (2.8 to 46.6) | 0.35 (0.22 to 0.48) | 3 (2 to 5) | 350 (219 to 481) | Low | Yes | NA | Imprecise | Low
Nifedipine 4 weeks | Shukla, 1995^130^ | 72 | 55.6 [11.1] | 5.0 (1.9 to 13.2) | 0.44 (0.25 to 0.64) | 2 (2 to 4) | 444 (252 to 637) | Medium | Yes | NA | Imprecise | Low
Dihydroergotamine 20 weeks | Pradalier, 2004^90^ | 384 | 60.9 [56.0] | 1.1 (0.9 to 1.3) | 0.05 (−0.05 to 0.15) | NS | NS | Low | Yes | NA | Imprecise | Low
Lisuride 12 weeks | Somerville, 1976^131^ | 150 | 37.3 [25.3] | 1.5 (0.9 to 2.4) | 0.12 (−0.03 to 0.27) | NS | NS | Medium | Yes | NA | Imprecise | Low
Flurbiprofen 8 weeks | Solomon, 1993^132^ | 46 | 69.6 [30.4] | 2.3 (1.2 to 4.5) | 0.39 (0.13 to 0.66) | 3 (2 to 8) | 391 (125 to 657) | Medium | Yes | NA | Imprecise | Low
Indomethacin 4 weeks | Anthony, 1968^91^ | 38 | 31.6 [26.3] | 1.2 (0.4 to 3.3) | 0.05 (−0.24 to 0.34) | NS | NS | Medium | Yes | NA | Imprecise | Low
Rofecoxib 12 weeks | Visser, 2004^133^ | 175 | 22.0 [9.5] | 2.3 (1.1 to 5.0) | 0.12 (0.02 to 0.23) | 8 (4 to 53) | 125 (19 to 230) | Medium | Yes | NA | Imprecise | Low
Tolfenamic Acid 10 weeks | Mikkelsen, 1982^134^ | 62 | 45.2 [6.5] | 7.0 (1.7 to 28.3) | 0.39 (0.19 to 0.58) | 3 (2 to 5) | 387 (192 to 582) | Medium | Yes | NA | Imprecise | Low
Aspirin 240 weeks (ever having migraine attack) | Buring, 1990^135^ | 22071 | 6.0 [7.4] | 0.8 (0.7 to 0.9) | −0.01 (−0.02 to −0.01) | −70 (48 to 131) | −14 (8 to 21) | Low | Yes | NA | Imprecise | Low
Montelukast 12 weeks | Brandes, 2004^136^ | 177 | 24.2 [21.8] | 1.2 (0.7 to 2.0) | 0.0 (−0.09 to 0.16) | NS | NS | Low | Yes | NA | Imprecise | Low

CI = confidence interval; NA = Not applicable; NS= not significant

Number needed to treat and number of attributable events were calculated for statistically significant differences

Bold = significant differences when 95% CI of absolute risk difference do not include 0.

Only a few RCTs examined quality of life, and they provided no consistent evidence of improvement with examined drugs. The studies rarely assess clinical importance of the changes in quality of life or disability scales. We describe those effects as well as changes in intermediate outcomes in the text and appendix tables.

#### Prevention of Chronic Migraine

##### Muscle Relaxants

###### Onabotulinumtoxin A

We identified 15 RCTs that examined the efficacy of botulinum toxin for migraine prevention; 13 RCTs examined onabotulinumtoxin A and two RCTs examined abobotulinumtoxin A (Appendix Table D8). The studies enrolled an average of 285 patients aged 18 to 65 years with four to 12 migraine attacks/month. Most trials included patients with 10 or more years of migraine experience. Women made up 85 percent of participants. More than half of enrolled patients had been previously treated with preventive medications for migraine. Most RCTs were industry funded and reported conflict of interest by study investigators (Appendix Table D9). All RCTs were double blind and most had low risk of bias (Appendix Table D10).

Onabotulinumtoxin A was better than placebo in reducing monthly migraine attacks by ≥50 percent (three RCTs of 459 adults, low-strength evidence) (Appendix Table D11).92–94 Onabotulinumtoxin A tended to increase the likelihood of ≥50 percent reduction in migraine frequency compared with placebo in all RCTs (Appendix Table D12). Pooled relative increase by 50 percent achieved statistical significance (pooled RR 1.5, 95% CI, 1.2 to 1.8). Pooled analyses demonstrated that 170 adults per 1,000 treated (95% CI, 82 to 258) would experience ≥50 percent reduction in migraine frequency with onabotulinumtoxin A (Table 10). No RCTs of abobotulinumtoxin A reported rates of ≥50 percent reduction in monthly migraine attacks.

A reduction in migraine days was considered as a primary outcome in the Phase III Research Evaluating Migraine Prophylaxis Therapy (PREEMPT) RCT that reported statistically significant reduction in frequency of headache days relative to 20 headache days at baseline (−9.0 days with onabotulinumtoxin A versus −6.7 days with placebo, p < .001).137 The same trial reported a statistically significant reduction in frequency of migraine days relative to 19 migraine days at baseline (mean difference with placebo −2.4 with 95% CI −3.3 to −1.4).137 We could not pool the results from other RCTs that examined a reduction in migraine days or hours because the trials failed to report data needed for reproducible results.137–139

For intermediate outcomes, the absolute number of migraine attacks did not differ between onabotulinumtoxin A and placebo (Appendix Table D13). Improvement in migraine severity was inconsistent across four RCTs (Appendix Table D14).92,139–141 Improvement in migraine disability assessment was inconsistent across two RCTs (Appendix Table D14).93,142 A single RCT of patients who had not benefitted from previous oral prophylactic treatment demonstrated significant improvement in most domains of quality of life as assessed by the Migraine Impact Questionnaire (Appendix Table D14).142 The PREEMPT clinical program RCT demonstrated statistically significant improvement in all domains of the Migraine-Specific Quality of Life Questionnaire.143 Significant improvement was demonstrated in global assessment, severity of migraine symptoms, self-management of migraine, and ability to work and participate in recreational activities (Appendix Table D14).142

In our separate analysis of RCTs of abobotulinumtoxin A we found inconsistent effects on patient global evaluation of treatment success. The Dysport Migraine Study Group reported a statistically significant increase in patient’s global evaluation of treatment efficacy.144 Slightly or much improved migraine frequency was reported in 281 patients per 1,000 treated (95% CI 46 to 516).144 In contrast, the Dysport^®^ In Migraine Without Aura Prophylaxis trial found no differences in patient or investigators’ perception of global assessment with the active drug versus placebo.139 Neither trial showed statistically significant reduction in absolute number of migraine attacks with abobotulinumtoxin A versus placebo.139,144

###### Tizanidine

Tizanidine was better than placebo in reducing migraine severity (one RCT of 136 adults) but had no effect on migraine frequency.145

##### Antiepileptics

The Topiramate Chronic Migraine Study Group RCT offered low-strength evidence that topiramate was better than placebo in reducing from baseline monthly migraine days, rates of 25 percent reduction in monthly migraine attacks, and frequency of associated symptoms.86,146,147 Topiramate was not better than placebo in reducing monthly migraine attacks by ≥50 percent.86 Topiramate did not decrease treatment discontinuation due to failure.146

The drug improved quality of life and migraine related disability in adult with chronic migraine. We estimated that 133 patients (95% CI, 27 to 239) per 1,000 treated would experience improvement in quality of life measured using the SGIC instrument (Subject’s Global Impression of Change). We estimated that 72 patients (95% CI, 7 to 137) per 1,000 treated experienced reduction in migraine related disability.147 Improvement in disability scale score was large and clinically important.100

#### Prevention of Episodic Migraine

##### Antiepileptics

###### Topiramate

Individual RCTs and two pooled analyses of individual patient data from RCTs examined efficacy of topiramate versus placebo for migraine prevention in adults (Appendix Table D15). Most trials were funded by industry (Appendix Table D16). All trials were double blind and most had low risk of bias (Appendix Table D17).

Topiramate was not better than placebo in achieving complete cessation of migraine (Table 9).84–86 Topiramate in doses of 50, 100, or 200 mg/day was better than placebo in reducing monthly migraine frequency by ≥50 percent (Table 10 and Appendix Table D18). The results were consistent across the studies and robust regardless of pooling methods (Appendix Table D19). Topiramate was also better than placebo in reducing monthly migraine days by ≥50 percent (Table 10). Topiramate tended to reduce treatment discontinuation due to lack of efficacy with borderline statistical significance in pooled analyses (pooled absolute risk difference −0.04 95% CI −0.07 to 0).84,85,96,99,146,148–150

Topiramate, 100 mg/day, decreased the absolute number of migraine days by 5 days/month in pooled analyses of RCTs (Appendix Table D20). The reduction in migraine severity scores was inconsistent across the studies (Appendix Table D21). Individual RCTs demonstrated significant improvement in quality of life as measured by scores on the Headache Impact Test,149 Migraine Specific Questionnaire,151 and Migraine Disability Assessment100 (Appendix Table D22). Topiramate was better than placebo in improving general health status in a previously published pooled analysis of individual patient data from RCTs (Appendix Table D23).152 Medical Outcome Study Short Form 36 (SF-36) scores improved by more than 200 percent for self-reported vitality and more than 100 percent for pain and general health (Appendix Table D23).152

Topiramate was better than placebo in reducing use of acute drugs (Appendix Table D24). Most individual RCTs demonstrated a small but significant reduction in the number of medications taken or in the reduction of days when drugs for acute attacks were needed (Appendix Table D24).

###### Divalproex

Three RCTs examined the efficacy of divalproex for migraine prevention in adults (Appendix Table D25).101–103 All three RCTs were funded by industry (Appendix Table D26) and all were double blind (Appendix Table D27).

Divalproex was better than placebo in reducing monthly migraine frequency by ≥50 percent (Table 10 and Appendix Table D28).101,102 A larger dose of divalproex (1500 mg/day) was effective in achieving a ≥50 percent reduction in migraine-related effects, including impairment of usual activities, need for symptomatic medication, and nausea, vomiting, phonophobia, or photophobia (Appendix Table D29).103 Evidence was low-strength due to imprecise treatment effects.103

###### Valproate

Small RCTs examined the efficacy of valproate for migraine prevention in adults (Appendix Table D25).120,153 The trials were double blind and had medium risk of bias because the investigators did not use planned intention-to-treat principles (Appendix Table D27).

Valproate was better than placebo in reducing monthly migraine frequency by ≥50 percent (Table 12).120 We estimated that 256 patients per 1,000 treated (95% CI, 77 to 435) would experience clinically important reduction in migraine attacks attributable to valproate.120 Valproate decreased the frequency of migraine attacks and severe attacks,153 duration of attacks,153 and the use of drugs for acute attacks120 (Appendix Table D30).

##### Beta Blockers

###### Propranolol

Most RCTs that examined the efficacy of propranolol versus placebo for migraine prevention in adults (Appendix Table D31) failed to report funding sources (Appendix Table D32). All trials were double blind but did not analyze the data according to planned intention-to-treat principles (Appendix Table D33).

Propranolol was better than placebo in reducing migraine monthly frequency by ≥50 percent (Table 10 and Appendix Table D34). The preventive effects of propranolol were consistent across the studies (Appendix Table D35). Propranolol caused a small but significant decrease in the absolute number of monthly migraine attacks (mean difference −1, 95% CI, −2 to −0.3).104, 105, 154,155 A single RCT demonstrated that propranolol decreased use of drugs for acute attacks, both analgesics (mean difference −0.3, 95% CI, −0.4 to −0.1 doses per patient day) and the acute drug ergotamine (mean difference −0.1, 95% CI, −0.3 to −0.1 doses per patient day).156

###### Timolol

Timolol was not better than placebo in achieving complete migraine cessation (Table 9).108 Timolol was better than placebo in reducing migraine monthly frequency by ≥50 percent (Table 10 and Appendix Table D36).104,107,109 Evidence was low-strength due to medium risk of bias and estimate imprecision (Appendix Table D37) Timolol also decreased absolute number of migraine attacks and severity of headaches (Appendix Table D38).

##### Off-Label Drugs

###### Off-Label Antiepileptic Drugs

Most RCTs that examined six off-label antiepileptic drugs: acetazolamide, gabapentin, vigabatrin, oxcarbazepine, carbamazepin, and lamotrigine (Appendix Table D39) were sponsored by industry (Appendix Table D40), and all were double blind (Appendix Table D41).

Gabapentin was not better than placebo in achieving complete cessation of migraine attacks (Table 9).87 Gabapentin was, however, better than placebo in reducing monthly migraine attacks by ≥50 percent (Table 11).87,110,111 Individual RCTs found that carbamazepin118 but not oxcarbazepine119 and acetazolamide117 were better than placebo in preventing migraine attacks (Table 11).

In addition to off-label antiepileptic drugs examined in RCTs, pregabalin was examined in one open-label uncontrolled trial.157 Pregabalin was associated with a significant decrease from baseline in headache frequency and severity and with global improvement defined as ≥50 in visual analog scale (VAS) score in 40 percent of patients.157

###### Beta Blockers

Most RCTs that examined the effects of off-label beta blockers versus placebo for migraine prevention in adults (Appendix Table D42) failed to report funding and conflict of interest (Appendix Table D43). All trials were double blind with medium risk of bias because the investigators did not use planned intention-to-treat principles (Appendix Table D44).

###### Metoprolol

Metoprolol was better than placebo in improving patient perception of marked reduction in migraine attacks (Appendix Tables D45).113,114 Pooled analysis found a significant increase in the likelihood of a clinical response (Appendix Table D46)113,114 but no effect on absolute number of migraine attacks (Appendix Table D47).113,114,158

Metoprolol reduced severity of migraine attacks in a single RCT (Appendix Table D48).114 Regarding use of drugs for acute attacks, evidence with metoprolol was mixed; one trial reported reduced use of such drugs and a second reported increased use of analgesics (Appendix Table D47).113,114

###### Atenolol

Atenolol was better than placebo in reducing monthly migraine attacks by ≥50 percent (Table 12 and Appendix Table D46).159 Atenolol significantly reduced use of ergotamine drugs in a single RCT (Appendix Table D46).159

###### Nadolol

Nadolol was better than placebo in reducing monthly migraine attacks by ≥50 percent (Table 12).124 In a single RCT, nadolol improved perceived relief in frequency, intensity, and severity of migraine attacks (Appendix Table D46).124

###### Alprenolol

Alprenolol was not better than placebo in achieving perceived treatment success (Table 12 and Appendix Table D46).122 Alprenolol did not reduce the absolute number of monthly migraine attacks or Headache Index scores (Appendix Table D47).122

###### Pindolol

Pindolol was not better than placebo in reducing headache indices by ≥50 percent (Appendix Table D48).160 Pindolol did not reduce the absolute number of monthly migraine attacks or Headache Index scores (Appendix Table D47).160

###### Acebutolol

Acebutolol was better than placebo in achieving patient perception of clinical response (Table 12).121

##### Antidepressants

Most RCTs that examined the effectiveness of off-label antidepressants for migraine prevention in adults (Appendix Table D49) were sponsored by industry (Appendix Table D50). Most trials were double blind with medium risk of bias (Appendix Table D51).

###### Amitriptyline

Amitriptyline was better than placebo in reducing monthly migraine attacks by ≥75 percent (Table 12).126 RCTs demonstrated inconsistent improvement in migraine days and intensity.126,161

###### Fluoxetine

Fluoxetine was not better than placebo in achieving an excellent self-reported clinical response.162 Improvement in pain indexes was inconsistent in RCTs.162–164

###### Venlafaxine

Venlafaxine in a dose of 150 but not 75 mg/day was better than placebo in achieving an excellent self-reported clinical response.165

###### Femoxetine

Femoxetine was not better than placebo in achieving patient satisfaction with treatment effect or migraine frequency and severity.166–168

###### Mianserin

Mianserin was not better than placebo in improving migraine index or reducing migraine frequency.169

##### Cortical Spreading Depression Inhibitor

###### Tonabersat

Tonabersat (one RCT of 124 adults, low strength of evidence) (Table 12) was not better than placebo in reducing monthly migraine attacks by ≥50 percent.127

##### Calcium Channel Antagonists

Most RCTs that examined calcium channel blockers for migraine prevention in adults (Appendix Table D52) were sponsored by industry and failed to disclose conflict of interest (Appendix Table D53). All trials were double blind, with medium risk of bias (Appendix Table D54).

###### Nimodipine

Nimodipine was better than placebo in complete cessation of migraine attacks (Table 9)89 Nimodipine was better than placebo in reducing monthly migraine attacks by ≥50 percent (Table 11).89,112

###### Nicardipine

Nicardipine was better than placebo in reducing migraine intensity and absolute number of migraine attacks.170

###### Verapamil

Verapamil was better than placebo in reducing composite migraine score and achieving patient satisfaction.171,172 Verapamil also reduced use of drugs for acute attacks.171

##### Angiotensin Converting Enzyme Inhibitors

Two RCTs examined the effects of ACE inhibitors for migraine prevention in adults (Appendix Table D55).88,128 One industry-funded RCT examined lisinopril (Appendix Table D56).128 One RCT of captopril reported neither funding source nor conflict of interest.88 Both trials were double blind with low risk of bias (Appendix Table D57).

###### Captopril

Captopril was examined in one small RCT that enrolled adults with comorbid hypertension and depressive symptoms for whom drugs had previously failed to prevent migraines.88 Captopril was better than placebo in achieving complete cessation of migraine (Table 9) and improvement in Headache Index scores by more than 60 percent.88 The effect was large. We estimated that 667 patients per 1,000 treated experienced no migraine (95% CI, 388 to 946).88 Captopril was also better than placebo in reducing depression symptoms.88

###### Lisinopril

Lisinopril was better than placebo in reducing migraine days and severity of symptoms in a single RCTs of 60 adults with episodic migraine.128 Lisinopril also reduced the absolute number of migraine days and body pain measured with SF-36 but did not decrease use of drugs for acute attacks.128

##### Angiotensin II Receptor Antagonists

Two RCTs examined the effects of angiotensin II receptor antagonists for migraine prevention in adults (Appendix Table D55).129,173 Both trials were funded by industry and reported conflict of interest (Appendix Table D56).129,173 Both trials were double blind (Appendix Table D57).

###### Candesartan

Candesartan was better than placebo in achieving ≥50 percent reduction in migraine days, hours, and severity (Table 12).129 Candesartan also decreased migraine-related disability but had no effect on use of drugs for acute attacks.129

###### Telmisartan

Telmisartan was not better than placebo in reducing monthly migraine days by ≥50 percent.173 Telmisartan reduced the absolute number of migraine days but had no effect on use of drugs for acute attacks.173

##### Antiadrenergics

###### Clonidine

Most RCTs that examined clonidine for its effects on migraine prevention in adults (Appendix Table D58) failed to report funding and conflict of interest (Appendix Table D59). Most trials were double blind but did not use intention-to-treat principles (Appendix Table D60).

Clonidine was better than placebo in ≥50 percent reduction in headache index174 but not in increasing the number of patients considered better according to self-reported global assessment.175 Clonidine also failed to achieve clinically noticeable reduction in migraine frequency.176 Clonidine was better than placebo in reducing migraine duration177 and use of drugs for acute attacks.178

###### Guanfacine

Guanfacine was better than placebo in reducing monthly migraine days and migraine days with nausea or vomiting in one small RCT.179

##### Ergot Alkaloids

All RCTs that examined effectiveness of ergot alkaloids for migraine prevention in adults (Appendix Table D61) failed to report funding and conflict of interest (Appendix Table D62). Most trials were double blind with medium risk of bias (Appendix Table D63).

###### Dihydroergotamine

Dihydroergotamine was not better than placebo in achieving complete cessation of migraine attacks90 (Table 9) or in reducing monthly migraine attacks by ≥50 percent (Table 12).90

##### Leukotriene Receptor Antagonists

###### Montelukast

Montelukast was not better than placebo in reducing monthly migraine attacks by ≥50 percent.136

##### Nonsteroid Anti-Inflammatory Drugs

Individual RCTs demonstrated that aspirin, flurbiprofen, rofecoxib, and tolfenamic acid were better than placebo in reducing migraine frequency by ≥50 percent (Table 12).

##### Antipsychotic Drugs

Published RCTs did not examine antipsychotic drugs for migraine prevention. Quetiapine was examined in one uncontrolled trial of refractory migraine, defined as migraine that was previously unresponsive to the combination of atenolol, nortriptyline, and flunarizine.180 Adult patients with <15 days of headache per month who were not overusing drugs for acute attacks were treated with quetiapine (75mg/day) for 10 weeks. Reduction in migraine frequency by ≥50 percent was achieved in 65 percent of the patients.180 Patients also experienced a significant reduction in migraine days (from 10.2 to 6.2 per month), and use of drugs for acute attacks (from 2.3 to 1.2 days/week).180

##### Antidementia Drugs

Published RCTs did not examine antidementia drugs. Retrospective review of case series and case reports demonstrated that with memantine treatment, 60 percent of the patients experienced ≥50 percent reduction in monthly migraine frequency, and 80 percent experienced a significant reduction in frequency of aura.181,182

### KQ1b How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared with active pharmacologic treatments?

Individual RCTs provided low-strength direct evidence about the comparative effectiveness of drugs and demonstrated few significant differences. Indirect adjusted analysis demonstrated no differences between approved drugs and greater odds of clinical response with the angiotensin II antagonist candesartan.

Exploratory network Bayesian meta-analyses demonstrated that approved drugs were similarly better than placebo. Among off-label drug classes; however, angiotensin inhibiting drugs demonstrated the largest significant odds of reducing monthly migraine by ≥50 percent.

#### Approved Drugs

##### Muscle Relaxants for Chronic Migraine

###### Onabotulinumtoxin A

Five RCTs of 350 adults examined comparative effectiveness of onabotulinumtoxin A versus other drugs for migraine prevention (Appendix Table D64). Trials enrolled an average of 70±18 patients ages 18 to 65. Subjects experienced 12 to 24 monthly migraine days. Women made up 91 percent of enrollees. Trials were funded by industry183,184 or grants,185 with most investigators disclosing conflict of interest (Appendix Table D65). All RCTs but one185 were double blind, with medium or high risk of bias due to inadequacy of randomization or unplanned intention-to-treat analyses (Appendix Table D66). The trials often concluded that both active treatments were successful based on statistically significant reduction from baseline in absolute number of migraine days or hours.

We focus on differences in outcomes at the end of the treatment with active and control drugs.

Comparative effectiveness of onabotulinumtoxin A versus topiramate was examined in two RCTs that found no significant differences in likelihood of migraine prevention or improvement in migraine disability assessment (Appendix Table D67).183,186 Physicians found marked improvement in migraine frequency more often with topiramate than onabotulinumtoxin A (ARD 0.33, 95% CI, 0.10 to 0.57) (Appendix Table D67).183 Absolute scores on the Headache Impact Test were significantly better with topiramate than onabotulinumtoxin A;183 however, use of drugs for acute attacks did not differ between the two.183

A single RCT examined the comparative effectiveness of onabotulinumtoxin A versus divalproex sodium and found no differences in migraine prevention with two drugs (Appendix Table D68).142 Neither did the two drugs differ for absolute number of migraine days or changes in scores from baseline in the migraine Disability Assessment Scores and/or Headache Impact Test.142

A single RCT examined the comparative effectiveness of onabotulinumtoxin A versus amitriptyline and found no differences in migraine prevention with the two drugs (Appendix Table D69).185 Evidence was insufficient due to a high risk of bias in this individual RCT.185

##### Beta Blockers for Chronic Migraine

The National Institute of Neurological Disorders and Stroke Clinical Research Collaboration trial demonstrated no benefits from combined propranolol and topiramate treatment on migraine prevention in adults with chronic migraine for whom previous topiramate monotherapy had failed.187 Propranolol combined with the antidepressant nortriptyline was no better than propranolol alone or nortriptyline in reducing the number of days with headache by ≥50 percent.188

##### Antiepileptics for Episodic Migraine

###### Topiramate

Nine RCTs of 872 adults examined the comparative effectiveness of topiramate and other drugs for migraine prevention (Appendix Table D70). Most trials did not report funding source or conflict of interest (Appendix Table D71). All trials but one were double blind with low or medium risk of bias (Appendix Table D72).

Individual RCTs provided low-strength evidence that topiramate was more effective than amitriptyline in reducing monthly headache days by ≥50 percent with no differences in monthly migraine days (Table 13).189 Topiramate was more effective than lamotrigine in reducing monthly headache intensity by ≥50 percent.99 Differences were small (less than 20 percent absolute risk difference) but statistically significant (Appendix Table D73). Decrease in headache frequency by ≥50 percent did not differ between topiramate and zonasamide,190 valproate,191 levetiracetam,192 or lamotrigine.99 Topiramate was more effective than propranolol in reducing absolute migraine frequency, duration, and intensity.193

Table 13 Comparative effectiveness of approved and off-label drugs on migraine prevention (50% or more reduction) in adults with episodic migraine, results from individual head-to-head randomized controlled clinical trials

Active vs. Control Drug Weeks From Randomization to Time to Measure Outcome | Reference | Sample | % With Outcome With Active [Control] Drug | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed to Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Risk of Bias | Direct | Consistency | Precision | Strength of Evidence
Topiramate vs. Amitriptyline 26 weeks | Dodick, 2009^189^ | 347 | 55.6 [45.9] | 1.2 (1.0 to 1.5) | 0.09 (−0.01 to 0.20) | NS | NS | Low | Yes | NA | Imprecise | Low
Topiramate vs. Lamotrigine 20 weeks | Gupta, 2007^99^ | 120 | 63.0 [46.0] | 1.4 (1.0 to 1.9) | 0.17 (−0.01 to 0.34) | NS | NS | Low | Yes | NA | Imprecise | Low
Topiramate vs. Propranolol 26 weeks | Diener, 2004^105^ | 288 | 34.7 [43.1] | 0.8 (0.6 to 1.1) | −0.08 (−0.20 to 0.03) | NS | NS | Low | Yes | NA | Imprecise | Low
Topiramate vs. Levetiracetam 8 weeks | de Tommaso, 2007^192^ | 28 | 61.5 [53.3] | 1.2 (0.6 to 2.2) | 0.08 (−0.28 to 0.45) | NS | NS | Medium | Yes | NA | Imprecise | Low
Propranolol vs. Clonidine 16 weeks | Kass, 1980^197^ | 46 | 56.5 [34.8] | 1.6 (0.8 to 3.2) | 0.22 (−0.06 to 0.50) | NS | NS | Medium | Yes | NA | Imprecise | Low
Propranolol vs. Femoxetine 12 weeks | Kangasniemi, 1983^201^ | 29 | 20.0 [7.1] | 2.8 (0.3 to 23.9) | 0.13 (−0.11 to 0.37) | NS | NS | Medium | Yes | NA | Imprecise | Low
Propranolol vs. Nadolol 12 weeks | Sudilovsky, 1987 211 | 91 | 11.4 [38.3] | 0.3 (0.1 to 0.7) | −0.27 (−0.44 to −0.10) | −4 (2 to 10) | −269 (102 to 437) | Medium | Yes | NA | Imprecise | Low
Femoxetine vs. Propranolol 12 weeks | Kangasniemi, 1983^201^ | 24 | 27.3 [7.7] | 3.5 (0.4 to 29.4) | 0.20 (−0.10 to 0.50) | NS | NS | Medium | Yes | NA | Imprecise | Low
Nortriptyline vs. Propranolol 8 weeks | Domingues, 2009^188^ | 49 | 29.2 [44.0] | 0.7 (0.3 to 1.4) | −0.15 (−0.41 to 0.12) | NS | NS | Medium | Yes | NA | Imprecise | Low
Metoprolol vs. Bisoprolol 12 weeks | Worz, 1992^205^ | 250 | 8.8 [9.6] | 0.9 (0.4 to 2.0) | −0.01 (−0.08 to 0.06) | NS | NS | Medium | Yes | NA | Imprecise | Low
Metoprolol vs. Nebivolol 18 weeks | Schellenberg, 2008^206^ | 30 | 57.0 [50.0] | 1.1 (0.6 to 2.2) | 0.07 (−0.29 to 0.43) | NS | NS | Medium | Yes | NA | Imprecise | Low
Metoprolol vs. Nifedipine 28 weeks | Gerber, 1991 195 | 39 | 27.3 [0.0] | 10.2 (0.6 to 168.9) | 0.27 (0.07 to 0.47) | 4 (2 to 14) | 273 (74 to 472) | Medium | Yes | NA | Imprecise | Low
Metoprolol vs. Clonidine 8 weeks | Louis, 1985^207^ | 62 | 32.3 [25.8] | 1.3 (0.6 to 2.7) | 0.06 (−0.16 to 0.29) | NS | NS | Medium | Yes | NA | Imprecise | Low
Nadolol vs. Propranolol 24 weeks | Olerud, 1986^199^ | 28 | 38.5 [60.0] | 0.6 (0.3 to 1.4) | −0.22 (−0.58 to 0.15) | NS | NS | Medium | Yes | NA | Imprecise | Low
Lisuride vs. Methysergide 12 weeks | Hermann, 1977^212^ | 253 | 53.1 [51.2] | 1. 0(0.8 to 1.3) | 0.02 (−0.10 to 0.14) | NS | NS | Medium | Yes | NA | Imprecise | Low

CI = confidence interval; NA = not applicable; NS= not significant

Number needed to treat and number of attributable events were calculated for statistically significant differences.

Bold = significant differences when 95% CI of absolute risk difference do not include 0.

##### Beta Blockers for Episodic Migraine

###### Propranolol

Most RCTs that examined the comparative effectiveness of propranolol for migraine prevention in adults (Appendix Table D74) failed to report funding (Appendix Table D75). Most trials were double blind but did not analyze the data according to planned intention-to-treat principles (Appendix Table D76). Few trials met pooling criteria (Table 14).

Table 14 Comparative effectiveness of drugs for migraine prevention in adults with episodic migraine, direct evidence from head-to-head randomized controlled clinical trials (pooled with random effects model)

Active Preventive Treatment References | Outcome | Sample | Rate, Percent With Active [Control] Drug | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed to Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Strength of Evidence Reasons for Lowering SOE
Timolol vs. Propranolol104,107 | ≥50% decrease in migraine frequency | 242 | 47.9 [52.1] | 1.0 (0.7 to 1.2) | −0.03(−0.15 to 0.10) | NS | NS | Low (medium ROB, imprecision)
Timolol vs. Propranolol104,107 | p value | | | 0.593 | 0.606
Timolol vs. Propranolol104,107 | I squared | | | 0 | 0
Propranolol vs. Metoprolol194,195 | ≥50% decrease in migraine frequency | 113 | 38.2 [50.0] | 0.8 (0.5 to 1.2) | −0.12 (−0.30 to 0.06) | NS | NS | Low (medium ROB, imprecision)
Propranolol vs. Metoprolol194,195 | p value | | | p = 0.371 | p = 0.361
Propranolol vs. Metoprolol194,195 | I squared | | | 0 | 0
Propranolol vs. Nifedipine195,196 | ≥50% decrease in migraine frequency | 76 | 46.2 [18.9] | 2.3 (1.1 to 4.6) | 0.27 (0.09 to 0.46) | 4 (2 to 11) | 274 (89 to 458) | Low (high ROB, imprecision)
Metoprolol vs. Aspirin202,203 | ≥50% decrease in migraine frequency | 326 | 33.1 [39.3] | 1.6 (0.2 to 11.0) | 0.11 (−0.43 to 0.65) | NS | NS | Low (medium ROB, imprecision)
Metoprolol vs. Aspirin202,203 | p value | | | 0.001 | 0
Metoprolol vs. Aspirin202,203 | I squared | | | 0.907 | 0.948

ROB = risk of bias; SOE = strength of evidence; NS= not significant; CI = confidence interval

Bold = significant effects of drugs on treatment response when 95% CI of attributable events per 1,000 treated do not include 0. Number needed to treat and number of attributable events were calculated for statistically significant differences

###### Propranolol Versus Topiramate

The likelihood of ≥50 percent reduction in monthly migraine frequency did not differ between topiramate and propranolol (Table 13 and Appendix Table D35).105 Topiramate was more effective than propranolol in reducing absolute migraine frequency, duration, and intensity.193 Use of drugs for acute attacks did not differ between the two drugs.105

###### Propranolol Versus Timolol

The likelihood of ≥50 percent reduction in monthly migraine frequency did not differ between propranolol and timolol (Table 14).104,107

###### Propranolol Versus Metoprolol

The likelihood of ≥50 percent reduction of the sum of severity scores or clinically important reduction in migraine days did not differ between propranolol and metoprolol (Table 14).194,195

###### Propranolol Versus Nifedipine

Propranolol was more effective than nifedipine in reducing monthly migraine frequency by ≥50 percent (Table 14).195,196

###### Propranolol Versus Clonidine

The likelihood of ≥50 percent reduction in migraine days did not differ between propranolol and clonidine (Table 13).197

###### Propranolol Versus Nadolol

Nadolol, 160 mg/day, was more effective than propranolol in achieving a reduction of ≥50 percent in migraine frequency, duration, and intensity (Table 13).198 Differences between a lower dose of nadolol (80 mg/day) and propranolol (160 mg/day) were not significant.198,199

###### Propranolol Versus Antidepressants

The likelihood of ≥50 percent reduction in monthly migraine attacks did not differ between propranolol and amitriptyline200 nortriptyline,188 or femoxetine.201 The likelihood of ≥50 percent reduction in the number of migraine days did not differ between a combined therapy using both drugs and propranolol alone.188

##### Off-Label Drugs

###### Off-Label Beta Blockers

RCTs that examined comparative effectiveness of off-label beta blockers for migraine prevention in adults (Appendix Table D77) failed to report funding and conflict of interest (Appendix Table D78). All trials were double blind (Appendix Table D79). All RCTs examined unique drug comparisons except two RCTs that compared the effects of metoprolol and aspirin.

###### Metoprolol Versus Aspirin

In pooled analyses, metoprolol and aspirin resulted in similar rates of ≥50 percent reduction in monthly migraine attacks (Table 14).202,203 Individual RCTs reported that metoprolol was more effective than aspirin, 300 mg/day,202 but less effective than aspirin, 1,500 mg/day.203

###### Metoprolol Versus Nifedipine

Metoprolol was more effective than nifedipine in reducing monthly migraine attacks by ≥50 percent (Table 13).195

###### Metoprolol Versus Bisoprolol (Appendix Table D80)

Metoprolol and bisoprolol did not differ for reduction in monthly migraine attacks by ≥50 percent nor absolute number of migraine days (Appendix Table D81).204,205

###### Metoprolol Versus Nebivolol (Appendix Table D80)

Reduction in monthly migraine attacks by ≥50 percent did not differ between metoprolol and nebivolol.206 Neither migraine-related disability, use of drugs for acute attacks (Appendix Table D82), nor quality of life (Appendix Table D80) differed between metoprolol and nebivolol.206

###### Metoprolol Versus Clonidine

Reduction in monthly migraine attacks by ≥50 percent did not differ between metoprolol and clonidine.207 However, more patients noticed a reduction in migraine days with metoprolol than clonidine (Appendix Table D82).207

##### Antidepressants

Individual RCTs found no differences in the comparative effectiveness of antidepressants for migraine prevention. The likelihood of reducing monthly migraine attacks by ≥50 percent did not differ between femoxetine and propranolol, nor did the duration or intensity of attacks or use of acute drugs differ.201 Fluoxetine combined with amitriptyline versus amitriptyline alone resulted in similar migraine frequency and severity.208 Fluvoxamine versus amitriptyline resulted in similar migraine frequency and severity.209 Venlafaxine versus amitriptyline resulted in similar migraine frequency and severity.210

#### Indirect Evidence of Comparative Effectiveness of Preventive Drugs for Episodic Migraine

Among all included RCTs, 97 percent examined the outcome of clinically important reduction in migraine frequency by ≥50 percent. We found no consistent differences in baseline patient characteristics in RCTs that examined the efficacy of various drugs for migraine prevention. We conducted exploratory Bayesian network meta-analysis (Appendix Table D83) and indirect adjusted analysis of such drugs (Appendix Table D84). We found no differences among approved drugs (Table 15). Approved drugs were more effective than off-label drugs except for the angiotensin II receptor blocker candesartan, which was more effective than topiramate, divalproex, and propranolol (Table 16). Exploratory Bayesian network meta-analysis demonstrated that the approved drugs topiramate, divalproex, and propranolol, and off-label drug classes except ergot alkaloids were better than placebo (Figure 3). The strength of the association was the largest with angiotensin inhibiting drugs (Table 17).

Table 15 Indirect adjusted comparative effectiveness of clinical response^*^ in RCTs of approved drugs for the prophylaxis of episodic migraine

Active | Control -- Propranolol | Control -- Timolol | Control -- Topiramate | Control -- Divalproex
Divalproex | 1.1 (0.4 to 2.9) | 1.0 (0.4 to 2.7) | 0.9 (0.3 to 2.5) | 1
Propranolol | 1 | 0.9 (0.4 to 1.7) | 0.8 (0.4 to 1.6) | 0.9(0.3;2.3)
Timolol | 1.2(0.6;2.3) | 1 | 1.0 (0.5 to 2.0) | 1.0(0.4;2.9)
Valproate | 1.4 (0.5 to 4.5) | 1.2 (0.4 to 4.1) | 1.2 (0.4 to 3.8) | 1.3 (0.3 to 5.0)

CI = confidence interval; RCT = randomized controlled trial

* Clinical response was defined as ≥50 percent reduction in monthly migraine frequency or self-reported substantial reduction in monthly migraine frequency Differences are significant when 95% CI of odds ratios do not include 1; odds ratios of each drug versus placebo were compared with each other to calculate presented odds ratios with 95% CI.

Table 16 Indirect adjusted comparative effectiveness of clinical response^*^ in RCTs of approved drugs versus off-label drugs for the prophylaxis of episodic migraine

Active | Control -- Divalproex | Control Propranolol | Control -- Timolol | Control -- Topiramate | Control -- Valproate
Acebutolol | 2.8 (0.5;16.7) | 3.2 (0.6;15.9) | 2.7 (0.5;14.2) | 2.6 (0.5;13.5) | 2.2 (0.3;14.5)
Acetazolamide | 0.3 (0.1;1.2) | 0.3 (0.1;1.1) | 0.3 (0.1;1.0) | 0.3 (0.1;0.9) | 0.2 (0.0;1.1)
Amitriptyline | 1.0 (0.3;3.9) | 1.1 (0.4;3.5) | 1.0 (0.3;3.2) | 0.9 (0.3;3.0) | 0.8 (0.2;3.5)
Aspirin | 0.3 (0.1;0.6) | 0.3 (0.2;0.4) | 0.2 (0.1;0.4) | 0.2 (0.1;0.4) | 0.2 (0.1;0.6)
Atenolol | 8.0 (0.4;167.6) | 9.0 (0.5;171.2) | 7.7 (0.4;150.9) | 7.5 (0.4;144.4) | 6.3 (0.3;139.7)
Candesartan | 5.7 (1.0;32.2) | 6.4 (1.4;30.4) | 5.5 (1.1;27.3) | 5.3 (1.1;26.0) | 4.5 (0.7;28.1)
Clonidine | 0.7 (0.2;2.4) | 0.8 (0.3;2.0) | 0.7 (0.3;1.9) | 0.7 (0.2;1.8) | 0.6 (0.1;2.1)
Dihydroergotamine | 0.4 (0.1;1.0) | 0.4 (0.2;0.8) | 0.4 (0.2;0.7) | 0.4 (0.2;0.7) | 0.3 (0.1;0.9)
Fenoprofen | 0.2 (0.1;0.9) | 0.3 (0.1;0.8) | 0.2 (0.1;0.8) | 0.2 (0.1;0.7) | 0.2 (0.0;0.8)
Flurbiprofen | 1.7 (0.4;7.6) | 1.9 (0.5;7.0) | 1.6 (0.4;6.3) | 1.5 (0.4;6.0) | 1.3 (0.3;6.7)
Indomethacin | 0.4 (0.1;2.1) | 0.5 (0.1;2.0) | 0.4 (0.1;1.8) | 0.4 (0.1;1.7) | 0.3 (0.1;1.9)
Lamotrigine | 0.6 (0.2;1.7) | 0.6 (0.3;1.4) | 0.5 (0.2;1.3) | 0.5 (0.2;1.3) | 0.4 (0.1;1.6)
Lisinopril | 11.9 (0.6;233.2) | 13.4 (0.8;237.7) | 11.6 (0.6;209.6) | 11.2 (0.6;200.5) | 9.4 (0.4;194.7)
Lisuride | 0.6 (0.2;1.7) | 0.6 (0.3;1.4) | 0.5 (0.2;1.3) | 0.5 (0.2;1.2) | 0.4 (0.1;1.5)
Montelukast | 0.4 (0.1;1.2) | 0.4 (0.2;1.0) | 0.4 (0.2;0.9) | 0.4 (0.2;0.8) | 0.3 (0.1;1.1)
Nadolol | 1.9 (0.1;42.4) | 2.1 (0.1;43.4) | 1.8 (0.1;38.2) | 1.8 (0.1;36.6) | 1.5 (0.1;35.3)
Nifedipine | 3.2 (0.7;14.2) | 3.6 (1.0;13.0) | 3.1 (0.8;11.8) | 3.0 (0.8;11.2) | 2.5 (0.5;12.6)
Oxcarbazepine | 0.3 (0.1;0.8) | Not able to calculate | 0.3 (0.1;0.6) | 0.3 (0.1;0.6) | 0.2 (0.1;0.7)
Rofecoxib | 0.8 (0.2;2.9) | 0.3 (0.1;0.6) | 0.8 (0.3;2.3) | 0.8 (0.3;2.2) | 0.7 (0.2;2.6)
Telmisartan | 0.5 (0.1;1.8) | 0.6 (0.2;1.6) | 0.5 (0.2;1.4) | 0.5 (0.2;1.4) | 0.4 (0.1;1.6)
Tolfenamic Acid | 3.8 (0.6;23.2) | 4.2 (0.8;22.1) | 3.7 (0.7;19.8) | 3.5 (0.7;18.8) | 3.0 (0.4;20.1)
Tonabersat | 0.4 (0.1;1.1) | 0.4 (0.2;1.0) | 0.4 (0.1;0.9) | 0.3 (0.1;0.8) | 0.3 (0.1;1.0)
Gabapentin | 0.8 (0.3;2.5) | 0.9 (0.4;1.8) | 0.7 (0.3;1.7) | 0.7 (0.3;1.6) | .59 (0.2;2.0)
Mg | 0.5 (0.1;1.7) | 0.5 (0.2;1.3) | 0.4 (0.2;1.2) | 0.4 (0.2;1.2) | 0.4 (0.1;1.4)
Nimodipine | 2.0 (0.2;0.0) | 2.1 (0.2;24.3) | 1.8 (0.2;21.6) | 1.8 (0.2;20.6) | 1.42 (0.1;0.0)

CI = confidence interval; RCT = randomized controlled trial

* Clinical response was defined as ≥50 percent reduction in monthly migraine frequency or self-reported substantial reduction in monthly migraine frequency Bold = differences are significant when 95% CI of odds ratios do not include 1; odds ratios of each drug vs. placebo were compared with each other to calculate presented odds ratios with 95% CI

Figure 3 Bayesian network meta-analysis of clinical response to drugs versus placebo (66 RCTs of 14,774 adults) in randomized controlled clinical trials that aimed to prevent migraine in adults

CrI = credible intervals; NSAID = nonsteroidal anti-inflammatory drugs

Clinical response was defined as ≥50% reduction in monthly migraine attacks or perceived clinically important treatment success. We used heterogeneous random effects model that assumes correlation within study (rho = 0.5) and heterogeneous between studies (WinBUG codes are in Appendix B).

The figure presents the results from Bayesian network meta-analysis of clinical response to drugs vs. placebo in randomized controlled clinical trials that aimed to prevent migraine in adults. Figure A is a forest plot diagram depicting odds ratios of clinically important reduction in monthly migraine with active drugs when compared to placebo. The plot has two columns. The left-hand column lists approved drugs such as topiramate, divalproex and propranolol, and off label drug classes such as angiotensin inhibiting drugs, non steroid anti-inflammatory drugs, beta-blockers, antidepressants, antiepileptic, ergot alkaloids, clonidine, and calcium channel blockers. The number of randomized controlled clinical trials and the number of the enrolled adults are presented after the names of the drugs. The right-hand column is a plot of Bayesian odds ratios with 2,5 and 97.5% credible intervals. Mean odds ratio is presented by a square incorporating credible intervals represented by horizontal lines. All approved drugs were similarly better than placebo. Among off-label drug classes, angiotensin inhibiting drugs demonstrated the largest significant odds of reducing monthly migraine by ≥50 percent.

Table 17 Odds ratio of clinical response with preventive drugs, results from exploratory Bayesian network meta-analysis

Active | Subjects | Control -- Divalproex | Control -- Propranolol | Control -- Angiotensin Inhibiting Drugs | Control -- NSAiD | Control -- Beta Blockers | Control -- Antidepressants | Control -- Antiepileptics | Control -- Ergot Alkaloids | Control -- Clonidine | Control -- Ca ++ Blockers
Topiramate 16 RCTs | 1,812 | 0.8 (0.4 to 1.4) | 0.9 (0.5 to 1.4) | 0.4 (0.2 to 1.1) | 1.0 (0.5 to 1.9) | 0.7 (0.4 to 1.2) | 1.2 (0.6 to 2.0) | 1.2 (0.7 to 2.0) | 1.7 (0.6 to 4.2) | 0.7 (0.3 to 1.3) | 0.9 (0.4 to 2.7)
Divalproex 8 RCTs | 419 | 1 | 1.1 (0.6 to 2.0) | 0.6 (0.2 to 1.6) | 1.3 (0.6 to 2.8) | 1.0 (0.5 to 1.9) | 1.5 (0.7 to 3.1) | 1.5 (0.8 to 3.1) | 2.2 (0.8 to 5.9) | 0.9 (0.4 to 1.9) | 1.2 (0.5 to 3.6)
Propranolol 24 RCTs | 1,172 | 0.9 (0.5 to 1.5) | 1 | 0.5 (0.2 to 1.2) | 1.1 (0.6 to 2.2) | 0.8 (0.5 to 1.3) | 1.3 (0.8 to 2.3) | 1.3 (0.8 to 2.4) | 1.9 (0.7 to 4.8) | 0.8 (0.4 to 1.4) | 1.0 (0.4 to 2.9)
Angiotensin inhibiting drugs 5 RCTs | 180 | 1.8 (0.6 to 5.2) | 2.1 (0.8 to 5.2) | 1 | 2.3 (0.8 to 6.6) | 1.7 (0.7 to 4.6) | 2.8 (1.0 to 7.5) | 2.7 (1.0 to 7.5) | 3.9 (1.2 to 13.8) | 1.6 (0.6 to 4.5) | 2.1 (0.7 to 8.2)
NSAID 9 RCTs | 11,442 | 0.8 (0.4 to 1.7) | 0.9 (0.5 to 1.7) | 0.4 (0.2 to 1.2) | 1 | 0.7 (0.4 to 1.4) | 1.2 (0.6 to 2.5) | 1.2 (0.6 to 2.6) | 1.7 (0.6 to 4.6) | 0.7 (0.3 to 1.6) | 0.9 (0.3 to 2.9)
Beta blockers 17 RCTs | 714 | 1.0 (0.5 to 2.0) | 1.2 (0.7 to 1.9) | 0.6 (0.2 to 1.5) | 1.3 (0.7 to 2.6) | 1 | 1.6 (0.9 to 2.9) | 1.6 (0.9 to 3.1) | 2.3 (0.9 to 5.9) | 0.9 (0.5 to 1.7) | 1.2 (0.5 to 3.6)
Antidepressants 10 RCTs | 595 | 0.7 (0.3 to 1.4) | 0.7 (0.4 to 1.3) | 0.4 (0.1 to 1.0) | 0.8 (0.4 to 1.8) | 0.6 (0.3 to 1.2) | 1 | 1.0 (0.5 to 2.0) | 1.4 (0.5 to 3.8) | 0.6 (0.3 to 1.2) | 0.8 (0.3 to 2.3)
Antiepileptics 9 RCTs | 457 | 0.7 (0.3 to 1.3) | 0.8 (0.4 to 1.3) | 0.4 (0.1 to 1.0) | 0.9 (0.4 to 1.8) | 0.6 (0.3 to 1.2) | 1.0 (0.5 to 2.0) | 1 | 1.4 (0.5 to 3.9) | 0.6 (0.3 to 1.3) | 0.8 (0.3 to 2.3)
Ergot alkaloids 2 RCTs | 259 | 0.5 (0.2 to 1.3) | 0.5 (0.2 to 1.4) | 0.3 (0.1 to 0.9) | 0.6 (0.2 to 1.7) | 0.4 (0.2 to 1.2) | 0.7 (0.3 to 1.9) | 0.7 (0.3 to 2.0) | 1 | 0.4 (0.1 to 1.2) | 0.5 (0.2 to 2.1)
Clonidine 7 RCTs | 271 | 1.1 (0.5 to 2.4) | 1.3 (0.7 to 2.3) | 0.6 (0.2 to 1.7) | 1.4 (0.6 to 3.2) | 1.1 (0.6 to 2.0) | 1.7 (0.8 to 3.6) | 1.7 (0.8 to 3.7) | 2.4 (0.8 to 6.7) | 1 | 1.3 (0.5 to 4.1)
Ca++ blockers 4 RCTs | 136 | 0.9 (0.3 to 2.2) | 1.0 (0.4 to 2.3) | 0.5 (0.1 to 1.5) | 1.1 (0.3 to 2.9) | 0.8 (0.3 to 2.0) | 1.3 (0.4 to 3.2) | 1.3 (0.4 to 3.4) | 1.8 (0.5 to 6.0) | 0.8 (0.2 to 2.1) | 1

NSAID = nonsteroidal anti-inflammatory drugs; RCT = randomized controlled trial

* Clinical response (defined as ≥50 percent reduction in monthly episodic migraine frequency or self-reported substantial reduction in monthly migraine frequency Bold = differences are significant when 2.5 to 97.5% credible intervals of odds ratios do not include 1.

We used heterogeneous random effects model that assumes correlation within study (rho = 0.5) and heterogeneous between studies (WinBUG codes are in Appendix B) NSAID nonsteroidal anti-inflammatory drugs.

Next, we analyzed the comparative effectiveness of nine treatments including propranolol, timolol, metoprolol, all other off-label beta blockers (atenolol, nadolol, pindolol, bisoprolol, or nebivolol), all off-label antidepressants, all approved and off-label antiepileptics, ACE inhibitors, or angiotensin II antagonists, and all other off-label drugs. This analysis clearly demonstrated that angiotensin inhibiting drugs were more effective than all other treatments. Propranolol, timolol, metoprolol, and all other off-label beta blockers resulted in significantly greater odds of migraine prevention than antiepileptics, antidepressants, and other off-label drugs.

### KQ1c How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared with active nonpharmacologic treatments?

#### Antiepileptics

##### Topiramate Versus Exercise or Relaxation

The likelihood of ≥50 percent reduction in monthly migraine frequency did not differ between topiramate and aerobic exercise or common forms of relaxation, breathing, and stress-management techniques.213 Migraine days, pain intensity, quality of life, or acute drug use did not differ between topiramate and aerobic exercise or relaxation.213

#### Beta Blockers

##### Propranolol Versus Biofeedback

The likelihood of a reduction in monthly migraine frequency of ≥25 percent did not differ between propranolol and diaphragmatic breathing and systematic relaxation that was assisted by biofeedback and also practiced at home.214

#### Antidepressants

##### Amitriptyline Versus Spinal Manipulation

Amitriptyline was more effective than spinal manipulation for reducing monthly migraine attacks during the trial but less effective during post-treatment followup period.215 Evidence was low-strength due to risk of bias and imprecision (Appendix Table D85). Evidence from a single high-risk-of-bias RCT was insufficient to conclude the comparative effectiveness of amitriptyline versus biofeedback.216

### KQ1d How do preventive pharmacologic treatments combined with nondrug treatments affect patient-centered and intermediate outcomes when compared with pharmacologic treatments alone?

Five RCTs compared the effectiveness of drugs combined with nondrug treatments with placebo or pharmacologic treatments alone (Appendix Table D86). Most trials were funded by nonprofit grants (Appendix Table D87). Risk of bias was low in one trial, medium in two, and high in two (Appendix Table D88).

#### Beta Blockers

Behavioral migraine management and relaxation combined with propranolol (maximum dose 240 mg/day) or nadolol (maximum dose 120 mg/day) was more effective than placebo in reducing monthly migraine frequency by ≥50 percent (Appendix Table D89). However, effects of the combined therapy did not differ from the effects of drugs alone.217 Evidence of effectiveness and safety was low due to imprecise estimates from a single RCT (Appendix Table D90).217 We estimated that 387 adults per 1,000 treated would experience a reduction in migraine frequency by ≥50 percent (95% CI, 157 to 618) with combined therapy (Table 18).217

Table 18 Comparative effectiveness of beta blockers combined with behavioral therapy^*^ for episodic migraine prevention in adults, results from individual low risk of bias randomized controlled clinical trial217

Outcome | Active Treatment | Control | Sample | Rate % in Active [Control] Group | Number Needed To Treat (95% CI) | Attributable Events (95% CI) | Strength of Evidence
Clinically improved (≥50% reduction in migraines) at month 10 | Behavioral migraine management + propranolol/nadolol | Placebo | 90 | 76.8 [40.0] | 3 (2 to 6) | 387 (157 to 618) | Low
Clinically improved (≥50% reduction in migraines) at month 10 | Behavioral migraine management + placebo | Propranolol/nadolol | 108 | 34.5 [34.0] | NS | NS | Low
Clinically improved (≥50% reduction in migraines) at month 10 | Behavioral migraine management + propranolol/nadolol | Propranolol/nadolol | 122 | 76.8 [34.0] | 2 (2 to 4) | 428 (267 to 590) | Low
Clinically improved (≥50% reduction in migraines) at month 10 | Behavioral migraine management + placebo | Behavioral migraine management + Propranolol/nadolol | 124 | 34.5 [76.8] | −2 (2 to 4) | −423 (262 to 583) | Low

CI = confidence interval; NS= not significant

* Behavioral therapy included orientation+relaxation training; migraine warning signs and triggers; effectively using migraine medication, and reducing impact of migraines; stress management or biofeedback training; migraine management plan; Bold = significant at 95% confidence limit when 95% CI of attributable events per 1,000 treated do not include 0. Number needed to treat and number of attributable events were calculated for statistically significant differences.

Propranolol (240 mg/day) or nadolol (120 mg/day) combined with behavioral therapy (orientation plus relaxation training, migraine warning signs and triggers, effectively using migraine medication, reducing impact of migraines, stress management or biofeedback training, and migraine management plan) was more effective than placebo in improving self-efficacy (Appendix Table D91).218

Evidence was insufficient from a single high-risk-of-bias RCT that compared the effectiveness of propranolol combined with biofeedback and propranolol alone for migraine prevention in adults.216

#### Antidepressants

##### Amitriptyline Combined With Spinal Manipulation Versus Amitriptyline Alone or Spinal Manipulation Alone (Table 19)215

Table 19 Comparative effectiveness of antidepressant amitriptyline and spinal manipulation for episodic migraine prevention in adults, individual medium risk of bias randomized controlled clinical trial215

Definition of the Outcome | Active Treatment | Control Treatment | Sample | Rate, % With Active vs. [Control] Treatment | Number Needed To Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Strength of Evidence
>60% reduction in HI in last 4 weeks of treatment phase | Spinal manipulation | Amitriptyline 100 mg/day | 147 | 22.1 [48.6] | −4 (−9 to −2) | −265 (−414 to −116) | Low
>60% reduction in HI during the 4-week post-treatment followup phase | Spinal manipulation | Amitriptyline 100 mg/day | 147 | 22.1 [15.7] | NS | NS | Low
Reduction in HI (headache index) scores during treatment compared with baseline | Spinal manipulation | Spinal manipulation + amitriptyline 100 mg/day | 148 | 40.3 [40.8] | NS | NS | Low
Reduction in HI from baseline during the post-treatment followup period | Spinal manipulation | Spinal manipulation + amitriptyline 100 mg/day | 148 | 41.6 [25.4] | 6 (3 to 80) | 162 (13 to 312) | Low
Reduction in HI (headache index) scores during treatment compared with baseline | Spinal manipulation | Spinal manipulation + amitriptyline 100 mg/day | 148 | 40.3 [40.8] | NS | NS | Low
Reduction in HI from baseline during the post-treatment followup period | Spinal manipulation | Spinal manipulation + amitriptyline 100 mg/day | 148 | 41.6 [25.4] | 6 (3 to 80) | 162 (13 to 312) | Low

CI = confidence interval; HI = Headache Index; NS = not significant

Number needed to treat and number of attributable events were calculated for statistically significant differences.

Bold = significant differences at 95% confidence limit when 95% CI of attributable events per 1,000 treated do not include 0.

Spinal manipulation was more effective than combined treatment in reducing Headache Index scores.215 Combined treatment was not more effective than amitriptyline alone in improving general health status or reducing use of drugs for acute attacks (Appendix Table D92).215 Evidence from a single high-risk-of-bias RCT was insufficient to conclude comparative effectiveness between amitriptyline combined with biofeedback and the drug alone.216

### KQ1e1 How might dosing regimens or duration of treatments influence the effects of the treatments on patient-centered outcomes?

#### Muscle Relaxants

##### Onabotulinumtoxin A

###### Dose Response Migraine Prevention With Onabotulinumtoxin A

Higher doses of onabotulinumtoxin A resulted in a greater decrease in absolute migraine frequency according to the BoNTA-024-026-036 Study Group in adults with chronic migraine.219 Higher doses of onabotulinumtoxin A resulted in less frequent use and overuse of acute pain medications at 1 and 3 months of followup according to the BoNTA-039 Study Group (Appendix Table D93).138 However, neither patients nor investigators found differences in global assessment of improvement with higher doses of onabotulinumtoxin A (Appendix Table D94).139

Higher doses of abobotulinumtoxin A did not increase the rates of positive global assessment of the treatment effect in the Dysport^®^ In Migraine Without Aura Prophylaxis trial.139 Higher doses of abobotulinumtoxin A did not reduce migraine duration or intensity139 or depression scores.144

#### Antiepileptics

##### Topiramate

Increase in topiramate dose from 50 to 100 mg/day resulted in a higher response rate (≥50 percent reduction in monthly migraine frequency) without additional benefit from increasing the dose to 200 mg/day (Appendix Table D95). Higher topiramate doses (50 to 100 mg) resulted in significant migraine prevention of ≥50 percent in one patient for every six treated (Table 20).

Table 20 Dose response reduction in migraine attacks by ≥50% from baseline with topiramate in adults

Reference Risk of Bias | Topiramate Daily Doses | Events/Randomized With Larger vs. Smaller Dose | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed To Treat (95% CI) | Attributable Events (95% CI)
Brandes, 2004^229^ Risk of bias Low | 100mg vs. 50mg/day | 60/122 47/120 | 1.3 (0.9 to 1.7) | 0.10 (−0.02 to 0.23) | NS | NS
Silberstein, 2003 97 Risk of bias: Medium | 100mg vs. 50mg/day | 68/125 41/117 | 1.5 (1.1 to 2.1) | 0.19 (0.07 to 0.31) | 5 (3 to 15) | 189 (67 to 312)
Silberstein, 2004 230 Risk of bias: Low | 100mg vs. 50mg/day | 69/128 45/125 | 1.5 (1.1 to 2.0) | 0.18 (0.06 to 0.30) | 6 (3 to 17) | 179 (58 to 300)
Pooled | 100mg vs. 50mg/day | 196/375 133/362 | 1.4 (1.2 to 1.7) | 0.16 (0.09 to 0.23) | 6 (4 to 12) | 157 (86 to 228)
Brandes, 2004^229^ Risk of bias: Low | 100mg vs. 50mg/day | 57/121 47/120 | 1.2 (0.9 to 1.6) | 0.08 (−0.05 to 0.20) | NS | NS
Silberstein, 2003 97 Risk of bias: Medium | 200mg/day vs. 50mg/day | 58/112 41/117 | 1.5 (1.1 to 2.0) | 0.17 (0.04 to 0.29) | 6 (3 to 24) | 167 (41 to 294)
Silberstein, 2004 230 Risk of bias: Low | 200mg/day vs. 50mg/day | 61/117 45/125 | 1.4 (1.1 to 1.9) | 0.16 (0.04 to 0.29) | 6 (4 to 26) | 161 (38 to 285)
Pooled | 200mg/day vs. 50mg/day | 176/350 133/362 | 1.4 (1.2 to 1.6) | 0.14 (0.06 to 0.21) | 7 (5 to 16) | 136 (64 to 208)
Brandes, 2004^229^ Risk of bias: Low | 200mg/day vs. 100mg/day | 57/121 60/122 | 1.0 (0.7 to 1.2) | −0.02 (−0.15 to 0.11) | NS | NS
Silberstein, 2003^97^ Risk of bias: Medium | 200mg/day vs. 100mg/day | 58/112 68/125 | 1.0 (0.8 to 1.2) | −0.02 (−0.15 to 0.11) | NS | NS
Silberstein, 2004^230^ Risk of bias: Low | 200mg/day vs. 100mg/day | 61/117 69/128 | 1.0 (0.8 to 1.2) | −0.02 (−0.14 to 0.11) | NS | NS
Pooled | 200mg/day vs. 100mg/day | 176/350 196/375 | 1.0 (0.8 to 1.1) | −0.02 (−0.09 to 0.05) | NS | NS

CI = confidence interval; NS = not significant

Bold = significant at 95% confidence limit when 95% CI of attributable events per 1,000 treated do not include 0.

Number needed to treat and number of attributable events were calculated for statistically significant differences.

##### Divalproex

Higher doses of divalproex did not result in a greater likelihood of clinically important migraine frequency reduction (Appendix Table D96).103

#### Beta Blockers

##### Propranolol

Increasing propranolol dose did not result in a greater likelihood of clinically important reduction in migraine frequency.220–223

#### Off-Label Beta Blockers

Individual RCTs examined dose response effects with pindolol,224 nadolol,225,226 and bisoprolol.227

##### Pindolol

Pindolol, 15 mg/day, was more effective than 7.5 mg in reducing migraine days and duration.224

##### Nadolol

Nadolol, 160 to 240 mg/day, was more effective than 80 mg/day in reducing migraine frequency and severity.225,226

##### Bisoprolol

Bisoprolol, 10 mg/day, was more effective than 5 mg/day in reducing migraine duration but not frequency.227

#### Antidepressants

##### Amitriptyline

Amitriptyline, 50 mg/day, was not more effective than 25 mg/day in reducing migraine frequency or severity.228

##### Venlafaxine

Venlafaxine, 150 mg/day, resulted in excellent global self-reported efficacy more often than 75 mg/day.165

### KQ1e2 How might approaches to drug management (such as patient-care teams, integrated care, coordinated care, patient education, drug surveillance, or interactive drug monitoring) influence results?

Six RCTs of 3,825 adults examined the effectiveness of drug management for migraine prevention in adults (Table 21 and Appendix Table D97). Most trials were sponsored by nonprofit organizations (Appendix Table D98). Half of the trials had low risk of bias, and the other half had medium risk of bias due to inadequacy of randomization (Appendix Table D99). Four RCTs examined the effectiveness of multidisciplinary migraine management programs and two examined the effectiveness of pharmacist-led drug management (Appendix Table D100).

Table 21 Prevention of migraine with drug management programs, results from individual randomized controlled clinical trials

Reference/Treatment vs. Control Sample/Risk of Bias | Description | Results
Lemstra, 2002^231^ Multidisciplinary intervention vs. standard medical care with the patient’s family physician Sample: 80 Risk of bias: Medium | Multidisciplinary intervention consisted of a neurologist intake, physical therapist intake, 18 group-supervised exercise therapy sessions with an exercise therapist, 2 group lectures with a registered psychologist 1 group lecture with a dietitian, 2 massage therapy sessions, and a neurologist and physical therapist. | More effective in improving quality of life and reducing migraine related disability with no statistically significant changes in the use of acute drugs or work status.
Matchar, 2008^232^ Headache management program vs. continue with current clinician Sample: 614 Risk of bias: Medium | Headache management program consisting of: (1) a class specifically designed to inform patients about headache types, triggers, and treatment options; (2) diagnosis and treatment by a professional especially trained in headache care (based on U.S. Headache Consortium guidelines); and (3) proactive followup by a case-manager. | More effective in improving quality of life and satisfaction with care; 196 adults per 1,000 treated (95% CI, 125 to 258) had no migraine-related disability with the headache management program.
Fritsche, 2010^233^ Cognitive-behavioral minimal contact program (MCT) vs. two brochures Sample: 158 Risk of bias: Low | The program consisted of 5 sessions with six participants and lasting 2 hours each: (1) Introduction and syndrome education; (2) Medication rules and the risk of medication overuse headache, including information about prophylactic migraine medication and medication overuse; (3) Medication intake behavior, aimed at raising awareness for “external” and “internal” influences on patient’s medication intake behavior; (4) General and personal risk factors for drug intake; and (5) Everyday transfer aimed at establishing individual goals for future drug intake and learning how to make use of social support to control intake behavior. | More effective in patient satisfaction. No effects on migraine frequency or duration of migraine related disability, social activity engagement, pain self-management, or migraine related anxiety and depression.
Rothrock, 2006^234^ Standardized course of didactic instructions regarding migraine biogenesis and management (“headache school”) Sample: 100 Risk of bias: Medium | The curriculum consisted of 3 90-minute classes held on evenings and weekends and taught by lay migraineurs who previously had undergone intensive classroom and in-clinic training by neurology investigators. All individuals serving as patient instructors underwent 12 hours of classroom instruction in headache theory and treatment, received and reviewed a related course syllabus, were required to pass a written examination based on that didactic instruction, and then served a minimum of 12 hours as observers in the headache clinics. | Decreased overuse of acute drugs and reduced migraine disability.
Hoffmann, 2008^235^ Pharmaceutical care for migraine vs. regular pharmaceutical consultation Sample: 410 Risk of bias: Low | Pharmacists from the intervention pharmacies participated in a 2-day central training program conducted by a physician and a pharmacist. Together with the patient, the intervention pharmacist prioritized problems, defined goals, and devised a plan to work toward them. The training was based on a comprehensive standard operation manual developed by the Federal Union of German Associations of Pharmacists, in cooperation with the principal. | Complete migraine cessation did not differ between active and control intervention.
Sondergaard, 2006^236^ Intensive pharmaceutical care campaign Sample: 2463 Risk of bias: Low | Pharmacists from the intervention pharmacies identified inappropriate triptan use, established a dialogue with individual patients and offered advice about migraine management with preventive drugs to reduce triptan overuse. The training package was developed in cooperation with the Danish College of Pharmacy Practice. | Significant improvement in mental health and self-efficacy; no statistically significant impact on use of triptans.

#### Multidisciplinary Intervention Versus Standard Care

The community-based multidisciplinary intervention included intake by a neurologist, physical therapist, and a psychologist, with group-supervised exercise therapy sessions, massage therapy sessions, and group lectures with a dietitian231 (Appendix Table D100). Adherence did not differ between the multidisciplinary intervention and standard medical care with the patient’s primary physician (Appendix Table D101).231 The multidisciplinary intervention was more effective in improving quality of life and reducing migraine-related disability (Appendix Table D102).231 We found no statistically significant changes in medication use or work status.231

#### Migraine Management Program Versus Usual Care

A multidisciplinary migraine management program was administered by a midlevel provider (e.g., nurse practitioner or physician assistant) with expertise in migraine evaluation and management.232 The program included an educational session in which patients received materials that described: migraine types and etiologies, triggers, sleep hygiene, pharmacologic treatment, and relaxation techniques.232 Patients in the control group continued with their current clinician, without access to the migraine management program. Fewer adults had migraine-related disability at 6 months of followup with the migraine management program (Appendix Table D103).232 We estimated that 196 adults per 1,000 treated (95% CI, 125 to 258) would have no migraine-related disability with the migraine management intervention.232 The program was also more effective than usual care in improving quality of life and treatment satisfaction (Appendix Table D104).232

#### Cognitive Behavioral Minimal Contact Program Versus Usual Care

The cognitive-behavioral minimal contact program consisted of five sessions that provided information about migraine and progressive muscle relaxation, acute and prophylactic migraine medications, and triggers for medication overuse (e.g., availability of drugs, fear of attack and loss of social functioning, and stress level in private and professional life). Participants also established individualized goals for future drug intake and improving quality of life.233 The cognitive-behavioral minimal contact program did not decrease migraine frequency or duration of migraine related disability (Appendix Table D105),233 nor did it improve engagement in social activity, self-management of pain, migraine-related anxiety, or depression.233 However, patient satisfaction with treatment was significantly greater with the cognitive-behavioral minimal contact program than with usual care.233

#### Headache School Versus Usual Care

Headache school involved a standardized curriculum of didactic instructions regarding migraine biogenesis and management. It consisted of classes taught by neurologists and migraine sufferers who previously had undergone intensive classroom training. Headache school classes focused mostly on acute preventive drug treatments.234 Patients in the control group received routine drug management.234 Patients who attended headache school less often overused drugs for acute attacks than patients receiving routine drug management (Appendix Table D106).234 Attending headache school also reduced migraine disability (Appendix Table D107).234

#### Pharmaceutical Care for Migraine Versus Standard Counseling

Pharmaceutical care intervention was defined as intensified structured counseling between patient and pharmacist and the use of drug databases. German pharmacists worked with patients individually to prioritize problems, define goals, and devise plans to work toward goals.235 Patients in the control group received standard counseling that included general information about benefits and possible adverse drug effects.235 Pharmaceutical care resulted in a statistically significant improvement from baseline in mental health and self-efficacy.236 However, the likelihood of complete migraine cessation did not differ between active and control interventions (Appendix Table D108)235 nor did the absolute number of migraine attacks or quality of life (Appendix Table D109).235

#### Intensive Pharmaceutical Care Campaign Versus Control Pharmacy

Danish pharmacists and pharmacy assistants provided the intervention according to the manual developed by the Danish College of Pharmacy Practice.236 The campaign targeted inappropriate use of triptans. Intervention pharmacy staff received information about migraine, detection of inappropriate triptan use and other drug-related problems, and techniques for establishing a private dialogue with patients.236 The campaign had no statistically significant impact on use of triptans (Appendix Table D110).236

## Key Question 2 What are the comparative harms from pharmacologic treatments for preventing migraine attacks in adults?

We identified 15 RCTs and six nonrandomized studies that examined the safety of onabotulinumtoxin A for chronic migraine prevention in adults. We identified 159 RCTs of 18,134 adults that examined the safety of drugs for episodic migraine prevention in adults.

Among approved drugs, onabotulinumtoxin A, topiramate, and propranolol resulted in bothersome adverse effects leading to treatment discontinuation more often than placebo.

The association was dose responsive for topiramate. Larger doses of topiramate caused higher risk of anorexia, depression, paresthesia, and difficulty in memory leading to treatment withdrawal. Larger doses of topiramate caused higher risk dry mouth, paresthesia or fatigue, mood problems, nausea, and weight loss.

Individual RCTs showed that divalproex caused adverse effects that led to treatment discontinuation, including nausea, somnolence, tremor, vomiting, and asthenia.

Among other drugs, pooled analyses demonstrated that off-label antidepressant amitriptyline caused bothersome adverse effects leading to treatment discontinuation more often than placebo.

Limited low-strength direct comparative evidence from individual head-to-head RCTs suggested that treatment discontinuation due to adverse effects was less frequent with onabotulinumtoxin A than topiramate or amitriptyline. Individual unique RCTs provided low-strength direct evidence about adverse effects with specific drugs with no consistent pattern across available drug comparisons.

Indirect adjusted analyses demonstrated no differences in treatment discontinuation due to adverse effects with approved drugs or approved versus off-label drugs. Exploratory Bayesian network meta-analyses demonstrated that topiramate and off-label antiepileptics and antidepressants resulted in bothersome adverse effects leading to treatment discontinuation more often than placebo. According to network meta-analysis, off-label angiotensin inhibiting drugs and beta blockers were the safest treatment option for adults with episodic migraine.

### KQ2a What are the harms from preventive pharmacologic treatments when compared with placebo or no active treatment?

We identified 83 RCTs that compared adverse drug effects with placebo. Most studies failed to disclose conflict of interest by trial investigators (Appendix Table D111). The results from these 83 trials that were a subset of RCTs that examined benefits with drugs for episodic migraine prevention in adults were applicable to the target population (Appendix Table D112). Women made up an average of 78 percent of all enrollees. Mean age of the enrollees varied from 29 to 49 years. Patients had an average 5.5 monthly migraine attacks. The trials followed for an average 18 weeks to assess adverse effects (Appendix Table D113). Sample size averaged 116 adults (range 12 to 818). RCTs reporting harms were not necessarily powered to detect statistically significant differences in adverse effects.

We concluded medium risk of bias in 54 RCTs and low risk of bias in 22 RCTs (Appendix Table D114). Most studies were double blind. Nonrandomized studies with high risk of bias suggested that 10 to 20 percent of patients discontinued antiepileptic drug treatments at one year or longer of followup (Appendix Table D115).

We focused on treatment discontinuation due to any and specific adverse effects from pooled analyses (Table 22).

Table 22 Treatment discontinuation due to adverse effects with migraine preventive drugs in adults, evidence from meta-analyzed randomized controlled clinical trials

Active Preventive Treatment | Sample | Rate, Percent With Drug [Control] | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed To Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Strength of Evidence Reasons for Lowering SOE
Compared With Placebo
Chronic Migraine
Onabotulinumtoxin A137,251 | 1384 | 3.8 [1.1] | 3.2 (1.4 to 7.1) | 0.03 (0.01 to 0.04) | 38 (23 to 100) | 26 (10 to 43) | Moderate (medium ROB)
Episodic Migraine
Topiramate27,85,96, 99,146,148,150,252 | 2055 | 16.6 [8.5] | 1.8 (1.3 to 2.4) | 0.06 (0.02 to 0.11) | 16(9 to 53) | 63(19 to 107) | Low (medium ROB, Imprecise)
Divalproex101,102 | 346 | 9.8 [7.8] | 1.2 (0.5 to 2.7) | 0.02 (−0.05 to 0.10) | NS | NS | Low (medium ROB, Imprecise, Inconsistent)
Valproate120,153 | 150 | 6.7 [5.3] | 1.3 (0.3 to 4.9) | 0.01 (−0.07 to 0.08) | NS | NS | Low (medium ROB, Imprecise)
Propranolol106,238 | 221 | 13.2 [5.6] | 2.1 (0.6 to 7.7) | 0.06 (0.00 to 0.12) | 16 (8 to 333) | 62 (3 to 120) | Low (medium ROB, Imprecise, Inconsistent)
Gabapentin87,110,111 | 270 | 17.0 [7.7] | 1.9 (0.9 to 4.2) | 0.07 (−0.01 to 0.15) | NS | NS | Low (medium ROB, Imprecise)
Lamotrigine99,240 | 178 | 12.8 [6.0] | 2.4 (0.5 to 12.2) | 0.14 (−0.17 to 0.44) | NS | NS | Low (Imprecise, Inconsistent)
Amitriptyline125,253 | 507 | 11.2 [5.8] | 1.9 (1.0 to 3.5) | 0.05 (0.01 to 0.10) | 19 (10 to 167) | 54 (6 to 102) | Low (medium ROB, Imprecise)
Femoxetine167,168 | 124 | 11.7 [6.3] | 1.9 (0.6 to 6.1) | 0.05 (−0.05 to 0.15) | NS | NS | Low (medium ROB, Imprecise)
Clonidine177,254 | 334 | 2.4 [0.6] | 2.8 (0.4 to 18.5) | 0.02 (−0.01 to 0.05) | NS | NS | Low (medium ROB, Imprecise)
Nimodipine112,244 | 155 | 3.9 [6.3] | 0.7 (0.2 to 2.6) | −0.03 (−0.09 to 0.04) | NS | NS | Low (medium ROB, Imprecise, Inconsistent)
Naproxen246,255 | 172 | 3.5 [1.2] | 2.3 (0.3 to 15.4) | 0.02 (−0.03 to 0.07) | NS | NS | Low (High ROB, Imprecise, Inconsistent)
Magnesium115,116 | 150 | 7.7 [1.4] | 3.8 (0.7 to 22.4) | 0.06 (0.00 to 0.13) | NS | NS | Low (Inconsistent Imprecise)
Compared With Active Treatment, Episodic Migraine
Topiramate vs. amitriptyline189,247 | 399 | 18.3 [21.3] | 0.9 (0.6 to 1.3) | −0.04 (−0.11 to 0.04) | NS | NS | Low (medium ROB, imprecision)

CI = confidence interval; ROB = risk of bias; SOE = strength of evidence; NS = not significant

Number needed to treat and number of attributable events were calculated for statistically significant differences.

#### Muscle Relaxants

##### Onabotulinumtoxin A

Fifteen RCTs examined the safety of botulinum toxin for chronic migraine prevention in adults including 13 RCTs of onabotulinumtoxin A and two RCTs of abobotulinumtoxin A (Appendix Table D8). Onabotulinumtoxin A resulted in adverse effects and treatment discontinuation due to adverse effects more often than placebo (Table 22). Pooled analyses demonstrated that per 1,000 patients treated, 155 experienced adverse effects and 26 discontinued treatments due to bothersome adverse effects (Table 23). The results were robust and remained significant with different methods of pooling (Appendix Tables D116 and D117). Abobotulinumtoxin A RCTs did not report treatment discontinuation due to adverse effects.139,144

Table 23 Adverse effect with onabotulinumtoxin A versus placebo for chronic migraine prevention in adults (magnitude of the effect and strength of evidence from randomized controlled clinical trials)

Adverse Effect | Sample, References | Rate, Percent With Onabotulinumtoxin A [Placebo] | Number Needed To Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Strength of Evidence
Any adverse effect | 5031^94,137,138,142,144,219,251,256,257^ | 47.5 [29.4] | 6 (5 to 11) | 155 (90 to 220) | Moderate
Back pain | 1112^93,138,257^ | 2.2 [0.5] | 59 (32 to 333) | 17 (3 to 31) | High
Discontinuations related to adverse effect | 1384^137,251^ | 3.8 [1.1] | 38 (23 to 100) | 26 (10 to 43) | Moderate
Dizziness | 893^93,94,139,257^ | 1.7 [0.9] | NS | NS | Moderate
Dysphagia | 1057^94,138^ | 3.3 [0.3] | 36 (23 to 83) | 28 (12 to 44) | High
Eyelid edema | 915^139,219,257^ | 3.6 [0.3] | NS | NS | High
Headache | 2204^94,138,139,219,256,257^ | 5.2 [4.5] | NS | NS | High
Hypertonia | 1426^94,138,257^ | 7.1 [1.3] | 16 (12 to 24) | 62 (42 to 82) | High
Neck pain | 2233^94,139,251,257^ | 14.1 [1.4] | 9 (6 to 17) | 111 (58 to 164) | Moderate
Neck rigidity | 1467^93,94,138,257^ | 9.2 [1.8] | 13 (9 to 24) | 75 (41 to 110) | Moderate
Pain | 2319^93,94,138,139,257^ | 3.6 [2.1] | NS | NS | Moderate
Blepharoptosis | 2454^92,94,138,139,144,219,256,257^ | 6.4 [0.8] | 20 (14 to 34) | 49 (29 to 69) | High
Muscle weakness | 1968^94,138,251,256^ | 15.8 [0.1] | 8 (5 to 18) | 132 (56 to 209) | Moderate
Fever | 587^93,139,219^ | 5.3 [7.1] | NS | NS | Moderate

CI = confidence interval; NS = not significant

Bold = Differences were significant when 95% CI of attributable events per 1,000 treated do not include 0.

Number needed to treat and number of attributable events were calculated for statistically significant differences.

Among individual adverse effects, neck pain and muscle weakness were the most common (Table 23). Increase in risk of adverse effects with onabotulinumtoxin A was lower in trials with higher placebo rates of adverse effects (Table 24). Increase in risk of adverse effects was dose responsive (Appendix Table D118). Patients experienced eyelid edema with 50U of onabotulinumtoxin A more often than with 25U.219 Higher doses of 150 to 225U of onabotulinumtoxin A resulted in greater risk of blepharoptosis, muscle weakness, and neck rigidity (Appendix Table D118).

Table 24 Adverse effects with onabotulinumtoxin A versus placebo in adults with chronic migraine, meta-regression by study level factors (log of relative risk in randomized controlled clinical trials)

Contributing Factor | Adverse Effect | Contributing Variable | Meta-Regression Coefficient | Lower 95% CI | Upper 95% CI
Drug | Blepharoptosis | Dose | 0.00 | −0.01 | 0.01
Patient | Blepharoptosis | Age | 0.22 | −0.30 | 0.74
Patient | Blepharoptosis | Years of migraine | −0.05 | −0.11 | 0.01
Study | Blepharoptosis | Percent of women | −0.02 | −0.15 | 0.11
Study | Blepharoptosis | Control rate | 0.99 | −102.24 | 104.22
Study | Blepharoptosis | Loss of followup | −0.04 | −0.10 | 0.03
Study | Blepharoptosis | Risk of bias | −0.56 | −1.79 | 0.67
Drug | Adverse effects | Dose | 0.00 | 0.00 | 0.01
Patient | Adverse effects | Age | 0.04 | −0.12 | 0.20
Patient | Adverse effects | Years of migraine | −0.05 | −0.11 | 0.01
Study | Adverse effects | Percent of women | −0.02 | −0.15 | 0.11
Study | Adverse effects | Control rate | −1.92 | −2.46 | −1.37
Study | Adverse effects | Loss of followup | 0.02 | 0.00 | 0.04
Study | Adverse effects | Risk of bias | 0.06 | −0.34 | 0.47
Drug | Headache | Dose | 0.00 | 0.00 | 0.01
Patient | Headache | Age | 0.25 | −0.16 | 0.67
Patient | Headache | Years of migraine | 0.01 | −0.10 | 0.11
Study | Headache | Percent of women | −0.08 | −0.25 | 0.08
Study | Headache | Control rate | 8.52 | −34.54 | 51.59
Study | Headache | Loss of followup | 0.01 | −0.03 | 0.06
Study | Headache | Risk of bias | −0.11 | −1.24 | 1.02

CI = confidence interval|

Bold = significant differences at 95% confidence limit when 95% CI do not include 0.

##### Abobotulinumtoxin A

Abobotulinumtoxin A RCTs reported increased risk of neck weakness in 109 patients per 1,000 treated (95% CI, 22 to 196).139,144 The rates of the total adverse effects were statistically higher with the increased dose of the drug (210U versus 80U).144 The rates of specific adverse effects did not differ between the active drug and placebo.139,144

#### Antiepileptics

##### Topiramate

Most RCTs that examined safety with topiramate versus placebo for episodic migraine prevention in adults (Appendix Table D119) were funded by industry and reported conflict of interest by principal investigators (Appendix Table D120). All trials were double blind (Appendix Table D121).

Patients stopped taking topiramate more often than placebo because of intolerable adverse effects including fatigue, paresthesia, and taste perversion (Table 25). Topiramate in doses of 100 and 200 mg/day (but not 50 mg/day) resulted in treatment discontinuation due to adverse effects more often than placebo (Appendix Table D122). Compared with placebo, topiramate more often resulted in bothersome taste perversion, paresthesia, and fatigue leading to withdrawal (Appendix Table D123).

Table 25 Treatment discontinuation due to adverse effects with topiramate versus placebo in adults, pooled with random effects results from randomized controlled clinical trials

Reason for Treatment Discontinuation References | Sample | Rate with Topiramate [Placebo] | Pooled Relative Risk (95% CI) | Pooled Absolute Risk Difference (95% CI) | Number Needed To Treat To Harm (95% CI) | Attributable Events per 1,000 Treated (95% CI)
Cognitive difficulties27,96,252 | 939 | 7.3 [2.0] | 2.8 (0.5 to 15.3) | 0.05 (−0.02 to 0.12) | NS | NS
Difficulty with memory237,252 | 765 | 1.7 [1.1] | 1.2 (0.1 to 16.3) | 0.01 (−0.01 to 0.03) | NS | NS
Dizziness27,252 | 824 | 1.9 [2.0] | 0.7 (0.1 to 5.1) | −0.02 (−0.11 to 0.07) | NS | NS
Fatigue27, 105,252 | 824 | 4.5 [0.9] | 2.8 (0.4 to 21.2) | 0.04 (0.01 to 0.06) | 28 (17 to 71) | 36 (14 to 58)
Insomnia27,252 | 824 | 3.1 [1.2] | 1.3 (0.1 to 15.1) | 0.01 (−0.04 to 0.06) | NS | NS
Language problems237,252 | 766 | 2.2 [0.4] | 3.7 (0.7 to 20.3) | 0.02 (0.00 to 0.03) | NS | 15 (0 to 31)
Paresthesia27,96,252 | 939 | 8.4 [0.7] | 9.6 (3.5 to 26.5) | 0.08 (0.05 to 0.10) | 13 (10 to 20) | 75 (49 to 101)
Somnolence96,237 | 831 | 2.1 [1.8] | 1.1 (0.4 to 3.2) | 0.00 (−0.02 to 0.02) | NS | NS
Taste perversion96,237,252 | 881 | 1.5 [0.0] | 3.8 (0.7 to 21.4) | 0.01 (0.00 to 0.02) | 77 (42 to 1000) | 13 (1 to 24)

CI = confidence interval; NS = not significant

Bold = significant differences when 95% CI of absolute risk difference do not include 0.

Number needed to treat and number of attributable events were calculated for statistically significant differences.

Pooled estimates were consistent with imprecision that decreased strength of evidence. Per 1,000 treated, topiramate resulted in bothersome adverse effects leading to treatment discontinuation in 36 (with 100 mg/day) or 146 (with 200 mg/day) patients. Published pooled analysis of individual patient data demonstrated topiramate discontinuation due to anorexia, anxiety, depression, hypoesthesia, and nausea (Appendix Table D124).237 Some adverse effects leading to treatment discontinuation were reported in individual RCTs that failed to show statistically significant increase in risk of specific harms with topiramate (Appendix Table D125).

Topiramate increased risk of specific adverse effects. Individual RCTs reported small numbers of events. Pooled analyses demonstrated a statistically significant increase in risk of any adverse effect, paresthesia, cognitive difficulties, diarrhea, dry mouth, fatigue, nausea, taste alteration or perversion, and weight loss (Appendix Table D126). Topiramate caused adverse effects in one patient for every eight treated. Taste alteration, weight loss, and paresthesia were the most common adverse effects (Table 26). Individual RCTs reported increased risk of severe anorexia and mood problems (Table D127).

Table 26 Adverse effects with topiramate in adults with migraine, significant results from pooled analysis of randomized controlled clinical trials

Outcome, Reference | Sample | Rate With Topiramate [Placebo] | Relative Risk (95% CI) | Absolute Risk Difference (95% CI) | Number Needed To Treat To Harm (95% CI) | Attributable Events per 1,000 Treated (95% CI)
Adverse events85,99,100,146,148,237 | 1700 | 59.9 [56.1] | 1.2 (1.0 to 1.3) | 0.12 (0.02 to 0.22) | 8 (4 to 42) | 124 (24 to 223)
Paresthesia85,95,96,98–100,146,148,237,252 | 1876 | 24.0 [5.5] | 4. 7(3.4 to 6.3) | 0.24 (0.14 to 0.33) | 4 (3 to 7) | 235 (142 to 328)
Weight decrease85,95,96,149,237,252 | 1648 | 12.3 [4.4] | 3.6 (1.5 to 8.3) | 0.10 (0.05 to 0.15) | 10 (6 to 19) | 104 (53 to 154)
Cognitive difficulties96,100,105,146,149,237,52 | 1782 | 8[3] | 2.2 (1.1 to 4.4) | 0.045 (0.01 to 0.08) | 22(13 to 100) | 45 (10 to 80)
Diarrhea148,150,237 | 1170 | 9.8 [3.6] | 2.7 (1.5 to 4.7) | 0.06 (0.01 to 0.10) | 18 (10 to 71) | 57 (14 to 100)
Dry mouth86,148,237 | 1429 | 6.1 [2.7] | 2.5 (1.4 to 4.3) | 0.04 (0.01 to 0.06) | 29 (18 to 71) | 35 (14 to 57)
Fatigue100,237 | 1857 | 9.6 [4.6] | 1.7 (1.3 to 2.3) | 0.05 (0.03 to 0.08) | 20 (13 to 38) | 50 (26 to 75)
Hyperesthesia146,148,237 | 1756 | 7.4 [1.6] | 3.5 (1.8 to 6.5) | 0.06 (0.03 to 0.08) | 18 (13 to 30) | 57 (33 to 80)
Insomnia84,105,150,252 | 878 | 4 [2] | 1.6 (0.5 to 4.7) | 0.02 (0.001 to 0.04) | NS | 21 (1 to 42)
Memory impairment85,86,100,105,150,237,252 | 1436 | 10.4 [3.9] | 2.4 (1.2 to 4.6) | 0.058 (0.017 to 0.099) | 17 (10 to 59) | 58 (17 to 99)
Nausea85,105,146,148,149,237 | 2156 | 11[6] | 1.5 (1.1 to 2.0) | 0.034 (0.003 to 0.065) | 29 (15 to 333) | 34 (3 to 65)
Taste perversion86,95,96,105,148,237,252 | 1634 | 5.9 [1.3] | 4.9 (2.5 to 9.8) | 0.083 (0.025 to 0.14) | 12 (7 to 40) | 83 (25 to 140)
Abdominal pain149,237 | 1229 | 2.0 [2.3] | 0.9 (0.4 to 2.0) | 0.00 (−0.02 to 0.02) | NS | NS
Anorexia85,95,99,100,146,148,149,237,252 | 2424 | 5.6 [3.3] | 1.8 (1.2 to 2.7) | 0.03 (0.00 to 0.05) | NS | NS
Back pain148,237 | 1100 | 4.6 [5.1] | 0.9 (0.5 to 1.6) | 0.00 (−0.03 to 0.02) | NS | NS
Giddiness85,99,100,146,148,237,252 | 1871 | 10.1 [7.8] | 1.2 (0.8 to 1.7) | 0.01 (−0.02 to 0.04) | NS | NS
Dyspepsia100,237 | 1018 | 1.5 [1.1] | 1.3 (0.4 to 3.8) | 0.01 (−0.03 to 0.05) | NS | NS
Infection, viral100,148 | 444 | 8.2 [8.0] | 1.0 (0.6 to 1.9) | 0.00 (−0.05 to 0.05) | NS | NS
Injury146,148,237 | 1672 | 5.0 [6.1] | 0.8 (0.2 to 3.2) | −0.01 (−0.07 to 0.04) | NS | NS
Adverse events: Serious86,149 | 842 | 7.9 [6.6] | 1.1 (0.6 to 2.1) | 0.01 (−0.05 to 0.06) | NS | NS
Sinusitis146,148,237 | 1429 | 7.4 [6.4] | 1.1 (0.7 to 1.7) | 0.01 (−0.02 to 0.03) | NS | NS
Sleepiness85,86,96,98,100,148,237,252 | 1893 | 4.4 [3.4] | 1.5 (0.8 to 3.0) | 0.02 (−0.01 to 0.04) | NS | NS
Language problems150,237,252 | 657 | 3.6 [0.5] | 4.8 (1.1 to 20.5) | 0.09 (−0.03 to 0.21) | NS | NS
Upper respiratory tract infection85,86,148,237 | 1641 | 8.7 [9.0] | 1.0 (0.7 to 1.4) | 0.00 (−0.03 to 0.03) | NS | NS
Vision, abnormal95,237 | 756 | 7.7 [2.2] | 3.3 (1.4 to 7.8) | 0.07 (−0.01 to 0.15) | NS | NS

CI = confidence interval; NS = not significant

Number needed to treat and number of attributable events were calculated for statistically significant differences.

Bold = significant differences when 95% CI of absolute risk difference do not include 0.

Risk of adverse effects was dose responsive according to the published pooled analyses of individual patient data (Appendix Table D128).237 Larger doses of topiramate increased risk of anorexia, depression, paresthesia, and difficulty in memory leading to treatment withdrawal.237 Larger doses of topiramate increased risk of dry mouth, paresthesia or fatigue, mood problems, nausea, and weight loss.237

##### Divalproex

Adverse effects with divalproex versus placebo were examined in three RCTs that examined efficacy of divalproex for episodic migraine prevention in adults (Appendix Table D25). All three RCTs were funded by industry (Appendix Table D26) and all were double blind (Appendix Table D27).

Treatment discontinuation due to adverse effects did not differ with divalproex versus placebo (Table 22 and Appendix Table D122).101,102 Divalproex caused alopecia, asthenia, nausea, and tremor more often than placebo (Table 27). Strength of evidence was low because of risk of bias and imprecision of the treatment effects. Larger doses of divalproex did not increase risk of bothersome adverse effects leading to treatment discontinuation (Appendix Table D129).103 Larger doses of divalproex increased risk of nausea and tremor (Appendix Table D130).103

Table 27 Treatment discontinuation due to bothersome adverse effects and adverse effects with divalproex versus placebo for episodic migraine prevention in adults, results from randomized controlled clinical trials

Outcome | Daily Dose | Reference | Sample | Rate, Percent With Divalproex [Placebo] | Number Needed To Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Strength of Evidence
Discontinuations due to intolerance | Mean average dose 1087 mg/d | Mathew, 1995^101^ | 107 | 12.9 [5.4] | NS | NS
Discontinuations due to intolerance | Mean average dose 871 mg/d | Freitag, 2002^102^ | 239 | 8.1 [8.6] | NS | NS
Discontinuations due to intolerance | Pooled | | 346 | 9.8 [7.8] | NS | NS | Low
Abdominal pain | Mean average dose 871 mg/d | Freitag, 2002^102^ | 239 | 6.5 [5.2] | NS | NS | Low
Alopecia | Mean average dose 1087 mg/d | Mathew, 1995 101 | 107 | 12.9 [0.0] | 8 (5 to 24) | 129 (41 to 216) | Low
Any | Mean average dose 871 mg/d | Freitag, 2002^102^ | 239 | 67.5 [69.8] | NS | NS | Low
Asthenia | Mean average dose 1087 mg/d | Mathew, 1995 101 | 107 | 31.4 [8.1] | 4 (3 to 11) | 233 (93 to 373) | Low
Asthenia | 500 mg | Klapper, 1997^103^ | 60 | 8.9 [9.1] | NS | NS | Low
Asthenia | 1000 mg | Klapper, 1997^103^ | 57 | 9.3 [9.1] | NS | NS | Low
Asthenia | 1500 mg | Klapper, 1997^103^ | 58 | 22.7 [9.3] | NS | NS | Low
Asthenia | Mean average dose 871 mg/d | Freitag, 2002^102^ | 239 | 7.3 [10.3] | NS | NS | Low
Back pain | 500 mg | Klapper, 1997^103^ | 60 | 6.7 [9.1] | NS | NS | Low
Back pain | 1000 mg | Klapper, 1997^103^ | 57 | 4.7 [9.1] | NS | NS | Low
Back pain | 1500 mg | Klapper, 1997^103^ | 58 | 13.6 [9.3] | NS | NS | Low
Diarrhea | 500 mg | Klapper, 1997^103^ | 60 | 6.7 [4.5] | NS | NS | Low
Diarrhea | 1000 mg | Klapper, 1997^103^ | 58 | 4.7 [4.5] | NS | NS | Low
Diarrhea | 1500 mg | Klapper, 1997^103^ | 59 | 18.2 [4.6] | NS | NS | Low
Diarrhea | Mean average dose 871 mg/d | Freitag, 2002^102^ | 239 | 7.3 [3.4] | NS | NS | Low
Dizziness | 500 mg | Klapper, 1997^103^ | 60 | 6.7 [4.5] | NS | NS | Low
Dizziness | 1000 mg | Klapper, 1997^103^ | 58 | 7.0 [4.5] | NS | NS | Low
Dizziness | 1500 mg | Klapper, 1997^103^ | 59 | 20.5 [4.6] | NS | NS | Low
Dyspepsia | 500 mg | Klapper, 1997^103^ | 60 | 6.7 [9.1] | NS | NS | Low
Dyspepsia | 1000 mg | Klapper, 1997^103^ | 57 | 18.6 [9.1] | NS | NS | Low
Dyspepsia | 1500 mg | Klapper, 1997^103^ | 58 | 15.9 [9.3] | NS | NS | Low
Dyspepsia | Mean average dose of study: 871 mg/d | Freitag, 2002^102^ | 239 | 6.5 [4.3] | NS | NS | Low
Flu syndrome | Mean average dose of study: 871 mg/d | Freitag, 2002^102^ | 239 | 8.1 [8.6] | NS | NS | Low
Infection | 500 mg | Klapper, 1997^103^ | 60 | 17.8 [18.2] | NS | NS | Low
Infection | 1000 mg | Klapper, 1997^103^ | 58 | 16.3 [18.2] | NS | NS | Low
Infection | 1500 mg | Klapper, 1997^103^ | 59 | 20.5 [18.6] | NS | NS | Low
Infection | Mean average dose of study: 871 mg/d | Freitag, 2002^102^ | 239 | 14.6 [13.8] | NS | NS | Low
Nausea | Mean average dose of divalproex sodium was 1087 mg/d | Mathew, 1995 101 | 107 | 45.7 [13.5] | 3 (2 to 6) | 322 (162 to 482) | Low
Nausea | 500 mg | Klapper, 1997 103 | 60 | 26.7 [6.8] | 5 (3 to 52) | 200 (19 to 381) | Low
Nausea | 1000 mg | Klapper, 1997^103^ | 57 | 9.3 [6.8] | NS | NS | Low
Nausea | 1500 mg | Klapper, 1997 103 | 59 | 34.1 [7.0] | 4 (2 to 12) | 274 (86 to 463) | Low
Nausea | Mean average dose of study: 871 mg/d | Freitag, 2002^102^ | 239 | 14.6 [8.6] | NS | NS | Low
Pain | 500 mg | Klapper, 1997^103^ | 60 | 8.9 [6.8] | NS | NS | Low
Pain | 1000 mg | Klapper, 1997^103^ | 57 | 7.0 [6.8] | NS | NS | Low
Pain | 1500 mg | Klapper, 1997^103^ | 59 | 11.4 [7.0] | NS | NS | Low
Sinusitis | Mean average dose of study: 871 mg/d | Freitag, 2002^102^ | 239 | 3.3 [7.8] | NS | NS | Low
Somnolence | Mean average dose 1087 mg/d | Mathew, 1995 101 | 107 | 30.0 [5.4] | 4 (3 to 9) | 246 (116 to 376) | Low
Somnolence | 500 mg | Klapper, 1997^103^ | 60 | 6.7 [4.5] | NS | NS | Low
Somnolence | 1000 mg | Klapper, 1997^103^ | 58 | 7.0 [4.5] | NS | NS | Low
Somnolence | 1500 mg | Klapper, 1997^103^ | 59 | 18.2 [4.6] | NS | NS | Low
Somnolence | Mean average dose of study: 871 mg/d | Freitag, 2002^102^ | 239 | 6.5 [1.7] | NS | NS | Low
Tremor | Mean average dose 1087 mg/d | Mathew, 1995 101 | 107 | 12.9 [0.0] | 8 (5 to 24) | 129 (41 to 216) | Low
Tremor | 500 mg | Klapper, 1997^103^ | 60 | 0.0 [0.0] | NS | NS | Low
Tremor | 1000 mg | Klapper, 1997^103^ | 57 | 7.0 [0.0] | NS | NS | Low
Tremor | 1500 mg | Mathew, 1995 101 | 59 | 15.9 [0.0] | 6 (3 to 48) | 159 (21 to 297) | Low
Vomiting | Mean average dose 1087 mg/d | Mathew, 1995 101 | 107 | 18.6 [0.0] | 5 (4 to 11) | 186 (88 to 284) | Low
Vomiting | 500 mg | Klapper, 1997^103^ | 60 | 4.4 [2.3] | NS | NS | Low
Vomiting | 1000 mg | Klapper, 1997^103^ | 57 | 4.7 [2.3] | NS | NS | Low
Vomiting | 1500 mg | Klapper, 1997^103^ | 58 | 11.4 [2.3] | NS | NS | Low
Vomiting | Mean average dose of study: 871 mg/d | Freitag, 2002^102^ | 239 | 6.5 [1.7] | NS | NS | Low

CI = confidence interval; NS = not significant

Bold = significant difference at 95% confidence limit when 95% CI of attributable events per 1,000 treated do not include 0.

Number needed to treat and number of attributable events were calculated for statistically significant differences.

##### Valproate

Adverse effects of valproate were examined in two small double-blind RCTs of 75 adults that examined efficacy of valproate for episodic migraine prevention in adults (Appendix Tables D25–D27).

Treatment discontinuation due to adverse effects did not differ with valproate versus placebo (Table 22).153 Rates of combined adverse effects did not differ between valproate and placebo (Appendix Table D131).120,153

#### Beta Blockers

##### Propranolol

All RCTs that examined safety with propranolol versus placebo in adults with episodic migraine (Appendix Table D31) were double blind but did not analyze the data according to planned intention-to-treat principles (Appendix Table D33). Propranolol increased risk of bothersome adverse effects leading to treatment discontinuation more often than placebo (Table 22).106,238

Propranolol resulted in adverse effects more often than placebo (Appendix Table D132). Among individual adverse effects, propranolol more often than placebo resulted in diarrhea (pooled 89 attributable events per 1,000 treated; 95% CI, 14 to 164) and nausea (pooled 43 attributable events per 1,000 treated 95% CI, 9 to 77).

##### Timolol

Treatment discontinuation due to bothersome adverse effects did not differ with timolol and placebo in adults with episodic migraine (low-strength evidence from individual RCT) (Table 28). Timolol increased risk of overall adverse effects but not of any specific examined adverse effects more often than placebo (Appendix Tables D133 and D134).

Table 28 Treatment discontinuation due to adverse effects with propranolol or timolol for episodic migraine prevention in adults, results from randomized controlled clinical trials

| Active Treatment | Control Treatment | Reference | Sample | Rate With Active Treatment, Percent | Rate With Control Treatment, Percent | Number Needed To Treat (95% CI) | Attributable Events (95% CI) | Strength of Evidence
Treatment discontinuation due to adverse effects | Propranolol | Aspirin | Baldrati, 1983^249^ | 36 | 11.1 | 16.7 | NS | NS | Low
Moderate chest pain on day 28 leading to discontinuation | Timolol | Placebo | Stellar, 1984^109^ | 94 | 2.1 | 0 | NS | NS | Low
Discontinued therapy because of severe epigastric distress and fecal impaction | Timolol | Placebo | Stellar, 1984^109^ | 94 | 2.1 | 0 | NS | NS | Low
Withdrew due to adverse experiences | Timolol | Placebo | Stellar, 1984^109^ | 94 | 4.3 | 0 | NS | NS | Low

CI = Confidence interval; NS = not significant

Bold = significant at 95% confidence limit when 95% CI of attributable events per 1,000 treated do not include 0.

Number needed to treat and number of attributable events were calculated for statistically significant differences.

#### Off-Label Drugs

##### Antiepileptics

All RCTs that examined the safety of six off-label antiepileptic drugs for episodic migraine, including acetazolamide, gabapentin, vigabatrin, oxcarbazepine, carbamazepin, and lamotrigine (Appendix Table D39) were double blind (Appendix Table D41). Pooled analyses demonstrated no differences in treatment discontinuation due to adverse effects with gabapentin or lamotrigine versus placebo (Table 22 and Appendix Table D135) but increase in risk of the total adverse effects with gabapentin (Appendix Table D136). Antiepileptic drugs increased risk of the specific adverse effects as follows.

###### Acetazolamide

Acetazolamide caused paresthesia, drowsiness, memory impairment, malaise, and fasciculation more often than placebo in adults with episodic migraine (Appendix Table D137).117

###### Carbamazepin

Carbamazepin caused adverse effects that led to dose reductions more often than placebo in adults with episodic migraine. Specific adverse effects included vertigo and drowsiness. (Appendix Table D138).118

###### Gabapentin

Gabapentin caused somnolence and dizziness more often than placebo in adults with episodic migraine (Appendix Table D139)111; [underlined: however, the validity of the results was questioned due to exclusion of patients from the analyses and biased tolerability conclusions.]239

###### Lamotrigine

Treatment discontinuation due to the specific side effects, including rash, occurred more frequently with lamotrigine than placebo in adults with episodic migraine (Appendix Table D140).240 A fixed dose of 200 mg/day of lamotrigine caused skin rash more often than placebo. In contrast, a gradually escalated dose of lamotrigine starting with 25 mg/day did not cause skin rash.240

###### Oxcarbazepine

Oxcarbazepine caused adverse effects including fatigue, dizziness, and nausea more often than placebo in adults with episodic migraine (Appendix Table D141).119

#### Antidepressants

Pooled analyses demonstrated that amitriptyline but not femoxetine caused adverse effects leading to treatment discontinuation more often than placebo in adults with episodic migraine (Table 22). Amitriptyline increased the risk of dizziness, drowsiness, and constipation (Appendix Table D142). Femoxetine and fluoxetine increased the risk of any adverse effects (Appendix Table D142).

#### Cortical Spreading Depression Inhibitor

Individual RCTs demonstrated no differences between placebo and tonabersat in treatment discontinuation due to bothersome adverse effects in adults with episodic migraine.127

#### Beta Blockers

##### Atenolol

Treatment discontinuation due to bothersome adverse effects did not differ between atenolol and placebo in adults with episodic migraine (Appendix Table D143).123,159,241 Less than 1 percent of participants discontinued atenolol due to bothersome side effects (Appendix Table D144).123,159,241 Among all examined adverse effects, only rates of slight orthostatic dizziness during the first week of treatments were greater with atenolol than with placebo.

##### Bisoprolol

Treatment discontinuation due to bothersome adverse effects did not differ between bisoprolol and placebo in adults with episodic migraine.227 In fact, side effects occurred no more often from bisoprolol than from placebo (Appendix Table D144). A higher dose of bisoprolol did not result in greater rates of adverse effects or treatment discontinuation due to adverse effects.227 Bisoprolol, 10 mg/day, decreased heart rate when compared with 5 mg/day.227 Systolic and diastolic blood pressure did not differ with two doses of bisoprolol.227

##### Metoprolol

Treatment discontinuation due to bothersome adverse effects did not differ between metoprolol and placebo in adults with episodic migraine.114 Rates of total adverse effects were greater with metoprolol than with placebo in a single RCT.113 Metoprolol caused fatigue and sleep disturbances more often than placebo (Appendix Table D145).113

##### Nadolol

Treatment discontinuation due to bothersome adverse effects did not differ between nadolol and placebo in adults with episodic migraine.124 In fact, nadolol caused adverse effects no more often than placebo. An increased dose of nadolol did not result in greater rates of adverse effects.225,226

##### Pindolol

Treatment discontinuation due to bothersome adverse effects did not differ with pindolol and placebo in adults with episodic migraine.160 Patients experienced orthostatic dizziness and faintness more often with pindolol than with placebo.160

#### Ergot Alkaloids

In individual underpowered RCTs, treatment discontinuation due to bothersome adverse effects did not differ with placebo, lisuride, or methysergide in adults with episodic migraine.131,242

#### Angiotensin Converting Enzyme Inhibitors

Individual RCTs of adults with episodic migraine did not examine treatment discontinuation to bothersome adverse effects with lisinopril128 or captopril.88 Captopril caused adverse effects no more often than placebo.88 The rates of any adverse effects were greater with lisinopril than placebo; however, rates of the most common adverse effects with ACE inhibitors (coughing, fatigue, dizziness, or tendency to faint) did not differ between lisinopril and placebo.128

#### Angiotensin II Antagonists

Individual RCTs did not examine treatment discontinuation to bothersome adverse effects with candesartan129 or telmisartan in adults with episodic migraine.173 Neither drug caused any adverse effect more often than placebo.129,173

#### Calcium Channel Antagonists

Treatment discontinuation due to bothersome adverse effects did not differ between placebo and nifedipine,243 nimodipine,112,244 or verapamil in adults with episodic migraine.171

Compared with placebo, verapamil more often caused tolerable constipation that did not result in treatment discontinuation.171 Nifedipine resulted in adverse effects more often than placebo.243 Among individual adverse effects, nifedipine increased rates of headache, dizziness, and edema.243 Nimodipine increased rates of abdominal cramps but no other examined adverse effects.89

#### NSAID

Individual RCTs found no differences in bothersome adverse effects leading to treatment discontinuation with fenoprofen,245 naproxen sodium,246 or tolfenamic acid in adults with episodic migraine.134 Among individual adverse effects, fenoprofen increased rates of fatigue and somnolence.245

### KQ2b What are the harms from preventive pharmacologic treatments when compared with active pharmacologic treatments?

There was low-strength evidence from individual RCTs that examined comparative safety with migraine preventive drugs.

#### Muscle Relaxants

##### Onabotulinumtoxin A for Chronic Migraine

Comparative safety of onabotulinumtoxin A versus topiramate was examined in two RCTs that demonstrated better safety with onabotulinumtoxin A than topiramate (Appendix Table D146).183,186 Patients experienced depression or mood disturbance, weight loss, paresthesias, or cognitive deficits more often with topiramate (Appendix Table D146).183,186

A single RCT examined the comparative safety of onabotulinumtoxin A versus divalproex sodium and found a higher risk of ptosis with onabotulinumtoxin A (Appendix Table D147).184 In contrast, risk of fatigue, nausea, and total adverse effects was higher with divalproex (Appendix Table D147).

A single RCT examined the comparative safety of onabotulinumtoxin A versus amitriptyline and concluded better safety with onabotulinumtoxin A (Appendix Table D148).185 Patients experienced dry mouth, constipation, somnolence, and weight gain several times more often with amitriptyline than with onabotulinumtoxin A.185

##### Topiramate

Treatment discontinuation due to adverse effects did not differ between topiramate and amitriptyline in adults with episodic migraine (Table 22).189,247 Comparative safety of topiramate with other drugs was examined in individual RCTs. Treatment discontinuation due to any adverse effects did not differ between topiramate and zonasamide or valproate (Table 29). Treatment discontinuation due to specific adverse effects differed with topiramate and other drugs according to individual RCTs (Appendix Table D149). Somnolence or weight increase leading to withdrawal was less common with topiramate than amitriptyline (Table 29).189,247 Treatment discontinuation to treatment failure, however, did not differ between topiramate and amitriptyline or lamotrigine (Appendix Table D150).

Table 29 Treatment discontinuation due to any adverse effects with topiramate versus other drugs for episodic migraine prevention in adults

Adverse Effects Leading to Withdrawal | Active | Control | Reference | Sample | Rate, Percent With Topiramate [Control Drug] | Number Needed To Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Strength of Evidence
Aggravation of migraine leading to withdrawal | Topiramate | Amitriptyline | Dodick, 2009^189^ | 347 | 0.0 [1.8] | NS | NS | Low
Anxiety leading to withdrawal | Topiramate | Amitriptyline | Dodick, 2009^189^ | 347 | 1.7 [0.0] | NS | NS | Low
Confusion leading to withdrawal | Topiramate | Amitriptyline | Dodick, 2009^189^ | 347 | 1.7 [0.0] | NS | NS | Low
Dizziness leading to withdrawal | Topiramate | Amitriptyline | Dodick, 2009^189^ | 347 | 1.7 [0.0] | NS | NS | Low
Dry mouth leading to withdrawal | Topiramate | Amitriptyline | Dodick, 2009^189^ | 347 | 0.0 [1.8] | NS | NS | Low
Fatigue leading to withdrawal | Topiramate | Amitriptyline | Dodick, 2009^189^ | 347 | 3.4 [2.4] | NS | NS | Low
Hypoesthesia leading to withdrawal | Topiramate | Amitriptyline | Dodick, 2009^189^ | 347 | 1.7 [0.0] | | | Low
Somnolence leading to withdrawal | Topiramate | Amitriptyline | Dodick, 2009 189 | 347 | 0.0 [4.1] | −24 (14 to 104) | −41 (10 to 73) | Low
Weight increase leading to withdrawal | Topiramate | Amitriptyline | Dodick, 2009 189 | 347 | 0.0 [4.7] | −21 (12 to 73) | −47 (14 to 81) | Low
Withdrew due to drowsiness | Topiramate | Valproate (slow-release) | Bartolini, 2005^191^ | 44 | 9.1 [13.6] | NS | NS | Low
Left the study due to impaired concentration | Topiramate | Zonasamide | Mohammadianinejad, 2011^190^ | 80 | 0.0 [2.5] | NS | NS | Low
Left the study due to intolerable paresthesia | Topiramate | Zonasamide | Mohammadianinejad, 2011^190^ | 80 | 5.0 [0.0] | NS | NS | Low
Left the study due to unbearable restless leg syndrome | Topiramate | Zonasamide | Mohammadianinejad, 2011^190^ | 80 | 0.0 [2.5] | NS | NS | Low
Discontinued due to adverse effects | Topiramate 100mg | Amitriptyline 100mg | Dodick, 2009^189^ | 347 | 19.7 [22.5] | NS | NS | Low
Discontinued due to adverse effects | Topiramate + Amitriptyline amitriptyline | Amitriptyline | Keskinbora, 2008^247^ | 51 | 4.3 [14.3] | NS | NS | Low
Discontinued due to adverse effects | Topiramate 200mg | Amitriptyline 150mg | Keskinbora, 2008^247^ | 52 | 8.3 [14.3] | NS | NS | Low
Discontinued due to adverse effects | Topiramate 200mg) | Topiramate + Amitriptyline | Keskinbora, 2008^247^ | 47 | 8.3 [4.3] | NS | NS | Low
Discontinued due to adverse effects | Topiramate 25mg BD | Lamotrigine 25mg BD | Gupta, 2007^99^ | 120 | 5.0 [5.0] | NS | NS | Low
Discontinued due to adverse effects | Topiramate 100mg BD | Levetiracetam 1000mg BD | de Tommaso, 2007^192^ | 28 | 7.7 [0.0] | NS | NS | Low

CI = confidence interval; NS = not significant

Bold = significant at 95% confidence limit when 95% CI of attributable events per 1,000 treated do not include 0.

Number needed to treat and number of attributable events were calculated for statistically significant differences.

Risk of specific adverse effects differed between topiramate and other drugs in individual RCTs in adults with episodic migraine (Appendix Table D151). Topiramate increased risk of weight loss when compared with amitriptyline,189 levetiracetam,192 and valproate248 (Appendix Table D151). Topiramate increased risk of paresthesia when compared with amitriptyline189,247 (Appendix Table D151). Risk of dry mouth and constipation was lower with topiramate than amitriptyline (Appendix Table D152).189,247 Individual RCTs demonstrated higher risk of headache with topiramate than amitriptyline (Appendix Table D153).

Comparative safety of topiramate combined with amitriptyline versus monotherapy was examined in one small RCT.247 Treatment discontinuation due to adverse effects did not differ between topiramate combined with amitriptyline and monotherapy.247 The risk of adverse effects was lower with combined therapy when compared with amitriptyline alone but not topiramate alone (Appendix Table D154).247

#### Beta Blockers for Episodic Migraine

##### Propranolol

Treatment discontinuation due to bothersome adverse effects did not differ between propranolol and aspirin (Table 28).249 Evidence of comparative safety with propranolol ergotamine intake was insufficient due to high risk of bias in individual RCT (Appendix Table D155).

Treatment discontinuation due to adverse effects did not differ between behavioral migraine management and propranolol (Appendix Table D156).217 Treatment discontinuation due to bothersome adverse effects did not differ between combined behavioral migraine management with propranolol versus propranolol alone.217 Combined therapy was more effective than propranolol alone in having self-efficacy and internal control over headache (Appendix Table D157).218

#### Off-Label Drugs for Episodic Migraine

##### Off-Label Beta Blockers

###### Metoprolol Versus Clonidine

Metoprolol resulted in treatment discontinuation due to bothersome adverse effects or treatment failure less often than clonidine (Table 30 and Appendix Table D158).207

Table 30 Comparative safety of beta blockers for episodic migraine prevention in adults, treatment discontinuation due to bothersome adverse effects in randomized controlled clinical trials

Definition of the Outcome | Reference | Active Drug | Control Drug | Sample | Rate of Outcome in Active Group [Rate of Outcome in Control Group], Percent | Number Needed To Treat To Harm One Patient (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Strength of Evidence
Withdrew because of side effects and/or lack of efficacy | Louis, 1985 207 | Metoprolol | Clonidine | 62 | 0.0 [12.9] | −8 (4 to 870) | −129 (1 to 257) | Low
Discontinued due to side-effects | Worz, 1991^204^ | Metoprolol | Bisoprolol | 156 | 6.4 [10.3] | NS | NS | Low
Patient withdrawal due to events | Schellenberg, 2008^206^ | Metoprolol | Nebivolol | 30 | 7. [6.3] | NS | NS | Low
Drowsiness leading to withdrawal | Grotemeyer, 1990^202^ | Metoprolol | Aspirin | 56 | 7.1 [0.0] | NS | NS | Low
Gastrointestinal side-effects leading to withdrawal | Grotemeyer, 1990 202 | Metoprolol | Aspirin | 56 | 0.0 [17.9] | −6 (3 to 35) | −179 (28 to 329) | Low
Discontinued treatment because of severe adverse reactions | Langohr, 1985 250 | Clomipramine | Metoprolol | 126 | 28.6 [0.0] | 3 (3 to 6) | 286 (173 to 399) | Low

CI = confidence interval; NS = not significant

Bold = significant differences at 95% confidence limit when 95% CI of attributable events per 1,000 treated do not include 0.

Number needed to treat and number of attributable events were calculated for statistically significant differences.

###### Metoprolol Versus Bisoprolol

Treatment discontinuation due to adverse effects did not differ between the two drugs (Table 30 and Appendix Table D158)204 nor did rates of individual examined adverse effects differ between the drugs (Appendix Table D159).

###### Metoprolol Versus Nebivolol

Treatment discontinuation due to adverse effects did not differ between the two drugs (Table 30).206 Patients experienced moderate adverse effects, fatigue, and bradycarida more often with metoprolol than with nebivolol (Appendix Table D159).206

###### Metoprolol Versus Aspirin

Gastrointestinal side effects leading to withdrawal were more common with aspirin than metoprolol (Table 30 and Appendix Table D158).202 However, autonomic nervous system and psychiatric disorders were more common with metoprolol than aspirin (Appendix Table D159).203

###### Metoprolol Versus Clomipramine

Treatment discontinuation because of severe adverse reactions was more common with clomipramine than metoprolol (Table 30).250 Clomipramine caused insomnia and sweating more often than metoprolol (Appendix Table D159).250

#### Antidepressants

##### Clomipramine Versus Metoprolol

Clomipramine resulted in treatment discontinuation due to bothersome adverse effects more often than metoprolol (Table 30).250

##### Femoxetine Versus Propranolol

Treatment discontinuation due to bothersome adverse effects did not differ between femoxetine and propranolol.201

##### Amitriptyline Versus Spinal Manipulation

Treatment discontinuation due to adverse effects occurred less with spinal stimulation than with amitriptyline (Table 31).215 Strength of evidence was low due to risk of bias and imprecise estimate (Appendix Table D160).215

Table 31 Treatment adherence and discontinuation due to adverse effects with antidepressant amitriptyline and spinal manipulation for migraine prevention in adults, individual medium risk of bias randomized controlled clinical trial215

Definition of the Outcome | Active Treatment | Control Treatment | Sample | Rate With Active, Percent [Control] Treatments | Number Needed To Treat (95% CI) | Attributable Events per 1,000 Treated (95% CI) | Strength of Evidence
Withdrawn due to side-effects | Spinal Manipulation | Amitriptyline 100mg/day | 147 | 0.0 [10.0] | −10 (−38 to −6) | −100 (−174 to −26) | Low
Withdrawn due to side effects | Spinal Manipulation + Amitriptyline 100 mg/day | Amitriptyline 100 mg/days | 141 | 5.6 [10.0] | NS | NS | Low
Withdrawn due to side effects | Spinal Manipulation | Spinal Manipulation + Amitriptyline 100 mg/day | 148 | 0.0 [5.6] | NS | NS | Low

CI = confidence interval; NS = not significant

Bold = significant differences at 95% confidence limit when 95% CI of attributable events per 1,000 treated do not include 0.

Number needed to treat and number of attributable events were calculated for statistically significant differences.

Treatment discontinuation due to adverse effects did not differ between combined treatment using spinal manipulation with amitriptyline and amitriptyline alone (Appendix Table D161).215

#### Ergot Alkaloids

A single RCT of 253 adults (low-strength evidence) found that treatment discontinuation due to adverse effects was less common with lisuride than with methysergide.212

#### Indirect Evidence of Comparative Safety of Drugs for Episodic Migraine Prevention in Adults

Bothersome adverse effects leading to treatment discontinuation were examined in 68 RCTs. Indirect adjusted analyses demonstrated no differences in treatment discontinuation due to adverse effects with approved drugs or approved versus off-label drugs (Appendix Table D162). Exploratory Bayesian network meta-analyses demonstrated that topiramate, off-label antiepileptics, and antidepressants resulted in bothersome adverse effects leading to treatment discontinuation more often than placebo (Figure 4). According to network meta-analysis, off-label angiotensin inhibiting drugs and beta blockers were the safest treatment option for adults with episodic migraine (Appendix Table D163)

Figure 4 Bayesian network meta-analysis of treatment discontinuation due to intolerable adverse effects with drugs versus placebo (47 RCTs of 3,054 adults) in randomized controlled clinical trials that aimed episodic migraine prevention in adults

CrI = credible intervals; NSAID = nonsteroidal anti-inflammatory drugs

Note: We used heterogeneous random effects model that assumes correlation within study (rho = 0.5) and heterogeneous between studies (WinBUG codes are in the Appendix B). RCTs of angiotensin inhibiting drugs do not report intolerable adverse effects.

The figure presents the results from Bayesian network meta-analysis of treatment discontinuation due to adverse effects with drugs vs. placebo in randomized controlled clinical trials that aimed to prevent migraine in adults. Figure B is a forest plot diagram depicting odds ratios of treatment discontinuation due to adverse effects with active drugs when compared to placebo. The plot has two columns. The left-hand column lists approved drugs such as topiramate, divalproex and propranolol, timolol, and off label drug classes such as antiepileptic, beta-blockers, calcium channel blockers antidepressants, ergot alkaloids, non steroid anti-inflammatory drugs, and clonidine. The number of randomized controlled clinical trials and the number of the enrolled adults are presented after the names of the drugs. The right-hand column is a plot of Bayesian odds ratios with 2,5 and 97.5% credible intervals. Mean odds ratio is presented by a square incorporating credible intervals represented by horizontal lines. Exploratory Bayesian network meta-analyses demonstrated that topiramate and off-label antiepileptics and antidepressants resulted in bothersome adverse effects leading to treatment discontinuation more often than placebo.

### KQ2c How might approaches to drug management (such as patient-care teams, integrated care, coordinated care, patient education, drug surveillance, or interactive drug monitoring) influence results?

We found no studies that examined adverse effects with different approaches to drug management (such as patient-care teams, integrated care, coordinated care, patient education, drug surveillance, or interactive drug monitoring).

## Key Question 3 Which patient characteristics predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks in adults?

### Muscle Relaxants

#### Onabotulinumtoxin A for Chronic Migraine

##### Placebo Responders

Four RCTs examined the efficacy of onabotulinumtoxin A among placebo responders versus nonresponders.94,257–259 Onabotulinumtoxin A was better than placebo in preventing migraine attacks/month by ≥50 percent, regardless of placebo response, according to the BOTULINUM TOXIN CDH Study Group.94 Magnitude of the effect was slightly larger in placebo nonresponders (RR 2.2, 95% CI, 1.4 to 3.4) than in placebo responders (RR 1.6, 95% CI, 1.1 to 2.4).94 The European BoNTA Headache Study Group demonstrated no additional benefits from increasing onabotulinumtoxin A dose, regardless of placebo response.259 The number of migraine days did not differ by dose of onabotulinumtoxin A (75, 15, or 225U).259

#### Baseline Migraine Frequency

Onabotulinumtoxin A was more effective in patients with a higher mean baseline migraine frequency in a single RCT from the BOTULINUM TOXIN North American Episodic Migraine Study Group.257 Onabotulinumtoxin A decreased the likelihood of use of drugs for acute attacks in patients with more than 12 migraine days per month at baseline (RR 0.78, 95% CI, 0.66 to 0.92).257

#### Concurrent Prophylactic Medication Use

Onabotulinumtoxin A caused adverse effects more often than placebo (blepharoptosis, muscle weakness, and neck pain, regardless of concurrent prophylactic medication use) according to the BOTULINUM TOXIN CDH Study Group.258

### Antiepileptics for Episodic Migraine

#### Topiramate

##### Presence of Aura

No trials directly compared drug effects in patients with and without aura. Several post hoc subgroup analysis of topiramate versus placebo trials provided conflicting evidence of the drug efficacy in respect to aura. Two publications suggested that topiramate was better than placebo in patients with aura. Post hoc subgroup analysis of one RCT found a statistically significant reduction in migraine frequency with topiramate versus placebo (−2.43 vs. −0.79 respectively, p value=0.02) only in subjects with aura.85 Post hoc subgroup analysis of the other RCTs found that in patients with aura, topiramate was better than placebo in reducing migraine frequency, number of migraine days, severity and duration of attacks, and photophobia.260 In contrast, however, post hoc analysis of the Prolonged Migraine Prevention found that topiramate efficacy was similar in patients with and without aura.261

### Beta Blockers for Episodic Migraine

#### Propranolol

##### Prior Medication Use

Subgroup analysis in chronic migraine patients by prior topiramate use or overuse of the drugs for acute migraine was conducted in a single RCT.187 This study examined adding propranolol to topiramate treatment for chronic migraine subjects for whom topiramate monotherapy had failed.187 Propranolol with topiramate was no better than topiramate alone in reducing migraine frequency, regardless of patients’ prior drug histories.187 Quality of life score changes from baseline difference depend on prior topiramate use (Figure 5). Patients with prior stable topiramate use experienced worsening in quality of life with combined therapy versus improvement in quality of life with topiramate monotherapy. In contrast, patients without stable prior topiramate use experienced improvement in quality of life with combined therapy versus insignificant changes with topiramate monotherapy.187

Figure 5 Change from baseline in Migraine Specific Quality of Life

Migraine Specific Quality of Life = MSQL scale, an increase in MSQL indicates an improvement) with combined propranolol with topiramate or topiramate monotherapy in patients with chronic migraine for whom topiramate monotherapy failed, results from a single randomized controlled trial.187

Figure 5 is a forest plot diagram depicting change from baseline in migraine specific quality of life with combined propranolol with topiramate or topiramate monotherapy in patients with chronic migraine who failed topiramate monotherapy. The results came from a single randomized controlled clinical trial. The plot has two columns. The left-hand column lists subgroups with or without prior, stable topiramate use. The right-hand column is a plot of mean differences from baseline in the Migraine Specific Quality of Life scale with 95% confidence intervals. Mean differences are presented by a square incorporating confidence intervals represented by horizontal lines. 189 Quality of life score changes from baseline difference depend on prior topiramate use. Patients with prior stable topiramate use experienced worsening in quality of life with combined therapy versus improvement in quality of life with topiramate monotherapy. In contrast, patients without stable prior topiramate use experienced improvement in quality of life with combined therapy versus insignificant changes with topiramate monotherapy.

##### Sex

Topiramate caused a complete cessation of migraine attacks and a reduction of monthly migraine attacks by 50 percent in women but not men according to one low-risk-of-bias RCT.84 Topiramate would cause a complete cessation of migraine attacks in 37 (95% CI, 8 to 67) and a reduction of monthly migraine attacks by 50 percent in 249 (95% CI, 178 to 320) per 1,000 treated women.84 However, both men and women experienced a reduction of monthly migraine 75 to 90 percent more often with topiramate than with placebo.84

#### Gabapentin for Episodic Migraine

##### Presence of Aura

Gabapentin reduced the frequency and intensity of migraine attacks significantly more than placebo, regardless of aura.262 Patients with aura experienced a slightly greater reduction in migraine frequency (mean difference −2.2, 95% CI, −2.7 to −1.7) than patients without aura (mean difference −1.6, 95% CI, −2.2 to −0.9). Patients with aura experienced a slightly greater reduction in migraine intensity (mean difference −0.83, 95%, CI, −1.12 to −0.54) than patients without aura (mean difference −0.42, 95% CI, −0.77 to −0.07).

##### Prior Medication Use

In a single, low-risk-of-bias RCT, gabapentin was not better than placebo in reducing acute drug use, regardless of prior use of triptans, opioids, or prescription or over-the-counter acute medications.87

### Antidepressants for Episodic Migraine

#### Amitriptyline

##### Baseline Migraine Frequency

Amitriptyline was better than placebo in reducing monthly migraine but only in patients with baseline frequent and severe migraine (Appendix Table D164).125 Amitriptyline was better than placebo in reducing monthly migraine only in depressed patients whose baseline migraine was frequent and severe (Appendix Table D165).253

A higher dose of amitriptyline increased the odds of reducing monthly migraine by ≥50 percent in accordance with increased baseline migraine days (odds ratio 2.35, 95%, CI 1.45 to 3.8 for every additional day of baseline migraine) (Appendix Table D166).228

### Selective Calcium Channel Blockers for Episodic Migraine

#### Nimodipine

##### Presence of Aura

A higher dose of nimodipine was not associated with increased response rates regardless of aura.263 Nimodipine, 40 mg/day versus 20 mg/day, reduced use of drugs for acute attacks but only in patients with classic and not common migraine.263