# References

1 Goadsby PJ, Raskin NH. Chapter 15 Headache. Fauci AS, Braunwald E, Kasper DL, Hauser SL, Longo DL, Jameson JL, et al., editors. Harrison’s principles of internal medicine. 17th ed. New York. The McGraw-Hill Companies. 2008.
2 Silberstein SD. Preventive migraine treatment. Neurol Clin. May. 2009;27(2):429-43. [pmid: 19289224].
3 Solomon GD, Santanello N. Impact of migraine and migraine therapy on productivity and quality of life. Neurology. 2000;55(9 Suppl 2):S29-35. [pmid: 11089517].
4 Diamond S, Bigal ME, Silberstein S, et al. Patterns of diagnosis and acute and preventive treatment for migraine in the United States: results from the American Migraine Prevalence and Prevention study. Headache. Mar. 2007;47(3):355-63. [pmid: 17371352].
5 Lipton RB, Scher AI, Kolodner K, et al. Migraine in the United States: epidemiology and patterns of health care use. Neurology. Mar. 26. 2002;58(6):885-94. [pmid: 11914403].
6 Bigal ME, Lipton RB, Winner P, et al. Migraine in adolescents: association with socioeconomic status and family history. Neurology. Jul. 3. 2007;69(1):16-25. [pmid: 17606878].
7 Hernandez-Latorre MA, Roig M. Natural history of migraine in childhood. Cephalalgia. Jul. 2000;20(6):573-9. [pmid: 11075841].
8 Charles A. Advances in the basic and clinical science of migraine. Ann Neurol. May. 2009;65(5):491-8. [pmid: 19479724].
9 Lipton RB, Bigal ME, Diamond M, et al. Migraine prevalence, disease burden, and the need for preventive therapy. Neurology. Jan. 30. 2007;68(5):343-9. [pmid: 17261680].
10 Natoli JL, Manack A, Dean B, et al. Global prevalence of chronic migraine: a systematic review. Cephalalgia. May. 2010;30(5):599-609. [pmid: 19614702].
11 Olesen J, Bousser MG, Diener HC, et al. New appendix criteria open for a broader concept of chronic migraine. Cephalalgia. Jun. 2006;26(6):742-6. [pmid: 16686915].
12 Solomon S. New appendix criteria open for a broader concept of chronic migraine. (Comment on: Cephalagia 2006 Jun:26(6):742–6). Cephalalgia. May. 2007;27(5):469. author reply - 70. [pmid: 17448186].
13 Stewart WF, Ricci JA, Chee E, et al. Lost productive work time costs from health conditions in the United States: results from the American Productivity Audit. J Occup Environ Med. Dec. 2003;45(12):1234-46. [pmid: 14665809].
14 Hu XH, Markson LE, Lipton RB, et al. Burden of migraine in the United States: disability and economic costs. Arch Intern Med. Apr. 26. 1999;159(8):813-8. [pmid: 10219926].
15 Burton WN, Landy SH, Downs KE, et al. The impact of migraine and the effect of migraine treatment on workplace productivity in the United States and suggestions for future research. Mayo Clin Proc. May. 2009;84(5):436-45. [pmid: 19411440].
16 Lipton RB, Scher AI, Steiner TJ, et al. Patterns of health care utilization for migraine in England and in the United States. Neurology. Feb. 11. 2003;60(3):441-8. [pmid: 12578925].
17 Lipton RB, Stewart WF. The epidemiology of migraine. Eur Neurol. Suppl 2. 1994;34:6-11. [pmid: 7835383].
18 Sprenger T, Goadsby PJ. Migraine pathogenesis and state of pharmacological treatment options. BMC Medicine. 2009;7:71. [pmid: 19917094].
19 Sanchez-Del-Rio M, Reuter U, Moskowitz MA. New insights into migraine pathophysiology. Curr Opin Neurol. Jun. 2006;19(3):294-8. [pmid: 16702838].
20 Rapoport AM. Acute and prophylactic treatments for migraine: present and future. Neurol Sci. May. Suppl 1. 2008;29:S110-22. [pmid: 18545911].
21 Stafford RS. Regulating off-label drug use--rethinking the role of the FDA. N Engl J Med. Apr. 3. 2008;358(14):1427-9. [pmid: 18385495].
22 Silberstein S, Tfelt-Hansen P, Dodick DW, et al. Guidelines for controlled trials of prophylactic treatment of chronic migraine in adults. Cephalalgia. May. 2008;28(5):484-95. [pmid: 18294250].
23 Schroeder BM. AAFP/ACP-ASIM release guidelines on the management and prevention of migraines. Am Fam Physician. Mar. 15. 5. 2003;67(6):1392-7. [pmid: 12674472].
24 Morey SS. Guidelines on migraine: part 4. General principles of preventive therapy. Am Fam Physician. Nov. 15. 2000;62(10):2359-60. [pmid: 11126860].
25 Silberstein SD. Practice parameter: evidence-based guidelines for migraine headache (an evidence-based review): report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. Sep. 26. 2000;55(6):754-62. [pmid: 10993991].
26 Schuurmans A, van Weel C. Pharmacologic treatment of migraine. Comparison of guidelines. Can Fam Physician. Jun. 2005;51:838-43. [pmid: 15986940].
27 Lainez MJ, Freitag FG, Pfeil J, et al. Time course of adverse events most commonly associated with topiramate for migraine prevention. Eur J Neurol. Aug. 2007;14(8):900-6. [pmid: 17662012].
28 Luykx J, Mason M, Ferrari MD, et al. Are migraineurs at increased risk of adverse drug responses? A meta-analytic comparison of topiramate-related adverse drug reactions in epilepsy and migraine. Clin Pharmacol Ther. Mar. 2009;85(3):283-8. [pmid: 18987621].
29 Evers S, Afra J, Frese A, et al. EFNS guideline on the drug treatment of migraine--revised report of an EFNS task force. Eur J Neurol. Sep. 2009;16(9):968-81. [pmid: 19708964].
30 Dowson AJ, Lipscombe S, Sender J, et al. New guidelines for the management of migraine in primary care. Curr Med Res Opin. 2002;18(7):414-39. [pmid: 12487508].
31 U.S. Food and Drug Administration. FDA News Release: FDA Approves Botox to Treat Chronic Migraine. 2010. www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm229782.htm. Accessed on July 25 2012.
32 Amanzio M, Corazzini LL, Vase L, et al. A systematic review of adverse events in placebo groups of anti-migraine clinical trials. Pain. Dec. 2009;146(3):261-9. [pmid: 19781854].
33 Whyte CA, Tepper SJ. Adverse effects of medications commonly used in the treatment of migraine. Expert Rev Neurother. Sep. 2009;9(9):1379-91. [pmid: 19769452].
34 Whitlock EP, Lopez SA, Chang S, et al. AHRQ series paper 3: identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):491-501. [pmid: 19540721].
35 Slutsky J, Atkins D, Chang S, et al. AHRQ series paper 1: comparing medical interventions: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):481-3. [pmid: 18834715].
36 Helfand M, Balshem H. AHRQ series paper 2: principles for developing guidance: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):484-90. [pmid: 19716268].
37 Shamilyan T. Comparative effectiveness of preventive pharmacological treatments for migraine in adults. Prospero. 2011:CRD42012001918.
38 Liberati A, Altman DG, Tetzlaff J, et al. The PRISMA statement for reporting systematic reviews and meta-analyses of studies that evaluate health care interventions: explanation and elaboration. Annals of Internal Medicine. Aug. 18. 2009;151(4):W65-94. [pmid: 19622512].
39 White CM, Ip S, McPheeters ML, et al. Chapter 11. Using existing systematic reviews to replace de novo processes in conducting comparative effectiveness reviews. Methods Guide for Effectiveness and Comparative Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Resarch and Quality. March 2011. 2009:136-51. www.effectivehealthcare.ahrq.gov.
40 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
41 Rothner AD. Complicated migraine and migraine variants. Curr Pain Headache Rep. Jun. 2002;6(3):233-9. [pmid: 12003695].
42 Headache Classification Subcommittee of the International Headache Society. The International Classification of Headache Disorders: 2nd edition. Cephalalgia. Suppl 1. 2004;24:9-160. [pmid: 14979299].
43 Hansen JM, Thomsen LL, Olesen J, et al. Calcitonin gene-related peptide does not cause the familial hemiplegic migraine phenotype. Neurology. Sep. 9. 2008;71(11):841-7. [pmid: 18779512].
44 Norris S, Atkins D, Bruening W, et al. Chapter 4 Selecting observational studies for comparing medical interventions. Methods Guide for Effectiveness and Comparative Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011:56-68. www.effectivehealthcare.ahrq.gov.
45 Higgins J, Green S, editors. Cochrane handbook for systematic reviews of interventions. Version 5.1.0. London. The Cochrane Collaboration. 2011.
46 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the Effective Health-Care Program. J Clin Epidemiol. Sep. 25. 2008;63(5):502-12. [pmid: 18823754].
47 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
48 Viswanathan M, Ansari MT, Berkman ND, Chang S, Hartling L, McPheeters LM, Santaguida PL, Shamliyan T, Singh K, Tsertsvadze A, Treadwell JR. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews. 2012. AHRQ Publication No. 12-EHC047-EF. www.effectivehealthcare.ahrq.gov/).
49 Viswanathan M, Berkman ND. Development of the RTI Item Bank on Risk of Bias and Precision of Observational Studies. Methods Research Report. (Prepared by the RTI International–University of North Carolina Evidence-based Practice Center under Contract No. 290-2007-0056-I) 2011; AHRQ Publication No 11-EHC028-EF. Rockville, MD. Agency for Healthcare Research and Quality. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
50 van der Velde G, van Tulder M, Cote P, et al. The sensitivity of review results to methods used to appraise and incorporate trial quality into data synthesis. Spine (Phila Pa 1976). Apr. 1. 2007;32(7):796-806. [pmid: 17414916].
51 Herbison P, Hay-Smith J, Gillespie WJ. Adjustment of meta-analyses on the basis of quality scores should be abandoned. J Clin Epidemiol. Dec. 2006;59(12):1249-56. [pmid: 17098567].
52 Ad Hoc Committee on Classification of Headache. Classification of headache. JAMA. 1962;179(9):717-8.
53 Wallace BC, Schmid CH, Lau J, et al. Meta-Analyst: software for meta-analysis of binary, continuous and diagnostic data. BMC Med Res Methodol. 2009;9:80. [pmid: 19961608].
54 Egger M, Smith GD, Altman DG. Systematic reviews in health care: meta-analysis in context. 2nd ed. London. BMJ Books. 2001.
55 Treadwell JR, Uhl S, Tipton K, et al. Assessing equivalence and noninferiority. J Clin Epidemiol. Nov. 2012;65(11):1144-9. [pmid: 22732455].
56 Friedrich JO, Adhikari NK, Beyene J. Ratio of means for analyzing continuous outcomes in meta-analysis performed as well as mean difference methods. Journal of Clinical Epidemiology. May. 2011;64(5):556-64. [pmid: 21447428].
57 Fu R, Gartlehner G, Grant M, et al. Chapter 9 Conducting quantitative synthesis when comparing medical interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011:104-19. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
58 Rucker G, Schwarzer G, Carpenter J, et al. Why add anything to nothing? The arcsine difference as a measure of treatment effect in meta-analysis with zero cells. Stat Med. Feb. 28. 2009;28(5):721-38. [pmid: 19072749].
59 Bradburn MJ, Deeks JJ, Berlin JA, et al. Much ado about nothing: a comparison of the performance of meta-analytical methods with rare events. Stat Med. Jan. 15. 2007;26(1):53-77. [pmid: 16596572].
60 Sweeting MJ, Sutton AJ, Lambert PC. What to add to nothing? Use and avoidance of continuity corrections in meta-analysis of sparse data. Stat Med. May. 15. 2004;23(9):1351-75. [pmid: 15116347].
61 Stijnen T, Hamza TH, Ozdemir P. Random effects meta-analysis of event outcome in the framework of the generalized linear mixed model with applications in sparse data. Stat Med. Dec. 20. 2010;29(29):3046-67. [pmid: 20827667].
62 White IR. Multivariate random-effects meta-regression: Updates to mvmeta. The Stata Journal. 2011;11(2).
63 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Quality and the Effective Health-Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
64 Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med. Jan. 15. 2007;26(1):37-52. [pmid: 16463355].
65 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
66 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
67 Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta-analysis. Caveats and pitfalls. Eval Health Prof. Jun. 2001;24(2):152-64. [pmid: 11523384].
68 Altman DG. Confidence intervals for the number needed to treat. BMJ. Nov. 7. 1998;317(7168):1309-12. [pmid: 9804726].
69 Coory M, Jordan S. Frequency of treatment-effect modification affecting indirect comparisons: a systematic review. Pharmcoeconomics. 2010;28(9):723-32.
70 Wells G, Sultan S, Chen L, et al. Indirect evidence: Indirect treatment comparisons in meta-analysis. Canadian Agency for Drugs and Technologies in Health. 2009. Ottawa.
71 Glenny AM, Altman DG, Song F, et al. Indirect comparisons of competing interventions. Health Technol Assess. Jul. 2005;9(26):1-134. iii. iv. [pmid: 16014203].
72 Song F, Loke YK, Walsh T, et al. Methodological problems in the use of indirect comparisons for evaluating healthcare interventions: survey of published systematic reviews. BMJ. 2009;338:b1147. [pmid: 19346285].
73 Donegan S, Williamson P, Gamble C, et al. Indirect comparisons: a review of reporting and methodological quality. PLoS One. 2010;5(11):e11054. [pmid: 21085712].
74 Jansen JP, Fleurence R, Devine B, et al. Interpreting indirect treatment comparisons and network meta-analysis for health-care decision making: report of the ISPOR Task Force on Indirect Treatment Comparisons Good Research Practices: part 1. Value Health. Jun. 2011;14(4):417-28. [pmid: 21669366].
75 Hoaglin DC, Hawkins N, Jansen JP, et al. Conducting indirect-treatment-comparison and network-meta-analysis studies: report of the ISPOR Task Force on Indirect Treatment Comparisons Good Research Practices: part 2. Value Health. Jun. 2011;14(4):429-37. [pmid: 21669367].
76 Dias S, Welton NJ, Caldwell DM, et al. Checking consistency in mixed treatment comparison meta-analysis. Stat Med. Mar. 30. 2010;29(7–8):932-44. [pmid: 20213715].
77 Carlin BP, Louis TA. Bayesian Methods for Data Analysis. Boca Raton, Fla. Chapman & Hall/CRC. 2009.
78 Higgins JPT, Jackson D, Barrett JK, et al. Consistency and inconsistency in network meta-analysis: concepts and models for multi-arm studies. Research Synthesis Methods. 2012;3(2):98-110. [pmid: 26062084].
79 Aschengrau A, Seage GR. Essentials of epidemiology in public health. Sudbury, MA. Jones and Bartlett. 2003.
80 Lunn D, Thomas A, Best N, et al. WinBUGS- a Bayesian modelling framework: concepts, structure, and extensibility. Statistics and Computing. 2000;10:325-37.
81 Berkman ND, Lohr KN, Morgan LC, et al. Reliability Testing of the AHRQ EPC Approach to Grading the Strength of Evidence in Comparative Effectiveness Reviews. Rockville (MD). 2012.
82 Guyatt G, Oxman AD, Kunz R, et al. GRADE guidelines 6. Rating the quality of evidence-imprecision. J Clin Epidemiol. 2011. Aug. 10. [pmid: 21839614].
83 Sterne JA, Sutton AJ, Ioannidis JP, et al. Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011;343:d4002. [pmid: 21784880].
84 Bussone G, Diener HC, Pfeil J, et al. Topiramate 100 mg/day in migraine prevention: a pooled analysis of double-blind randomised controlled trials. Int J Clin Pract. Aug. 2005;59(8):961-8. [pmid: 16033621].
85 Silberstein SD, Hulihan J, Karim MR, et al. Efficacy and tolerability of topiramate 200 mg/d in the prevention of migraine with/without aura in adults: a randomized, placebo-controlled, double-blind, 12-week pilot study. Clin Ther. Jul. 2006;28(7):1002-11. [pmid: 16990078].
86 Silberstein S, Lipton R, Dodick D, et al. Topiramate treatment of chronic migraine: a randomized, placebo-controlled trial of quality of life and other efficacy measures. Headache. Sep. 2009;49(8):1153-62. [pmid: 19719543].
87 NCT00742209. Prevention Study in Adult Patients Suffering From Migraine Headaches. 2010.
88 Minervini MG, Pinto K. Captopril relieves pain and improves mood depression in depressed patients with classical migraine. Cephalalgia. 1987:485-6.
89 Gelmers HJ. Nimodipine, a new calcium antagonist, in the prophylactic treatment of migraine. Headache. 1983:106-9. [pmid: 6347970].
90 Pradalier A, Lanteri-Minet M, Geraud G, et al. The PROMISE study: PROphylaxis of MIgraine with SEglor (dihydroergotamine mesilate) in French primary care. CNS Drugs. 2004;18(15):1149-63. [pmid: 15581385].
91 Anthony M, Lance JW. Indomethacin in migraine. Med J Aust. Jan. 13. 1968;1(2):56-7. [pmid: 4867513].
92 Silberstein S, Mathew N, Saper J, et al. Botulinum toxin type A as a migraine preventive treatment. For the BOTOX Migraine Clinical Research Group. Headache. Jun. 2000;40(6):445-50. [pmid: 10849039].
93 Freitag FG, Diamond S, Diamond M, et al. Botulinum Toxin Type A in the treatment of chronic migraine without medication overuse. Headache. Feb. 2008;48(2):201-9. [pmid: 18042229].
94 Mathew NT, Frishberg BM, Gawel M, et al. Botulinum toxin type A (BOTOX) for the prophylactic treatment of chronic daily headache: a randomized, double-blind, placebo-controlled trial. Headache. Apr. 2005;45(4):293-307. [pmid: 15836565].
95 Storey JR, Calder CS, Hart DE, et al. Topiramate in migraine prevention: a double-blind, placebo-controlled study. Headache. Nov–Dec. 2001;41(10):968-75. [pmid: 11903524].
96 Mei D, Capuano A, Vollono C, et al. Topiramate in migraine prophylaxis: a randomised double-blind versus placebo study. Neurol Sci. Dec. 2004;25(5):245-50. [pmid: 15624081].
97 Silberstein S. Efficacy and safety of topiramate in migraine prevention: a dose-ranging, placebo-controlled, double-blind, multicenter study. Advanced Studies in Medicine. 2003;3(6C):S565-8.
98 Silvestrini M, Bartolini M, Coccia M, et al. Topiramate in the treatment of chronic migraine. Cephalalgia. Oct. 2003;23(8):820-4. [pmid: 14510929].
99 Gupta P, Singh S, Goyal V, et al. Low-dose topiramate versus lamotrigine in migraine prophylaxis (the Lotolamp study). Headache. Mar. 2007;47(3):402-12. [pmid: 17371357].
100 Diener HC, Bussone G, Van Oene JC, et al. Topiramate reduces headache days in chronic migraine: a randomized, double-blind, placebo-controlled study. Cephalalgia. Jul. 2007;27(7):814-23. [pmid: 17441971].
101 Mathew NT, Saper JR, Silberstein SD, et al. Migraine prophylaxis with divalproex. Arch Neurol. Mar. 1995;52(3):281-6. [pmid: 7872882].
102 Freitag FG, Collins SD, Carlson HA, et al. A randomized trial of divalproex sodium extended-release tablets in migraine prophylaxis. Neurology. Jun. 11. 2002;58(11):1652-9. [pmid: 12058094].
103 Klapper J. Divalproex sodium in migraine prophylaxis: a dose-controlled study. Cephalalgia. Apr. 1997;17(2):103-8. [pmid: 9137847].
104 Tfelt-Hansen P, Standnes B, Kangasneimi P, et al. Timolol vs propranolol vs placebo in common migraine prophylaxis: a double-blind multicenter trial. Acta Neurol Scand. Jan. 1984;69(1):1-8. [pmid: 6367336].
105 Diener HC, Tfelt-Hansen P, Dahlof C, et al. Topiramate in migraine prophylaxis--results from a placebo-controlled trial with propranolol as an active control. J Neurol. Aug. 2004;251(8):943-50. [pmid: 15316798].
106 Diamond S, Medina JL. Double blind study of propranolol for migraine prophylaxis. Headache. 1976:24-7. [pmid: 767299].
107 Standnes B. The prophylactic effect of timolol versus propranolol and placebo in common migraine: Beta-blockers in migraine. Cephalalgia. 1982:165-70. [pmid: 6758949].
108 Briggs RS, Millac PA. Timolol in migraine prophylaxis. Headache. Nov. 1979;19(7):379-81. [pmid: 511540].
109 Stellar S, Ahrens SP, Meibohm AR, et al. Migraine prevention with timolol. A double-blind crossover study. JAMA. Nov. 9. 1984;252(18):2576-80. [pmid: 6387197].
110 Wessely P, Baumgartner C, Klingler D, et al. Preliminary results of a double-blind study with the new migraine prophylactic drug Gabapentin. Cephalalgia. 1987:477-8.
111 Mathew NT, Rapoport A, Saper J, et al. Efficacy of gabapentin in migraine prophylaxis. Headache. Feb. 2001;41(2):119-28. [pmid: 11251695].
112 Havanka-Kanniainen H, Hokkanen E, Myllylä VV. Efficacy of nimodipine in the prophylaxis of migraine. Cephalalgia an international journal of headache. 1985:39-43. [pmid: 3886153].
113 Kangasniemi P, Andersen AR, Andersson PG, et al. Classic migraine: effective prophylaxis with metoprolol. Cephalalgia. Dec. 1987;7(4):231-8. [pmid: 3322569].
114 Andersson PG, Dahl S, Hansen JH, et al. Prophylactic treatment of classical and non-classical migraine with metoprolol--a comparison with placebo. Cephalalgia. Dec. 1983;3(4):207-12. [pmid: 6640652].
115 Peikert A, Wilimzig C, Kohne-Volland R. Prophylaxis of migraine with oral magnesium: results from a prospective, multi-center, placebo-controlled and double-blind randomized study. Cephalalgia. Jun. 1996;16(4):257-63. [pmid: 8792038].
116 Pfaffenrath V, Wessely P, Meyer C, et al. Magnesium in the prophylaxis of migraine--a double-blind placebo-controlled study. Cephalalgia. Oct. 1996;16(6):436-40. [pmid: 8902254].
117 Vahedi K, Taupin P, Djomby R, et al. Efficacy and tolerability of acetazolamide in migraine prophylaxis: a randomised placebo-controlled trial. J Neurol. Feb. 2002;249(2):206-11. [pmid: 11985388].
118 Rompel H, Bauermeister PW. Aetiology of migraine and prevention with carbamazepine (Tegretol): results of a double-blind, cross-over study. S Afr Med J. Jan. 24. 1970;44(4):75-80. [pmid: 4905910].
119 Silberstein S, Saper J, Berenson F, et al. Oxcarbazepine in migraine headache: a double-blind, randomized, placebo-controlled study. Neurology. Feb. 12. 2008;70(7):548-55. [pmid: 18268247].
120 Jensen R, Brinck T, Olesen J. Sodium valproate has a prophylactic effect in migraine without aura: a triple-blind, placebo-controlled crossover study. Neurology. Apr. 1994;44(4):647-51. [pmid: 8164818].
121 Nanda RN, Johnson RH, Gray J, et al. A double blind trial of acebutolol for migraine prophylaxis. Headache. 1978:20-2. [pmid: 348644].
122 Ekbom K. Alprenolol for migraine prophylaxis. Headache. 1975:129-32. [pmid: 1097368].
123 Forssman B, Lindblad CJ, Zbornikova V. Atenolol for migraine prophylaxis. Headache. 1983:188-90. [pmid: 6350226].
124 Freitag FG, Diamond S. Nadolol and placebo comparison study in the prophylactic treatment of migraine. The Journal of the American Osteopathic Association. 1984:343-7. [pmid: 6150909].
125 Couch JR. Amitriptyline in the prophylactic treatment of migraine and chronic daily headache. Headache. Jan. 2011;51(1):33-51. [pmid: 21070231].
126 Couch JR, Hassanein RS. Migraine and depression: effect of amitriptyline prophylaxis. Trans Am Neurol Assoc. 1976:234-7. [pmid: 800690].
127 Goadsby PJ, Ferrari MD, Csanyi A, et al. Randomized, double-blind, placebo-controlled, proof-of-concept study of the cortical spreading depression inhibiting agent tonabersat in migraine prophylaxis. Cephalalgia. Jul. 2009;29(7):742-50. [pmid: 19222510].
128 Schrader H, Stovner LJ, Helde G, et al. Prophylactic treatment of migraine with angiotensin converting enzyme inhibitor (lisinopril): randomised, placebo controlled, crossover study. BMJ. Jan. 6. 2001;322(7277):19-22. [pmid: 11141144].
129 Tronvik E, Stovner LJ, Helde G, et al. Prophylactic treatment of migraine with an angiotensin II receptor blocker: a randomized controlled trial. JAMA. Jan. 1. 2003;289(1):65-9. [pmid: 12503978].
130 Shukla R, Garg RK, Nag D, et al. Nifedipine in migraine and tension headache: a randomised double blind crossover study. J Assoc Physicians India. Nov. 1995;43(11):770-2. [pmid: 8773038].
131 Somerville BW, Herrmann WM. Migraine prophylaxis with lisuride. A double blind study of lisuride versus placebo. Headache. 1976:85-6.
132 Solomon GD, Kunkel RS. Flurbiprofen in the prophylaxis of migraine. Cleve Clin J Med. Jan–Feb. 1993;60(1):43-8. [pmid: 8443934].
133 Visser WH, Malbecq W, Strohmaier K, et al. Preventive treatment of migraine headache with rofecoxib. Olesen J, Silberstein SD, Tfelt Hansen P, editors. Preventive Pharmacotherapy of Headache Disorders. Oxford. Oxford University Press. 2004:44-9.
134 Mikkelsen BM, Falk JV. Prophylactic treatment of migraine with tolfenamic acid. A comparative double-blind crossover study between tolfenamic acid and placebo. Acta neurologica Scandinavica. 1982:105-11. [pmid: 7051739].
135 Buring JE, Peto R, Hennekens CH. Low-dose aspirin for migraine prophylaxis. JAMA. Oct. 3. 1990;264(13):1711-3. [pmid: 2204739].
136 Brandes JL, Visser WH, Farmer MV, et al. Montelukast for migraine prophylaxis: a randomized, double-blind, placebo-controlled study. Headache. Jun. 2004;44(6):581-6. [pmid: 15186302].
137 Diener HC, Dodick DW, Aurora SK, et al. OnabotulinumtoxinA for treatment of chronic migraine: results from the double-blind, randomized, placebo-controlled phase of the PREEMPT 2 trial. Cephalalgia. Jul. 2010;30(7):804-14. [pmid: 20647171].
138 Silberstein SD, Stark SR, Lucas SM, et al. Botulinum toxin type A for the prophylactic treatment of chronic daily headache: a randomized, double-blind, placebo-controlled trial. Mayo Clin Proc. Sep. 2005;80(9):1126-37. [pmid: 16178492].
139 Chankrachang S, Arayawichanont A, Poungvarin N, et al. Prophylactic botulinum type A toxin complex (Dysport(R)) for migraine without aura. Headache. Jan. 2011;51(1):52-63. [pmid: 21083558].
140 Anand KS, Prasad A, Singh MM, et al. Botulinum toxin type A in prophylactic treatment of migraine. Am J Ther. May–Jun. 2006;13(3):183-7. [pmid: 16772757].
141 Vo AH, Satori R, Jabbari B, et al. Botulinum toxin type-a in the prevention of migraine: a double-blind controlled trial. Aviat Space Environ Med. May. 2007;78(5 Suppl):B113-8. [pmid: 17547312].
142 Cady R, Schreiber C. Botulinum toxin type A as migraine preventive treatment in patients previously failing oral prophylactic treatment due to compliance issues. Headache. Jun. 2008;48(6):900-13. [pmid: 18047501].
143 Lipton RB, Varon SF, Grosberg B, et al. OnabotulinumtoxinA improves quality of life and reduces impact of chronic migraine. Neurology. Oct. 11. 2011;77(15):1465-72. [pmid: 21956721].
144 Petri S, Tolle T, Straube A, et al. Botulinum toxin as preventive treatment for migraine: a randomized double-blind study. Eur Neurol. 2009;62(4):204-11. [pmid: 19622887].
145 Saper JR, Lake AE 3rd, Cantrell DT, et al. Chronic daily headache prophylaxis with tizanidine: a double-blind, placebo-controlled, multicenter outcome study. Headache. Jun. 2002;42(6):470-82. [pmid: 12167135].
146 Silberstein SD, Lipton RB, Dodick DW, et al. Efficacy and safety of topiramate for the treatment of chronic migraine: a randomized, double-blind, placebo-controlled trial. Headache. Feb. 2007;47(2):170-80. [pmid: 17300356].
147 Dodick DW, Silberstein S, Saper J, et al. The impact of topiramate on health-related quality of life indicators in chronic migraine. Headache. Nov–Dec. 2007;47(10):1398-408. [pmid: 18052949].
148 Lipton RB, Silberstein S, Dodick D, et al. Topiramate intervention to prevent transformation of episodic migraine: the topiramate INTREPID study. Cephalalgia. Jan. 2011;31(1):18-30. [pmid: 20974598].
149 Diener HC, Agosti R, Allais G, et al. Cessation versus continuation of 6-month migraine preventive therapy with topiramate (PROMPT): a randomised, double-blind, placebo-controlled trial. Lancet Neurol. Dec. 2007;6(12):1054-62. [pmid: 17988947].
150 Edwards KR, Potter DL, Wu SC, et al. Topiramate in the preventive treatment of episodic migraine: a combined analysis from pilot, double-blind, placebo-controlled trials. CNS Spectr. Jun. 2003;8(6):428-32. [pmid: 12858132].
151 Brandes JL, Kudrow DB, Rothrock JF, et al. Assessing the ability of topiramate to improve the daily activities of patients with migraine. Mayo Clin Proc. Oct. 2006;81(10):1311-9. [pmid: 17036556].
152 Dahlof C, Loder E, Diamond M, et al. The impact of migraine prevention on daily activities: a longitudinal and responder analysis from three topiramate placebo-controlled clinical trials. Health Qual Life Outcomes. 2007;5:56. [pmid: 17916258].
153 Hering R, Kuritzky A. Sodium valproate in the prophylactic treatment of migraine: a double-blind study versus placebo. Cephalalgia. Apr. 1992;12(2):81-4. [pmid: 1576648].
154 Wideroe TE, Vigander T. Propranolol in the treatment of migraine. Br Med J. Jun. 29. 1974;2(5921):699-701. [pmid: 4604977].
155 Ahuja GK, Verma AK. Propranolol in prophylaxis of migraine. Indian J Med Res. Sep. 1985;82:263-5. [pmid: 3908306].
156 Forssman B, Henriksson KG, Johannsson V, et al. Propranolol for migraine prophylaxis. Headache. 1976:238-45. [pmid: 977330].
157 Calandre EP, Garcia-Leiva JM, Rico-Villademoros F, et al. Pregabalin in the treatment of chronic migraine: an open-label study. Clinical Neuropharmacology. Jan–Feb. 2010;33(1):35-9. [pmid: 19935409].
158 Siniatchkin M, Andrasik F, Kropp P, et al. Central mechanisms of controlled-release metoprolol in migraine: a double-blind, placebo-controlled study. Cephalalgia. Sep. 2007;27(9):1024-32. [pmid: 17680819].
159 Forssman B. Atenolol for Migraine Prophylaxis. Acta Neurologica Scandinavica. 1982;65(S90):75-6.
160 Sjaastad O, Stensrud P. Clinical trial of a beta-receptor blocking agent (LB 46) in migraine prophylaxis. Acta neurologica Scandinavica. 1972:124-8. [pmid: 4401692].
161 Gomersall JD, Stuart A. Amitriptyline in migraine prophylaxis. Changes in pattern of attacks during a controlled clinical trial. J Neurol Neurosurg Psychiatry. Aug. 1973;36(4):684-90. [pmid: 4731336].
162 Adly C, Straumanis J, Chesson A. Fluoxetine prophylaxis of migraine. Headache. Feb. 1992;32(2):101-4. [pmid: 1551787].
163 d’Amato CC, Pizza V, Marmolo T, et al. Fluoxetine for migraine prophylaxis: a double-blind trial. Headache. Nov–Dec. 1999;39(10):716-9. [pmid: 11279947].
164 Steiner TJ, Ahmed F, Findley LJ, et al. S-fluoxetine in the prophylaxis of migraine: a phase II double-blind randomized placebo-controlled study. Cephalalgia. Jun. 1998;18(5):283-6. [pmid: 9673809].
165 Ozyalcin SN, Talu GK, Kiziltan E, et al. The efficacy and safety of venlafaxine in the prophylaxis of migraine. Headache. Feb. 2005;45(2):144-52. [pmid: 15705120].
166 Zeeberg I, Orholm M, Nielsen JD, et al. Femoxetine in the prophylaxis of migraine: A randomized comparison with placebo. Acta-Neurol-Scand. 1981:452-9. [pmid: 6753446].
167 Orholm M, Le Fevre P. Prophylactic treatment of migraine with femoxetine - a randomized comparison with placebo. Cephalalgia. 1985:516-7.
168 Orholm M, Honore PF, Zeeberg I. A randomized general practice group-comparative study of femoxetine and placebo in the prophylaxis of migraine. Acta Neurol Scand. Sep. 1986;74(3):235-9. [pmid: 3538753].
169 Monro P, Swade C, Coppen A. Mianserin in the prophylaxis of migraine: a double-blind study. Acta psychiatrica Scandinavica. Supplementum. 1985:98-103. [pmid: 3901676].
170 Leandri M, Rigardo S, Schizzi R, et al. Migraine treatment with nicardipine. Cephalalgia. Jun. 1990;10(3):111-6. [pmid: 2245455].
171 Markley HG, Cheronis JC, Piepho RW. Verapamil in prophylactic therapy of migraine. Neurology. 1984:973-6. [pmid: 6539877].
172 Solomon GD, Steel JG, Spaccavento LJ. Verapamil prophylaxis of migraine. A double-blind, placebo-controlled study. JAMA. Nov. 11. 1983;250(18):2500-2. [pmid: 6355533].
173 Diener HC, Gendolla A, Feuersenger A, et al. Telmisartan in migraine prophylaxis: a randomized, placebo-controlled trial. Cephalalgia. Sep. 2009;29(9):921-7. [pmid: 19250283].
174 Behan PO. Prophylactic treatment for migraine - a comparison of pizotifen and clonidine. Cephalalgia. 1985:524-5.
175 Ryan RE, Diamond S. Double blind study of clonidine and placebo for the prophylactic treatment of migraine. Headache. 1975:202-10. [pmid: 1100565].
176 Kallanranta T, Hakkarainen H, Hokkanen E, et al. Clonidine in migraine prophylaxis. Headache. 1977:169-72. [pmid: 893090].
177 Adam EI, Gore SM, Price WH. Double blind trial of clonidine in the treatment of migraine in a general practice. J R Coll Gen Pract. Oct. 1978;28(195):587-90. [pmid: 368333].
178 Bredfeldt RC, Sutherland JE, Kruse JE. Efficacy of transdermal clonidine for headache prophylaxis and reduction of narcotic use in migraine patients. A randomized crossover trial. J Fam Pract. Aug. 1989;29(2):153-6. discussion 7–8. [pmid: 2666565].
179 Elkind AH, Webster C, Herbertson RK Jr. Efficacy of guanfacine in a double blind parallel study for migraine prophylaxis. Cephalalgia. 1989:369-70.
180 Krymchantowski AV, Jevoux C, Moreira PF. An open pilot study assessing the benefits of quetiapine for the prevention of migraine refractory to the combination of atenolol, nortriptyline, and flunarizine. Pain Med. Jan. 2010;11(1):48-52. [pmid: 20002594].
181 Charles A, Flippen C, Romero Reyes M, et al. Memantine for prevention of migraine: a retrospective study of 60 cases. J Headache Pain. Sep. 2007;8(4):248-50. [pmid: 17901918].
182 Spengos K, Theleritis C, Paparrigopoulos T. Memantine and NMDA antagonism for chronic migraine: a potentially novel therapeutic approach?. Headache. Feb. 2008;48(2):284-6. [pmid: 18194287].
183 Mathew NT, Jaffri SF. A double-blind comparison of onabotulinumtoxina (BOTOX) and topiramate (TOPAMAX) for the prophylactic treatment of chronic migraine: a pilot study. Headache. Nov–Dec. 2009;49(10):1466-78. [pmid: 19912346].
184 Blumenfeld AM, Schim JD, Chippendale TJ. Botulinum toxin type A and divalproex sodium for prophylactic treatment of episodic or chronic migraine. Headache. Feb. 2008;48(2):210-20. [pmid: 18047502].
185 Magalhaes E, Menezes C, Cardeal M, et al. Botulinum toxin type A versus amitriptyline for the treatment of chronic daily migraine. Clin Neurol Neurosurg. Jul. 2010;112(6):463-6. [pmid: 20399553].
186 Cady RK, Schreiber CP, Porter JA, et al. A multi-center double-blind pilot comparison of onabotulinumtoxinA and topiramate for the prophylactic treatment of chronic migraine. Headache. Jan. 2011;51(1):21-32. [pmid: 21070228].
187 Silberstein SD, Dodick DW, Lindblad AS, et al. Randomized, placebo-controlled trial of propranolol added to topiramate in chronic migraine. Neurology. Mar. 27. 2012;78(13):976-84. [pmid: 22377815].
188 Domingues RB, Silva AL, Domingues SA, et al. A double-blind randomized controlled trial of low doses of propranolol, nortriptyline, and the combination of propranolol and nortriptyline for the preventive treatment of migraine. Arq Neuropsiquiatr. Dec. 2009;67(4):973-7. [pmid: 20069203].
189 Dodick DW, Freitag F, Banks J, et al. Topiramate versus amitriptyline in migraine prevention: a 26-week, multicenter, randomized, double-blind, double-dummy, parallel-group noninferiority trial in adult migraineurs. Clin Ther. Mar. 2009;31(3):542-59. [pmid: 19393844].
190 Mohammadianinejad SE, Abbasi V, Sajedi SA, et al. Zonisamide versus topiramate in migraine prophylaxis: a double-blind randomized clinical trial. Clin Neuropharmacol. Jul–Aug. 2011;34(4):174-7. [pmid: 21738025].
191 Bartolini M, Silvestrini M, Taffi R, et al. Efficacy of topiramate and valproate in chronic migraine. Clin Neuropharmacol. Nov–Dec. 2005;28(6):277-9. [pmid: 16340383].
192 de Tommaso M, Marinazzo D, Nitti L, et al. Effects of levetiracetam vs topiramate and placebo on visually evoked phase synchronization changes of alpha rhythm in migraine. Clin Neurophysiol. Oct. 2007;118(10):2297-304. [pmid: 17709295].
193 Ashtari F, Shaygannejad V, Akbari M. A double-blind, randomized trial of low-dose topiramate vs propranolol in migraine prophylaxis. Acta Neurol Scand. Nov. 2008;118(5):301-5. [pmid: 18713156].
194 Kangasniemi P, Hedman C. Metoprolol and propranolol in the prophylactic treatment of classical and common migraine. A double-blind study. Cephalalgia. Jun. 1984;4(2):91-6. [pmid: 6428749].
195 Gerber WD, Diener HC, Scholz E, et al. Responders and non-responders to metoprolol, propranolol and nifedipine treatment in migraine prophylaxis: a dose-range study based on time-series analysis. Cephalalgia. Feb. 1991;11(1):37-45. [pmid: 2036669].
196 Albers GW, Simon LT, Hamik A, et al. Nifedipine versus propranolol for the initial prophylaxis of migraine. Headache. Apr. 1989;29(4):215-8. [pmid: 2654067].
197 Kass B, Nestvold K. Propranolol (Inderal) and clonidine (Catapressan) in the prophylactic treatment of migraine. A comparative trial. Acta Neurol Scand. Jun. 1980;61(6):351-6. [pmid: 6998250].
198 Sudilovsky A, Elkind AH, Ryan RES, et al. Comparative efficacy of nadolol and propranolol in the management of migraine. Headache. 1987:421-6. [pmid: 3312113].
199 Olerud B, Gustavsson CL, Furberg B. Nadolol and propranolol in migraine management. Headache. 1986:490-3. [pmid: 3546194].
200 Ziegler DK, Hurwitz A, Hassanein RS, et al. Migraine prophylaxis. A comparison of propranolol and amitriptyline. Arch Neurol. May. 1987;44(5):486-9. [pmid: 3579659].
201 Kangasniemi PJ, Nyrke T, Lang AH, et al. Femoxetine - a new 5-HT uptake inhibitor - and propranolol in the prophylactic treatment of migraine. Acta Neurol Scand. 1983:262-7. [pmid: 6606930].
202 Grotemeyer KH, Scharafinski HW, Schlake HP, et al. Acetylsalicylic acid vs. metoprolol in migraine prophylaxis--a double-blind cross-over study. Headache. Oct. 1990;30(10):639-41. [pmid: 2272812].
203 Diener HC, Hartung E, Chrubasik J, et al. A comparative study of oral acetylsalicyclic acid and metoprolol for the prophylactic treatment of migraine. A randomized, controlled, double-blind, parallel group phase III study. Cephalalgia. Mar. 2001;21(2):120-8. [pmid: 11422094].
204 Worz R, Reinhardt-Benmalek B, Grotemeyer KH, et al. Bisoprolol and metoprolol in the prophylactic treatment of migraine with and without aura - A randomized double-blind cross-over multicenter study. Cephalalgia. 1991:152-3.
205 Worz R, Reinhardt-Benmalek B, Foeh M, et al. Migraine prophylaxis with bisoprolol. Headache Quarterly. 1992:64-72.
206 Schellenberg R, Lichtenthal A, Wohling H, et al. Nebivolol and metoprolol for treating migraine: an advance on beta-blocker treatment?. Headache. Jan. 2008;48(1):118-25. [pmid: 18184294].
207 Louis P, Schoenen J, Hedman C. Metoprolol v. clonidine in the prophylactic treatment of migraine. Cephalalgia. Sep. 1985;5(3):159-65. [pmid: 3899370].
208 Krymchantowski AV, Silva MT, Barbosa JS, et al. Amitriptyline versus amitriptyline combined with fluoxetine in the preventative treatment of transformed migraine: a double-blind study. Headache. Jun. 2002;42(6):510-4. [pmid: 12167139].
209 Bank J. A comparative study of amitriptyline and fluvoxamine in migraine prophylaxis. Headache. Sep. 1994;34(8):476-8. [pmid: 7960733].
210 Bulut S, Berilgen MS, Baran A, et al. Venlafaxine versus amitriptyline in the prophylactic treatment of migraine: randomized, double-blind, crossover study. Clin Neurol Neurosurg. Dec. 2004;107(1):44-8. [pmid: 15567552].
211 Sudilovsky A, Elkind AH, Ryan RE Sr, et al. Comparative efficacy of nadolol and propranolol in the management of migraine. Headache. Sep. 1987;27(8):421-6. [pmid: 3312113].
212 Herrmann WM, Horowski R, Dannehl K, et al. Clinical effectiveness of lisuride hydrogen maleate: a double-blind trial versus methysergide. Headache. May. 1977;17(2):54-60. [pmid: 324950].
213 Varkey E, Cider A, Carlsson J, et al. Exercise as migraine prophylaxis: a randomized study using relaxation and topiramate as controls. Cephalalgia. Oct. 2011;31(14):1428-38. [pmid: 21890526].
214 Kaushik R, Kaushik RM, Mahajan SK, et al. Biofeedback assisted diaphragmatic breathing and systematic relaxation versus propranolol in long term prophylaxis of migraine. Complement Ther Med. Sep. 2005;13(3):165-74. [pmid: 16150370].
215 Nelson CF, Bronfort G, Evans R, et al. The efficacy of spinal manipulation, amitriptyline and the combination of both therapies for the prophylaxis of migraine headache. J Manipulative Physiol Ther. Oct. 1998;21(8):511-9. [pmid: 9798179].
216 Mathew NT. Prophylaxis of migraine and mixed headache. A randomized controlled study. Headache. May. 1981;21(3):105-9. [pmid: 7021472].
217 Holroyd KA, Cottrell CK, O’Donnell FJ, et al. Effect of preventive (beta blocker) treatment, behavioural migraine management, or their combination on outcomes of optimised acute treatment in frequent migraine: randomised controlled trial. BMJ. 2010;341:c4871. [pmid: 20880898].
218 Seng EK, Holroyd KA. Dynamics of changes in self-efficacy and locus of control expectancies in the behavioral and drug treatment of severe migraine. Annals of behavioral medicine : a publication of the Society of Behavioral Medicine. 2010:235-47. [pmid: 20812037].
219 Elkind AH, O’Carroll P, Blumenfeld A, et al. A series of three sequential, randomized, controlled studies of repeated treatments with botulinum toxin type A for migraine prophylaxis. J Pain. Oct. 2006;7(10):688-96. [pmid: 17018329].
220 Stensrud P, Sjaastad O. Short-term clinical trial of phopranolol in racemic form (Inderal), D-propranolol and placebo in migraine. Acta neurologica Scandinavica. 1976:229-32. [pmid: 773081].
221 Carroll JD, Reidy M, Savundra PA, et al. Long-acting propranolol in the prophylaxis of migraine: a comparative study of two doses. Cephalalgia. Apr. 1990;10(2):101-5. [pmid: 2193712].
222 Havanka-Kanniainen H, Hokkanen E, Myllyla VV. Long acting propranolol in the prophylaxis of migraine. Comparison of the daily doses of 80 mg and 160 mg. Headache. 1988:607-11. [pmid: 3248938].
223 al-Qassab HK, Findley LJ. Comparison of propranolol LA 80 mg and propranolol LA 160 mg in migraine prophylaxis: a placebo controlled study. Cephalalgia. Apr. 1993;13(2):128-31. [pmid: 8495455].
224 Ekbom K, Lundberg PO. Clinical trial of LB-46 (d, 1-4-(2-hydroxy-3-isopropylaminopropoxy)indol. An adrenergic beta-receptor blocking agent in migraine prophylaxis. Headache. 1972:15-7. [pmid: 4402287].
225 Ryan R, Ryan R, Sudilovsky A. Nadolol and placebo comparison study in the prophylactic treatment of migraine. Panminerva Med. 1982:89-94. [pmid: 6128710].
226 Ryan R, Ryan R, Sudilovsky A. Nadolol: Its use in the prophylactic treatment of migraine. Headache. 1983:26-31. [pmid: 6131052].
227 van de Ven LL, Franke CL, Koehler PJ. Prophylactic treatment of migraine with bisoprolol: a placebo-controlled study. Cephalalgia. Aug. 1997;17(5):596-9. [pmid: 9251876].
228 Lampl C, Huber G, Adl J, et al. Two different doses of amitriptyline ER in the prophylaxis of migraine: long-term results and predictive factors. Eur J Neurol. Aug. 2009;16(8):943-8. [pmid: 19456855].
229 Brandes JL, Saper JR, Diamond M, et al. Topiramate for migraine prevention: a randomized controlled trial. JAMA. Feb. 25. 2004;291(8):965-73. [pmid: 14982912].
230 Silberstein SD, Neto W, Schmitt J, et al. Topiramate in migraine prevention: results of a large controlled trial. Arch Neurol. Apr. 2004;61(4):490-5. [pmid: 15096395].
231 Lemstra M, Stewart B, Olszynski WP. Effectiveness of multidisciplinary intervention in the treatment of migraine: a randomized clinical trial. Headache. Oct. 2002;42(9):845-54. [pmid: 12390609].
232 Matchar DB, Harpole L, Samsa GP, et al. The headache management trial: a randomized study of coordinated care. Headache. Oct. 2008;48(9):1294-310. [pmid: 18547268].
233 Fritsche G, Frettlöh J, Hüppe M, et al. Prevention of medication overuse in patients with migraine. Pain. 2010:404-13. [pmid: 20800968].
234 Rothrock JF, Parada VA, Sims C, et al. The impact of intensive patient education on clinical outcome in a clinic-based migraine population. Headache. May. 2006;46(5):726-31. [pmid: 16643574].
235 Hoffmann W, Herzog B, Muhlig S, et al. Pharmaceutical care for migraine and headache patients: a community-based, randomized intervention. Ann Pharmacother. Dec. 2008;42(12):1804-13. [pmid: 19001531].
236 Sondergaard J, Foged A, Kragstrup J, et al. Intensive community pharmacy intervention had little impact on triptan consumption: a randomized controlled trial. Scand J Prim Health Care. Mar. 2006;24(1):16-21. [pmid: 16464810].
237 Adelman J, Freitag FG, Lainez M, et al. Analysis of safety and tolerability data obtained from over 1,500 patients receiving topiramate for migraine prevention in controlled trials. Pain Med. Mar. 2008;9(2):175-85. [pmid: 18298700].
238 Pradalier A, Serratrice G, Collard M, et al. Long-acting propranolol in migraine prophylaxis: results of a double-blind, placebo-controlled study. Cephalalgia. Dec. 1989;9(4):247-53. [pmid: 2692838].
239 Schoonman GG, Wiendels NJ, Ferrari MD. Gabapentin in migraine prophylaxis: is it effective and well tolerated?. Headache. Mar. 2002;42(3):235. [pmid: 11903552].
240 Steiner TJ, Findley LJ, Yuen AW. Lamotrigine versus placebo in the prophylaxis of migraine with and without aura. Cephalalgia. Apr. 1997;17(2):109-12. [pmid: 9137848].
241 Johannsson V, Nilsson LR, Widelius T, et al. Atenolol in migraine prophylaxis: a double-blind cross-over multicenter study. Headache. 1987:372-4. [pmid: 3308768].
242 Whewell J. Methysergide in prophylaxis of migraine: a clinical trial in general practice. Br Med J. Aug. 13. 1966;2(5510):394-5. [pmid: 5331176].
243 McArthur JC, Marek K, Pestronk A, et al. Nifedipine in the prophylaxis of classic migraine: a crossover, double-masked, placebo-controlled study of headache frequency and side effects. Neurology. 1989:284-6. [pmid: 2644581].
244 (MINES) M-NESG. European multicenter trial of nimodipine in the prophylaxis of classic migraine (migraine with aura). Headache. Nov. 1989;29(10):639-42. [pmid: 2693406].
245 Diamond S, Solomon GD, Freitag FG, et al. Fenoprofen in the prophylaxis of migraine: a double-blind, placebo controlled study. Headache. 1987:246-9. [pmid: 3298164].
246 Welch KMA, Ellis DJ, Keenan PA. Successful migraine prohpylaxis with naproxen sodium. Neurology. 1985.
247 Keskinbora K, Aydinli I. A double-blind randomized controlled trial of topiramate and amitriptyline either alone or in combination for the prevention of migraine. Clin Neurol Neurosurg. Dec. 2008;110(10):979-84. [pmid: 18620801].
248 Shaygannejad V, Janghorbani M, Ghorbani A, et al. Comparison of the effect of topiramate and sodium valporate in migraine prevention: a randomized blinded crossover study. Headache. Apr. 2006;46(4):642-8. [pmid: 16643559].
249 Baldrati A, Cortelli P, Procaccianti G, et al. Propranolol and acetylsalicylic acid in migraine prophylaxis. Double-blind crossover study. Acta Neurol Scand. 1983:181-6. [pmid: 6868956].
250 Langohr HD, Gerber WD, Koletzki E, et al. Clomipramine and metoprolol in migraine prophylaxis--a double-blind crossover study. Headache. Mar. 1985;25(2):107-13. [pmid: 3886599].
251 Aurora SK, Dodick DW, Turkel CC, et al. OnabotulinumtoxinA for treatment of chronic migraine: results from the double-blind, randomized, placebo-controlled phase of the PREEMPT 1 trial. Cephalalgia. Jul. 2010;30(7):793-803. [pmid: 20647170].
252 Mei D, Ferraro D, Zelano G, et al. Topiramate and triptans revert chronic migraine with medication overuse to episodic migraine. Clin Neuropharmacol. Sep-Oct. 2006;29(5):269-75. [pmid: 16960472].
253 Couch JR, Hassanein RS. Amitriptyline in migraine prophylaxis. Arch Neurol. Nov. 1979;36(11):695-9. [pmid: 508127].
254 Boisen E, Deth S, Hübbe P, et al. Clonidine in the prophylaxis of migraine. Acta neurologica Scandinavica. 1978:288-95. [pmid: 367043].
255 Ziegler DK, Ellis DJ. Naproxen in prophylaxis of migraine. Archives of neurology. 1985:582-4. [pmid: 4004602].
256 Saper JR, Mathew NT, Loder EW, et al. A double-blind, randomized, placebo-controlled comparison of botulinum toxin type a injection sites and doses in the prevention of episodic migraine. Pain Med. Sep. 2007;8(6):478-85. [pmid: 17716321].
257 Aurora SK, Gawel M, Brandes JL, et al. Botulinum toxin type a prophylactic treatment of episodic migraine: a randomized, double-blind, placebo-controlled exploratory study. Headache. Apr. 2007;47(4):486-99. [pmid: 17445098].
258 Dodick DW, Mauskop A, Elkind AH, et al. Botulinum toxin type a for the prophylaxis of chronic daily headache: subgroup analysis of patients not receiving other prophylactic medications: a randomized double-blind, placebo-controlled study. Headache. Apr. 2005;45(4):315-24. [pmid: 15836567].
259 Relja M, Poole AC, Schoenen J, et al. A multicentre, double-blind, randomized, placebo-controlled, parallel group study of multiple treatments of botulinum toxin type A (BoNTA) for the prophylaxis of episodic migraine headaches. Cephalalgia. Jun. 2007;27(6):492-503. [pmid: 17428299].
260 Freitag FG. Topiramate prophylaxis in patients suffering from migraine with aura: results from a randomized, double-blind, placebo-controlled trial. Advanced Studies in Medicine. 2003:S562-s4.
261 Reuter U, Del Rio MS, Diener HC, et al. Migraines with and without aura and their response to preventive therapy with topiramate. Cephalalgia an international journal of headache. 2010:543-51. [pmid: 19732072].
262 Di Trapani G, Mei D, Marra C, et al. Gabapentin in the prophylaxis of migraine: a double-blind randomized placebo-controlled study. Clin Ter. May–Jun. 2000;151(3):145-8. [pmid: 10958046].
263 Meyer JS, Hardenberg J. Clinical effectiveness of calcium entry blockers in prophylactic treatment of migraine and cluster headaches. Headache. 1983:266-77. [pmid: 6358126].
264 Barden J, Derry S, McQuay HJ, et al. Bias from industry trial funding? A framework, a suggested approach, and a negative result. Pain. Apr. 2006;121(3):207-18. [pmid: 16495012].
265 Fox AW. Disease modification in migraine: study design and sample size implications. Headache. Sep. 2008;48(8):1169-75. [pmid: 18819175].
266 Arends LR, Hoes AW, Lubsen J, et al. Baseline risk as predictor of treatment benefit: three clinical = meta-re-analyses. Stat Med. 2000;19:3497-518. [pmid: 11122510].
267 Hazard E, Munakata J, Bigal ME, et al. The burden of migraine in the United States: current and emerging perspectives on disease management and economic analysis. Value in Health. Jan. 2009;12(1):55-64. [pmid: 18671771].
268 Russell MB, Hilden J, Sorensen SA, et al. Familial occurrence of migraine without aura and migraine with aura. Neurology. Jul. 1993;43(7):1369-73. [pmid: 8392151].
269 Gentile G, Missori S, Borro M, et al. Frequencies of genetic polymorphisms related to triptans metabolism in chronic migraine. Journal of Headache & Pain. Apr. 2010;11(2):151-6. [pmid: 20213484].
270 Schurks M, Zee RY, Buring JE, et al. ACE D/I polymorphism, migraine, and cardiovascular disease in women. Neurology. Feb. 17. 2009;72(7):650-6. [pmid: 19221299].
271 Feldman HL. Pushing drugs: genomics and genetics, the pharmaceutical industry, and the law of negligence. Washburn Law Journal. 2003;42(3):575-99. [pmid: 15115000].
272 Tomson T, Battino D. Teratogenic effects of antiepileptic drugs. Lancet Neurol. Sep. 2012;11(9):803-13. [pmid: 22805351].
273 Coebergh JA, Waldinger MD. Reversible anorgasmia with topiramate for migraine prophylaxis. J Neuropsychiatry Clin Neurosci. Mar. 1. 2012;24(2):E30-1. [pmid: 22772690].
274 Huang CY, Keller JJ, Sheu JJ, et al. Migraine and erectile dysfunction: evidence from a population-based case-control study. Cephalalgia. Apr. 2012;32(5):366-72. [pmid: 22407657].
275 Antonaci F, Chimento P, Diener H-C, et al. Lessons from placebo effects in migraine treatment. Journal of Headache & Pain. Feb. 2007;8(1):63-6. [pmid: 17361384].
276 Bingham MF, Johnson FR, Miller D. Modeling choice behavior for new pharmaceutical products. Value in Health. Jan–Feb. 2001;4(1):32-44. [pmid: 11704970].
277 Silberstein SD, Holland S, Freitag F, et al. Evidence-based guideline update: pharmacologic treatment for episodic migraine prevention in adults: report of the Quality Standards Subcommittee of the American Academy of Neurology and the American Headache Society. Neurology. Apr. 24. 2012;78(17):1337-45. [pmid: 22529202].
278 Brouwers MC, Kho ME, Browman GP, et al. AGREE II: advancing guideline development, reporting and evaluation in health care. J Clin Epidemiol. Dec. 2010;63(12):1308-11. [pmid: 20656455].
279 Etemad LR, Yang W, Globe D, et al. Costs and utilization of triptan users who receive drug prophylaxis for migraine versus triptan users who do not receive drug prophylaxis. Journal of Managed Care Pharmacy. Mar. 2005;11(2):137-44. [pmid: 15766320].
280 Radley DC, Finkelstein SN, Stafford RS. Off-label prescribing among office-based physicians. Arch Intern Med. May. 8. 2006;166(9):1021-6. [pmid: 16682577].
281 Edwards IR. Off-label pharmacovigilance. Drug Safety. Oct. 1. 2011;34(10):795-7. [pmid: 21879775].
282 Layton D, Hazell L, Shakir SA. Modified prescription-event monitoring studies: a tool for pharmacovigilance and risk management. Drug Safety. Dec. 1. 2011;34(12):e1-9. [pmid: 22077508].
283 Mullan RJ, Flynn DN, Carlberg B, et al. Systematic reviewers commonly contact study authors but do so with limited rigor. J Clin Epidemiol. Feb. 2009;62(2):138-42. [pmid: 19013767].
284 Agency for Healthcare Research and Quality. Finding Evidence and Assessing for Reporting Biases when Comparing Medical Interventions: AHRQ and the Effective Health Care Program. In press. 2012.