# Methods

We followed an a priori research protocol that we developed with the clinical and methodological input of a technical expert panel. The protocol followed the Effective Health Care Program’s “Methods Guide for Effectiveness and Comparative Effectiveness Review.”

## Literature Search Strategy

### Search Strategy

We searched for published studies in several databases including MEDLINE^®^ (via Ovid and PubMed^®^), the Cochrane Library, and the SCIRUS bibliographic database to find original studies published in English up to May 20, 2012. We searched the FDA Web site for medical and statistical reviews of eligible drugs. We searched clinical trial registries, including ClinicalTrials.gov and the World Health Organization International Clinical Trials Registry, to find ongoing, completed, and published trials of migraine prevention. The Scientific Resource Center requested Scientific Information Packets from appropriate manufacturers (Appendix A) per usual procedures. We did not contact the investigators of the primary studies for missing data or clarifications.

To identify related articles, we developed an a priori search strategy based on relevant medical subject heading (MeSH^®^) terms, text words, and weighted word-frequency algorithms. Exact search strategies are shown in Appendix A.

Searches for relevant literature involved several steps: (1) evaluating previously published systematic reviews,39 (2) conducting a comprehensive literature search in the databases listed above to retrieve identified references, (3) screening abstracts against the inclusion/exclusion criteria, and (4) reviewing full text articles of eligible studies to determine potential inclusion in the synthesis.

### Inclusion Criteria

- Original epidemiologic studies that aimed to examine preventive pharmacologic treatments for migraine.
- Publication in English.
- Target population of community-dwelling adults with episodic migraine, chronic daily headache, or chronic migraine defined according to International Headache Society criteria for chronic migraine (Appendix B).11
- Eligible intermediate and patient-centered outcomes as listed in Figure 1.
- Drugs approved by the FDA for migraine prevention and off-label drugs examined in clinical trials (Appendix B Table 1).

Figure 1 Analytical framework35,36,40

KQ = Key Question; SES = socioeconomic status

K1 What are the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in adults?

K2 What are the comparative harms from pharmacologic treatments for preventing migraine attacks in adults?

K3 Which patient characteristics predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks in adults?

This figure presents a conceptual model and the analytical framework for the key questions within the context of the Population, Interventions, Comparators, Outcomes, and Settings. The framework includes eight headers: target Population for question as adults with migraine, pharmacological and nonpharmacological treatments for adults with migraine, intermediate outcomes such as number of monthly headache days, and clinical outcomes such as quality of life, prevention of migraine attacks, reduction in frequency of migraine attack by at least 50% from baseline, patient satisfaction, emergency visits, and loss of working days. In general, the figure illustrates pharmacological or combined modalities versus placebo, regular care, or active control may result in intermediate outcomes and clinical outcomes. Adverse events may occur at any point after treatment is received. Treatment effects may be modified by age, gender, race, aura, prior treatment, comorbidity, family history, and access to care. The figure also gives information about the research questions: KQ1 What is the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in adults? KQ2 What are the comparative harms from pharmacologic treatments for preventing migraine attacks in adults? KQ3 Which patient characteristics predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks in adults?

We reviewed RCTs that included adults with migraine, comorbid headache disorders, or tension headache if they examined prevention of migraine.

### Exclusion Criteria

- Studies of treatments aimed at acute migraine attacks.
- Studies that involved patients with migraine variants, such as hemiplegic migraines, basilar migraine, retinal migraine, complicated migraines, and ophthalmoplegic migraine; hospitalized patients; or patients in emergency rooms.41,42,43 Studies of short-term prevention of migraine, including menstrual migraines.
- Studies that included some patients with migraine but did not separately report those outcomes.
- Studies that involved surgical treatments for migraine.
- Preclinical pharmacokinetic studies of eligible drugs; studies that examined the pathophysiology of migraine and reported instrumental measurements or biochemical outcomes.
- Studies that examined eligible drugs on populations with other diseases.

## Study Selection

We followed the AHRQ Methods Guide to select evidence from controlled trials and observational studies.44 Three investigators worked independently to determine study eligibility resolving disagreements through discussion.45 We used all included randomized controlled trials (RCTs) to assess effectiveness with drugs. We used all included RCTs and nonrandomized studies to assess adverse effects and treatment discontinuation due to adverse effects.44 To assess harms of treatments, we included published and unpublished evidence of the adverse effects of drugs in patients with migraine.46 We defined harms as a totality of all possible adverse consequences of an intervention46 and analyzed all harms, regardless of how authors perceived causality of treatments.

We defined eligible preventive treatments, outcomes, time, and outpatient setting following the analytical PICOTS framework (Population, Intervention, Comparator, Outcomes, Timing, and Settings). We defined the target population as community-dwelling adults with episodic or chronic migraine. We formulated a list of eligible interventions after discussions with key informants and technical experts and after consideration of public comments (Appendix B Table 1). Eligible comparators included pharmacologic, nonpharmacologic, and combined preventive treatments. We defined eligible intermediate and patient-centered outcomes (presented in the analytical framework in Figure 1).

## Data Extraction

Researchers used standardized forms to extract data (available at https://netfiles.umn.edu/xythoswfs/webui/_xy-21041343_1-t_zdhvSpvy). One reviewer abstracted an article and a second reviewed the abstracted data for accuracy. We assessed errors by comparing established ranges for each variable with data charts from the original articles and discussed detected discrepancies. We abstracted the information relevant to the PICOTS framework. We abstracted minimum datasets to reproduce the results presented by the authors. For categorical variables we abstracted the number of events among treatment groups to calculate rates, relative risk, and absolute risk differences. We abstracted means and standard deviations of continuous variables to calculate mean differences with a 95% confidence interval (CI).

For RCTs in the quantitative analysis set we abstracted the number randomized to each treatment group as the denominator and calculated estimates by applying intention-to-treat principles assuming that the same proportions apply in the missing data. 45 We abstracted the time when the outcomes were assessed as weeks from randomization and the time of followup after treatments.

We abstracted inclusion and exclusion criteria, drug regimen and doses, and patient characteristics (demographics, baseline frequency, severity, and prior treatment status) as factors that can modify treatment effects. We abstracted the definition of migraine used in each study. We abstracted sponsorship of the studies, sponsor participation in study design and in analysis and presentation of data, and conflict of interest by the authors.

## Risk of Bias Assessment

We evaluated the risk of bias in individual studies of benefits and harms according to recommendations from the “Cochrane Handbook for Systematic Reviews of Interventions.”45 First, we classified studies by their design as either interventional (RCTs, nonrandomized controlled clinical trials, and nonrandomized uncontrolled clinical trials) or observational (cohort or case-control studies, cross-sectional studies, or case series).

Then, using the criteria from the Cochrane risk of bias tool in interventional studies,47 we evaluated: (1) random allocation of the subjects to the treatment groups; (2) masking of the treatment status to the participants and investigators; (3) adequacy of allocation concealment; (4) adequacy of randomization as similarity of the subjects in treatment groups by demographics, migraine frequency and severity, and response to previous treatments; (5) intention-to-treat principles; and (6) selective outcome reporting when compared with methods section in the articles. Since all outcomes in the review were self-reported, masking of outcome assessment was not essential in evaluating risk of bias, but masking of treatment was. Masking of treatment status was not feasible for RCTs that examined nondrug therapies as comparators; therefore, we did not include it in risk-of-bias assessment for those studies.

We assumed a low risk of bias when RCTs met all the risk of bias criteria, a medium risk of bias if at least one of the risk of bias criteria was not met, and a high risk of bias if two or more risk of bias criteria were not met.48 We concluded an unknown risk of bias for the studies with poorly reported risk of bias criteria. We assessed risk of bias in nonrandomized studies according to adjustment for confounding factors to address selection bias and exclusion of subjects from the analyses to address attrition biases.49

We evaluated disclosure of conflict of interest by the authors of individual studies and funding sources, but we did not use this information to downgrade quality of individual studies.

## Data Synthesis

We categorized drugs according to The Anatomical Therapeutic Chemical Classification System of the World Health Organization. Accordingly, we categorized botulinum toxin treatments under one category-M03AX01. We analyzed together and separately the effects of onabotulinumtoxin A (approved by the FDA), botulinum neurotoxin type A, and abobotulinumtoxin A.

We focused on patient-centered outcomes, such as ≥50 percent reduction in migraine attacks from baseline, quality of life, patient satisfaction, and composite measures of response, including frequency and severity of migraine. We incorporated risk of bias in individual studies into the synthesis of evidence by using individual risk of bias criteria rather than a global score or a ranking category of overall risk of bias.50,51 Synthesis of evidence about comparative benefits and safety with drugs from individual RCTs was restricted to studies with low or medium risk of bias.22

We synthesized the evidence according to patient characteristics that could modify treatment effect, including age, sex, race, and duration of migraine, baseline frequency and severity of acute migraine attacks, presence of aura, previous drug treatments, history of drug overuse, and others described in the PICOTS framework. We addressed the role of comorbidities and concomitant treatments in association with patient-centered outcomes. When possible, based on the reporting in original studies, we conducted subgroup and sensitivity analyses according to patient characteristics, drug dose, and timing of followup.

We examined whether the definition of migraine could contribute to the differences in trial results. The FDA approved four drugs for prevention of episodic migraine based on trials conducted before the implementation of the most recent migraine definition proposed by the International Headache Society.11 Thus, older eligible studies published before 2004 defined migraine according to previous definitions of the International Headache Society or according to definitions of the Ad Hoc Committee on Classification of Headache.52 We compared baseline patient characteristics and treatment effects depending on the exact migraine definition and here we report the results when they differed significantly.

Using Meta-Analyst53 and STATA^®^54 software, we calculated the relative risk and absolute risk difference from the abstracted events. We evaluated statistical significance at a 95 percent confidence level. We used default software continuity coefficients for 0 events and intention to treat as recommended calculations for missing data. We hypothesized superiority of drugs versus placebo and versus each other.55

For continuous outcomes we calculated the mean differences from the reported means and standard deviations. We also calculated ratios of means that describe clinically interpretable percentage differences in outcomes with active versus control treatments.56 We calculated Cohen standardized mean differences for different measures of the same outcome.

We used a logarithmic scale to analyze the adjusted regression coefficient with a standard error of association between treatments and patient-centered outcomes. We used correction coefficients (0.5 as a default option in both software applications) and intention to treat as recommended calculations for missing data.45

For sparse adverse effects data, we used multiple models to test robustness of inferential statistics. Models included random and fixed effects inverse variance methods, maximum likelihood methods, Peto odds ratio,57 double arcsine transformation for comparing two proportions, and odds ratios from random-effects generalized nonlinear mixed-effect models.53,58–61

Pooling criteria for Key Questions 1 and 2 included the same active drug treatments and comparators and the same definitions of the outcomes. We calculated and pooled Cohen standardized mean differences for different continuous measures of the same outcome. In cases of multiarm trials, we created a single pair-wise comparison.47 To avoid the spurious increase in precision in multiarm trials, we divided placebo arms approximately evenly among the comparisons according to randomization ratio.45,62

We tested consistency in the results by comparing the direction and strength of the association.63 We assessed heterogeneity in results with Chi-squared and I-squared tests.64,65 We explored heterogeneity with meta-regression and sensitivity analysis; we report the results from random effects models only.66 We used the random effects model to incorporate in the pooled analysis any differences across trials in patient populations, baseline rates of the outcomes, dosage of drugs, and other factors.57 We explored heterogeneity by risk-of-bias criteria, disclosed conflicts of interest, study sponsorship, dose and duration of drug treatments, time of followup, inclusion of minorities, proportion of women and elderly adults, and other patient characteristics described above. To avoid ecological fallacy, we did not use patient level variables (for example, mean age or body mass index) in meta-regression.66

We calculated the number needed to treat to achieve one event of a patient-centered outcome as reciprocal to absolute risk differences (ARD) in rates of outcome events in the active and control groups.54,67 We calculated means and 95% CIs for the number needed to treat as reciprocal to pooled ARD when ARD was significant.68 The number of avoided or excess events (respectively) per population of 1,000 is the difference between the two event rates multiplied by 1,000.

In cases when very few studies were available to provide evidence from direct head-to-head comparisons, we conducted indirect comparisons. To conduct indirect comparisons, we used statistical techniques to estimate the treatment effects from studies of each given treatment against controls under an assumption of consistency.69–73

- We used adjusted indirect frequentist comparisons for individual drugs that were compared with placebo.71 This analysis provided pair-wise triangular comparisons for drugs that were compared with placebo rather than network meta-analysis.
- To address the problems with inevitable differences across studies, we used mixed (or multiple) treatment comparisons (MTCs), or so-called network meta-analysis.71–73 Network meta-analysis refers to methods that, in the absence of head-to-head comparisons, compare treatments by combining all available evidence from studies that form a network of evidence (including studies that compare three or more treatment arms).

By synthesizing direct and indirect comparisons, we improved the precision of estimates for treatment effects. A Bayesian analysis can easily construct complicated models with fewer assumptions. Bayesian analysis also permits explicit posterior inference regarding the probability that each treatment is “best” for a specific outcome.74–76 We calculated Bayesian odds ratios53,61 with 2.5 to 97.5 percent credible intervals. We conducted exploratory Bayesian network random effects meta-analysis assuming heterogeneous variances across treatments (Appendix B Table 2).77 We synthesized evidence from drug classes in network meta-analysis when individual drugs from the same class demonstrated no significant differences in outcomes. We compared odds ratios from network meta-analyses with odds ratios from direct head-to-head RCTs to examine consistency of the estimates.78 We concluded no differences in drug effect (hereafter called similar effects) if confidence or credible intervals included one (no effect or no difference).79 All Bayesian results were obtained from the WinBUGS software,80 using Markov chain Monte Carlo (MCMC) samples after a 50,000-sample algorithm burn-in. WinBUG codes are presented in Appendix B Table 3.

## Grading the Evidence for Each Key Question

We assessed strength of evidence according to risk of bias, consistency, directness, and precision for each patient-centered outcome including reduction in monthly migraine frequency by 100 percent or ≥50 percent, patient global assessment of treatment success, rates of clinically important improvement in migraine-related disability and quality of life. We also assessed treatment discontinuation due to harms.63 We based our criteria on published guidelines acknowledging inevitable subjectivity of the assessment.47,81 We assigned a medium or high risk of bias in the body of evidence when at least one individual RCT had medium or high risk of bias, respectively.

We defined treatment effect estimates as precise when pooled estimates had reasonably narrow 95% CIs, and pooled sample size was greater than 300 (using 25% relative effect difference for calculation of optimal information size).82 We did not include justification of the sample size into grading of the evidence nor did we conduct post hoc statistical power analysis.

We defined reporting bias as publication bias, selective outcomes reporting, and multiple publication bias. We did not perform formal statistical tests quantifying reporting biases due to the questionable statistical validity of the available tests.83 We assess publication bias by analyses of the publication rates of the registered studies and the NIH funded studies. We assess selective reporting of the patient centered outcomes by comparing protocols with published results.

In assessing strength of evidence, we looked at dose-response association, strength of association, and reporting bias in nonrandomized studies. We evaluated the strength of the association, defining a priori a large effect when relative risk was >2 and a very large effect when relative risk was >5.^45^ We defined low magnitude of the effect when relative risk is significant but <2.

We defined high level of evidence on the basis of consistent findings from well-designed RCTs (Table 1). We downgraded strength of evidence to moderate if at least one of the four strength-of-evidence criteria was not met; for example, the studies had medium risk of bias or the results were not consistent or precise. We downgraded strength of evidence to low if two or more criteria were not met. We assigned a low level of evidence to nonrandomized studies and upgraded strength of evidence for strong or dose response associations. We defined evidence as insufficient when a single study with high risk of bias examined treatment effects or associations. We applied this approach regardless of whether the results were statistically significant.

Table 1 Strength of evidence ranks and definitions

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit a conclusion.

## Assessing Applicability

We estimated applicability of the population by evaluating the selection of adults with migraine in observational studies and clinical trials.79 Studies of community-dwelling adults receiving drug treatments with 6 or more months of followup had high applicability, as did large observational cohorts based on national registries, population-based effectiveness trials, and nationally representative administrative and clinical databases.

### Peer Review and Public Commentary

We invited external peer review of this Comparative Effectiveness Review (CER) from experts in migraine management fields and individuals representing stakeholder and user communities; AHRQ and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revised the text as appropriate, and documented everything in a disposition of comments report that will be made available 3 months after the Agency posts the final CER on the AHRQ Web site.