# Introduction

Migraine is a central nervous system disorder characterized by vascular headaches.1 Migraine headaches range from moderate to very severe, can cause debilitating pain, and can last from 4 to 72 hours.2,3 In the United States, migraine affects 17 percent of women and 6 percent of men.4–7 The cumulative lifetime incidence of migraine in the U.S. population is 43 percent for women and 18 percent for men.8

Although the frequency and severity of migraine vary considerably, the American Migraine Prevalence and Prevention expert advisory group recommends that prevention for episodic migraine defined as ≥4 monthly migraine days with normal functioning or ≥2 migraine days with severe impairment.9 For 1.4 to 2.2 percent of those who experience migraine, the condition is chronic10 as defined by the National Headache Foundation (i.e., headache that occurs >15 days per month for at least 3 months).11,12 Both migraine types significantly affect patients’ physical, psychological, and social well-being and can impose serious lifestyle restrictions.

Migraine also exacts a heavy economic toll. Each year, lost work time and diminished productivity from migraines cost American employers $225.8 billion.13–15 Forty percent of adults with episodic migraine and all adults with chronic migraine might benefit from preventive medication,5,16,17 thus reducing lost productivity and work time. Yet, results from several studies demonstrate that only 12.4 percent of adults who experience migraine take preventive medication.4,5,16,17

Migraine pain results primarily from increased activity of several agents that regulate blood vessels and sensory function of the brain.1 In about 15 percent of patients, migraine attacks may be accompanied by aura (visual, sensory, or language symptoms). Other accompanying symptoms may include photophobia (excessive sensitivity to light), phonophobia (fear of loud sounds), osmophobia (hypersensitivity to smells), nausea, or vomiting.2

Preventive medications from several drug classes presumably affect various aspects of migraine pathophysiology.18,19 The four drugs approved by the U.S. Food and Drug Administration (FDA) for episodic migraine prevention in adults are propranolol, timolol, topiramate, and divalproex sodium.20 For chronic migraine, the FDA has approved only one drug, onabotulinumtoxin A. Doctors also prescribe off-label drugs (approved for clinical conditions other than migraine prevention) for migraine prevention, including novel antiepileptic drugs, calcium channel blockers, serotonin and noradrenaline reuptake inhibitors, glutamate blockers, and drugs from several other classes.20,21

Preventive treatment aims to eliminate headache pain without intolerable harms.22–24 However, some degree of pain often persists; therefore, treatment success is usually defined by a decrease in migraine frequency by ≥50 percent after 3 months.2 In addition to relieving pain, preventive drugs can decrease severity of migraine attacks, reduce use of acute drugs, improve quality of life, normalize brain activity, and eliminate photophobia, phonophobia, nausea, and vomiting.25,26

Long-term adherence to preventive treatments is low. Between 17 and 29 percent of patients discontinue medication because of adverse effects such as anxiety, nausea, vomiting, reduced sleep time, drowsiness, and weakness.27,28 Drug choices are based on efficacy and adverse effects as well as headache frequency, presence of aura, and comorbid conditions.11,22,23,29,30 Some guidelines recommend preventive treatments for patients who have five or more migraine attacks per month,1 while others suggest it for those who experience a headache on most days of the month.11,12,31 Often, preventive treatment is recommended for only 6 to 9 months; however, very limited research exists regarding migraine frequency after discontinuation of preventive treatment.2

Several gaps remain in published literature on preventive treatments for migraines. Systematic reviews have focused on the efficacy of specific drugs rather than comparative effectiveness of all pharmacologic and nonpharmacologic treatment options.32 Little attention has been paid to the comparative effectiveness of off-label drugs used for migraine prevention. Published reviews have not examined quality of life. Clinical reviews have compared the safety with only a few drugs.32,33 The majority of patients seen in headache specialty clinics that practice multidisciplinary coordinated care had chronic migraine.8

Our review focuses on the comparative effectiveness and safety of the drugs used for migraine prevention in adults; our results may help inform treatment recommendations. By the nature of the question, this review focuses on outpatient care.

## Topic Refinement and Review Protocol

The topic was anonymously nominated via the public domain. During the topic refinement stage, we solicited input from Key Informants representing medical professional societies/clinicians in the areas of neurology, primary care, consumers, scientific experts, and payers, to help define the Key Questions (KQs).34 The KQs were then posted for public comment for 4 weeks, and the comments received were considered in the development of the research protocol. We next convened a Technical Expert Panel (TEP) comprising clinical, content, and methodological experts to provide input in defining populations, interventions, comparisons, and outcomes, and in identifying particular studies or databases to search. The Key Informants and members of the TEP were required to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts. Any potential conflicts of interest were balanced or mitigated. Neither Key Informants nor members of the TEP performed analysis of any kind, nor did any of them contribute to the writing of this report. Members of the TEP were invited to provide feedback on an initial draft of the review protocol, which was then refined based on their input, reviewed by AHRQ, and posted for public access from April 12, 2012, to May 10, 2012, at the AHRQ Effective Health Care Web site.

We conducted a comprehensive literature review following the principles in the “Methods Guide for Effectiveness and Comparative Effectiveness Reviews” (hereafter Methods Guide) developed by the Agency for Healthcare Research and Quality (AHRQ) Evidence-based Practice Center Program35,36 and PRISMA guidelines.37 The protocol is posted in the systematic review registry (protocol registration number is CRD42012001918, available at www.crd.york.ac.uk/prospero/display_record.asp?ID=CRD42012001918).38

### Key Questions

#### KQ 1 What are the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in adults?

a. How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared with placebo or no active treatment?
b. How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared with active pharmacologic treatments?
c. How do preventive pharmacologic treatments affect patient-centered and intermediate outcomes when compared with active nonpharmacologic treatments?
d. How do preventive pharmacologic treatments combined with nondrug treatments affect patient-centered and intermediate outcomes when compared with pharmacologic treatments alone?
e. How might dosing regimens or duration of treatments influence the effects of the treatments on patient-centered outcomes? How might approaches to drug management (such as patient-care teams, integrated care, coordinated care, patient education, drug surveillance, or interactive drug monitoring) influence results?

#### KQ 2 What are the comparative harms from pharmacologic treatments for preventing migraine attacks in adults?

a. What are the harms from preventive pharmacologic treatments when compared with placebo or no active treatment?
b. What are the harms from preventive pharmacologic treatments when compared with active pharmacologic treatments?
c. How might approaches to drug management (such as patient-care teams, integrated care, coordinated care, patient education, drug surveillance, or interactive drug monitoring) influence results?

#### KQ 3 Which patient characteristics predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks in adults?