# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Andrew Blumenfeld, M.D.
  Kaiser Permanente
  San Diego, CA
- Frederick Freitag, D.O., FAHS
  Baylor Research Institute
  Dallas, TX
- Rochelle Fu, Ph.D.
  Oregon Evidence-based Practice Center
  Portland, OR
- Bray Patrick-Lake, M.F.S.
  Consumer representative
  Erie, CO