# Discussion

Our report, in accordance with previously published reviews,23,24 demonstrated that all approved drugs were better than placebo in reducing monthly migraine frequency by ≥50 percent. In addition, we found that, compared with approved drugs, some off-label beta blockers and angiotensin inhibiting drugs are more effective and safer for preventing adult migraine. The relative effect of drugs was moderate, with drugs resulting in 200 to 400 cases of clinical response (of ≥50 percent reduction in monthly migraine frequency) per 1,000 treated.

Critical assessment of the strength of the available evidence suggested low risk of bias in one-third and medium risk of bias in more than half of included RCTs. We relied on direct evidence from head-to-head RCTs. We also analyzed previously published meta-analyses of individual patient data that provided valid estimation of dose response effects with drugs. However, strength of evidence was moderate only for topiramate and low for other drugs due to risk of bias and imprecise estimates. Many authors of individual trials did not provide sufficient details about allocation concealment methods or about planned measurements of clinically important changes in quality of life scores. In addition, many investigators failed to use intention-to-treat principles for all examined outcomes. Finally, many trials did not fully adhere to the recommendations from the Task Force of the International Headache Society Clinical Trials Subcommittee in design and reporting of the controlled clinical trials for preventing migraine in adults.22

We incorporated risk of bias in our evaluation of the strength of evidence, but we could not estimate the effect of risk of bias criteria on drug benefits or safety because most evidence came from individual RCTs. The role of financial conflict of interest and industry sponsor participation in data analyses and interpretation was difficult to evaluate due to inconsistent reporting in individual studies and insufficient reporting of details.264 For instance, the same authors disclosed no or different relationships with industry in multiple publications. Studies inconsistently reported subjects’ baseline severity and frequency of migraine attacks as well as comorbidities and concomitant treatments.2,265

The results from eligible studies were applicable to the target population. The trials enrolled predominantly middle-aged Caucasian women. However, average treatment effects in a clinically diverse population may not reflect the actual effects for a specific subgroup.266 Very few studies provided evidence for individualized treatment decisions with clear descriptions of planned stratified randomization and subgroup analyses. Published RCTs rarely reported important patient characteristics that could modify drug effects (history of migraine, socioeconomic status, or response to prior preventive treatments).267,268 No trials examined the role of genetic polymorphism in drug metabolism and effects.269–271 Migraine prevention trials did not address teratogenic effects, anorgasmia, impotence, and other harms of anti-epileptic drugs that can deter long-term adherence to preventive drugs. 272,273,274

A few RCTs reported treatment effects in patient subpopulations by baseline migraine frequency of placebo response. Low-strength evidence suggested that onabotulinumtoxin A257 and amitriptyline228 were more effective in patients with frequent baseline migraine. Rates of migraine prevention in placebo arms ranged from 6 to 30 percent in examined RCTs. Previous research demonstrated a high placebo response in trials aimed to treat acute migraine attacks.28,275 Our review demonstrated that a relative risk of adverse effects with onabotulinumtoxin A was lower in trials with higher placebo rates of adverse effects.94 Previous research has demonstrated that patients with migraine quit taking topiramate due to bothersome adverse effects more often than patients with epilepsy.28 Most trials in our review excluded patients with severe medical or psychiatric illnesses, stroke, and vascular migraine. Substantial variability in reporting comorbidities precluded using this information in quantitative synthesis of evidence.

Comparative effectiveness and safety with preventive drugs were examined in individual RCTs that failed to meet pooling criteria. Variability in examined drug comparisons in head-to-head RCTs precluded meta-analysis of direct evidence. However, indirect comparisons were feasible because we found no evident differences in baseline patient characteristics across RCTs. Thus, we conducted Bayesian network meta-analyses, which indicated that angiotensin inhibiting drugs and beta blockers were the most effective and safe drugs. Head-to-head trials were not designed to test safety with migraine preventive drugs. Very few trials were designed to detect significant increase in rates of bothersome adverse effects leading to treatment discontinuation when compared with placebo. In contrast, network meta-analysis demonstrated that patients stopped taking drugs more often with topiramate, off-label antiepileptics, and antidepressants than with placebo. Individual adverse effects varied depending on the pharmacodynamic properties of the drugs.

Multidisciplinary drug management programs demonstrated improvement in migraine-related disability and patient satisfaction, but long-term adherence and benefits are unclear.

Only a few RCTs examined quality of life, providing no consistent evidence of improvement with examined drugs. The authors rarely measured quality of life using disease-specific instruments such as the Migraine Specific Questionnaire, Migraine Disability Assessment, or the Headache Impact Test. We could not determine the clinical importance of statistically different changes in scores.

Our review has implications for clinical practice. Informed decisions in clinical settings should take into account exact rates of benefits and harms with specific drugs.276

The most recent guidelines from the American Academy of Neurology and the American Headache Society recommend the four FDA-approved drugs—the antiepileptics topiramate and divalproex and the beta-blockers propranolol and timolol—for adult migraine prevention.277 The aforementioned guidelines, which focused on published evidence, differed regarding their recommendations for off-label drugs. Further, current guidelines do not include consideration of the balance between benefits and harms of drugs as a basis for clinical decisonmaking.278 Our review analyzed benefits and harms of drugs and provided evidence for using effective and relatively safe off-label angiotensin inhibiting drugs and other off-label beta-blockers as alternatives based on patient preferences, comorbidities, and contraindications to the medications.

We could not find published controlled observational studies about preventive drug use or about the comparative effectiveness of approved versus off-label drugs. A single retrospective administrative database study found that migraine prophylaxis medications (tricyclic antidepressants, serotonin reuptake inhibitors antidepressants, mirtazapine, venlafaxine, phenelzine, beta blockers, calcium channel blockers, valproic acid and derivatives, gabapentin, tiagabine, topiramate, and carbamazepine) were associated with a significant reduction in migraine-related costs.279 Large observational studies of health care use for migraine did not analyze comparative effectiveness of preventive drugs.5,16

Some evidence suggested that use of off-label drugs is common in the United States, despite having little or no scientific support.21 For instance, the Institute of Medical Informatics Health National Disease and Therapeutic Index analysis suggested that 20 percent of all outpatient drug prescriptions for adults were for off-label drugs. The most commonly prescribed off-label drugs were anticonvulsants, gabapentin, and amitriptyline hydrochloride.280 We found that off-label antiepileptics and antidepressants demonstrated worse benefits and safety profiles than beta blockers or angiotensin inhibiting drugs. Evidence of off-label drug use and associated adverse effects has been evaluated with prospective pharmacovigilance surveys in European countries.281,282 Routine monitoring of harms with off-label drugs is needed in the United States in order to collect and analyze evidence of comparative safety in clinical settings.

Our report has limitations, including possible reporting bias. We restricted our review to studies published in English in journals, reviewed by the FDA, or reported on the ClinicalTrials.gov Web site. Even after such a comprehensive review of evidence, we do not know how many funded but unregistered studies we may have missed. Published articles rarely provided unique trial registration numbers from Clinicaltrials.gov. We concluded multiple reports of the same data based on available information and did not contact the authors for further clarifications. We suspected selective harms reporting because published articles reported common and expected adverse effects. In contrast, few RCTs that posted results in Clinicaltrials.gov reported all harms regardless of the rate or the assumed association with active drugs. We did not contact the authors requesting unreported benefits and harms; [underlined: the cost-effectiveness of this pursuit is still being debated.]283,284 For studies in which methodological quality criteria were poorly reported, we did not contact the authors for additional details. Vast variability in examined treatment option, risk of bias, and imprecise estimates from small individual RCTs hampered synthesis of evidence.

## Future Research Needs

We identified gaps and biases in available evidence that can direct future research (Table 32). Future randomized well-designed clinical trials should examine comparative effectiveness of the approved drugs and the most effective off-label ACE inhibitors, angiotensin II blockers, and off-label beta blockers. Future trials should examine the potential modification of treatment effects by factors such as patient age, sex, race, migraine family history, comorbidities, and prior treatment response. Observational studies should analyze off-label drug use as well as the comparative effectiveness and safety of migraine preventive drugs. Analysis of administrative databases should examine visits to doctors and emergency rooms among adults taking migraine preventive drugs. Prospective pharmacovigilance methods should be used for routine monitoring of off-label drug utilization and associated adverse effects with migraine preventive drugs. All interventional studies should be registered in ClinicalTrials.gov. All clinical trials of migraine preventive drugs should be required to post their results in ClinicalTrials.gov.

Table 32 Future research needs

Key Question | Findings | Types of Studies Needed To Answer Question | Future Research Recommendation
KQ 1: What are the efficacy and comparative effectiveness of pharmacologic treatments for preventing migraine attacks in adults? | - All approved drugs, some off-label beta blockers, and ACE inhibitors were better than placebo in reducing monthly migraine frequency by ≥50% (clinical response).; - Individual RCTs provided low strength of evidence about comparative effectiveness of drugs with few significant differences.; - Network Bayesian meta-analysis of 59 drugs from 14 drug classes demonstrated that all approved drugs were similarly better than placebo. Among off-label drugs angiotensin inhibiting drugs, and some off-label beta blockers are more effective than all other drugs. | - Randomized clinical trials.; - Creating of migraine registry with individual patient data from electronic medical records and quarterly completed migraine diaries.; - Analysis of health insurance, Medicare, and Medicaid databases.; - Prospective pharmacovigilance surveys. | - Design low-risk-of-bias RCTs following recommendations from the International Headache Society about migraine definitions, inclusion, and exclusion criteria of the subjects, assessments of patient centered outcomes at the end of the treatments and at 6 months or more of followup.; - Conduct observational studies reducing risk of bias by matching, adjustment, and propensity score.; - Examine comparative effectiveness of the most effective and safe angiotensin inhibiting drugs and beta blockers with approved antiepileptics and beta blockers.; - Examine comparative effectiveness of combined treatments with approved and off-label Angiotensin inhibiting drugs vs. monotherapy.; - Examine treatment effects in patient subpopulations by age, sex, race, socioeconomic status, prior treatment history, comorbidity, family history of migraine, and baseline migraine type, severity, and frequency.; - Focus on validated measures of quality of life and migraine related disability.; - Examined preventive drug utilization and the effects on health care utilization (emergency visits, hospitalizations, abortive drug utilization and overuse).; - Examine which patient and provider characteristics are associated with preventive drug utilization.; - Examine the benefits with multidisciplinary migraine management programs and combined pharmacologic and self-administrated migraine management interventions.
KQ 2: What are the comparative harms from pharmacologic treatments for preventing migraine attacks in adults? | - Among approved drugs, onabotulinumtoxin A, topiramate, and propranolol resulted in bothersome adverse effects leading to treatment discontinuation more often than placebo.; - The association was dose responsive for topiramate. Larger doses of topiramate caused higher risk of anorexia, depression, paresthesia, and difficulty in memory leading to treatment withdrawal. Larger doses of topiramate caused higher risk dry mouth, paresthesia or fatigue, mood problems, nausea, and weight loss.; - Individual RCTs showed that divalproex led to treatment discontinuation due to adverse effects that included nausea, somnolence, tremor, vomiting, and asthenia.; - Among other drugs, pooled analyses demonstrated that off-label antidepressant amitriptyline caused bothersome adverse effects leading to treatment discontinuation more often than placebo.; - Limited low-strength evidence from individual head-to-head RCTs suggested that treatment discontinuation due to adverse effects was less frequent with onabotulinumtoxin A than topiramate or amitriptyline.; - Individual unique RCTs provided low-strength direct evidence about adverse effects with specific drugs, with no consistent pattern across available drug comparisons.; - Indirect adjusted analyses demonstrated no differences in treatment discontinuation due to adverse effects with approved drugs or approved versus off-label drugs. Exploratory Bayesian network meta-analyses demonstrated that topiramate, off-label antiepileptics, and antidepressants resulted in bothersome adverse effects leading to treatment discontinuation more often than placebo. According to network meta-analysis, off-label angiotensin inhibiting drugs and beta-blockers were the safest treatment option for adults with episodic migraine | - Randomized clinical trials.; - Creating migraine registry with individual patient data from electronic medical records and quarterly completed migraine diaries.; - Analysis of health insurance, Medicare, and Medicaid databases.; - Prospective pharmacovigilance surveys | - Design low-risk-of-bias fully powered to assess harms RCTs following recommendations from the HIS about migraine definitions, inclusion, and exclusion criteria of the subjects, comorbidities, assessments of patient centered outcomes at the end of the treatments and at 6 months or more of followup.; - Conduct observational studies reducing risk of bias by matching, adjustment, and propensity score.; - Examine comparative safety of the commonly used approved and off-label drugs with the most effective and safe angiotensin inhibiting drugs and beta blockers.; - Examine treatment harms in patient subpopulations by age, sex, race, socioeconomic status, prior treatment history, comorbidity, concomitant treatments, family history of migraine, and doses of the drugs.; - Analyze all harms the patient experienced irrespective of investigator determination about causality between drugs and harms.; - Examined preventive drug utilization and the effects on health care utilization (treatments for adverse effects, hospitalizations for drug harms).; - Examine the effects of multidisciplinary migraine management programs on patient safety.; - Routinely analyze all harms in patients with migraine taking preventive drugs.
KQ 3: Which patient characteristics predict the effectiveness and safety of pharmacologic treatments for preventing migraine attacks in adults? | - Evidence was limited to individual RCTs that examined the drug effect modification by selected patient characteristics. | - Randomized clinical trials.; - Creating of migraine registry with individual patient data from electronic medical records and quarterly completed migraine diaries.; - Analysis of health insurance, Medicare, and Medicaid databases; prospective pharmacovigilance surveys. | - Conduct low-risk-of-bias RCTs with planned subgroup analysis of treatment benefits by age, sex, race, socioeconomic status, prior treatment history, comorbidity, family history of migraine, and baseline migraine type, severity, and frequency.; - Conduct low-risk-of-bias powered RCTs with planned subgroup analysis of treatment harms by age, sex, race, socioeconomic status, prior treatment history, comorbidity, concomitant treatments, family history of migraine, and doses of the drugs.; - Conduct pharmacogenomic studies to examine the effects of genetically predisposed drug metabolism on treatment benefits and harms.; - Evaluate treatment effects in patient subpopulations by age, sex, race, socioeconomic status, prior treatment history, comorbidity, family history of migraine, and baseline migraine type, severity, and frequency.; - Examine treatment harms in patient subpopulations by age, sex, race, socioeconomic status, prior treatment history, comorbidity, concomitant treatments, family history of migraine, and doses of the drugs.; - Routinely analyze which patient and provider characteristics are associated with drug adverse effects in patients with migraine taking preventive drugs.; - Routinely analyze which patient and provider characteristics are associated with treatment discontinuation in patients with migraine taking preventive drugs.

RCT = randomized controlled trial

## Key Messages

### Efficacy and Comparative Effectiveness of Pharmacologic Treatments for Preventing Migraine Attacks in Adults

#### Effect of Preventive Pharmacologic Treatments on Patient-centered and Intermediate Outcomes Compared With Placebo or No Active Treatment

- For chronic migraine, onabotulinumtoxin A was more effective than placebo in reducing monthly chronic migraine attacks by ≥50 percent with inconsistent improvement in quality of life.
- For episodic migraine, all approved drugs were better than placebo in reducing monthly migraine frequency by ≥50 percent (clinical response).
- Relative effect of drugs was moderate: drugs would result in clinical response in 200 to 400 patients per 1,000 treated.
- Strength of evidence was lowered due to medium risk of bias and imprecise estimates.
- Low-strength evidence from individual RCTs suggested a dose-responsive increase in migraine prevention with higher doses of onabotulinumtoxin A and topiramate (from 50–100 mg with no additional benefits with 200 mg/day).
- Among off-label drugs, pooled analyses offered low-strength evidence that the antiepileptic gabapentin, the beta-blocker metoprolol, and the calcium channel blocker nimodipine were better than placebo in reducing monthly migraine attacks by ≥50 percent.
- Individual RCTs offered low-strength evidence that off-label beta blockers acebutolol atenolol, and nadolol were better than placebo in reducing monthly migraine attacks by ≥50 percent. Individual RCTs demonstrated that compared with placebo, the angiotensin converting enzyme inhibitors captopril and lisinopril and the angiotensin II antagonist candesartan were better in reducing monthly migraine attacks by ≥50 percent.

#### Effect of Preventive Pharmacologic Treatments on Patient-Centered and Intermediate Outcomes Compared With Active Pharmacologic Treatments

- Individual RCTs provided low-strength direct evidence about the comparative effectiveness of drugs and demonstrated few significant differences.
- Indirect adjusted analysis demonstrated no differences between approved drugs and greater odds of clinical response with angiotensin II antagonist candesartan.
- Exploratory network Bayesian meta-analyses demonstrated that approved drugs were similarly better than placebo. Among off-label drug classes, angiotensin inhibiting drugs demonstrated the largest significant odds of reducing monthly migraine by ≥50 percent.

#### Effect of Preventive Pharmacologic Treatments on Patient-centered and Intermediate Outcomes Compared With Active Nonpharmacologic Treatments

- Individual RCTs provided low-strength evidence that a ≥50 percent reduction in monthly migraine attacks did not differ with propranolol versus biofeedback.

#### Influence of Approaches to Drug Management Versus Usual Care (Such as Patient-Care Teams, Integrated Care, Coordinated Care, Patient Education, Drug Surveillance, or Interactive Drug Monitoring)

- Multidisciplinary team care improved quality of life and reduced migraine-related disability.
- Headache management program resulted in complete cessation of migraine (100 percent reduction in monthly migraine attacks).
- A cognitive-behavioral minimal contact program improved patient satisfaction with treatments.
- Headache school decreased overuse of acute drugs and reduced migraine disability.
- An intensive pharmaceutical care campaign had no statistically significant impact on use of drugs for acute attacks.

#### Comparative Harms From Pharmacologic Treatments for Preventing Migraine Attacks in Adults

- Among approved drugs, onabotulinumtoxin A, topiramate, and propranolol resulted in bothersome adverse effects leading to treatment discontinuation more often than placebo.
- The association was dose responsive for topiramate. Larger doses of topiramate caused higher risk of anorexia, depression, paresthesia, and difficulty in memory leading to treatment withdrawal. Larger doses of topiramate caused higher risk dry mouth, paresthesia or fatigue, mood problems, nausea, and weight loss.
- Individual RCTs showed that divalproex led to treatment discontinuation, nausea, somnolence, tremor, vomiting, and asthenia.
- Among other drugs, pooled analyses demonstrated that the off-label antidepressant amitriptyline caused bothersome adverse effects leading to treatment discontinuation more often than placebo.
- Limited low-strength evidence from individual head-to-head RCTs suggested that treatment discontinuation due to adverse effects was less frequent with onabotulinumtoxin A than topiramate or amitriptyline.
- Individual unique RCTs provided low-strength direct evidence about adverse effects with specific drugs with no consistent pattern across available drug comparisons.
- Indirect adjusted analyses demonstrated no differences in treatment discontinuation due to adverse effects with approved drugs or approved versus off-label drugs. Exploratory Bayesian network meta-analyses demonstrated that topiramate, off-label antiepileptics and antidepressants resulted in bothersome adverse effects leading to treatment discontinuation more often than placebo. According to network meta-analysis, off-label angiotensin inhibiting drugs and beta blockers were the safest treatment option for adults with episodic migraine.

#### Influence of Patient Characteristics on the Effectiveness and Safety of Pharmacologic Treatments for Preventing Migraine Attacks in Adults

- Evidence was limited to individual RCTs that examined the drug effect modification by selected patient characteristics.
- Onabotulinumtoxin A was more effective in patients with a higher mean baseline migraine frequency.
- Amitriptyline was better than placebo in reducing monthly migraine only in patients with frequent and severe baseline migraine and in depressed patients with baseline severe migraine.