# Evidence Tables

Appendix Table D1 Pharmacological groups and agents examined in randomized controlled trials for migraine prevention in adults

Appendix Table D2 Funding, ethical approval, and disclosure of conflict of interest in randomized controlled clinical trials of drugs for migraine prevention in adults

Appendix Table D3 Definition of migraine in randomized controlled clinical trials that examined drugs for migraine prevention in adults

Appendix Table D4 Total sample, weeks of followup, and percentage of loss of followup in randomized controlled clinical trials that examined drugs for migraine prevention in adults

Appendix Table D5 Reporting of baseline patient characteristics in randomized controlled clinical trials that examined drugs for migraine prevention in adults

Appendix Table D6 Differences in subject characteristics in randomized controlled clinical trials that examined efficacy of the drugs for migraine prevention in adults (differences are statistically significant when 95% CI do not include 0)

Appendix Table D7 Risk of bias in randomized controlled clinical trials of drugs for migraine prevention in adults

Appendix Table D8 Randomized controlled clinical trials that examined efficacy of botulinum toxin for migraine prevention in adults

Appendix Table D9 Funding and conflict of interest in randomized controlled clinical trials that examined efficacy of botulinum toxin for migraine prevention in adults

Appendix Table D10 Risk of bias in randomized controlled clinical trials that examined efficacy of botulinum toxin for migraine prevention in adults

Appendix Table D11 Strength of evidence of decrease in migraine frequency by ≥50% with onabotulinumtoxin A

Appendix Table D12 Decrease in migraine frequency by ≥50% with onabotulinumtoxin A, pooled results from randomized controlled clinical trials, random effects models with inverse variance weights

Appendix Table D13 Migraine headache frequency (change from baseline) with onabotulinumtoxin A, pooled results from randomized controlled clinical trials, random effects models

Appendix Table D14 Severity, disability, and quality of life with onabotulinumtoxin A vs. placebo for migraine prevention in adults (results from randomized controlled clinical trials)

Appendix Table D15 Randomized controlled clinical trials that examined efficacy of topiramate for migraine prevention in adults (sorted by year of publication)

Appendix Table D16 Funding, ethical approval, and conflict of interest in randomized controlled clinical trials that examined efficacy of topiramate for migraine prevention in adults (sorted by year of publication)

Appendix Table D17 Risk of bias in randomized controlled clinical trials that examined efficacy of topiramate for migraine prevention in adults (sorted by year of publication)

Appendix Table D18 Strength of evidence of migraine prevention with topiramate in adults

Appendix Table D19 Migraine prevention with topiramate vs. placebo in adults (pooled results from randomized controlled clinical trials)

Appendix Table D20 Reduction in migraine frequency and duration in randomized controlled clinical trials that examined efficacy of topiramate in adults

Appendix Table D21 Reduction in migraine severity and symptoms in randomized controlled clinical trials that examined efficacy of topiramate in adults

Appendix Table D22 Quality of life in randomized controlled clinical trials that examined efficacy of topiramate for migraine prevention in adults

Appendix Table D23 General health status in pooled analysis of individual patient data from randomized controlled clinical trials that examined efficacy of topiramate for migraine prevention in adults (Medical Outcome Study Short Form 36 (SF-36) scores for each domain range from 0 to 100 with a higher score representing better function, a change of five points on the SF-36 is generally considered clinically meaningful)37

Appendix Table D24 Drug utilization for acute migraine attacks in randomized controlled clinical trials that examined efficacy of topiramate for migraine prevention in adults

Appendix Table D25 Randomized controlled clinical trials that examined efficacy of divalproex or valproate for migraine prevention in adults

Appendix Table D26 Funding and conflict of interest in randomized controlled clinical trials that examined efficacy of divalproex or valproate for migraine prevention in adults

Appendix Table D27 Risk of bias in randomized controlled clinical trials that examined efficacy of divalproex or valproate for migraine prevention in adults

Appendix Table D28 Strength of evidence of migraine prevention in adults with divalproex vs. placebo, results from randomized controlled clinical trials

Appendix Table D29 Migraine prevention in adults with divalproex vs. placebo, results from randomized controlled clinical trials

Appendix Table D30 Migraine frequency, severity, and drug utilization with valproate vs. placebo for migraine prevention in adults, results from medium risk of bias randomized controlled clinical trials

Appendix Table D31 Randomized controlled clinical trials that examined efficacy of propranolol for migraine prevention in adults

Appendix Table D32 Funding and conflict of interest in randomized controlled clinical trials that examined efficacy of propranolol for migraine prevention in adults

Appendix Table D33 Risk of bias in randomized controlled clinical trials that examined efficacy of propranolol for migraine prevention in adults

Appendix Table D34 Strength of evidence of migraine prevention with propranolol (randomized controlled clinical trials)

Appendix Table D35 Migraine prevention with propranolol, results from randomized controlled clinical trials

Appendix Table D36 Reduction in frequency of migraine attack by ≥50% from baseline with timolol 10mg twice a day (pooled with random effects model results from randomized controlled clinical trials)

Appendix Table D37 Strength of evidence of migraine prevention with timolol

Appendix Table D38 Reduction in migraine attack frequency and severity with timolol 10mg twice a day (results from randomized controlled clinical trial60)

Appendix Table D39 Randomized controlled clinical trials that examined off label anti-epileptic drugs for migraine prevention in adults

Appendix Table D40 Funding and conflict of interest in randomized controlled clinical trials that examined off label anti-epileptic drugs for migraine prevention in adults

Appendix Table D41 Risk of bias in randomized controlled clinical trials that examined off label anti-epileptic drugs for migraine prevention in adults

Appendix Table D42 Randomized controlled clinical trials that examined efficacy of beta-blockers for migraine prevention in adults

Appendix Table D43 Funding and conflict of interest in randomized controlled clinical trials that examined efficacy of beta-blockers for migraine prevention in adults

Appendix Table D44 Risk of bias in randomized controlled clinical trials that examined efficacy of beta-blockers for migraine prevention in adults

Appendix Table D45 Strength of evidence of migraine prevention with beta-blockers in adults (sorted by drug name)

Appendix Table D46 Efficacy of beta-blockers in prevention of migraine in adults; results from randomized controlled clinical trials (sorted by drug name)

Appendix Table D47 Efficacy of beta-blockers for migraine prevention in adults on intermediate outcomes of migraine frequency, duration, and severity (results from randomized controlled clinical trials) (sorted by drug name)

Appendix Table D48 Efficacy of beta-blockers on migraine severity in adults; results from randomized controlled clinical trials (sorted by drug name)

Appendix Table D49 Randomized controlled clinical trials that examined off label antidepressants for migraine prevention in adults

Appendix Table D50 Funding and conflict of interest in randomized controlled clinical trials that examined off label antidepressants for migraine prevention in adults

Appendix Table D51 Risk of bias in randomized controlled clinical trials that examined off label antidepressants and tonabersat for migraine prevention in adults

Appendix Table D52 Randomized controlled clinical trials that examined calcium channel antagonists for migraine prevention in adults

Appendix Table D53 Funding and conflict of interest in randomized controlled clinical trials that examined calcium channel antagonists for migraine prevention in adults

Appendix Table D54 Risk of bias in randomized controlled clinical trials that examined calcium channel antagonists for migraine prevention in adults

Appendix Table D55 Randomized controlled clinical trials that examined ACE inhibitors of Angiotensin II receptor blockers for migraine prevention in adults

Appendix Table D56 Funding and conflict of interest in randomized controlled clinical trials that examined ACE inhibitors of Angiotensin II receptor blockers for migraine prevention in adults

Appendix Table D57 Risk of bias in randomized controlled clinical trials that examined ACE inhibitors of Angiotensin II receptor blockers for migraine prevention in adults

Appendix Table D58 Randomized controlled clinical trials that examined clonidine for migraine prevention in adults

Appendix Table D59 Sponsorship and conflict of interest in randomized controlled clinical trials that examined clonidine for migraine prevention in adults

Appendix Table D60 Risk of bias in randomized controlled clinical trials that examined clonidine for migraine prevention in adults

Appendix Table D61 Randomized controlled clinical trials that examined ergot alkaloids for migraine prevention in adults

Appendix Table D62 Funding and conflict of interest in randomized controlled clinical trials that examined ergot alkaloids for migraine prevention in adults

Appendix Table D63 Risk of bias in randomized controlled clinical trials that examined ergot alkaloids for migraine prevention in adults

Appendix Table D64 Randomized controlled clinical trials that examined comparative effectiveness of onabotulinumtoxin A for migraine prevention in adults

Appendix Table D65 Funding and conflict of interest in randomized controlled clinical trials that examined comparative effectiveness of botulinum toxin for migraine prevention in adults

Appendix Table D66 Risk of bias in randomized controlled clinical trials that examined comparative effectiveness of botulinum toxin for migraine prevention in adults

Appendix Table D67 Comparative effectiveness of onabotulinumtoxin A vs. topiramate in migraine prevention (results from individual randomized controlled clinical trials)

Appendix Table D68 Comparative effectiveness of onabotulinumtoxin A vs. divalproex sodium in migraine prevention (results from a single medium risk of bias randomized controlled clinical trial)165

Appendix Table D69 Comparative effectiveness of onabotulinumtoxin A vs. amitriptyline in migraine prevention (results from a single high risk of bias randomized controlled clinical trial)162

Appendix Table D70 Randomized controlled clinical trials of comparative effectiveness of topiramate for migraine prevention in adults (all trials did not report prior migraine preventive treatments)

Appendix Table D71 Funding and conflict of interest in randomized controlled clinical trials that examined comparative effectiveness of topiramate for migraine prevention in adults

Appendix Table D72 Risk of bias in randomized controlled clinical trials that examined comparative effectiveness of topiramate for migraine prevention in adults

Appendix Table D73 Comparative effectiveness of topiramate for migraine prevention in adults (individual randomized controlled clinical trials)

Appendix Table D74 Randomized controlled clinical trials that examined comparative effectiveness of propranolol of migraine prevention in adults

Appendix Table D75 Funding and conflict of interest in randomized controlled clinical trials that examined comparative effectiveness of propranolol for migraine prevention in adults

Appendix Table D76 Risk of bias in randomized controlled clinical trials that examined comparative effectiveness of propranolol for migraine prevention in adults

Appendix Table D77 Randomized controlled clinical trials that examined comparative effectiveness of beta-blockers for migraine prevention in adults

Appendix Table D78 Funding and conflict of interest in randomized controlled clinical trials that examined comparative effectiveness of beta-blockers for migraine prevention in adults

Appendix Table D79 Risk of bias in randomized controlled clinical trials that examined comparative effectiveness of beta-blockers for migraine prevention in adults

Appendix Table D80 Strength of evidence of comparative effectiveness of beta-blockers for migraine prevention in adults

Appendix Table D81 Comparative effectiveness of beta-blockers on migraine frequency, severity, and impact (results from randomized controlled clinical trials)

Appendix Table D82 Comparative effectiveness of beta-blockers for migraine prevention in adults (results from randomized controlled clinical trials)

Appendix Table D83 Exploratory Network Bayesian Meta-analysis of clinical response (defined as ≥50% reduction in migraine or self reported substantial reduction in monthly migraine frequency) with preventive approved drugs and off label drug classes in adults, results from randomized controlled clinical trials

Appendix Table D84 Clinical response defined as ≥50 percent reduction in monthly migraine frequency or self reported substantial reduction in monthly migraine frequency; indirect adjusted frequentist comparisons of migraine preventive drugs in adults from RCTs (analyzed for drugs that were more effective than placebo) (Strength of indirect evidence is low due to risk of bias and imprecision)

Appendix Table D85 Comparative effectiveness of antidepressant amitriptyline and spinal manipulation for migraine prevention in adults, individual medium risk of bias randomized controlled clinical trial204

Appendix Table D86 Comparative effectiveness of drugs with nonpharmacological treatments for migraine prevention in adults, randomized controlled clinical trials

Appendix Table D87 Funding and conflict of interest in randomized controlled clinical trials that examined comparative effectiveness of drugs and nonpharmacological migraine preventive treatments in adults

Appendix Table D88 Risk of bias in randomized controlled clinical trials that examined comparative effectiveness of drugs and nonpharmacological migraine preventive treatments in adults

Appendix Table D89 Migraine prevention with beta-blockers combined with behavior therapy vs. placebo in adults, results from individual low risk of bias randomized controlled clinical trial193

Appendix Table D90 Strength of evidence - efficacy and safety of beta-blockers combined with behavioral therapy (orientation + relaxation training; migraine warning signs and triggers; effectively using migraine medication and reducing impact of migraines; stress management or biofeedback training; migraine management plan) vs. placebo for migraine prevention in adults, results from individual low risk of bias randomized controlled clinical trial193

Appendix Table D91 Efficacy of beta-blockers combined with behavioral therapy (orientation + relaxation training; migraine warning signs and triggers; effectively using migraine medication and reducing impact of migraines; stress management or biofeedback training; migraine management plan) vs. placebo for migraine prevention in adults, results from individual medium risk of bias randomized controlled clinical trial207

Appendix Table D92 Comparative effectiveness of antidepressant amitriptyline, 100mg/day and spinal manipulation on intermediate outcomes in adults with migraine, individual medium risk of bias randomized controlled clinical trial204

Appendix Table D93 Dose response in acute treatment utilization with onabotulinumtoxin A for migraine prevention in adults (individual low risk of bias RCT)11

Appendix Table D94 Dose response in global assessment of treatment success with onabotulinumtoxin A for migraine prevention in adults (individual low risk of bias RCT)8

Appendix Table D95 Dose response reduction in migraine attacks by ≥ 50% from baseline with topiramate in adults

Appendix Table D96 Dose response migraine prevention with divalproex in adults, results from low risk of bias randomized controlled clinical trial47

Appendix Table D97 Migraine management programs examined in randomized controlled clinical trials

Appendix Table D98 Funding and conflict of interest in randomized controlled clinical trials that examined migraine management programs in adults

Appendix Table D99 Risk of bias in randomized controlled clinical trials that examined migraine management programs in adults

Appendix Table D100 Description of disease management programs for migraine prevention in adults

Appendix Table D101 Adherence to multidisciplinary intervention for migraine prevention in adults compared to standard care, results from medium risk of bias randomized controlled clinical trial210

Appendix Table D102 Effectiveness of multidisciplinary intervention for migraine prevention in adults compared to standard care (results from medium risk of bias randomized controlled clinical trial)210

Appendix Table D103 Reduction in disability with headache management program for migraine prevention in adults compared to standard care (results from medium risk of bias randomized controlled clinical trial)211

Appendix Table D104 Effectiveness of headache management program for migraine prevention in adults compared to standard care (results from medium risk of bias randomized controlled clinical trial)211

Appendix Table D105 Effectiveness of cognitive-behavioral minimal contact program for migraine prevention in adults compared to educational brochure (results from medium risk of bias randomized controlled clinical trial)216

Appendix Table D106 Reduction in acute drug overuse with headache school for migraine prevention in adults on acute drug utilization (results from medium risk of bias randomized controlled clinical trial)212

Appendix Table D107 Effectiveness of headache school for migraine prevention in adults (results from medium risk of bias randomized controlled clinical trial)212

Appendix Table D108 Migraine cessation with specialized pharmaceutical care for migraine compared to standard counseling in adults (results from low risk of bias randomized controlled clinical trial)215

Appendix Table D109 Effectiveness of specialized pharmaceutical care for migraine compared to standard counseling for migraine prevention in adults (results from low risk of bias randomized controlled clinical trial)215

Appendix Table D110 Effectiveness of intensive pharmaceutical care campaign for migraine prevention in adults (results from low risk of bias randomized controlled clinical trial)214

Appendix Table D111 Funding, ethical approval, and disclosure of conflict of interest in placebo controlled randomized controlled clinical trials of drugs for migraine prevention that included adverse effects

Appendix Table D112 Patient characteristics in placebo controlled randomized controlled clinical trials of adverse effects with drugs for migraine prevention in adults

Appendix Table D113 Followup characteristics in placebo controlled randomized controlled clinical trials of adverse effects with drugs for migraine prevention in adults

Appendix Table D114 Risk of bias in placebo controlled randomized controlled clinical trials of adverse effects with drugs for migraine prevention

Appendix Table D115 Adverse effects with drugs for migraine prevention in adults, results from nonrandomized studies

Appendix Table D116 Adverse effects with onabotulinumtoxin A vs. placebo for migraine prevention in adults (results from randomized controlled clinical trials were pooled with random effects model, inverse variance weights)

Appendix Table D117 Adverse effects with onabotulinumtoxin A vs. placebo for migraine prevention in adults (results from randomized controlled clinical trials were pooled with Bayesian odds ratios and maximum likelihood absolute risk difference)

Appendix Table D118 Dose response adverse effects with onabotulinumtoxin A for migraine prevention in adults (results from individual randomized controlled clinical trials)

Appendix Table D119 Randomized controlled clinical trials that examined adverse effects with topiramate vs. placebo

Appendix Table D120 Funding and conflict of interest in randomized controlled clinical trials that examined adverse effects with topiramate vs. placebo

Appendix Table D121 Risk of bias in randomized controlled clinical trials that examined adverse effects with topiramate vs. placebo

Appendix Table D122 Treatment discontinuation due to adverse effects with approved drugs vs. placebo (pooled with random effects models results from randomized controlled clinical trials)

Appendix Table D123 Treatment discontinuation due to specific adverse effects with topiramate vs. placebo, pooled with random effects model results from individual randomized controlled clinical trials

Appendix Table D124 Discontinuation due to adverse effects with topiramate in pooled analysis of individual patient data from three randomized controlled clinical trials of migraine prevention in adults40

Appendix Table D125 Treatment discontinuation due to adverse effects with approved and off label drugs vs. placebo, results from individual randomized controlled clinical trials

Appendix Table D126 Adverse effects with topiramate in adults with migraine (pooled with random effects models—results from randomized controlled clinical trials)

Appendix Table D127 Significant increase in risk of adverse effects with migraine preventive drugs vs. placebo, results from individual RCTs

Appendix Table D128 Dose response adverse effects with topiramate in adults

Appendix Table D129 Dose response in treatment discontinuation due to bothersome adverse effects with divalproex for migraine prevention in adults, results from low risk of bias randomized controlled clinical trial47

Appendix Table D130 Dose response in adverse effects with divalproex for migraine prevention in adults, results from low risk of bias randomized controlled clinical trial47

Appendix Table D131 Adverse effects with valproate vs. placebo for migraine prevention in adults, results from medium risk of bias randomized controlled clinical trials

Appendix Table D132 Adverse effects with propranolol vs. placebo, pooled results from randomized controlled clinical trials (random effects model)

Appendix Table D133 Adverse effects with timolol 10mg twice a day (results from randomized controlled clinical trials pooled with random effects model)

Appendix Table D134 Adverse effects with timolol 10mg twice a day (results from randomized controlled clinical trials)

Appendix Table D135 Treatment discontinuation due to adverse effects with off label migraine preventive drugs vs. placebo, pooled with random effects model results from randomized controlled clinical trials

Appendix Table D136 Adverse effects with antiepileptic drugs vs. placebo, pooled results from randomized controlled clinical trials (random effects model)

Appendix Table D137 Adverse effects with acetazolamide, 500 mg/day vs. placebo for migraine prevention in adults, results from low risk of bias randomized controlled clinical trial80

Appendix Table D138 Adverse effects with carbamazepine vs. placebo for migraine prevention in adults, results from medium risk of bias randomized controlled clinical trial86

Appendix Table D139 Adverse effects with gabapentin, titrated up to 2400 mg daily vs. placebo for migraine prevention in adults, results from medium risk of bias randomized controlled clinical trial81

Appendix Table D140 Treatment discontinuation due to bothersome adverse effects with lamotrigine, titrated up to 200 mg daily vs. placebo for migraine prevention in adults, results from low risk of bias randomized controlled clinical trial87

Appendix Table D141 Adverse effects with oxcarbazepine, titrated to a maximum tolerated dose of 1,200 mg/day vs. placebo for migraine prevention in adults, results from low risk of bias randomized controlled clinical trial83

Appendix Table D142 Adverse effects with off label antidepressants vs. placebo, pooled results from randomized controlled clinical trials (random effects model)

Appendix Table D143 Strength of evidence of treatment discontinuation due to adverse effects with beta-blockers for migraine prevention in adults (evidence from randomized controlled clinical trials)

Appendix Table D144 Treatment discontinuation due to adverse effects with beta-blockers for migraine prevention in adults, results from individual randomized controlled clinical trials

Appendix Table D145 Adverse effects with beta-blockers for migraine prevention in adults (results from randomized controlled clinical trials)

Appendix Table D146 Comparative safety of topiramate vs. onabotulinumtoxin A for migraine prevention in adults (results from individual randomized controlled clinical trials)

Appendix Table D147 Comparative safety of divalproex sodium vs. onabotulinumtoxin A for migraine prevention in adults (results from a single medium risk of bias randomized controlled clinical trial)164

Appendix Table D148 Comparative safety of amitriptyline vs. botulinum toxin type A for migraine prevention in adults (results from a single high risk of bias randomized controlled clinical trial)162

Appendix Table D149 Treatment discontinuation due to adverse effects with migraine preventive drugs compared to each other, results from individual randomized controlled clinical trials

Appendix Table D150 Discontinuation due to treatment failure with topiramate versus other drugs for migraine prevention in adults

Appendix Table D151 Adverse effects with preventive drugs compared to each other, pooled with random effects models results from randomized controlled clinical trials

Appendix Table D152 Comparative safety of topiramate for migraine prevention in adults (individual randomized controlled clinical trials)

Appendix Table D153 Adverse effects with migraine preventive drugs compared to each other, significant results from individual randomized controlled clinical trials

Appendix Table D154 Risk of any adverse effects with topiramate vs. amitriptyline for migraine prevention in adults

Appendix Table D155 Treatment discontinuation due to adverse effects with propranolol for migraine prevention in adults (results from randomized controlled clinical trials)

Appendix Table D156 Comparative effectiveness and safety of beta-blockers combined with behavioral therapy (orientation + relaxation training; migraine warning signs and triggers; effectively using migraine medication and reducing impact of migraines; stress management or biofeedback training; migraine management plan) vs. beta-blockers alone for migraine prevention in adults, results from individual low risk of bias randomized controlled clinical trial193

Appendix Table D157 Headache specific locus of control at month 16 with beta-blockers combined with behavioral therapy (orientation + relaxation training; migraine warning signs and triggers; effectively using migraine medication and reducing impact of migraines; stress management or biofeedback training; migraine management plan) vs. beta-blockers alone for migraine prevention in adults, results from individual medium risk of bias randomized controlled clinical trial207

Appendix Table D158 Strength of evidence of comparative safety of beta-blockers for migraine prevention in adults (treatment discontinuation due to bothersome adverse effects in randomized controlled clinical trials)

Appendix Table D159 Comparative safety of beta-blockers for migraine prevention in adults, adverse effects in randomized controlled clinical trials

Appendix Table D160 Strength of evidence about treatment adherence and discontinuation due to adverse effects with antidepressant amitriptyline and spinal manipulation for migraine prevention in adults, individual medium risk of bias randomized controlled clinical trial204

Appendix Table D161 Treatment adherence and discontinuation due to adverse effects with antidepressant amitriptyline and spinal manipulation for migraine prevention in adults, individual medium risk of bias randomized controlled clinical trial204

Appendix Table D162 Indirect adjusted analysis of the comparative effects on the treatment discontinuation due to bothersome adverse effects with preventive drugs in adults, results from randomized controlled clinical trials (results with approved drugs and statistically significant results when off label drugs were compared with each other) (strength of evidence is low due to risk of bias and imprecision)

Table D163 Exploratory network Bayesian meta-analysis of treatment discontinuation due to bothersome adverse effects with preventive drugs in adults, results from randomized controlled clinical trials

Appendix Table D164 Decrease in frequency of migraine >50% with amitriptyline vs. placebo in adults with different baseline migraine frequency, results from medium risk of bias RCT111

Appendix Table D165 Improvement of M score >50%^*^ with amitriptyline vs. placebo in adults with different baseline M score and depressive symptoms, results from medium risk of bias RCT103

Appendix Table D166 Prediction of ≥50% in migraine days reduction per month with different doses of amitriptyline (50 vs. 25mg/day) for migraine prevention in adults, results from medium risk of bias RCT110

## References for Appendix D

1 Aurora SK, Dodick DW, Turkel CC, et al. OnabotulinumtoxinA for treatment of chronic migraine: results from the double-blind, randomized, placebo-controlled phase of the PREEMPT 1 trial. Cephalalgia. Jul. 2010;30(7):793-803. [pmid: 20647170].
2 Diener HC, Dodick DW, Aurora SK, et al. OnabotulinumtoxinA for treatment of chronic migraine: results from the double-blind, randomized, placebo-controlled phase of the PREEMPT 2 trial. Cephalalgia. Jul. 2010;30(7):804-14. [pmid: 20647171].
3 Lipton RB, Varon SF, Grosberg B, et al. OnabotulinumtoxinA improves quality of life and reduces impact of chronic migraine. Neurology. Oct. 11. 2011;77(15):1465-72. [pmid: 21956721].
4 Saper JR, Mathew NT, Loder EW, et al. A double-blind, randomized, placebo-controlled comparison of botulinum toxin type a injection sites and doses in the prevention of episodic migraine. Pain Med. Sep. 2007;8(6):478-85. [pmid: 17716321].
5 Freitag FG, Diamond S, Diamond M, et al. Botulinum Toxin Type A in the treatment of chronic migraine without medication overuse. Headache. Feb. 2008;48(2):201-9. [pmid: 18042229].
6 Silberstein S, Mathew N, Saper J, et al. Botulinum toxin type A as a migraine preventive treatment. For the BOTOX Migraine Clinical Research Group. Headache. Jun. 2000;40(6):445-50. [pmid: 10849039].
7 Elkind AH, O’Carroll P, Blumenfeld A, et al. A series of three sequential, randomized, controlled studies of repeated treatments with botulinum toxin type A for migraine prophylaxis. J Pain. Oct. 2006;7(10):688-96. [pmid: 17018329].
8 Chankrachang S, Arayawichanont A, Poungvarin N, et al. Prophylactic botulinum type A toxin complex (Dysport(R)) for migraine without aura. Headache. Jan. 2011;51(1):52-63. [pmid: 21083558].
9 Petri S, Tolle T, Straube A, et al. Botulinum toxin as preventive treatment for migraine: a randomized double-blind study. Eur Neurol. 2009;62(4):204-11. [pmid: 19622887].
10 Mathew NT, Frishberg BM, Gawel M, et al. Botulinum toxin type A (BOTOX) for the prophylactic treatment of chronic daily headache: a randomized, double-blind, placebo-controlled trial. Headache. Apr. 2005;45(4):293-307. [pmid: 15836565].
11 Silberstein SD, Stark SR, Lucas SM, et al. Botulinum toxin type A for the prophylactic treatment of chronic daily headache: a randomized, double-blind, placebo-controlled trial. Mayo Clin Proc. Sep. 2005;80(9):1126-37. [pmid: 16178492].
12 Anand KS, Prasad A, Singh MM, et al. Botulinum toxin type A in prophylactic treatment of migraine. Am J Ther. May–Jun. 2006;13(3):183-7. [pmid: 16772757].
13 Cady R, Schreiber C. Botulinum toxin type A as migraine preventive treatment in patients previously failing oral prophylactic treatment due to compliance issues. Headache. Jun. 2008;48(6):900-13. [pmid: 18047501].
14 Vo AH, Satori R, Jabbari B, et al. Botulinum toxin type-a in the prevention of migraine: a double-blind controlled trial. Aviat Space Environ Med. May. 2007;78(5 Suppl):B113-8. [pmid: 17547312].
15 Aurora SK, Gawel M, Brandes JL, et al. Botulinum toxin type a prophylactic treatment of episodic migraine: a randomized, double-blind, placebo-controlled exploratory study. Headache. Apr. 2007;47(4):486-99. [pmid: 17445098].
16 Barrientos N, Chana P. Botulinum toxin type A in prophylactic treatment of migraine headaches: a preliminary study. J. Headache Pain. 2003;4(3):146-51.
17 Relja M, Poole AC, Schoenen J, et al. A multicentre, double-blind, randomized, placebo-controlled, parallel group study of multiple treatments of botulinum toxin type A (BoNTA) for the prophylaxis of episodic migraine headaches. Cephalalgia. Jun. 2007;27(6):492-503. [pmid: 17428299].
18 Storey JR, Calder CS, Hart DE, et al. Topiramate in migraine prevention: a double-blind, placebo-controlled study. Headache. Nov–Dec. 2001;41(10):968-75. [pmid: 11903524].
19 Edwards KR, Potter DL, Wu SC, et al. Topiramate in the preventive treatment of episodic migraine: a combined analysis from pilot, double-blind, placebo-controlled trials. CNS Spectr. Jun. 2003;8(6):428-32. [pmid: 12858132].
20 Silvestrini M, Bartolini M, Coccia M, et al. Topiramate in the treatment of chronic migraine. Cephalalgia. Oct. 2003;23(8):820-4. [pmid: 14510929].
21 Silberstein S. Efficacy and safety of topiramate in migraine prevention: a dose-ranging, placebo-controlled, double-blind, multicenter study. Advanced Studies in Medicine. 2003;3(6C):S565-8.
22 Brandes JL, Saper JR, Diamond M, et al. Topiramate for migraine prevention: a randomized controlled trial. JAMA. Feb. 25. 2004;291(8):965-73. [pmid: 14982912].
23 Silberstein SD, Neto W, Schmitt J, et al. Topiramate in migraine prevention: results of a large controlled trial. Arch Neurol. Apr. 2004;61(4):490-5. [pmid: 15096395].
24 Mei D, Capuano A, Vollono C, et al. Topiramate in migraine prophylaxis: a randomised double-blind versus placebo study. Neurol Sci. Dec. 2004;25(5):245-50. [pmid: 15624081].
25 Bussone G, Diener HC, Pfeil J, et al. Topiramate 100 mg/day in migraine prevention: a pooled analysis of double-blind randomised controlled trials. Int J Clin Pract. Aug. 2005;59(8):961-8. [pmid: 16033621].
26 Diamond M, Dahlof C, Papadopoulos G, et al. Topiramate improves health-related quality of life when used to prevent migraine. Headache. Sep. 2005;45(8):1023-30. [pmid: 16109116].
27 Silberstein SD, Loder E, Forde G, et al. The impact of migraine on daily activities: effect of topiramate compared with placebo. Curr Med Res Opin. Jun. 2006;22(6):1021-9. [pmid: 16846536].
28 Mei D, Ferraro D, Zelano G, et al. Topiramate and triptans revert chronic migraine with medication overuse to episodic migraine. Clin Neuropharmacol. Sep–Oct. 2006;29(5):269-75. [pmid: 16960472].
29 Silberstein SD, Hulihan J, Karim MR, et al. Efficacy and tolerability of topiramate 200 mg/d in the prevention of migraine with/without aura in adults: a randomized, placebo-controlled, double-blind, 12-week pilot study. Clin Ther. Jul. 2006;28(7):1002-11. [pmid: 16990078].
30 Brandes JL, Kudrow DB, Rothrock JF, et al. Assessing the ability of topiramate to improve the daily activities of patients with migraine. Mayo Clin Proc. Oct. 2006;81(10):1311-9. [pmid: 17036556].
31 Silberstein SD, Lipton RB, Dodick DW, et al. Efficacy and safety of topiramate for the treatment of chronic migraine: a randomized, double-blind, placebo-controlled trial. Headache. Feb. 2007;47(2):170-80. [pmid: 17300356].
32 Lofland JH, Gagne JJ, Pizzi LT, et al. Impact of topiramate migraine prophylaxis on workplace productivity: results from two US randomized, double-blind, placebo-controlled, multicenter trials. J Occup Environ Med. Mar. 2007;49(3):252-7. [pmid: 17351510].
33 Limmroth V, Biondi D, Pfeil J, et al. Topiramate in patients with episodic migraine: reducing the risk for chronic forms of headache. Headache. Jan. 2007;47(1):13-21. [pmid: 17355489].
34 Diener HC, Bussone G, Van Oene JC, et al. Topiramate reduces headache days in chronic migraine: a randomized, double-blind, placebo-controlled study. Cephalalgia. Jul. 2007;27(7):814-23. [pmid: 17441971].
35 Lainez MJ, Freitag FG, Pfeil J, et al. Time course of adverse events most commonly associated with topiramate for migraine prevention. Eur J Neurol. Aug. 2007;14(8):900-6. [pmid: 17662012].
36 Freitag FG, Forde G, Neto W, et al. Analysis of pooled data from two pivotal controlled trials on the efficacy of topiramate in the prevention of migraine. J Am Osteopath Assoc. Jul. 2007;107(7):251-8. [pmid: 17682112].
37 Dahlof C, Loder E, Diamond M, et al. The impact of migraine prevention on daily activities: a longitudinal and responder analysis from three topiramate placebo-controlled clinical trials. Health Qual Life Outcomes. 2007;5:56. [pmid: 17916258].
38 Diener HC, Agosti R, Allais G, et al. Cessation versus continuation of 6-month migraine preventive therapy with topiramate (PROMPT): a randomised, double-blind, placebo-controlled trial. Lancet Neurol. Dec. 2007;6(12):1054-62. [pmid: 17988947].
39 Dodick DW, Silberstein S, Saper J, et al. The impact of topiramate on health-related quality of life indicators in chronic migraine. Headache. Nov–Dec. 2007;47(10):1398-408. [pmid: 18052949].
40 Adelman J, Freitag FG, Lainez M, et al. Analysis of safety and tolerability data obtained from over 1,500 patients receiving topiramate for migraine prevention in controlled trials. Pain Med. Mar. 2008;9(2):175-85. [pmid: 18298700].
41 Silberstein S, Lipton R, Dodick D, et al. Topiramate treatment of chronic migraine: a randomized, placebo-controlled trial of quality of life and other efficacy measures. Headache. Sep. 2009;49(8):1153-62. [pmid: 19719543].
42 Lipton RB, Silberstein S, Dodick D, et al. Topiramate intervention to prevent transformation of episodic migraine: the topiramate INTREPID study. Cephalalgia. Jan. 2011;31(1):18-30. [pmid: 20974598].
43 Diener HC, Tfelt-Hansen P, Dahlof C, et al. Topiramate in migraine prophylaxis--results from a placebo-controlled trial with propranolol as an active control. J Neurol. Aug. 2004;251(8):943-50. [pmid: 15316798].
44 Gupta P, Singh S, Goyal V, et al. Low-dose topiramate versus lamotrigine in migraine prophylaxis (the Lotolamp study). Headache. Mar. 2007;47(3):402-12. [pmid: 17371357].
45 Mathew NT, Saper JR, Silberstein SD, et al. Migraine prophylaxis with divalproex. Arch Neurol. Mar. 1995;52(3):281-6. [pmid: 7872882].
46 Freitag FG, Collins SD, Carlson HA, et al. A randomized trial of divalproex sodium extended-release tablets in migraine prophylaxis. Neurology. Jun. 11. 2002;58(11):1652-9. [pmid: 12058094].
47 Klapper J. Divalproex sodium in migraine prophylaxis: a dose-controlled study. Cephalalgia. Apr. 1997;17(2):103-8. [pmid: 9137847].
48 Hering R, Kuritzky A. Sodium valproate in the prophylactic treatment of migraine: a double-blind study versus placebo. Cephalalgia. Apr. 1992;12(2):81-4. [pmid: 1576648].
49 Jensen R, Brinck T, Olesen J. Sodium valproate has a prophylactic effect in migraine without aura: a triple-blind, placebo-controlled crossover study. Neurology. Apr. 1994;44(4):647-51. [pmid: 8164818].
50 Diamond S, Medina JL. Double blind study of propranolol for migraine prophylaxis. Headache. 1976:24-7. [pmid: 767299].
51 Stensrud P, Sjaastad O. Short-term clinical trial of phopranolol in racemic form (Inderal), D-propranolol and placebo in migraine. Acta neurologica Scandinavica. 1976:229-32. [pmid: 773081].
52 Forssman B, Henriksson KG, Johannsson V, et al. Propranolol for migraine prophylaxis. Headache. 1976:238-45. [pmid: 977330].
53 Pradalier A, Serratrice G, Collard M, et al. Long-acting propranolol in migraine prophylaxis: results of a double-blind, placebo-controlled study. Cephalalgia. Dec. 1989;9(4):247-53. [pmid: 2692838].
54 Nadelmann JW, Stevens J, Saper JR. Propranolol in the prophylaxis of migraine. Headache. 1986:175-82. [pmid: 3519529].
55 Sargent J, Solbach P, Damasio H, et al. A comparison of naproxen sodium to propranolol hydrochloride and a placebo control for the prophylaxis of migraine headache. Headache. 1985:320-4. [pmid: 3902723].
56 Ahuja GK, Verma AK. Propranolol in prophylaxis of migraine. Indian J Med Res. Sep. 1985;82:263-5. [pmid: 3908306].
57 Malvea BP, Gwon N, Graham JR. Propranolol prophylaxis of migraine. Headache. 1973:163-7. [pmid: 4566216].
58 Wideroe TE, Vigander T. Propranolol in the treatment of migraine. Br Med J. Jun. 29. 1974;2(5921):699-701. [pmid: 4604977].
59 Palferman TG, Gibberd FB, Simmonds JP. Prophylactic propranolol in the treatment of headache. Br J Clin Pract. Jan. 1983;37(1):28-9. [pmid: 6340710].
60 Tfelt-Hansen P, Standnes B, Kangasneimi P, et al. Timolol vs propranolol vs placebo in common migraine prophylaxis: a double-blind multicenter trial. Acta Neurol Scand. Jan. 1984;69(1):1-8. [pmid: 6367336].
61 Standnes B. The prophylactic effect of timolol versus propranolol and placebo in common migraine: Beta-blockers in migraine. Cephalalgia. 1982:165-70. [pmid: 6758949].
62 Stensrud P, Sjaastad O. Comparative trial of Tenormin (atenolol) and Inderal (propranolol) in migraine. Ups J Med Sci Suppl. 1980;31:37-40. [pmid: 7006182].
63 al-Qassab HK, Findley LJ. Comparison of propranolol LA 80 mg and propranolol LA 160 mg in migraine prophylaxis: a placebo controlled study. Cephalalgia. Apr. 1993;13(2):128-31. [pmid: 8495455].
64 Rafieian-Kopaei M, Mehvari J, Shirzadeh H. Different profile of propranolol and amitriptyline effects on migraine prophylaxis. International Journal of Pharmacology. 2005;1:366-8.
65 Weber RB, Reinmuth OM. The treatment of migraine with propranolol. Neurology. 1972:366-9. [pmid: 4552716].
66 Pradalier A, Serratrice G, Collard M, et al. Double-blind placebo controlled study of the use of long-acting propranolol in migraine prophylaxis. Cephalalgia. 1989:367-8.
67 Kuritzky A, Hering R. Prophylactic treatment of migraine with long acting propranolol - a comparison with placebo. Cephalalgia. 1987:457-8.
68 Kaniecki RG. A comparison of divalproex with propranolol and placebo for the prophylaxis of migraine without aura. Arch Neurol. Sep. 1997;54(9):1141-5. [pmid: 9311358].
69 Kass B, Nestvold K. Propranolol (Inderal) and clonidine (Catapressan) in the prophylactic treatment of migraine. A comparative trial. Acta Neurol Scand. Jun. 1980;61(6):351-6. [pmid: 6998250].
70 Kangasniemi P, Hedman C. Metoprolol and propranolol in the prophylactic treatment of classical and common migraine. A double-blind study. Cephalalgia. Jun. 1984;4(2):91-6. [pmid: 6428749].
71 Gerber WD, Diener HC, Scholz E, et al. Responders and non-responders to metoprolol, propranolol and nifedipine treatment in migraine prophylaxis: a dose-range study based on time-series analysis. Cephalalgia. Feb. 1991;11(1):37-45. [pmid: 2036669].
72 Sudilovsky A, Elkind AH, Ryan RES, et al. Comparative efficacy of nadolol and propranolol in the management of migraine. Headache. 1987:421-6. [pmid: 3312113].
73 Olerud B, Gustavsson CL, Furberg B. Nadolol and propranolol in migraine management. Headache. 1986:490-3. [pmid: 3546194].
74 Albers GW, Simon LT, Hamik A, et al. Nifedipine versus propranolol for the initial prophylaxis of migraine. Headache. Apr. 1989;29(4):215-8. [pmid: 2654067].
75 Domingues RB, Silva AL, Domingues SA, et al. A double-blind randomized controlled trial of low doses of propranolol, nortriptyline, and the combination of propranolol and nortriptyline for the preventive treatment of migraine. Arq Neuropsiquiatr. Dec. 2009;67(4):973-7. [pmid: 20069203].
76 Ziegler DK, Hurwitz A, Hassanein RS, et al. Migraine prophylaxis. A comparison of propranolol and amitriptyline. Arch Neurol. May. 1987;44(5):486-9. [pmid: 3579659].
77 Kangasniemi PJ, Nyrke T, Lang AH, et al. Femoxetine - a new 5-HT uptake inhibitor - and propranolol in the prophylactic treatment of migraine. Acta Neurol Scand. 1983:262-7. [pmid: 6606930].
78 Silberstein SD, Dodick DW, Lindblad AS, et al. Randomized, placebo-controlled trial of propranolol added to topiramate in chronic migraine. Neurology. Mar. 27. 2012;78(13):976-84. [pmid: 22377815].
79 Stellar S, Ahrens SP, Meibohm AR, et al. Migraine prevention with timolol. A double-blind crossover study. JAMA. Nov. 9. 1984;252(18):2576-80. [pmid: 6387197].
80 Vahedi K, Taupin P, Djomby R, et al. Efficacy and tolerability of acetazolamide in migraine prophylaxis: a randomised placebo-controlled trial. J Neurol. Feb. 2002;249(2):206-11. [pmid: 11985388].
81 Mathew NT, Rapoport A, Saper J, et al. Efficacy of gabapentin in migraine prophylaxis. Headache. Feb. 2001;41(2):119-28. [pmid: 11251695].
82 Ghose K, Niven B, Berry D. A double-blind crossover comparison of the effects of vigabatrin with placebo in the prevention of migraine headache. J Headache Pain. 2002;3:79-85.
83 Silberstein S, Saper J, Berenson F, et al. Oxcarbazepine in migraine headache: a double-blind, randomized, placebo-controlled study. Neurology. Feb. 12. 2008;70(7):548-55. [pmid: 18268247].
84 Wessely P, Baumgartner C, Klingler D, et al. Preliminary results of a double-blind study with the new migraine prophylactic drug Gabapentin. Cephalalgia. 1987:477-8.
85 Di Trapani G, Mei D, Marra C, et al. Gabapentin in the prophylaxis of migraine: a double-blind randomized placebo-controlled study. Clin Ter. May–Jun. 2000;151(3):145-8. [pmid: 10958046].
86 Rompel H, Bauermeister PW. Aetiology of migraine and prevention with carbamazepine (Tegretol): results of a double-blind, cross-over study. S Afr Med J. Jan. 24. 1970;44(4):75-80. [pmid: 4905910].
87 Steiner TJ, Findley LJ, Yuen AW. Lamotrigine versus placebo in the prophylaxis of migraine with and without aura. Cephalalgia. Apr. 1997;17(2):109-12. [pmid: 9137848].
88 Ekbom K, Lundberg PO. Clinical trial of LB-46 (d, 1-4-(2-hydroxy-3-isopropylaminopropoxy)indol. An adrenergic beta-receptor blocking agent in migraine prophylaxis. Headache. 1972:15-7. [pmid: 4402287].
89 Sjaastad O, Stensrud P. Clinical trial of a beta-receptor blocking agent (LB 46) in migraine prophylaxis. Acta neurologica Scandinavica. 1972:124-8. [pmid: 4401692].
90 Ekbom K. Alprenolol for migraine prophylaxis. Headache. 1975:129-32. [pmid: 1097368].
91 Nanda RN, Johnson RH, Gray J, et al. A double blind trial of acebutolol for migraine prophylaxis. Headache. 1978:20-2. [pmid: 348644].
92 Briggs RS, Millac PA. Timolol in migraine prophylaxis. Headache. Nov. 1979;19(7):379-81. [pmid: 511540].
93 Ryan R, Ryan R, Sudilovsky A. Nadolol and placebo comparison study in the prophylactic treatment of migraine. Panminerva Med. 1982:89-94. [pmid: 6128710].
94 Ryan R, Ryan R, Sudilovsky A. Nadolol: Its use in the prophylactic treatment of migraine. Headache. 1983:26-31. [pmid: 6131052].
95 Forssman B. Atenolol for Migraine Prophylaxis. Acta Neurologica Scandinavica. 1982;65(S90):75-6.
96 Forssman B, Lindblad CJ, Zbornikova V. Atenolol for migraine prophylaxis. Headache. 1983:188-90. [pmid: 6350226].
97 Andersson PG, Dahl S, Hansen JH, et al. Prophylactic treatment of classical and non-classical migraine with metoprolol--a comparison with placebo. Cephalalgia. Dec. 1983;3(4):207-12. [pmid: 6640652].
98 Freitag FG, Diamond S. Nadolol and placebo comparison study in the prophylactic treatment of migraine. The Journal of the American Osteopathic Association. 1984:343-7. [pmid: 6150909].
99 Johannsson V, Nilsson LR, Widelius T, et al. Atenolol in migraine prophylaxis: a double-blind cross-over multicenter study. Headache. 1987:372-4. [pmid: 3308768].
100 Kangasniemi P, Andersen AR, Andersson PG, et al. Classic migraine: effective prophylaxis with metoprolol. Cephalalgia. Dec. 1987;7(4):231-8. [pmid: 3322569].
101 van de Ven LL, Franke CL, Koehler PJ. Prophylactic treatment of migraine with bisoprolol: a placebo-controlled study. Cephalalgia. Aug. 1997;17(5):596-9. [pmid: 9251876].
102 Siniatchkin M, Andrasik F, Kropp P, et al. Central mechanisms of controlled-release metoprolol in migraine: a double-blind, placebo-controlled study. Cephalalgia. Sep. 2007;27(9):1024-32. [pmid: 17680819].
103 Couch JR, Hassanein RS. Amitriptyline in migraine prophylaxis. Arch Neurol. Nov. 1979;36(11):695-9. [pmid: 508127].
104 Gomersall JD, Stuart A. Amitriptyline in migraine prophylaxis. Changes in pattern of attacks during a controlled clinical trial. J Neurol Neurosurg Psychiatry. Aug. 1973;36(4):684-90. [pmid: 4731336].
105 Mathew NT. Prophylaxis of migraine and mixed headache. A randomized controlled study. Headache. May. 1981;21(3):105-9. [pmid: 7021472].
106 Bank J. A comparative study of amitriptyline and fluvoxamine in migraine prophylaxis. Headache. Sep. 1994;34(8):476-8. [pmid: 7960733].
107 Oguzhanoglu A, Sahiner T, Kurt T, et al. Use of amitriptyline and fluoxetine in prophylaxis of migraine and tension-type headaches. Cephalalgia. Jun. 1999;19(5):531-2. [pmid: 10403070].
108 Krymchantowski AV, Silva MT, Barbosa JS, et al. Amitriptyline versus amitriptyline combined with fluoxetine in the preventative treatment of transformed migraine: a double-blind study. Headache. Jun. 2002;42(6):510-4. [pmid: 12167139].
109 Bulut S, Berilgen MS, Baran A, et al. Venlafaxine versus amitriptyline in the prophylactic treatment of migraine: randomized, double-blind, crossover study. Clin Neurol Neurosurg. Dec. 2004;107(1):44-8. [pmid: 15567552].
110 Lampl C, Huber G, Adl J, et al. Two different doses of amitriptyline ER in the prophylaxis of migraine: long-term results and predictive factors. Eur J Neurol. Aug. 2009;16(8):943-8. [pmid: 19456855].
111 Couch JR. Amitriptyline in the prophylactic treatment of migraine and chronic daily headache. Headache. Jan. 2011;51(1):33-51. [pmid: 21070231].
112 Couch JR, Hassanein RS. Migraine and depression: effect of amitriptyline prophylaxis. Trans Am Neurol Assoc. 1976:234-7. [pmid: 800690].
113 Orholm M, Honore PF, Zeeberg I. A randomized general practice group-comparative study of femoxetine and placebo in the prophylaxis of migraine. Acta Neurol Scand. Sep. 1986;74(3):235-9. [pmid: 3538753].
114 Zeeberg I, Orholm M, Nielsen JD, et al. Femoxetine in the prophylaxis of migraine: A randomized comparison with placebo. Acta-Neurol-Scand. 1981:452-9. [pmid: 6753446].
115 Orholm M, Le Fevre P. Prophylactic treatment of migraine with femoxetine - a randomized comparison with placebo. Cephalalgia. 1985:516-7.
116 Adly C, Straumanis J, Chesson A. Fluoxetine prophylaxis of migraine. Headache. Feb. 1992;32(2):101-4. [pmid: 1551787].
117 Saper JR, Silberstein SD, Lake AE 3rd, et al. Double-blind trial of fluoxetine: chronic daily headache and migraine. Headache. Oct. 1994;34(9):497-502. [pmid: 8002320].
118 Steiner TJ, Ahmed F, Findley LJ, et al. S-fluoxetine in the prophylaxis of migraine: a phase II double-blind randomized placebo-controlled study. Cephalalgia. Jun. 1998;18(5):283-6. [pmid: 9673809].
119 d’Amato CC, Pizza V, Marmolo T, et al. Fluoxetine for migraine prophylaxis: a double-blind trial. Headache. Nov–Dec. 1999;39(10):716-9. [pmid: 11279947].
120 Monro P, Swade C, Coppen A. Mianserin in the prophylaxis of migraine: a double-blind study. Acta psychiatrica Scandinavica. Supplementum. 1985:98-103. [pmid: 3901676].
121 Goadsby PJ, Ferrari MD, Csanyi A, et al. Randomized, double-blind, placebo-controlled, proof-of-concept study of the cortical spreading depression inhibiting agent tonabersat in migraine prophylaxis. Cephalalgia. Jul. 2009;29(7):742-50. [pmid: 19222510].
122 Ozyalcin SN, Talu GK, Kiziltan E, et al. The efficacy and safety of venlafaxine in the prophylaxis of migraine. Headache. Feb. 2005;45(2):144-52. [pmid: 15705120].
123 Tarlaci S. Escitalopram and venlafaxine for the prophylaxis of migraine headache without mood disorders. Clin Neuropharmacol. Sep–Oct. 2009;32(5):254-8. [pmid: 19667978].
124 Markley HG, Cheronis JC, Piepho RW. Verapamil in prophylactic therapy of migraine. Neurology. 1984:973-6. [pmid: 6539877].
125 Stewart DJ, Gelston A, Hakim A. Effect of prophylactic administration of nimodipine in patients with migraine. Headache. May. 1988;28(4):260-2. [pmid: 3170182].
126 Leandri M, Rigardo S, Schizzi R, et al. Migraine treatment with nicardipine. Cephalalgia. Jun. 1990;10(3):111-6. [pmid: 2245455].
127 Gelmers HJ. Nimodipine, a new calcium antagonist, in the prophylactic treatment of migraine. Headache. 1983:106-9. [pmid: 6347970].
128 (MINES) M-NESG. European multicenter trial of nimodipine in the prophylaxis of common migraine (migraine without aura). Headache. Nov. 1989;29(10):633-8. [pmid: 2693405].
129 McArthur JC, Marek K, Pestronk A, et al. Nifedipine in the prophylaxis of classic migraine: a crossover, double-masked, placebo-controlled study of headache frequency and side effects. Neurology. 1989:284-6. [pmid: 2644581].
130 Solomon GD, Steel JG, Spaccavento LJ. Verapamil prophylaxis of migraine. A double-blind, placebo-controlled study. JAMA. Nov. 11. 1983;250(18):2500-2. [pmid: 6355533].
131 Meyer JS, Hardenberg J. Clinical effectiveness of calcium entry blockers in prophylactic treatment of migraine and cluster headaches. Headache. 1983:266-77. [pmid: 6358126].
132 Havanka-Kanniainen H, Hokkanen E, Myllylä VV. Efficacy of nimodipine in the prophylaxis of migraine. Cephalalgia an international journal of headache. 1985:39-43. [pmid: 3886153].
133 (MINES) M-NESG. European multicenter trial of nimodipine in the prophylaxis of classic migraine (migraine with aura). Headache. Nov. 1989;29(10):639-42. [pmid: 2693406].
134 Ansell E, Fazzone T, Festenstein R, et al. Nimodipine in migraine prophylaxis. Cephalalgia an international journal of headache. 1988:269-72. [pmid: 3064919].
135 Shukla R, Garg RK, Nag D, et al. Nifedipine in migraine and tension headache: a randomised double blind crossover study. J Assoc Physicians India. Nov. 1995;43(11):770-2. [pmid: 8773038].
136 Schrader H, Stovner LJ, Helde G, et al. Prophylactic treatment of migraine with angiotensin converting enzyme inhibitor (lisinopril): randomised, placebo controlled, crossover study. BMJ. Jan. 6. 2001;322(7277):19-22. [pmid: 11141144].
137 Minervini MG, Pinto K. Captopril relieves pain and improves mood depression in depressed patients with classical migraine. Cephalalgia. 1987:485-6.
138 Tronvik E, Stovner LJ, Helde G, et al. Prophylactic treatment of migraine with an angiotensin II receptor blocker: a randomized controlled trial. JAMA. Jan. 1. 2003;289(1):65-9. [pmid: 12503978].
139 Diener HC, Gendolla A, Feuersenger A, et al. Telmisartan in migraine prophylaxis: a randomized, placebo-controlled trial. Cephalalgia. Sep. 2009;29(9):921-7. [pmid: 19250283].
140 Ryan RE Sr, Ryan RE Jr. The effects of clonidine in the prophylactic treatment of migraine. Headache. 1975:199-212. [pmid: 1123303].
141 Ryan RE, Diamond S. Double blind study of clonidine and placebo for the prophylactic treatment of migraine. Headache. 1975:202-10. [pmid: 1100565].
142 Shafar J, Tallett ER, Knowlson PA. Evaluation of clonidine in prophylaxis of migraine. Double-blind trial and follow-up. Lancet. Feb. 19. 1972;1(7747):403-7. [pmid: 4110641].
143 Stensrud P, Sjaastad O. Clonidine (Catapresan)-double-blind study after long-term treatment with the drug in migraine. Acta neurologica Scandinavica. 1976:233-6. [pmid: 773082].
144 Martucci N, Manna V, Porto C, et al. Migraine and the noradrenergic control of vasomotricity: a study with alpha-2 stimulant and alpha-2 blocker drugs. Headache. Mar. 1985;25(2):95-100. [pmid: 3886600].
145 Denaro A, Martucci N, Ruggieri S, et al. Headache and noradrenergic involvement: the effects of alpha 2-stimulants and alpha 2-antagonists. Acta Psychiatr Scand Suppl. 1985;320:20-5. [pmid: 3901672].
146 Boisen E, Deth S, Hübbe P, et al. Clonidine in the prophylaxis of migraine. Acta neurologica Scandinavica. 1978:288-95. [pmid: 367043].
147 Wilkinson M. Preliminary report on the use of clonidine (Boehringer Ingelheim) in the treatment of migraine. Research and clinical studies in headache. 1970:315-20. [pmid: 4949837].
148 Adam EI, Gore SM, Price WH. Double blind trial of clonidine in the treatment of migraine in a general practice. J R Coll Gen Pract. Oct. 1978;28(195):587-90. [pmid: 368333].
149 Bredfeldt RC, Sutherland JE, Kruse JE. Efficacy of transdermal clonidine for headache prophylaxis and reduction of narcotic use in migraine patients. A randomized crossover trial. J Fam Pract. Aug. 1989;29(2):153-6. discussion 7–8. [pmid: 2666565].
150 Kallanranta T, Hakkarainen H, Hokkanen E, et al. Clonidine in migraine prophylaxis. Headache. 1977:169-72. [pmid: 893090].
151 Das SM, Ahuja GK, Narainaswamy AS. Clonidine in prophylaxis of migraine. Acta neurologica Scandinavica. 1979:214-7. [pmid: 393047].
152 Martucci N, Manna V, Mattesi P, et al. Ergot derivatives in the prophylaxis of migraine: a multicentric study with a timed-release dihydroergotamine formulation. Cephalalgia. Aug. 1983;3(Suppl 1):151-5. [pmid: 6352046].
153 Herrmann WM, Horowski R, Dannehl K, et al. Clinical effectiveness of lisuride hydrogen maleate: a double-blind trial versus methysergide. Headache. May. 1977;17(2):54-60. [pmid: 324950].
154 Whewell J. Methysergide in prophylaxis of migraine: a clinical trial in general practice. Br Med J. Aug. 13. 1966;2(5510):394-5. [pmid: 5331176].
155 Pradalier A, Lanteri-Minet M, Geraud G, et al. The PROMISE study: PROphylaxis of MIgraine with SEglor (dihydroergotamine mesilate) in French primary care. CNS Drugs. 2004;18(15):1149-63. [pmid: 15581385].
156 Neuman M, Demarez JP, Harmey JL, et al. Prevention of migraine attacks through the use of dihydroergotamine. International journal of clinical pharmacology research. 1986:11-3. [pmid: 3514491].
157 Buscaino GA, Sorge F, Bussone G, et al. Preventive treatment of headache with slow-release dihydroergotamine: Comparison of dosage protocols. Curr Ther Res Clin Exp. 1991:925-35.
158 Somerville BW, Herrmann WM. Migraine prophylaxis with lisuride. A double blind study of lisuride versus placebo. Headache. 1976:85-6.
159 Bonuso S, Di Stasio E, Barone P, et al. Timed-release dihydroergotamine in the prophylaxis of mixed headache. A study versus amitriptyline. Cephalalgia. 1983:175-8. [pmid: 6352047].
160 Millan-Guerrero RO, Isais-Millan S, Barreto-Vizcaino S, et al. Subcutaneous histamine versus botulinum toxin type A in migraine prophylaxis: a randomized, double-blind study. Eur J Neurol. Jan. 2009;16(1):88-94. [pmid: 19087155].
161 Mathew NT, Jaffri SF. A double-blind comparison of onabotulinumtoxina (BOTOX) and topiramate (TOPAMAX) for the prophylactic treatment of chronic migraine: a pilot study. Headache. Nov–Dec. 2009;49(10):1466-78. [pmid: 19912346].
162 Magalhaes E, Menezes C, Cardeal M, et al. Botulinum toxin type A versus amitriptyline for the treatment of chronic daily migraine. Clin Neurol Neurosurg. Jul. 2010;112(6):463-6. [pmid: 20399553].
163 Cady RK, Schreiber CP, Porter JA, et al. A multi-center double-blind pilot comparison of onabotulinumtoxinA and topiramate for the prophylactic treatment of chronic migraine. Headache. Jan. 2011;51(1):21-32. [pmid: 21070228].
164 Blumenfeld AM, Schim JD, Chippendale TJ. Botulinum toxin type A and divalproex sodium for prophylactic treatment of episodic or chronic migraine. Headache. Feb. 2008;48(2):210-20. [pmid: 18047502].
165 Freitag F, Taylor FR, Hamid MA, et al. Elimination of migraine-associated nausea in patients treated with rizatriptan orally disintegrating tablet (ODT): a randomized, double-blind, placebo-controlled study. Headache. Mar. 2008;48(3):368-77. [pmid: 18047500].
166 Bartolini M, Silvestrini M, Taffi R, et al. Efficacy of topiramate and valproate in chronic migraine. Clin Neuropharmacol. Nov–Dec. 2005;28(6):277-9. [pmid: 16340383].
167 Shaygannejad V, Janghorbani M, Ghorbani A, et al. Comparison of the effect of topiramate and sodium valporate in migraine prevention: a randomized blinded crossover study. Headache. Apr. 2006;46(4):642-8. [pmid: 16643559].
168 de Tommaso M, Marinazzo D, Nitti L, et al. Effects of levetiracetam vs topiramate and placebo on visually evoked phase synchronization changes of alpha rhythm in migraine. Clin Neurophysiol. Oct. 2007;118(10):2297-304. [pmid: 17709295].
169 Millan-Guerrero RO, Isais-Millan R, Barreto-Vizcaino S, et al. Subcutaneous histamine versus topiramate in migraine prophylaxis: a double-blind study. Eur Neurol. 2008;59(5):237-42. [pmid: 18264012].
170 Keskinbora K, Aydinli I. A double-blind randomized controlled trial of topiramate and amitriptyline either alone or in combination for the prevention of migraine. Clin Neurol Neurosurg. Dec. 2008;110(10):979-84. [pmid: 18620801].
171 Ashtari F, Shaygannejad V, Akbari M. A double-blind, randomized trial of low-dose topiramate vs propranolol in migraine prophylaxis. Acta Neurol Scand. Nov. 2008;118(5):301-5. [pmid: 18713156].
172 Dodick DW, Freitag F, Banks J, et al. Topiramate versus amitriptyline in migraine prevention: a 26-week, multicenter, randomized, double-blind, double-dummy, parallel-group noninferiority trial in adult migraineurs. Clin Ther. Mar. 2009;31(3):542-59. [pmid: 19393844].
173 Mohammadianinejad SE, Abbasi V, Sajedi SA, et al. Zonisamide versus topiramate in migraine prophylaxis: a double-blind randomized clinical trial. Clin Neuropharmacol. Jul–Aug. 2011;34(4):174-7. [pmid: 21738025].
174 Behan PO, Reid M. Propranolol in the treatment of migraine. Practitioner. 1980:201-4. [pmid: 6988825].
175 Carroll JD, Reidy M, Savundra PA, et al. Long-acting propranolol in the prophylaxis of migraine: a comparative study of two doses. Cephalalgia. Apr. 1990;10(2):101-5. [pmid: 2193712].
176 Kaushik R, Kaushik RM, Mahajan SK, et al. Biofeedback assisted diaphragmatic breathing and systematic relaxation versus propranolol in long term prophylaxis of migraine. Complement Ther Med. Sep. 2005;13(3):165-74. [pmid: 16150370].
177 Andersson PG, Petersen EN. Propranolol and femoxetine, a 5HT-uptake inhibitor, in migraine prophylaxis. A double-blind crossover study. Acta Neurol Scand. 1981:280-8. [pmid: 7032183].
178 Havanka-Kanniainen H, Hokkanen E, Myllyla VV. Long acting propranolol in the prophylaxis of migraine. Comparison of the daily doses of 80 mg and 160 mg. Headache. 1988:607-11. [pmid: 3248938].
179 Solomon GD. Verapamil and propranolol in migraine prohylaxis: a double-blind crossover study. Headache. 1986:325.
180 Ryan RE Sr. Comparative study of nadolol and propranolol in prophylactic treatment of migraine. Am Heart J. Oct. 1984;108(4 Pt 2):1156-9. [pmid: 6148878].
181 Olsson JE, Behring HC, Forssman B, et al. Metoprolol and propranolol in migraine prophylaxis: A double-blind multicentre study. Acta Neurol Scand. 1984:160-8. [pmid: 6391066].
182 Diener HC, Matias-Guiu J, Hartung E, et al. Efficacy and tolerability in migraine prophylaxis of flunarizine in reduced doses: a comparison with propranolol 160 mg daily. Cephalalgia. Apr. 2002;22(3):209-21. [pmid: 12047461].
183 Louis P, Schoenen J, Hedman C. Metoprolol v. clonidine in the prophylactic treatment of migraine. Cephalalgia. Sep. 1985;5(3):159-65. [pmid: 3899370].
184 Langohr HD, Gerber WD, Koletzki E, et al. Clomipramine and metoprolol in migraine prophylaxis--a double-blind crossover study. Headache. Mar. 1985;25(2):107-13. [pmid: 3886599].
185 Grotemeyer KH, Scharafinski HW, Schlake HP, et al. Acetylsalicylic acid vs. metoprolol in migraine prophylaxis--a double-blind cross-over study. Headache. Oct. 1990;30(10):639-41. [pmid: 2272812].
186 Worz R, Reinhardt-Benmalek B, Grotemeyer KH, et al. Bisoprolol and metoprolol in the prophylactic treatment of migraine with and without aura - A randomized double-blind cross-over multicenter study. Cephalalgia. 1991:152-3.
187 Worz R, Reinhardt-Benmalek B, Foeh M, et al. Migraine prophylaxis with bisoprolol. Headache Quarterly. 1992:64-72.
188 Diener HC, Hartung E, Chrubasik J, et al. A comparative study of oral acetylsalicyclic acid and metoprolol for the prophylactic treatment of migraine. A randomized, controlled, double-blind, parallel group phase III study. Cephalalgia. Mar. 2001;21(2):120-8. [pmid: 11422094].
189 Schellenberg R, Lichtenthal A, Wohling H, et al. Nebivolol and metoprolol for treating migraine: an advance on beta-blocker treatment?. Headache. Jan. 2008;48(1):118-25. [pmid: 18184294].
190 Togha M, Rahmat Jirde M, Nilavari K, et al. Cinnarizine in refractory migraine prophylaxis: efficacy and tolerability. A comparison with sodium valproate. J Headache Pain. Apr. 2008;9(2):77-82. [pmid: 18286231].
191 Sudilovsky A, Elkind AH, Ryan RE Sr, et al. Comparative efficacy of nadolol and propranolol in the management of migraine. Headache. Sep. 1987;27(8):421-6. [pmid: 3312113].
192 NCT00742209. Prevention Study in Adult Patients Suffering From Migraine Headaches. 2010.
193 Holroyd KA, Cottrell CK, O’Donnell FJ, et al. Effect of preventive (beta blocker) treatment, behavioural migraine management, or their combination on outcomes of optimised acute treatment in frequent migraine: randomised controlled trial. BMJ. 2010;341:c4871. [pmid: 20880898].
194 Pfaffenrath V, Wessely P, Meyer C, et al. Magnesium in the prophylaxis of migraine--a double-blind placebo-controlled study. Cephalalgia. Oct. 1996;16(6):436-40. [pmid: 8902254].
195 Peikert A, Wilimzig C, Kohne-Volland R. Prophylaxis of migraine with oral magnesium: results from a prospective, multi-center, placebo-controlled and double-blind randomized study. Cephalalgia. Jun. 1996;16(4):257-63. [pmid: 8792038].
196 Buring JE, Peto R, Hennekens CH. Low-dose aspirin for migraine prophylaxis. JAMA. Oct. 3. 1990;264(13):1711-3. [pmid: 2204739].
197 Masel BE, Chesson AL, Peters BH, et al. Platelet antagonists in migraine prophylaxis. A clinical trial using aspirin and dipyridamole. Headache. 1980:13-8. [pmid: 6985888].
198 Solomon GD, Freitag FG, Mehta N, et al. Fenoprofen calcium in migraine prophylaxis - a double-blind, placebo controlled study. Cephalalgia. 1987:473-4.
199 Solomon GD, Kunkel RS. Flurbiprofen in the prophylaxis of migraine. Cleve Clin J Med. Jan–Feb. 1993;60(1):43-8. [pmid: 8443934].
200 Anthony M, Lance JW. Indomethacin in migraine. Med J Aust. Jan. 13. 1968;1(2):56-7. [pmid: 4867513].
201 Visser WH, Malbecq W, Strohmaier K, et al. Preventive treatment of migraine headache with rofecoxib. Olesen J, Silberstein SD, Tfelt Hansen P, editors. Preventive Pharmacotherapy of Headache Disorders. Oxford. Oxford University Press. 2004:44-9.
202 Mikkelsen BM, Falk JV. Prophylactic treatment of migraine with tolfenamic acid. A comparative double-blind crossover study between tolfenamic acid and placebo. Acta neurologica Scandinavica. 1982:105-11. [pmid: 7051739].
203 Brandes JL, Visser WH, Farmer MV, et al. Montelukast for migraine prophylaxis: a randomized, double-blind, placebo-controlled study. Headache. Jun. 2004;44(6):581-6. [pmid: 15186302].
204 Nelson CF, Bronfort G, Evans R, et al. The efficacy of spinal manipulation, amitriptyline and the combination of both therapies for the prophylaxis of migraine headache. J Manipulative Physiol Ther. Oct. 1998;21(8):511-9. [pmid: 9798179].
205 Holroyd KA, France JL, Cordingley GE, et al. Enhancing the effectiveness of relaxation-thermal biofeedback training with propranolol hydrochloride. J Consult Clin Psychol. Apr. 1995;63(2):327-30. [pmid: 7751496].
206 Streng A, Linde K, Hoppe A, et al. Effectiveness and tolerability of acupuncture compared with metoprolol in migraine prophylaxis. Headache. Nov–Dec. 2006;46(10):1492-502. [pmid: 17115982].
207 Seng EK, Holroyd KA. Dynamics of changes in self-efficacy and locus of control expectancies in the behavioral and drug treatment of severe migraine. Annals of behavioral medicine : a publication of the Society of Behavioral Medicine. 2010:235-47. [pmid: 20812037].
208 Wang LP, Zhang XZ, Guo J, et al. Efficacy of acupuncture for migraine prophylaxis: a single-blinded, double-dummy, randomized controlled trial. Pain. Aug. 2011;152(8):1864-71. [pmid: 21616596].
209 Dahlof C. No clearcut longterm prophylactic effect of one month of treatment with propranolol in migraineurs. Cephalalgia. 1987:459-60.
210 Lemstra M, Stewart B, Olszynski WP. Effectiveness of multidisciplinary intervention in the treatment of migraine: a randomized clinical trial. Headache. Oct. 2002;42(9):845-54. [pmid: 12390609].
211 Matchar DB, Harpole L, Samsa GP, et al. The headache management trial: a randomized study of coordinated care. Headache. Oct. 2008;48(9):1294-310. [pmid: 18547268].
212 Rothrock JF, Parada VA, Sims C, et al. The impact of intensive patient education on clinical outcome in a clinic-based migraine population. Headache. May. 2006;46(5):726-31. [pmid: 16643574].
213 Fritsche G, Frettlöh J, Hüppe M, et al. Prevention of medication overuse in patients with migraine. Pain. 2010:404-13. [pmid: 20800968].
214 Sondergaard J, Foged A, Kragstrup J, et al. Intensive community pharmacy intervention had little impact on triptan consumption: a randomized controlled trial. Scand J Prim Health Care. Mar. 2006;24(1):16-21. [pmid: 16464810].
215 Hoffmann W, Herzog B, Muhlig S, et al. Pharmaceutical care for migraine and headache patients: a community-based, randomized intervention. Ann Pharmacother. Dec. 2008;42(12):1804-13. [pmid: 19001531].
216 Fritsche G, Diener HC. Medication overuse headaches -- what is new?. Expert Opinion on Drug Safety. Nov. 2002;1(4):331-8. [pmid: 12904133].
217 Guyuron B, Rose K, Kriegler JS, et al. Hourglass deformity after botulinum toxin type A injection. Headache. Mar. 2004;44(3):262-4. [pmid: 15012666].
218 Omoigui S, Irene S. Treatment of ptosis as a complication of botulinum toxin injection. Pain Medicine. Mar–Apr. 2005;6(2):149-51. [pmid: 15773880].
219 Villani V, Ciuffoli A, Prosperini L, et al. Zonisamide for migraine prophylaxis in topiramate-intolerant patients: an observational study. Headache. Feb. 2011;51(2):287-91. [pmid: 21284610].
220 Ashkenazi A, Benlifer A, Korenblit J, et al. Zonisamide for migraine prophylaxis in refractory patients. Cephalalgia. Oct. 2006;26(10):1199-202. [pmid: 16961786].
221 Pizza V, Busillo V, Agresta A, et al. Elderly patients with migraine: an open-label study on prophylaxis therapy with levetiracetam. Cent Nerv Syst Agents Med Chem. Mar. 1. 2011;11(1):31-4. [pmid: 21250937].
222 Vukovic V, Lovrencic-Huzjan A, Bosnar-Puretic M, et al. The efficacy of gabapentin in migraine prophylaxis: an observational open label study. Acta Clinica Croatica. Jun. 2009;48(2):145-51. [pmid: 19928412].
223 Silberstein SD, Collins SD. Safety of divalproex sodium in migraine prophylaxis: an open-label, long-term study. Long-term Safety of Depakote in Headache Prophylaxis Study Group. Headache. Oct. 1999;39(9):633-43. [pmid: 11284461].
224 Kinze S, Clauss M, Reuter U, et al. Valproic acid is effective in migraine prophylaxis at low serum levels: a prospective open-label study. Headache. Sep. 2001;41(8):774-8. [pmid: 11576201].
225 Vijayan N, Spillane T. Valproic acid treatment of chronic daily headache. Headache. Oct. 1995;35(9):540-3. [pmid: 8530278].
226 Ghose K. Efficacy and safety of long-term sodium valproate therapy in the prophylaxis of migraine headache. Headache Quarterly. 1999;10(2):127-30.
227 Anthony M, Lance JW, Somerville B. A comparative trial of prindolol, clonidine and carbamazepine in the interval therapy of migraine. Med J Aust. 1972:1343-6. [pmid: 4404482].
228 Rosen JA. Observations on the efficacy of propranolol for the prophylaxis of migraine. Ann Neurol. Jan. 1983;13(1):92-3. [pmid: 6338806].
229 Steardo L, Bonuso S, Di Stasio E, et al. Selective and non-selective beta-blockers: are both effective in prophylaxis of migraine? A clinical trial versus methysergide. Acta Neurol (Napoli). 1982:196-204. [pmid: 7136885].
230 Curran DA, Lance JW. Clinical Trial of Methysergide and Other Preparations in the Management of Migraine. J Neurol Neurosurg Psychiatry. Oct. 1964;27:463-9. [pmid: 14213477].
231 Kim MD, Lee G, Shin SW. Ergotamine-induced upper extremity ischemia: a case report. Korean Journal of Radiology. Apr–Jun. 2005;6(2):130-2. [pmid: 15968153].
232 Bavrasad R. Assessment of the middle-dose of topiramate in comparison with sodium valproate for migraine prophylaxis: a randomized double-blind study. International Journal of Pharmacology. 2010;6(5):670-5.
233 Bousser MG, Chick J, Fuseau E, et al. Combined low-dose acetylsalicylic acid and dihydroergotamine in migraine prophylaxis. A double-blind, placebo-controlled crossover study. Cephalalgia an international journal of headache. 1988:187-92. [pmid: 3197098].
234 Saper JR, Lake AE 3rd, Cantrell DT, et al. Chronic daily headache prophylaxis with tizanidine: a double-blind, placebo-controlled, multicenter outcome study. Headache. Jun. 2002;42(6):470-82. [pmid: 12167135].
235 Diamond S, Solomon GD, Freitag FG, et al. Fenoprofen in the prophylaxis of migraine: a double-blind, placebo controlled study. Headache. 1987:246-9. [pmid: 3298164].
236 Nadelmann JW, Phil M, Stevens J, et al. Propranolol in the prophylaxis of migraine. Headache. Apr. 1986;26(4):175-82. [pmid: 3519529].
237 Welch KMA, Ellis DJ, Keenan PA. Successful migraine prohpylaxis with naproxen sodium. Neurology. 1985.
238 Welch KM. Naproxen sodium in the treatment of migraine. Cephalalgia. 1986:85-92. [pmid: 3539362].
239 Ziegler DK, Ellis DJ. Naproxen in prophylaxis of migraine. Archives of neurology. 1985:582-4. [pmid: 4004602].
240 Frediani F, Grazzi L, Zanotti A, et al. Dihydroergokryptine versus dihydroergotamine in migraine prophylaxis: a double-blind clinical trial. Cephalalgia. Jul. 1991;11(3):117-21. [pmid: 1909603].
241 Bisceglia A, Cesarino F, Cerbo R, et al. Lisuride prophylactic treatment of migraine: A double blind study at two different dosages. New Trends in Clinical Neuropharmacology. 1990:35-40.
242 Rodríguez-Leyva I. Topiramate versus amitriptyline in prophylactic treatment of migraine: a controlled clinical trial. Revista Mexicana de Neurociencia. 2010;11(5):338-42.
243 Afshari D, Rafizadeh S, Rezaei M. A comparative study of the effects of low-dose topiramate versus sodium valproate in migraine prophylaxis. Int J Neurosci. Feb. 2012;122(2):60-8. [pmid: 21950578].
244 Micieli G, Cavallini A, Marcheselli S, et al. Alpha-dihydroergocryptine and predictive factors in migraine prophylaxis. Int J Clin Pharmacol Ther. Apr. 2001;39(4):144-51. [pmid: 11332869].