# Excluded Studies

## Not Eligible Exposure

1 Pharmacological prevention of migraine: to be considered case by case. Prescrire International. Oct. 2006;15(85):184-8. [pmid: 17128528].
2 Topiramate: new indication. Migraine prevention: best avoided. Prescrire International. Aug. 2006;15(84):132-3. [pmid: 16989025].
3 Molecule of the month. Lasmiditan hydrochloride. Drug News Perspect. Sep. 2010;23(7):455. [pmid: 20862397].
4 Agnoli A, Bussone G, Manzoni GC, et al. Dihydroergokryptine (DEK) versus flunarizine (FLU) in common migraine. A multicentre double-blind study. Cephalalgia. 1989:373-5.
5 Agro F, Liguori A, Petti FB, et al. Acupuncture versus pharmacological therapy in the treatment of migraine without aura: Clinical results. Pain Clinic. 2005:245-7.
6 Ahmed HE, White PF, Craig WF, et al. Use of percutaneous electrical nerve stimulation (PENS) in the short-term management of headache. Headache. Apr. 2000;40(4):311-5. [pmid: 10759936].
7 Ahonen K, Hamalainen ML, Eerola M, et al. A randomized trial of rizatriptan in migraine attacks in children. Neurology. Oct. 10. 2006;67(7):1135-40. [pmid: 16943370].
8 Alecrim-Andrade J, Maciel-Junior JA, Carne X, et al. Acupuncture in migraine prevention: a randomized sham controlled study with 6-months posttreatment follow-up. Clin J Pain. Feb. 2008;24(2):98-105. [pmid: 18209514].
9 Alecrim-Andrade J, Maciel-Junior JA, Cladellas XC, et al. Acupuncture in migraine prophylaxis: a randomized sham-controlled trial. Cephalalgia. May. 2006;26(5):520-9. [pmid: 16674760].
10 Allais G, D'Andrea G, Moschiano F, et al. A randomized, prospective, cross-over, double blind, placebo-controlled multicentre study to assess the efficacy and tolerability of almotriptan 12.5 mg in menstrually-related migraine. Cephalalgia. 2009:13.
11 Allais G, De Lorenzo C, Quirico PE, et al. Non-pharmacological approaches to chronic headaches: transcutaneous electrical nerve stimulation, lasertherapy and acupuncture in transformed migraine treatment. Neurol Sci. May. Suppl 2. 2003;24:S138-42. [pmid: 12811613].
12 Allen RA, Mills GK. The effects of unilateral plethysmographic feedback of temporal artery activity during migraine head pain. J-Psychosom-Res. 1982:133-40. [pmid: 7077545].
13 Almaraz AC, Dilli E, Dodick DW. The effect of prophylactic medications on TMS for migraine aura. Headache. Nov. 2010;50(10):1630-3. [pmid: 21198566].
14 Alpay K, Ertas M, Orhan EK, et al. Diet restriction in migraine, based on IgG against foods: a clinical double-blind, randomised, cross-over trial. Cephalalgia: an international journal of headache. 2010:829-37. [pmid: 20647174].
15 Alstadhaug KB, Odeh F, Salvesen R, et al. Prophylaxis of migraine with melatonin: a randomized controlled trial. Neurology. Oct. 26. 2010;75(17):1527-32. [pmid: 20975054].
16 Altieri M, Di Giambattista R, Di Clemente L, et al. Combined pharmacological and short-term psychodynamic psychotherapy for probable medication overuse headache: a pilot study. Cephalalgia. Mar. 2009;29(3):293-9. [pmid: 19220310].
17 Alzoubi KH, Mhaidat N, Azzam SA, et al. Prevalence of migraine and tension-type headache among adults in Jordan. Journal of Headache & Pain. Aug. 2009;10(4):265-70. [pmid: 19387792].
18 Amery WK, Waelkens J. Prevention of the last chance: An alternative pharmacologic treatment of migraine. Headache. 1983:37-8. [pmid: 6337976].
19 Andersson PG. Flunarizine and propranolol in the treatment of migraine. Journal Of Neurology. 1985;232:220.
20 Andrasik F, Blanchard EB, Neff DF, et al. Biofeedback and relaxation training for chronic headache: a controlled comparison of booster treatments and regular contacts for long-term maintenance. J Consult Clin Psychol. Aug. 1984;52(4):609-15. [pmid: 6381563].
21 Archambault ME. Do triptans increase the risk of thromboembolic stroke?. JAAPA. Jul. 2006;19(7):57-8. [pmid: 16869155].
22 Arora A, Arora S. Spontaneous splenic infarction associated with sumatriptan use. Journal of Headache & Pain. Sep. 2006;7(4):214-6. [pmid: 16767537].
23 Arruda MA, Guidetti V, Galli F, et al. Primary headaches in childhood--a population-based study. Cephalalgia. Sep. 2010;30(9):1056-64. [pmid: 20713556].
24 Arthur GP, Hornabrook RW. The treatment of migraine with BC 105 (pizotifen): a double blind trial. The New Zealand medical journal. 1971:5-9. [pmid: 4925988].
25 Ashkenazi A, Mushtaq A, Yang I, et al. Ictal and interictal phonophobia in migraine-a quantitative controlled study. Cephalalgia: an international journal of headache. 2009:1042-8. [pmid: 19735532].
26 Aurora SK, Barrodale PM, McDonald SA, et al. Revisiting the efficacy of sumatriptan therapy during the aura phase of migraine. Headache. Jul. 2009;49(7):1001-4. [pmid: 19438735].
27 Aurora SK, Barrodale PM, Vermaas AR, et al. Topiramate modulates excitability of the occipital cortex when measured by transcranial magnetic stimulation. Cephalalgia. Jun. 2010;30(6):648-54. [pmid: 19732073].
28 Ausband SC, Goodman PE. An unusual case of clarithromycin associated ergotism. Journal of Emergency Medicine. Nov. 2001;21(4):411-3. [pmid: 11728770].
29 Baars MAE, van Boxtel MPJ, Jolles J. Migraine does not affect cognitive decline: results from the Maastricht aging study. Headache. Feb. 2010;50(2):176-84. [pmid: 19925622].
30 Backer M, Grossman P, Schneider J, et al. Acupuncture in migraine: investigation of autonomic effects. Clin J Pain. Feb. 2008;24(2):106-15. [pmid: 18209515].
31 Bademosi O, Osuntokun BO. Pizotifen in the management of migraine. Practitioner. Feb. 1978;220(1316):325-7. [pmid: 345259].
32 Bakker MK, Kerstjens-Frederikse WS, Buys CH, et al. First-trimester use of paroxetine and congenital heart defects: a population-based case-control study. Birth Defects Res A Clin Mol Teratol. Feb. 2010;88(2):94-100. [pmid: 19937603].
33 Barbanti P, Fabbrini G, Aurilia C, et al. A case-control study on excessive daytime sleepiness in episodic migraine. Cephalalgia. Oct. 2007;27(10):1115-9. [pmid: 17725651].
34 Barbanti P, Fabbrini G, Pesare M, et al. Unilateral cranial autonomic symptoms in migraine. Cephalalgia. May. 2002;22(4):256-9. [pmid: 12100086].
35 Barry J, von Baeyer CL. Brief cognitive-behavioral group treatment for children's headache. Clin J Pain. Sep. 1997;13(3):215-20. [pmid: 9303253].
36 Baser O, Palmer L, Stephenson J. The estimation power of alternative comorbidity indices. Value in Health. Sep–Oct. 2008;11(5):946-55. [pmid: 18489502].
37 Bassi S, Amersey R, Henderson R, et al. Thyrotoxicosis, sumatriptan and coronary artery spasm. Journal of the Royal Society of Medicine. Jun. 2004;97(6):285-7. [pmid: 15173333].
38 Baykal B, Alpay KEM, Orhan EK. Diet restriction in migraine based on IgG antibodies against food antigens: a clinical double-blind, randomized crossover trial. Neurology. 2009:A182. Abstract no: P04.070.
39 Becker C, Brobert GP, Almqvist PM, et al. The risk of newly diagnosed asthma in migraineurs with or without previous triptan prescriptions. Headache. Apr. 2008;48(4):606-10. [pmid: 18194300].
40 Becker WJ. Zolmitriptan versus sumatriptan comparison trial. Headache. Mar. 2001;41(3):321-3. [pmid: 11264695].
41 Beckmann-Reinhold A, Schauer U, Wellensiek B, et al. A homeopathic complex remedy proves efficacious in migraine therapy: a randomized, double blind, parallel group clinical trial. Headache World. 2000. Sep. 3–7. London, England. 2000.
42 Behan PO. Pizotifen in the treatment of severe recurrent headache single and divided dose therapy compared. The British journal of clinical practice. 1982:13-7. [pmid: 7082549].
43 Behan PO. Prophylactic treatment for migraine - a comparison of pizotifen and clonidine. Cephalalgia. 1985:524-5.
44 Behan PO, Connelly K. Prophylaxis of migraine: a comparison between naproxen sodium and pizotifen. Headache. 1986:237-9. [pmid: 3522482].
45 Bellavance AJ, Meloche JP. A comparative study of naproxen sodium, pizotyline and placebo in migraine prophylaxis. Headache. Nov. 1990;30(11):710-5. [pmid: 2074163].
46 Beorchia S, Loisy C. Randomized, double-blind, placebo-controlled study of vasobral in the treatment of migraine. <ORIGINAL> ETUDE RANDOMISEE, EN DOUBLE AVEUGLE CONTRE PLACEBO, DU VASOBRAL (R) DANS LE TRAITEMENT DE LA MIGRAINE. J Med Lyon. 1989:71-7.
47 Beorchia S, Loisy C. Dihydrortgocryptine plus caffeine in treatment of migraine: A randomized double-blind trial against placebo. <ORIGINAL> ETUDE RANDOMISEE EN DOUBLE AVEUGLE CONTRE PLACEBO, DU VASOBRAL (R) DANS LE TRAITEMENT DE LA MIGRAINE. Gaz Med. 1989:69-75.
48 Bermejo PE, Dorado R, Gomez-Arguelles JM. Variation in almotriptan effectiveness according to different prophylactic treatments. Headache. Oct. 2009;49(9):1277-82. [pmid: 19788470].
49 Bernhardt M. Zentramine in migraine-like states. Die Medizinische Welt. 1984:772-3.
50 Besser RE, Stern CM. Raynaud phenomena and migraine in two children: inclusion within a family of related disorders. Acta Paediatrica. Dec. 2005;94(12):1860-2. [pmid: 16421056].
51 Beyer D. Clinical experiences with a new migraine-preparation HM 72 (Migraeflux). Munchener Medizinische Wochenschrift. 1975:733-4.
52 Bigal ME, Golden W, Buse D, et al. Triptan use as a function of cardiovascular risk. A population-based study. Headache. Feb. 2010;50(2):256-63. [pmid: 20039953].
53 Bigal ME, Rapoport AM, Lipton RB, et al. Assessment of migraine disability using the migraine disability assessment (MIDAS) questionnaire: a comparison of chronic migraine with episodic migraine. Headache. Apr. 2003;43(4):336-42. [pmid: 12656704].
54 Bigal ME, Rapoport AM, Sheftell FD, et al. Transformed migraine and medication overuse in a tertiary headache centre--clinical characteristics and treatment outcomes. Cephalalgia. Jun. 2004;24(6):483-90. [pmid: 15154858].
55 Bigal ME, Serrano D, Reed M, et al. Chronic migraine in the population: burden, diagnosis, and satisfaction with treatment. Neurology. Aug. 19. 2008;71(8):559-66. [pmid: 18711108].
56 Bild R, Adams HE. Modification of migraine headaches by cephalic blood volume pulse and EMG biofeedback. J Consult Clin Psychol. Feb. 1980;48(1):51-7. [pmid: 7365042].
57 Bille B, Ludvigsson J, Sanner G. Prophylaxis of migraine in children. Headache. 1977:61-3. [pmid: 324951].
58 Black KJ, Sheline YI. Paroxetine as migraine prophylaxis. Journal of Clinical Psychiatry. Jul. 1995;56(7):330-1. [pmid: 7615489].
59 Black L, Jones M, Boswell D, et al. Naratriptan compared with nonspecific/nonselective therapies reduces migraine-associated lost workplace productivity. European Journal of Neurology (Abstracts of the 4th Congress of the European Federation of Neurological Sciences). September 7–11. Lisbon, Portugal. 1999. 1999:21.
60 Blanchard EB, Andrasik F, Neff DF, et al. Biofeedback and relaxation training with three kinds of headache: treatment effects and their prediction. J Consult Clin Psychol. Aug. 1982;50(4):562-75. [pmid: 6749918].
61 Blanchard EB, Theobald DE, Williamson DA, et al. Temperature biofeedback in the treatment of migraine headaches: a controlled evaluation. Arch Gen Psychiatry. May. 1978;35(5):581-8. [pmid: 365125].
62 Boccia G, Del Giudice E, Crisanti AF, et al. Functional gastrointestinal disorders in migrainous children: efficacy of flunarizine. Cephalalgia. Oct. 2006;26(10):1214-9. [pmid: 16961789].
63 Boehnke C, Reuter U, Flach U, et al. High-dose riboflavin treatment is efficacious in migraine prophylaxis: an open study in a tertiary care centre. European Journal of Neurology. Jul. 2004;11(7):475-7. [pmid: 15257686].
64 Bonetto N, Santelli L, Battistin L, et al. Serotonin syndrome and rhabdomyolysis induced by concomitant use of triptans, fluoxetine and hypericum. Cephalalgia. Dec. 2007;27(12):1421-3. [pmid: 17868285].
65 Bono G, Criscuoli M, Martignoni E, et al. Serotonin precursors in migraine prophylaxis. Adv Neurol. 1982:357-63. [pmid: 7034490].
66 Bonuso S, Di Stasio E, Marano E, et al. Long-term outcome of migraine therapy: predictive value of the frontotemporal nitroglycerin test. Neurology. Nov. 1998;51(5):1475-8. [pmid: 9818888].
67 Bonuso S, Di Stasio E, Marano E, et al. Sublingual flunarizine: a new effective management of the migraine attack. A comparison versus ergotamine. Headache. May. 1986;26(5):227-30. [pmid: 3087910].
68 Bonuso S, Marano E, Di Stasio E, et al. The frontotemporal region plays a role in the genesis of migraine without aura. Headache. Mar. 1995;35(3):154-7. [pmid: 7721576].
69 Borgesen SE, Nielsen JL, Moller CE. Letter: Propranolol in migraine. Lancet. 1974:58. [pmid: 4134719].
70 Borhani Haghighi A, Motazedian S, Rezaii R, et al. Cutaneous application of menthol 10% solution as an abortive treatment of migraine without aura: a randomised, double-blind, placebo-controlled, crossed-over study. Int J Clin Pract. Mar. 2010;64(4):451-6. [pmid: 20456191].
71 Bottini F, Celle ME, Calevo MG, et al. Metabolic and genetic risk factors for migraine in children. Cephalalgia: an international journal of headache. 2006:731-7. [pmid: 16686913].
72 Bou J, Gras J, Cortijo J, et al. Vascular effects of the new anti-migraine agent almotriptan on human cranial and peripheral arteries. Cephalalgia. Oct. 2001;21(8):804-12. [pmid: 11737005].
73 Brandes JL, Cady RK, Freitag FG, et al. Needle-free subcutaneous sumatriptan (Sumavel DosePro): bioequivalence and ease of use. Headache. Nov–Dec. 2009;49(10):1435-44. [pmid: 19849720].
74 Brandes JL, Poole A, Kallela M, et al. Short-term frovatriptan for the prevention of difficult-to-treat menstrual migraine attacks. Cephalalgia. Nov. 2009;29(11):1133-48. [pmid: 19811503].
75 Brandes JL, Smith T, Diamond M, et al. Open-label, long-term tolerability of naratriptan for short-term prevention of menstrually related migraine. Headache. Jun. 2007;47(6):886-94. [pmid: 17578540].
76 Brescia-Morra V, De Marinis T, Gentile S, et al. Flunarizine versus indobuphene: Open study in the prophylaxis of migraine. Rassegna Internazionale di Clinica e Terapia. 1990:260-4.
77 Briars GL, Travis SE, Anand B, et al. Weight gain with pizotifen therapy. Archives of Disease in Childhood. Jul. 2008;93(7):590-3. [pmid: 18381348].
78 Brighina F, Piazza A, Vitello G, et al. rTMS of the prefrontal cortex in the treatment of chronic migraine: a pilot study. J Neurol Sci. Dec. 15. 2004;227(1):67-71. [pmid: 15546593].
79 Brigo B, Serpelloni G. Homeopathic treatment of migraines: a randomized double-blind controlled study of sixty cases (homeopathic remedy versus placebo). Berlin Journal of Research in Homeopathy. 1991;1(2):98-106.
80 Brigo B, Serpelloni G, Bosco O. Homeopathic treatment of migraine: a sixty case; double-blind; controlled study (homeopathic remedy vs placebo). (In French). Proceedings of the 42nd Congress of the Liga Medicorum Homoeopathica Internationalis (Arlington). (Unpublished). 1987:318-29.
81 Brun J, Claustrat B, Saddier P, et al. Nocturnal melatonin excretion is decreased in patients with migraine without aura attacks associated with menses. Cephalalgia. Apr. 1995;15(2):136-9. discussion 79. [pmid: 7641249].
82 Bryson J, Buse DC, Lipton RB. Assessment and treatment of the burden of migraine: a case series. Neurologist. Jul. 2010;16(4):254-61. [pmid: 20592569].
83 Burns C. Migraine in a rural practice (1958–1963). A five-year study of a controlled clinical trial. J Coll Gen Pract. 1965:230-8. [pmid: 4378868].
84 Bussone G, Baldini S, D'Andrea G, et al. Nimodipine versus flunarizine in common migraine: a controlled pilot trial. Headache. 1987;27:76-9. [pmid: 3553069].
85 Bussone G, Manzoni GC, Cortelli P, et al. Efficacy and tolerability of sumatriptan in the treatment of multiple migraine attacks. Neurol Sci. Oct. 2000;21(5):272-8. [pmid: 11286039].
86 Cabanas A, Rodriguez R, Rosado F, et al. Subcutaneous sumatriptan comparative study versus placebo in migraine attacks. Journal of The Neurological Sciences. 1997:S303.
87 Cabarrocas X, Esbri R, Peris F, et al. Long-term efficacy and safety of oral almotriptan: interim analysis of a 1-year open study. Headache. Jan. 2001;41(1):57-62. [pmid: 11168604].
88 Cady R. Looking forward: the expanding utility of sumatriptan and naratriptan. Cephalalgia. Suppl 1. 2001;21:35-8. [pmid: 11678821].
89 Cady R, Elkind A, Goldstein J, et al. Randomized, placebo-controlled comparison of early use of frovatriptan in a migraine attack versus dosing after the headache has become moderate or severe. Curr Med Res Opin. Sep. 2004;20(9):1465-72. [pmid: 15383196].
90 Cady RC, Ryan R, Jhingran P, et al. Sumatriptan injection reduces productivity loss during a migraine attack: results of a double-blind, placebo-controlled trial. Neurology. 1997:A121.
91 Cady RK, Farmer KU, Altura BT, et al. The effect of magnesium on the responsiveness of migraine sufferers to a 5-HT1 agonist. [abstract]. Neurology. 1998:A340.
92 Cady RK, Mathew N, Diener HC, et al. Evaluation of carisbamate for the treatment of migraine in a randomized, double-blind trial. Headache. Feb. 2009;49(2):216-26. [pmid: 19222595].
93 Calhoun A, Ford S. Elimination of menstrual-related migraine beneficially impacts chronification and medication overuse. Headache. Sep. 2008;48(8):1186-93. [pmid: 18819179].
94 Cano A, Sanz P, Palomeras E, et al. Low doses of flunarizine in the prophylaxis treatment of migraine. Neurología. 1998:480.
95 Capildeo R, Clifford RF. Singe-dose pizotifen, 1.5 mg nocte: a new approach in the prophylaxis of migraine. Headache. 1982;22:272-5. [pmid: 7174305].
96 Capildeo R, Rose FC. Single-dose pizotifen, 1.5 mg nocte: a new approach in the prophylaxis of migraine. Headache. 1982:272-5. [pmid: 7174305].
97 Carasso RL, Yehuda S. The prevention and treatment of migraine with an analgesic combination. Br J Clin Pract. Jan. 1984;38(1):25-7. [pmid: 6367797].
98 Caro G, Getsios D, Caro JJ, et al. Sumatriptan: economic evidence for its use in the treatment of migraine, the Canadian comparative economic analysis. Cephalalgia. Feb. 2001;21(1):12-9. [pmid: 11298658].
99 Caro JJ, Getsios D, Raggio G, et al. Treatment of migraine in Canada with naratriptan: a cost-effectiveness analysis. Headache. May. 2001;41(5):456-64. [pmid: 11380643].
100 Carroll JD, Maclay WP. Pizotifen (BC 105) in migraine prophylaxis. Curr Med Res Opin. 1975;3(2):68-71. [pmid: 1095308].
101 Castellana M, Carini C, Caprici G, et al. Calcium entry blockers in the treatment of primary headached in childhood: our experiecne with flunarizine and nimodipine. Paper presented at, 1989; Headache in children and adolescents. Proceedings of the First International Symposium on Headache in Children and Adolescents. 1988 May 19–20. Pavia Italy.
102 Ceccherelli F, Ambrosio F, Avila M, et al. Acupuncture vs. placebo in the common migraine: a double blind study. [abstract]. Cephalalgia. 1987:499-500.
103 Cerbo R, Casacchia M, Formisano R, et al. Double-blind clinical trial of flunarizine against pizotifen in a single evening dose in patients with migraine. Rivista di Neurologia. 1985:139-46. [pmid: 4012191].
104 Cerbo R, Casacchia M, Formisano R, et al. Flunarizine-pizotifen single-dose double-blind cross-over trial in migraine prophylaxis. Cephalalgia. Mar. 1986;6(1):15-8. [pmid: 3516406].
105 Chan KY, Baun M, de Vries R, et al. Pharmacological characterization of VIP and PACAP receptors in the human meningeal and coronary artery. Cephalalgia. Jan. 2011;31(2):181-9. [pmid: 20974589].
106 Chappell AS, Bay JM, Botzum GD. Sergolexole maleate and placebo for migrane prophylaxis. Cephalalgia. 1991:170-1.
107 Chappell AS, Bay JM, Cohen ML. A multicentre trial of sergolexole maleate, a 5HT2 receptor antagonist, and placebo for migraine prophylaxis. J Drug Dev. 1992:75-81.
108 Chayasirisobhon S. Use of a pine bark extract and antioxidant vitamin combination product as therapy for migraine in patients refractory to pharmacologic medication. Headache. May. 2006;46(5):788-93. [pmid: 16643582].
109 Christensen MF. Double blind placebo controlled trial of pizotifen syrup in the treatment of abdominal migraine. Archives of disease in childhood. 1995:183. [pmid: 7574874].
110 Christoph-Diener H, Ferrari M, Mansbach H, et al. Predicting the response to sumatriptan: the Sumatriptan Naratriptan Aggregate Patient Database. Neurology. Aug. 10. 2004;63(3):520-4. [pmid: 15304585].
111 Ciancarelli I, Tozzi-Ciancarelli MG, Di Massimo C, et al. Flunarizine effects on oxidative stress in migraine patients. Cephalalgia. Jul. 2004;24(7):528-32. [pmid: 15196294].
112 Cianchetti C, Serci MC, Pisano T, et al. Compression of superficial temporal arteries by a handmade device: a simple way to block or attenuate migraine attacks in children and adolescents. Journal of Child Neurology. Jan. 2010;25(1):67-70. [pmid: 19525492].
113 Claghorn JL, Mathew RJ, Largen JW, et al. Directional effects of skin temperature self-regulation on regional cerebral blood flow in normal subjects and migraine patients. Am J Psychiatry. Sep. 1981;138(9):1182-7. [pmid: 7270721].
114 Clayton AH, West SG, McGarvey E, et al. Biochemical evidence of the placebo effect during the treatment of menstrual migraines. Journal of Clinical Psychopharmacology. Aug. 2005;25(4):400-1. [pmid: 16012294].
115 Cockey CD. Relief for menstruation-related migraines. AWHONN Lifelines. Dec. 2002;6(6):497. [pmid: 12593251].
116 Colman SS, Brod MI, Krishnamurthy A, et al. Treatment satisfaction, functional status, and health-related quality of life of migraine patients treated with almotriptan or sumatriptan. Clin Ther. Jan. 2001;23(1):127-45. [pmid: 11219473].
117 Colman SS, Rothermich BA, Rowland CR, et al. Application of the extended Q-Twist methodology among migraine sufferers: results from a clinical trial. [abstract]. Quality of Life Research. 2000:258.
118 Colucci D'Amato C, Pizza V, Marmolo T, et al. Paroxetine versus flunarizine in the preventive treatment of migraine. Headache Quarterly. 1998;9(3):266-7. PMID.
119 Combremont PC, Marcus EM. Intracranial hemorrhages associated with sumatriptan. Neurology. May. 8. 2001;56(9):1243-4. [pmid: 11342701].
120 Connor HE. Building on the sumatriptan experience: the development of naratriptan. Cephalalgia. Suppl 1. 2001;21:32-4. [pmid: 11678820].
121 Cooke LJ, Becker WJ. Migraine prevalence, treatment and impact: the canadian women and migraine study. Can J Neurol Sci. Sep. 2010;37(5):580-7. [pmid: 21059502].
122 Cooper PE. The optimal use of triptans--sooner is better. Canadian Journal of Neurological Sciences. Feb. 2006;33(1):3-4. [pmid: 16583715].
123 Coulam CB, Annegers JF. Do anticonvulsants reduce the efficacy of oral contraceptives?. Epilepsia. Oct. 1979;20(5):519-25. [pmid: 477641].
124 Cruz A, Buhling M, Seibel K. Double-blind study on migraine therapy with etilefrine pivalate. <ORIGINAL> DOPPELBLINDSTUDIE ZUR MIGRANETHERAPIE MIT ETILEFRINPIVALAT. Arzneim-Forsch/Drug Res. 1985:1086-9. [pmid: 2864937].
125 Cunnington M, Ephross S, Churchill P. The safety of sumatriptan and naratriptan in pregnancy: what have we learned?. Headache. Nov–Dec. 2009;49(10):1414-22. [pmid: 19804390].
126 Cupini LM, Santorelli FM, Iani C, et al. Cyclic vomiting syndrome, migraine, and epilepsy: a common underlying disorder?. Headache. Apr. 2003;43(4):407-9. [pmid: 12656714].
127 Cupini LM, Troisi E, Placidi F, et al. Does the antimigraine action of flunarizine involve the dopaminergic system? A clinical-neuroendocrinological study. Cephalalgia. Jan. 1999;19(1):27-31. [pmid: 10099857].
128 Cutler NR, Salazar DE, Jhee SS, et al. Pharmacokinetics and pharmacodynamics of avitriptan in patients with migraine after oral dosing. Headache. Jun. 1998;38(6):446-52. [pmid: 9664749].
129 Cuvellier J-C, Donnet A, Gu, et al. Treatment of primary headache in children: a multicenter hospital-based study in France. Journal of Headache & Pain. Dec. 2009;10(6):447-53. [pmid: 19771388].
130 Dahlof C. How to assess patient preference of migraine treatments. Cephalalgia. Jul. Suppl 24. 1999;19:2-5. discussion -6. [pmid: 10526675].
131 Dalla Volta G, Griffini S, Pezzini A. Influence of sumatriptan on the autonomic system during migraine attacks. Journal of Headache & Pain. Apr. 2006;7(2):116-7. [pmid: 16688414].
132 Dalsgaard-Nielsen T. Therapeutic results of prophylactic treatment for "classic" migraine with antaminic substance (B P 400 Sandoz). Headache. 1968:6-15. [pmid: 4384742].
133 D'Andrea G, Cananzi AR, Grigoletto F, et al. The effect of dopamine receptor agonists on prolactin secretion in childhood migraine. Headache. 1988:354-9. [pmid: 3403257].
134 D'Arcy Y. Going the distance. New pain treatment provide longer stronger relief. Advance for Nurse Practitioners. Jun. 2007;15(6):32-6. quiz 7. [pmid: 19999007].
135 Dash S, Bogdanova O, Xavier A, et al. Cerebral vasospasm from sumatriptan. Neurology. Dec. 14. 2004;63(11):2128. [pmid: 15596760].
136 de Almeida R, Roldão F, et al. Migraine with persistent visual aura: response to furosemide. Clinics (Sao Paulo, Brazil). 2009;64(4):375-6. [pmid: 19488599].
137 De Benedittis G, Massei R. Serotonin precursors in chronic primary headache. A double-blind cross-over study with L-5-hydroxytryptophan vs. placebo. Journal of neurosurgical sciences. 1985:239-48. [pmid: 3913752].
138 de Weerdt CJ, Bootsma HPR, Hendriks H. Herbal medicines in migraine prevention. Randomized double-blind placebo-controlled crossover trial of a feverfew preparation. Phytomedicine. 1996:225-30. [pmid: 23195074].
139 Del Bene E, Poggioni M, Michelacci S. Lisuride as a migraine prophylactic in children: an open clinical trial. Int J Clin Pharmacol Res. 1983;3(2):137-41. [pmid: 6679514].
140 Deleu D, Khan MA, Humaidan H, et al. Prevalence and clinical characteristics of headache in medical students in oman. Headache. Sep. 2001;41(8):798-804. [pmid: 11576205].
141 Demarquay G, Lothe A, Royet JP, et al. Brainstem changes in 5-HT1A receptor availability during migraine attack. Cephalalgia. Jan. 2011;31(1):84-94. [pmid: 21036859].
142 Denaro A, Martucci N, Ruggieri S, et al. Headache and noradrenergic involvement: the effects of alpha 2-stimulants and alpha 2-antagonists. Acta Psychiatr Scand Suppl. 1985;320:20-5. [pmid: 3901672].
143 Denuelle M, Fabre N, Payoux P, et al. Hypothalamic activation in spontaneous migraine attacks. Headache. Nov–Dec. 2007;47(10):1418-26. [pmid: 18052951].
144 Devic M. Comparative trial of 3 migraine remedies. Lyon Medical. 1985:245-50.
145 Di Rosa G, Attinà S, et al. Efficacy of folic acid in children with migraine, hyperhomocysteinemia and MTHFR polymorphisms. Headache. Oct. 2007;47(9):1342-4. [pmid: 17927652].
146 Diamond ML, Cady RK, Mao L, et al. Characteristics of migraine attacks and responses to almotriptan treatment: a comparison of menstrually related and nonmenstrually related migraines. Headache. Feb. 2008;48(2):248-58. [pmid: 18234046].
147 Diamond S, Bigal ME, Silberstein S, et al. Patterns of diagnosis and acute and preventive treatment for migraine in the United States: results from the American Migraine Prevalence and Prevention study. Headache. Mar. 2007;47(3):355-63. [pmid: 17371352].
148 Diamond S, Freitag FG, Diamond ML. Flunarizine in migraine therapy. Clin Pharmacol Ther. 1990:165.
149 Diener H. Efficacy and tolerability of flunarizine and propranolol in the prophylactic treatment of migraine. Cephalalgia. 1999;19(4):374. PMID.
150 Diener HC, Foh M, Iaccarino C, et al. Cyclandelate in the prophylaxis of migraine: a randomized, parallel, double-blind study in comparison with placebo and propranolol. The Study group. Cephalalgia. Oct. 1996;16(6):441-7. [pmid: 8902255].
151 Diener HC, Kronfeld K, Boewing G, et al. Efficacy of acupuncture for the prophylaxis of migraine: a multicentre randomised controlled clinical trial. Lancet Neurol. Apr. 2006;5(4):310-6. [pmid: 16545747].
152 Diener HC, Krupp P, Schmitt T, et al. Cyclandelate in the prophylaxis of migraine: a placebo-controlled study. Cephalalgia. Feb. 2001;21(1):66-70. [pmid: 11298666].
153 Diener HC, Louis P, Schellens R, et al. Treatment of migraine attacks with intranasal alniditan: an open study. Cephalalgia. Mar. 2001;21(2):140-4. [pmid: 11422097].
154 Diener HC, Pfaffenrath V, Schnitker J, et al. Efficacy and safety of 6.25 mg t.i.d. feverfew CO2-extract (MIG-99) in migraine prevention--a randomized, double-blind, multicentre, placebo-controlled study. Cephalalgia. Nov. 2005;25(11):1031-41. [pmid: 16232154].
155 Diener HC, Rahlfs VW, Danesch U. The first placebo-controlled trial of a special butterbur root extract for the prevention of migraine: reanalysis of efficacy criteria. Eur Neurol. 2004;51(2):89-97. [pmid: 14752215].
156 Diener H-C, Dowson A, Whicker S, et al. Development and validation of a pharmacy migraine questionnaire to assess suitability for treatment with a triptan. Journal of Headache & Pain. Dec. 2008;9(6):359-65. [pmid: 18953489].
157 Diez-Tejedor FA. Assessment of response consistency to oral sumatriptan in migraine attacks. Journal of The Neurological Sciences. 1997.
158 Dodick D, Blumenfeld A, Silberstein SD. Botulinum neurotoxin for the treatment of migraine and other primary headache disorders. Clinics in Dermatology. Jan–Feb. 2004;22(1):76-81. [pmid: 15158549].
159 Dora B, Balkan S, et al. Normalization of high interictal cerebrovascular reactivity in migraine without aura by treatment with flunarizine. Headache. May. 2003;43(5):464-9. [pmid: 12752751].
160 Dowson A. Can oral 311C90, a novel 5-HT1D agonist, prevent migraine headache when taken during an aura?. Eur Neurol. Suppl 2. 1996;36:28-31. [pmid: 8791030].
161 Dowson A. Bringing sumatriptan to primary care. Cephalalgia. Suppl 1. 2001;21:29-31. [pmid: 11678819].
162 Dowson A, Ball K, Haworth D. Comparison of a fixed combination of domperidone and paracetamol (Domperamol) with sumatriptan 50 mg in moderate to severe migraine: a randomised UK primary care study. Curr Med Res Opin. 2000;16(3):190-7. [pmid: 11191009].
163 Dowson AJ, Fuat A, Gruffydd-Jones K. Clinical and economic issues associated with switching between triptans in clinical practice. Current Medical Research & Opinion. Mar. 2005;21(3):375-9. [pmid: 15811206].
164 Dowson AJ, Muir K, Mullen M, et al. A prospective, multicenter, randomised, placebo-controlled trial to evaluate the efficacy of PFO closure with the STARFlex implant to prevent refractory migraine: the MIST trial. 15th European Stroke Conference. 2006.
165 Dowson AJ, Wilmshurst P, Muir KW, et al. A prospective, multicentre, randomised, double-blind, placebo-controlled trial to evaluate the efficacy of PFO closure with the STARFLEX device to prevent refractory migraine: the MIST trial. European Journal of Neurology. 2006:22.
166 Drake ME Jr, Greathouse NI, Renner JB, et al. Open-label zonisamide for refractory migraine. Clinical Neuropharmacology. Nov–Dec. 2004;27(6):278-80. [pmid: 15613932].
167 Drillisch C, Girke W. Therapeutic results of cinnarizine and flunarizine in patients suffering from migraine. Medizinische Welt. 1980:1870-2. [pmid: 6110158].
168 D'Souza PJ, Lumley MA, Kraft CA, et al. Relaxation training and written emotional disclosure for tension or migraine headaches: a randomized, controlled trial. Ann Behav Med. Aug. 2008;36(1):21-32. [pmid: 18696172].
169 Duckmanton L. Drug information incorrect. Canadian Family Physician. Apr. 2000;46:780. [pmid: 10790808].
170 Ebinger F. Exteroceptive suppression of masseter muscle activity in juvenile migraineurs. Cephalalgia: an international journal of headache. 2006:722-30. [pmid: 16686912].
171 Egger J, Carter CM, Wilson J, et al. Is migraine food allergy? A double-blind controlled trial of oligoantigenic diet treatment. Lancet. Oct. 15. 1983;2(8355):865-9. [pmid: 6137694].
172 Elbarbry FA, Mabrouk MM, El-Dawy MA. Determination of the analgesic components of Spasmomigraine tablet by liquid chromatography with ultraviolet detection. Journal of AOAC International. Jan–Feb. 2007;90(1):94-101. [pmid: 17373440].
173 Elkind A, Laurenza A, Austin R, et al. Efficacy and tolerability of naratriptan tablets in the treatment of migraine: Results of a double-blind, placebo-controlled, parallel group trial. (Abstract). Journal of the Neurological Sciences. 1997:S262.
174 Elkind A, McDaris HL, Satin L, et al. The cardiovascular safety of frovatriptan during a migraine attack in patients with known or at high risk of coronary artery disease. European Journal of Neurology (Abstracts of the 4th Congress of the European Federation of Neurological Sciences). September 7–11. Lisbon, Portugal. 1999. 1999:141.
175 Elkind AH, Satin LZ, Nila A, et al. Frovatriptan use in migraineurs with or at high risk of coronary artery disease. Headache. May. 2004;44(5):403-10. [pmid: 15147247].
176 Elouni B, Ben Salem C, Zamy M, et al. Fulminant hepatitis possibly related to pizotifen therapy. Annals of Pharmacotherapy. Jul–Aug. 2010;44(7–8):1348-9. [pmid: 20571104].
177 Elser Jm, Woody RC. Migraine headache in the infant and young child. Headache. 1990:366-8. [pmid: 2370139].
178 Endres HG, Böwing G, Diener HC, et al. Acupuncture for tension-type headache: a multicentre, sham-controlled, patient-and observer-blinded, randomised trial. The journal of headache and pain. 2007:306-14. [pmid: 17955168].
179 Esposito SB, Gherpelli JL. Chronic daily headaches in children and adolescents: a study of clinical characteristics. Cephalalgia: an international journal of headache. 2004:476-82. [pmid: 15154857].
180 Etemad LR, Yang W, Globe D, et al. Costs and utilization of triptan users who receive drug prophylaxis for migraine versus triptan users who do not receive drug prophylaxis. Journal of Managed Care Pharmacy. Mar. 2005;11(2):137-44. [pmid: 15766320].
181 Evans BJ, Patel R, Wilkins AJ. Optometric function in visually sensitive migraine before and after treatment with tinted spectacles. Ophthalmic Physiol Opt. Mar. 2002;22(2):130-42. [pmid: 12014487].
182 Evans RW, Baskin SM. Why do migraineurs abuse butalbital-containing combination analgesics?. Headache. Jul. 2010;50(7):1194-7. [pmid: 20649651].
183 Evans RW, Davenport RJ. Benign or sinister? Distinguishing migraine from subarachnoid hemorrhage. Headache. Mar. 2007;47(3):433-5. [pmid: 17371361].
184 Evans RW, Diamond ML. Is sumatriptan use safe during pregnancy?. Headache. Nov–Dec. 2000;40(10):856-7. [pmid: 11135034].
185 Evans RW, Mannix LK. Triptans for migraine prodrome. Headache. Jan. 2002;42(1):83-4. [pmid: 12005282].
186 Evans RW, Pascual J, et al. Bending the rule of monotherapy for migraine prevention?. Headache. Jun. 2005;45(6):748-50. [pmid: 15953308].
187 Evans RW, Seifert T, Mathew NT. Are triptans effective and safe when taken during the aura phase of migraine?. Headache. May. 2005;45(5):601-3. [pmid: 15953281].
188 Evans RW, Solomon S. Is it migraine or cluster?. Headache. Sep. 2000;40(8):694-5. [pmid: 10971670].
189 Evans RW, Tepper SJ, Shapiro RE, et al. The FDA alert on serotonin syndrome with use of triptans combined with selective serotonin reuptake inhibitors or selective serotonin-norepinephrine reuptake inhibitors: American Headache Society position paper. [Summary for patients in Headache. 2010 Jun;50(6):1101–2; PMID: 20618824]. Headache. Jun. 2010;50(6):1089-99. [pmid: 20618823].
190 Ferrari A, Leone S, Vergoni AV, et al. Similarities and differences between chronic migraine and episodic migraine. Headache. Jan. 2007;47(1):65-72. [pmid: 17355496].
191 Ferrari A, Pinetti D, Bertolini A, et al. Interindividual variability of oral sumatriptan pharmacokinetics and of clinical response in migraine patients. European Journal of Clinical Pharmacology. May. 2008;64(5):489-95. [pmid: 18180912].
192 Ferrari MD. Sumatriptan by injection. Cephalalgia. Suppl 1. 2001;21:6-8. [pmid: 11678812].
193 Ferrari MD, Haan J, Blokland JA, et al. Cerebral blood flow during migraine attacks without aura and effect of sumatriptan. Arch Neurol. Feb. 1995;52(2):135-9. [pmid: 7848120].
194 Ferrari MD, James MH, Bates D, et al. Oral sumatriptan: effect of a second dose, and incidence and treatment of headache recurrences. Cephalalgia. Oct. 1994;14(5):330-8. [pmid: 7828190].
195 Ferrari MD, Wilkinson M, Hirt D, et al. Efficacy of ICS 205-930, a novel 5-hydroxytryptamine3 (5-HT3) receptor antagonist, in the prevention of migraine attacks. A complex answer to a simple question. ICS 205-930 Migraine Study Group. Pain. Jun. 1991;45(3):283-91. [pmid: 1876437].
196 Ferrigno V, Scaffidi L, Russo S, et al. Comparison of buflomedil and verapamil as alternatives in prophylaxis of essential migraine. Rassegna di Medicina Interna. 1985:279-86.
197 Fichtel A. Recurrent Headache among Swedish Adolescents. Uppsala. Social Sciences, Universitatis Upsaliensis. 2003.
198 Fichtel A, Larsson B. Does relaxation treatment have differential effects on migraine and tension-type headache in adolescents?. Headache. Mar. 2001;41(3):290-6. [pmid: 11264690].
199 Fichtel A, Larsson B. Relaxation treatment administered by school nurses to adolescents with recurrent headaches. Headache. Jun. 2004;44(6):545-54. [pmid: 15186298].
200 Fiseau E, Webster C, Asgharnejad M, et al. Naratriptan oral pharmacokinetics in migraine subjects. [Abstract]. Journal of the Neurological Sciences. 1997:S33.
201 Flanagan M. Thermography in migraine: a pilot study. [abstract]. Australian & New Zealand Journal of Medicine. 1989:639.
202 Flexman AM, Del Vicario G, Schwarz SKW. Dark green blood in the operating theatre. Lancet. Jun. 9. 2007;369(9577):1972. [pmid: 17560450].
203 Forcelini CM, Dantas DC, Luz C, et al. Analysis of leukocytes in medication-overuse headache, chronic migraine, and episodic migraine. Headache. Sep. 2011;51(8):1228-38. [pmid: 21649652].
204 Forssman B, Henriksson KG, Kihlstrand S. A comparison between BC 105 and methysergide in the prophylaxis of migraine. Acta neurologica Scandinavica. 1972:204-12. [pmid: 4556413].
205 Forsythe WI, Redmond A. Two controlled trials of tyramine in children with migraine. Developmedchild Neurol. 1974:794-9.
206 Fox AW. Onset of effect of 5-HT1B/1D agonists: a model with pharmacokinetic validation. Headache. Feb. 2004;44(2):142-7. [pmid: 14756852].
207 Fox AW. Subcutaneous sumatriptan pharmacokinetics: delimiting the monoamine oxidase inhibitor effect. Headache. Feb. 2010;50(2):249-55. [pmid: 19925626].
208 Frediani F, Cannatà AP, et al. The patient with medication overuse: clinical management problems. Neurological Sciences. May. Suppl 2. 2003;24:S108-11. [pmid: 12811605].
209 Freitag FG, Finlayson G, Rapoport AM, et al. Effect of pain intensity and time to administration on responsiveness to almotriptan: results from AXERT 12.5 mg Time Versus Intensity Migraine Study (AIMS). Headache. Apr. 2007;47(4):519-30. [pmid: 17445101].
210 French DJ, Gauthier JO, Roberge C, et al. Self-efficacy in the thermal biofeedback treatment of migraine sufferers. Behavior Therapy. 1997:109-25.
211 Fumio G, Kunio T, Naoyuki K, et al. Clinical Evaluation of KB-2796 (lomerizine hydrochloride) on Migraine. Late Phase II Study. Rinsho Hyoka (Clinical Evaluation). 1995:13-37.
212 Fumio G, Kunio T, Naoyuki K, et al. Clinical Evaluation of Lomerizine on Migraine. Double-blind Study in Comparison with Dimetotiazine. Rinsho Hyoka (Clinical Evaluation). 1995:183-214.
213 Furman JM, Marcus DA. A pilot study of rizatriptan and visually-induced motion sickness in migraineurs. Int J Med Sci. 2009;6(4):212-7. [pmid: 19680473].
214 Furman JM, Marcus DA, Balaban CD. Rizatriptan reduces vestibular-induced motion sickness in migraineurs. J Headache Pain. Feb. 2011;12(1):81-8. [pmid: 20862509].
215 Fuseau E, Webster C, Asgharnejad M, et al. Naratriptan oral pharmacokinetic-pharmacodynamic modelling of pain relief in migraine subjects. [Abstract]. Journal of the Neurological Sciences. 1997:S167.
216 Fuseau E, Webster M, Aspharnejad M, et al. Factors affecting oral naratriptan pharmacokinetics in migraine subjects. [abstract]. Journal of the Neurological Sciences. 1997:S33.
217 Gallagher RM, Kunkel R. Migraine medication attributes important for patient compliance: concerns about side effects may delay treatment. Headache. Jan. 2003;43(1):36-43. [pmid: 12864756].
218 Gallagher RM, Mueller L. Managing intractable migraine with naratriptan. Headache. Oct. 2003;43(9):991-3. [pmid: 14511276].
219 Gamzu Elkan, Pradalier A, Guerard DLA, Scheck F, et al. The Pharmacology of CERETATÍ (CNS1102) and Early Clinical Results: The association of calcium carbasalate-metoclopramide versus dihydroergotamine in the treatment of migraine attacks. 8th-ECNP-(European-College-of-Neuropsychopharmacology)-Congress. Venice, Italy. Pathologie Biologie. 1995:806-13.
220 Gao S, Zhao D, Xie Y. A comparative study on the treatment of migraine headache with combined distant and local acupuncture points versus conventional drug therapy. Am J Acupunct. 1999;27(1–2):27-30. [pmid: 10513096].
221 García-del-Pozo J, et al. Antimigraine drug consumption in Spain (1990–2000). Acta Neurologica Scandinavica. Feb. 2003;107(2):158-60. [pmid: 12580869].
222 Garza I. Tonabersat: a cortical spreading depression inhibitor as potential pharmacologic prophylaxis in migraine with aura. Curr Neurol Neurosci Rep. Jan. 2010;10(1):7-9. [pmid: 20425219].
223 Gauthier J, Cote G, French D. The role of home practice in the thermal biofeedback treatment of migraine headache. J Consult Clin Psychol. Feb. 1994;62(1):180-4. [pmid: 8034821].
224 Gawel M, Kreeft J, Nelson R, et al. Flunarizine is comparable to propanolol in the prophylaxis of migraine with and without aura. Cephalalgia. 1991:156.
225 Gentile G, Borro M, Lala N, et al. Genetic polymorphisms related to efficacy and overuse of triptans in chronic migraine. J Headache Pain. Oct. 2010;11(5):431-5. [pmid: 20652353].
226 Gerber WD, Diener HC, Kropp P, et al. The efficacy of flunarizine and etilefrinepivalate in migraine: An empirical double-blind and placebo controlled study. Cephalalgia. 1989:450-1.
227 Gerber WD, Schellenberg R, Thom M, et al. Cyclandelate versus propranolol in the prophylaxis of migraine--a double-blind placebo-controlled study. Funct Neurol. Jan–Feb. 1995;10(1):27-35. [pmid: 7649498].
228 Gerth WC, Dasback EJ, Musser BJ. Impact of migraine symptoms on health care utilization and work loss. [abstract]. Neurology. 1997:A123.
229 Gibb CM, Davies PT, Glover V, et al. Chocolate is a migraine-provoking agent. Cephalalgia: an international journal of headache. 1991:93-5. [pmid: 1860135].
230 Gillies D, Sills M, Forsythe I. Pizotifen (Sanomigran) in childhood migraine. A double-blind controlled trial. European neurology. 1986:32-5. [pmid: 3510125].
231 Gnecchi-Ruscone T, Bernard X, Pierre P, et al. Effect of naratriptan on myocardial blood flow and coronary vasodilator reserve in migraineurs. Neurology. Jul. 12. 2000;55(1):95-9. [pmid: 10891912].
232 Goadsby PJ, Winter P, Asgharnejad M. Twenty-four hour maintenance of headache relief after treatment of migraine with naratriptan tablets: a review of data from controlled clinical trials. [abstract]. Neurology. 1998:A340-1.
233 Göbel H, Heinze A, Kuhn K, et al. Effect of operationalized computer diagnosis on the therapeutic results of sumatriptan in general practice. Cephalalgia: an international journal of headache. 1998:481-6. [pmid: 9793701].
234 Göbel H, Krapat S, Dworschak M, et al. Exteroceptive suppression of temporalis muscle activity during migraine attack and migraine interval before and after treatment with sumatriptan. Cephalalgia: an international journal of headache. 1994:143-8. [pmid: 8062353].
235 Gobel H, Krapat S, Soyka D. Effect of sumatriptan on psychological status during migraine attack and migraine interval. [abstract]. 1993 Meeting of the European Federation of Neurological Societies. Berlin. Dec 1993. 1993.
236 Goldstein DJ, Offen WW, Klein EG, et al. Lanepitant, an NK-1 antagonist, in migraine prevention. Cephalalgia. Mar. 2001;21(2):102-6. [pmid: 11422091].
237 Goldstein J, Keywood C, Hutchison J. 24-hour migraine recurrence was low during treatment with frovatriptan. European Journal of Neurology (Abstracts of the 4th Congress of the European Federation of Neurological Sciences). September 7–11. Lisbon, Portugal. 1999. 1999:139.
238 Goldstein J, Mathew N, Rapoport A. The safety and tolerability of Frovatriptan, a selective 5HT1B/1D agonist, used for prophylaxis of menstrually associated migraine. American Academy of Neurology Annual Meeting. 29 March-5 April, 2003. 2003. P06.141.
239 Good PA, Taylor RH, Mortimer MJ. The use of tinted glasses in childhood migraine. Headache. Sep. 1991;31(8):533-6. [pmid: 1960058].
240 Gottschling S, Meyer S, Gribova I, et al. Laser acupuncture in children with headache: a double-blind, randomized, bicenter, placebo-controlled trial. Pain. 2008:405-12. [pmid: 18022318].
241 Gottschling S, Meyer S, Gribova I, et al. Laser acupuncture in children with headache: a double-blind, randomized, bicenter, placebo-controlled trial. Deutsche Zeitschrift fur Akupunktur. 2009:52.
242 Grazzi L, Andrasik F, D'Amico D, et al. Behavioral and pharmacologic treatment of transformed migraine with analgesic overuse: outcome at 3 years. Headache. Jun. 2002;42(6):483-90. [pmid: 12167136].
243 Grazzi L, Bussone G. Effect of biofeedback treatment on sympathetic function in common migraine and tension-type headache. Cephalalgia. Jun. 1993;13(3):197-200. [pmid: 8358778].
244 Grazzi L, Bussone G. Italian experience of electromyographic-biofeedback treatment of episodic common migraine: preliminary results. Headache. Sep. 1993;33(8):439-41. [pmid: 8262785].
245 Grotemeyer KH, Schlake HP, Husstedt IW. Normalization of platelet-reactivity under successful migraine-prophylaxis with metoprolol or flunarizin. Cephalalgia. 1989:435-6.
246 Grotemeyer KH, Schlake HP, Husstedt IW. Etilefrine pivalate vs. dihydroergotamine and flunarizine in prophylactic treatment of migraine in patients with low blood pressure - a randomized double blind study. Cephalalgia. 1989:433-4.
247 Grotemeyer KH, Schlake HP, Husstedt IW. Etilefrine pivalate VS. Dihydroergotamin and flunarizin in prophylactic treatment of migraine in patients with low blood pressure - A randomized double-blind-study. Cephalalgia. 1989:433-4.
248 Gueorguieva I, Nestorov IA, Aarons L, et al. Uncertainty analysis in pharmacokinetics and pharmacodynamics: application to naratriptan. Pharmaceutical Research. Oct. 2005;22(10):1614-26. [pmid: 16180118].
249 Guerrero RO, Cardenas MA, Ocampo AA, et al. Histamine as a therapeutic alternative in migraine prophylaxis: a randomized, placebo-controlled, double-blind study. Headache. Sep. 1999;39(8):576-80. [pmid: 11279974].
250 Guidotti M, Mauri M, Barril, et al. Frovatriptan vs. transdermal oestrogens or naproxen sodium for the prophylaxis of menstrual migraine. Journal of Headache & Pain. Oct. 2007;8(5):283-8. [pmid: 17955167].
251 Guidotti M, Zanasi S, Garagiola U. Pirprofen in the treatment of migraine and episodic headache attacks: a placebo-controlled crossover clinical trial. J Int Med Res. Jan–Feb. 1989;17(1):48-54. [pmid: 2651177].
252 Guyuron B, Kriegler JS, Davis J, et al. Comprehensive surgical treatment of migraine headaches. Plast Reconstr Surg. Jan. 2005;115(1):1-9. [pmid: 15622223].
253 Guyuron B, Tucker T, Kriegler J. Botulinum toxin A and migraine surgery. Plastic & Reconstructive Surgery. Oct. 2003;112(5 Suppl):171S-3S. discussion 4S-6S. [pmid: 14504501].
254 Gysin TZC. Clinical hypnosis therapy/self hypnosis for aspecific and episodic headache or migraine and other defined types of headaches in children and adolescents. Schweizerische Medizinische Wochenschrift Supplementum. 1994:64-6. [pmid: 8073241].
255 Habek D, Habek JC, Barbir A. Using acupuncture to treat premenstrual syndrome. Archives of gynecology and obstetrics. 2002:23-6. [pmid: 12410369].
256 Haddock CK, Rowan AB, Andrasik F, et al. Home-based behavioral treatments for chronic benign headache: a meta-analysis of controlled trials. Cephalalgia. Apr. 1997;17(2):113-8. [pmid: 9137849].
257 Hadjiloizou N, Rakhit R. Frovatriptan, a probable cause of coronary vasoconstriction. International Journal of Clinical Practice. Jul. 2008;62(7):1121-2. [pmid: 18564276].
258 Hagen K, Vatten L, Stovner LJ, et al. Low socio-economic status is associated with increased risk of frequent headache: a prospective study of 22718 adults in Norway. Cephalalgia. Oct. 2002;22(8):672-9. [pmid: 12383064].
259 Hall GC, Brown MM, Mo J, et al. Triptans in migraine: the risks of stroke, cardiovascular disease, and death in practice. Neurology. Feb. 24. 2004;62(4):563-8. [pmid: 14981171].
260 Hansen TM, Hansen B. The effect of aromatherapy on health complaints. A randomised, controlled trial. International Journal of Essential Oil Therapeutics. 2007:67-71.
261 Hardten DR, Hira NK, Lombardo AJ. Triptans and the incidence of epithelial defects during laser in situ keratomileusis. Journal of Refractive Surgery. Jan–Feb. 2005;21(1):72-6. [pmid: 15724687].
262 Harizanov M, Neykova L, Márquez M, et al. Efficacy and safety of dotarizine versus flunarizine in the prophylaxis of migraine. Neurología. 1997:211.
263 Hauge AW, Asghar MS, Schytz HW, et al. Effects of tonabersat on migraine with aura: a randomised, double-blind, placebo-controlled crossover study. Lancet Neurol. Aug. 2009;8(8):718-23. [pmid: 19570717].
264 Havanka-Kanniainen H, Hokkanen E, Myllyla V. Efficacy of nimodipine in comparison with pizotifen (Sandomigrin) in the prophylaxis of migraine. Cephalalgia. 1985:530-31.
265 Havanka-Kanniainen H, Hokkanen E, Myllylä VV. Efficacy of nimodipine in comparison with pizotifen in the prophylaxis of migraine. Cephalalgia: an international journal of headache. 1987:7-13. [pmid: 3555838].
266 Helseth EK, Erickson JC. The prevalence and impact of migraine on US Military officer trainees. Headache. Jun. 2008;48(6):883-9. [pmid: 18005047].
267 Herrmann WM, Kristof M, Sastre M. Preventive treatment of migraine headache with a new isoergolenyl derivative. J Int Med Res. 1978;6(6):476-82. [pmid: 363486].
268 Hershey AD, Powers SW, Vockell A-LB, et al. Coenzyme Q10 deficiency and response to supplementation in pediatric and adolescent migraine. Headache. Jan. 2007;47(1):73-80. [pmid: 17355497].
269 Ho AP, Dahlof CG, Silberstein SD, et al. Randomized, controlled trial of telcagepant over four migraine attacks. Cephalalgia. Dec. 2010;30(12):1443-57. [pmid: 20974601].
270 Hodge JA, Hodge KD. Ischemic colitis related to sumatriptan overuse. Journal of the American Board of Family Medicine: JABFM. Jan–Feb. 2010;23(1):124-7. [pmid: 20051552].
271 Hoffman L, Mayzell G, Pedan A, et al. Evaluation of a monthly coverage maximum (drug-specific quantity limit) on the 5-HT1 agonists (triptans) and dihydroergotamine nasal spray. Journal of Managed Care Pharmacy. Jul–Aug. 2003;9(4):335-45. [pmid: 14613452].
272 Hoivik HO, Laurijssens BE, Harnisch LO, et al. Lack of efficacy of the selective iNOS inhibitor GW274150 in prophylaxis of migraine headache. Cephalalgia. Dec. 2010;30(12):1458-67. [pmid: 20974604].
273 Horga J, Matias-Guiu J, Castillo J, et al. Comparison of dotarizine and pizotifen in prophylactic treatment of migraine - a crossover double blind multicentre study. [abstract]. Journal of Neurology. 1996:S97.
274 Houghton LA, Foster JM, Whorwell PJ, et al. Is chest pain after sumatriptan oesophageal in origin?. Lancet. 1994:985-6. [pmid: 7934431].
275 Hu XH, Ng-Mak D, Cady R. Does early migraine treatment shorten time to headache peak and reduce its severity?. Headache. Jun. 2008;48(6):914-20. [pmid: 18005142].
276 Hubbe P. The prophylactic treatment of migraine with an antiserotonin pizotifen. Acta Neurol Scand. 1973:108-14. [pmid: 4567747].
277 Hudgson P, Foster JB, Newell DJ. Controlled trial of demigran in the prophylaxis of migraine. Br Med J. Apr. 8. 1967;2(5544):91-3. [pmid: 6020856].
278 Hui JS. Migraines. Clinical Neuropharmacology. Nov–Dec. 2001;24(6):307-12. [pmid: 11801805].
279 Humphrey PP. How it started. Cephalalgia. Suppl 1. 2001;21:2-5. [pmid: 11678811].
280 Humphrey PPA. The discovery and development of the triptans, a major therapeutic breakthrough. Headache. May. 2008;48(5):685-7. [pmid: 18471110].
281 Hutchison J. Efficacy of frovatriptan. Headache. Sep. 2007;47(8):1227. [pmid: 17883538].
282 Imai N, Konishi T, Serizawa M, et al. Do the effects of long-term lomerizine administration differ with age?. Intern Med. 2007;46(10):683-4. [pmid: 17527044].
283 Innes GD, Macphail I, Dillon EC, et al. Dexamethasone prevents relapse after emergency department treatment of acute migraine: a randomized clinical trial. CJEM. Apr. 1999;1(1):26-33. [pmid: 17659098].
284 Ishida K, Sato H. Kampo medicines as alternatives for treatment of migraine: six case studies. Complementary Therapies in Clinical Practice. Nov. 2006;12(4):276-80. [pmid: 17030300].
285 Ivers H, McGrath PJ, Purdy RA, et al. Decision making in migraine patients taking sumatriptan: an exploratory study. Headache. Feb. 2000;40(2):129-36. [pmid: 10759912].
286 Iwasaki S, Ushio M, Chihara Y, et al. Migraine-associated vertigo: clinical characteristics of Japanese patients and effect of lomerizine, a calcium channel antagonist. Acta Otolaryngol Suppl. Dec. 2007;(559):45-9. [pmid: 18340570].
287 Jacobs H. A trial of opipramol in the treatment of migraine. Journal of neurology, neurosurgery, and psychiatry. 1972:500-4.
288 Jacobson JA, Call NB, Kasworm EM, et al. Safety and efficacy of topical norfloxacin versus tobramycin in the treatment of external ocular infections. Antimicrob Agents Chemother. Dec. 1988;32(12):1820-4. [pmid: 3072923].
289 Jensen K, Bulow P, Hansen H. Experimental toothclenching in common migraine. Cephalalgia. Dec. 1985;5(4):245-51. [pmid: 4084979].
290 Jeske AH. Migraine drug therapy: dental implications. Texas Dental Journal. Feb. 2006;123(2):190-7. [pmid: 16579506].
291 Jessup B, et al. Autogenic training and hand temperature biofeedback in the treatment of migraine: a preliminary analysis. 1976:22.
292 Johnson N, Fethke C. Postdischarge outcomes and care planning for the elderly hospitalized. McCleland E, Kelly K, Buckwalter K, editors. Continuity of Care. New York. Grune & Stratton. 1985.
293 Johnson RH, Hornabrook RW, Lambie DG. Comparison of mefenamic acid and propranolol with placebo in migraine prophylaxis. Acta neurologica Scandinavica. 1986:490-2. [pmid: 3524092].
294 Joish VN, Cady PS. Effect of sumatriptan on health care resource use among patients with migraine. Managed Care Interface. Jan. 2001;14(1):68-72. [pmid: 11214537].
295 Jurgens TP, Busch V, Schmidt-Wilcke T, et al. Migraine-like headache in intracranial haemorrhage is alleviated by sumatriptan and almotriptan. Cephalalgia. Mar. 2008;28(3):302-4. [pmid: 18201253].
296 Kakisaka Y, Wakusawa K, Haginoya K, et al. Abdominal migraine associated with ecchymosis of the legs and buttocks: does the symptom imply an unknown mechanism of migraine?. Tohoku Journal of Experimental Medicine. 2010;221(1):49-51. [pmid: 20453457].
297 Kallen B, Lygner PE. Delivery outcome in women who used drugs for migraine during pregnancy with special reference to sumatriptan. Headache. Apr. 2001;41(4):351-6. [pmid: 11318881].
298 Kang EH, Park JE, Chung CS, et al. Effect of biofeedback-assisted autogenic training on headache activity and mood states in Korean female migraine patients. J Korean Med Sci. Oct. 2009;24(5):936-40. [pmid: 19794995].
299 Kangasniemi P. Placebo, 1-isopropylnoradrenochrome-5-monosemicarbazono and pizotifen in migraine prophylaxis. Headache. 1979:219-22. [pmid: 156165].
300 Kangasniemi P, Tokola R. Flunarizine in the prophylaxis of migraine patients without aura. Cephalalgia. 1989:425.
301 Kaniecki R. Bringing closure to the triptan grab bag. Headache. Sep. 2002;42(8):838-9. [pmid: 12390656].
302 Karam B, Farah E, Ashoush R, et al. Ergotism precipitated by erythromycin: a rare case of vasospasm. European Journal of Vascular & Endovascular Surgery. Jan. 2000;19(1):96-8. [pmid: 10706847].
303 Katsarava Z, Limmroth V, Finke M, et al. Rates and predictors for relapse in medication overuse headache: a 1-year prospective study. Neurology. May. 27. 2003;60(10):1682-3. [pmid: 12771266].
304 Kaube H, May A, Pfaffenrath V. Sumatriptan. BMJ (Clinical research ed.). 1994:1573-4.
305 Kinnunen E, Erkinjuntti T, Farkkila M, et al. Placebo-controlled double-blind trial of pirprofen and an ergotamine tartrate compound in migraine attacks. Cephalalgia. Sep. 1988;8(3):175-9. [pmid: 3143482].
306 Kjaersgard Rasmussen MJ, Holt Larsen B, Borg L, et al. Tolfenamic acid versus propranolol in the prophylactic treatment of migraine. Acta Neurol Scand. Jun. 1994;89(6):446-50. [pmid: 7976233].
307 Klein AW. Introduction. Botox. Disease-A-Month. May. 2002;48(5):296-8. [pmid: 12195261].
308 Koehler SM, Glaros A. The effect of aspartame on migraine headache. Headache. 1988:10-4. [pmid: 3277925].
309 Kohlenberg RJ, Cahn T. Self-help treatment for migraine headaches: a controlled outcome study. Headache. 1981:196-200. [pmid: 7287417].
310 Kosinski M, Bjorner JB, Ware JE Jr, et al. The responsiveness of headache impact scales scored using 'classical' and 'modern' psychometric methods: a re-analysis of three clinical trials. Quality of Life Research. Dec. 2003;12(8):903-12. [pmid: 14651411].
311 Kothare SV. Efficacy of flunarizine in the prophylaxis of cyclical vomiting syndrome and abdominal migraine. European Journal of Paediatric Neurology. 2005;9(1):23-6. [pmid: 15701563].
312 Kraft CA, Lumley MA, D'Souza PJ, et al. Emotional approach coping and self-efficacy moderate the effects of written emotional disclosure and relaxation training for people with migraine headaches. Br J Health Psychol. Feb. 2008;13(Pt 1):67-71. [pmid: 18230235].
313 Krobot KJ, Kaufman JS, Christensen DB, et al. Accessing a new medication in Germany: a novel approach to assess a health insurance-related barrier. Annals of Epidemiology. Nov. 2005;15(10):756-61. [pmid: 15961317].
314 Krobot KJ, Miller WC, Kaufman JS, et al. The disparity in access to new medication by type of health insurance: lessons from Germany. Medical Care. May. 2004;42(5):487-91. [pmid: 15083110].
315 Krobot KJ, Schroder-Bernhardi D, Pfaffenrath V. Migraine consultation patterns in primary care. Results from the PCAOM study 1994–96. Cephalalgia. Nov. 1999;19(9):831-40. [pmid: 10595294].
316 Kroener-Herwig B, Denecke H. Cognitive-behavioral therapy of pediatric headache: are there differences in efficacy between a therapist-administered group training and a self-help format?. J Psychosom Res. Dec. 2002;53(6):1107-14. [pmid: 12479993].
317 Kroner Herwig B, Diergarten D, Seeger Siewert R. Psychophysiological reactivity of migraine sufferers in conditions of stress and relaxation. J-Psychosom-Res. 1988:483-92. [pmid: 3070015].
318 Kroner-Herwig B, Fritsche G, Brauer H. The physiological stress response and the role of cognitive coping in migraine patients and non-headache controls. J Psychosom Res. Jul. 1993;37(5):467-80. [pmid: 8350289].
319 Krusz JC, Nett R. Naratriptan prevents migraine recurrence after initial relief with sumatriptan. Jns. 2001.
320 Krymchantowski AV, Moreira PF. Out-patient detoxification in chronic migraine: comparison of strategies. Cephalalgia. Dec. 2003;23(10):982-93. [pmid: 14984232].
321 Kutluhan S, Incekara F, Sozen A, et al. Temporary confusion depending on the usage of naratriptan. Journal of Headache & Pain. Dec. 2007;8(6):340-1. [pmid: 18071630].
322 Kwong WJ, Taylor FR, Adelman JU. The effect of early intervention with sumatriptan tablets on migraine-associated productivity loss. Journal of Occupational & Environmental Medicine. Nov. 2005;47(11):1167-73. [pmid: 16282878].
323 Labbe E, Williamson DA. Temperature biofeedback in the treatment of children with migraine headaches. J Pediatr Psychol. 1983:317-26. [pmid: 6668525].
324 Labbe EE. Treatment of childhood migraine with autogenic training and skin temperature biofeedback: a component analysis. Headache. Jan. 1995;35(1):10-3. [pmid: 7868327].
325 Labbe EL, Williamson DA. Treatment of childhood migraine using autogenic feedback training. J Consult Clin Psychol. Dec. 1984;52(6):968-76. [pmid: 6520289].
326 Lake A, Rainey J, Papsdorf JD. Biofeedback and rational-emotive therapy in the management of migraine headache. J Appl Behav Anal. Spring. 1979;12(1):127-40. [pmid: 468745].
327 Lampl C, Buzath A, Baumhackl U, et al. One-year prevalence of migraine in Austria: a nation-wide survey. Cephalalgia. May. 2003;23(4):280-6. [pmid: 12716346].
328 Lampl C, Yazdi K, Buzath A, et al. Migraine-like headache in bacterial meningitis. Cephalalgia. Oct. 2000;20(8):738-9. [pmid: 11167904].
329 Lance JW, Anthony M. Clinical trial of a new serotonin antagonist, BC105, in the prevention of migraine. Med J Aust. Jan. 13. 1968;1(2):54-5. [pmid: 4867512].
330 Landy S, McGinnis J, Curlin D, et al. Selective serotonin reuptake inhibitors for migraine prophylaxis. Headache. Jan. 1999;39(1):28-32. [pmid: 15613191].
331 Landy S, Savani N, Shackelford S, et al. Efficacy and tolerability of sumatriptan tablets administered during the mild-pain phase of menstrually associated migraine. Int J Clin Pract. Oct. 2004;58(10):913-9. [pmid: 15587768].
332 Landy SH, McGinnis JE, McDonald SA. Clarification of developing and established clinical allodynia and pain-free outcomes. Headache. Feb. 2007;47(2):247-52. [pmid: 17300364].
333 Lanfranconi S, Corti S, Bersano A, et al. Aphasic and visual aura with increased vasogenic leakage: an atypical migrainosus status. Journal of the Neurological Sciences. Oct. 15. 2009;285(1–2):227-9. [pmid: 19573879].
334 Lantéri-Minet M, et al. Evaluating patient satisfaction with specific migraine therapy based on initial treatment expectations: the PAX study. Current Medical Research & Opinion. Feb. 2010;26(2):465-72. [pmid: 20001575].
335 LaPorta LD. Relief from migraine headache with aripiprazole treatment. Headache. Jun. 2007;47(6):922-6. [pmid: 17578547].
336 Larsson B, Carlsson J, Fichtel A, et al. Relaxation treatment of adolescent headache sufferers: results from a school-based replication series. Headache. Jun. 2005;45(6):692-704. [pmid: 15953302].
337 Larsson B, Melin L. Chronic headaches in adolescents: treatment in a school setting with relaxation training as compared with information-contact and self-registration. Pain. Jun. 1986;25(3):325-36. [pmid: 3528989].
338 Lassen LH, Jacobsen VB, Haderslev PA, et al. Involvement of calcitonin gene-related peptide in migraine: regional cerebral blood flow and blood flow velocity in migraine patients. J Headache Pain. Jun. 2008;9(3):151-7. [pmid: 18437288].
339 Lawler SP, Cameron LD. A randomized, controlled trial of massage therapy as a treatment for migraine. Ann Behav Med. Aug. 2006;32(1):50-9. [pmid: 16827629].
340 Lawrence ER, Hossain M, Littlestone W. Sanomigran for migraine prophylaxis, controlled multicenter trial in general practice. Headache. 1977:109-12. [pmid: 330465].
341 Levitan BS, Andrews EB, Gilsenan A, et al. Application of the BRAT framework to case studies: observations and insights. Clin Pharmacol Ther. Feb. 2011;89(2):217-24. [pmid: 21178990].
342 Li ZF, Wu ZD, Chen JX, et al. Curative effect observation of fluoxetine used combing with flunarizine in treatment of 86 cases of migraine. Modern Hospital. 2003:33-4.
343 Lidegaard O. Oral contraceptives, pregnancy and the risk of cerebral thromboembolism: the influence of diabetes, hypertension, migraine and previous thrombotic disease. Br J Obstet Gynaecol. Feb. 1995;102(2):153-9. [pmid: 7756208].
344 Liguori A, Petti F, Bangrazi A, et al. Comparison of pharmacological treatment versus acupuncture treatment for migraine without aura--analysis of socio-medical parameters. J Tradit Chin Med. Sep. 2000;20(3):231-40. [pmid: 11038990].
345 Linde M, Mellberg A, Dahl, et al. Subcutaneous sumatriptan provides symptomatic relief at any pain intensity or time during the migraine attack. Cephalalgia. Feb. 2006;26(2):113-21. [pmid: 16426264].
346 Linde M, Mellberg A, Dahlof C. The natural course of migraine attacks. A prospective analysis of untreated attacks compared with attacks treated with a triptan. Cephalalgia. Jun. 2006;26(6):712-21. [pmid: 16686911].
347 Lipton RB, Dodick DW, Adelman JU, et al. Consistency of response to sumatriptan/naproxen sodium in a placebo-controlled, crossover study. Cephalalgia. Aug. 2009;29(8):826-36. [pmid: 19220307].
348 Lipton RB, Gobel H, Einhaupl KM, et al. Petasites hybridus root (butterbur) is an effective preventive treatment for migraine. Neurology. Dec. 28. 2004;63(12):2240-4. [pmid: 15623680].
349 Lipton RB, Stewart WF, Cady R, et al. Sumatriptan for the range of headaches in migraine sufferers: results of the Spectrum Study. (2000 Wolfe Award. ). Headache. 2000:783-91. [pmid: 11135021].
350 Lisotto C, Mainardi F, Maggioni F, et al. Hemicrania continua with contralateral episodic cluster headache: a case report. Cephalalgia. Nov. 2003;23(9):929-30. [pmid: 14616936].
351 Liu JG, Yan PJ, Li YX, et al. Metoclopramide in the treatment of 40 cases of migraine. Herald of Medicine. 2003:88-9.
352 Lofland JH, Locklear JC, Frick KD. Different approaches to valuing the lost productivity of patients with migraine. Pharmacoeconomics. 2001;19(9):917-25. [pmid: 11700778].
353 Loh L, Nathan PW, Schott GD, et al. Acupuncture versus medical treatment for migraine and muscle tension headaches. J Neurol Neurosurg Psychiatry. 1984:333-7. [pmid: 6726258].
354 Lohman JJHM, van der Kuy-de Ree MM, Group of Co-operating Pharmacists S-G, et al. Patterns of specific antimigraine drug use--a study based on the records of 18 community pharmacies. Cephalalgia. Mar. 2005;25(3):214-8. [pmid: 15689197].
355 Low NCP, Du Fort GG, Cervantes P. Prevalence, clinical correlates, and treatment of migraine in bipolar disorder. Headache. Oct. 2003;43(9):940-9. [pmid: 14511270].
356 Lucas C, Auray JP, Gaudin AF, et al. Use and misuse of triptans in France: data from the GRIM2000 population survey. Cephalalgia. Mar. 2004;24(3):197-205. [pmid: 15009013].
357 Lucas C, Géraud G, et al. Recognition and therapeutic management of migraine in 2004, in France: results of FRAMIG 3, a French nationwide population-based survey. Headache. May. 2006;46(5):715-25. [pmid: 16643573].
358 Luciani RJ, Osterhaus JT, Gutterman DL. Patient preferences for migraine therapy: subcutaneous sumatriptan compared with other medications. The Journal of family practice. 1995:147-52. [pmid: 7636454].
359 Ludin HP. A comparative trial with flunarizine and propranolol in migraine. Cephalalgia. 1987:469-70.
360 Lugardon S, Roussel H, Sciortino V, et al. Triptan use and risk of cardiovascular events: a nested-case-control study from the French health system database. European Journal of Clinical Pharmacology. Aug. 2007;63(8):801-7. [pmid: 17576547].
361 Lundberg PO. Prophylactic treatment of migraine with flumedroxone. Acta neurologica Scandinavica. 1969:309-26. [pmid: 5817457].
362 Lynch JJ Jr, Regan CP, Edvinsson L, et al. Comparison of the vasoconstrictor effects of the calcitonin gene-related peptide receptor antagonist telcagepant (MK-0974) and zolmitriptan in human isolated coronary arteries. Journal of Cardiovascular Pharmacology. May. 2010;55(5):518-21. [pmid: 20164785].
363 Maas HJ, Spruit MAH, Danhof M, et al. Relevance of absorption rate and lag time to the onset of action in migraine. Clinical Pharmacokinetics. 2008;47(2):139-46. [pmid: 18193920].
364 MacGregor EA, Brandes JL, Silberstein S, et al. Safety and tolerability of short-term preventive frovatriptan: a combined analysis. Headache. Oct. 2009;49(9):1298-314. [pmid: 19788471].
365 MacGregor EA, Wilkinson M, Bancroft K. Domperidone plus paracetamol in the treatment of migraine. Cephalalgia. Apr. 1993;13(2):124-7. [pmid: 8495454].
366 MacLennan SC, Wade FM, Forrest KM, et al. High-dose riboflavin for migraine prophylaxis in children: a double-blind, randomized, placebo-controlled trial. J Child Neurol. Nov. 2008;23(11):1300-4. [pmid: 18984840].
367 Maizels M, Blumenfeld A, Burchette R. A combination of riboflavin, magnesium, and feverfew for migraine prophylaxis: a randomized trial. Headache. Oct. 2004;44(9):885-90. [pmid: 15447697].
368 Maneyapanda SB, Venkatasubramanian A. Relationship between significant perinatal events and migraine severity. Pediatrics. Oct. 2005;116(4):e555-8. [pmid: 16199683].
369 Mannix LK, Martin VT, Cady RK, et al. Combination treatment for menstrual migraine and dysmenorrhea using sumatriptan-naproxen: two randomized controlled trials. Obstet Gynecol. Jul. 2009;114(1):106-13. [pmid: 19546766].
370 Mannix LK, Savani N, Landy S, et al. Efficacy and tolerability of naratriptan for short-term prevention of menstrually related migraine: data from two randomized, double-blind, placebo-controlled studies. Headache. Jul–Aug. 2007;47(7):1037-49. [pmid: 17635595].
371 Martin PR. How do trigger factors acquire the capacity to precipitate headaches?. Behaviour research and therapy. 2001:545-54. [pmid: 11341251].
372 Martin PR, Nathan PR, Milech D, et al. Cognitive therapy vs. self-management training in the treatment of chronic headaches. The British journal of clinical psychology / the British Psychological Society. 1989:347-61. [pmid: 2605388].
373 Martin VT, Wernke S, Mandell K, et al. Defining the relationship between ovarian hormones and migraine headache. Headache. Oct. 2005;45(9):1190-201. [pmid: 16178949].
374 Martucci N, Manna V, Porto C, et al. Migraine and the noradrenergic control of vasomotricity: a study with alpha-2 stimulant and alpha-2 blocker drugs. Headache. Mar. 1985;25(2):95-100. [pmid: 3886600].
375 Marziniak M, Herzog AL, Mossner R, et al. Investigation of the functional brain-derived neurotrophic factor gene variant Val66MET in migraine. J Neural Transm. Sep. 2008;115(9):1321-5. [pmid: 18478177].
376 Mastrosimone F, Iaccarino C, de Caterina G. Efficacy and tolerance of cyclandelate versus pizotifen in the prophylaxis of migraine. J Med. 1992;23(1):1-16. [pmid: 1573338].
377 Mathew NT. 5-Hydroxytryptophane in the prophylaxis of migraine: a double blind study. Headache. 1978:111.
378 Mathew NT, Kailasam J, Seifert T. Clinical recognition of allodynia in migraine. Neurology. Sep. 14. 2004;63(5):848-52. [pmid: 15365135].
379 Mathew NT, Peykamian M, Laurenza A, et al. Efficacy and tolerability of naratriptan tablets in the treatment of migraine: Results of a double-blind placebo controlled, crossover trial. Journal of the Neurological Sciences. 1997:S35.
380 Matias-Guiu J, Horga J, Asensio M, et al. Comparison of dotarizine and pizotifen in prophilactic treatment of migraine: a crossover double-blind multicentre study. Functional Neurology. 1996:155.
381 Matías-Guiu J, Horga J, Asensio M, et al. Comparison of dotarizine and pizotifen in the prophylaxis treatment of migraine: double-blind, cross-over and multicenter study. Neurología. 1996:379.
382 Mattimoe D, Newton W. High-dose riboflavin for migraine prophylaxis. J Fam Pract. Jul. 1998;47(1):11. [pmid: 9673596].
383 Matts SG. Metoclopramide in the treatment of migraine. The Practitioner. 1974:887-90. [pmid: 4607730].
384 Mattsson P. The name of a drug used for the treatment of migraine. European Journal of Public Health. Jun. 2002;12(2):155. [pmid: 12073756].
385 Mavromichalis I, Zaramboukas T, Giala MM. Migraine of gastrointestinal origin. European journal of pediatrics. 1995:406-10. [pmid: 7641777].
386 Mazzoleni R, Kreisler A, Lucas C, et al. Seizure after use of almotriptan. Clinical Neurology & Neurosurgery. Sep. 2008;110(8):850-1. [pmid: 18599194].
387 Mazzone L, Vitiello B, Incorpora G, et al. Behavioural and temperamental characteristics of children and adolescents suffering from primary headache. Cephalalgia: an international journal of headache. 2006:194-201. [pmid: 16426275].
388 McGrath PJ, Humphreys P, Goodman JT, et al. Relaxation prophylaxis for childhood migraine: a randomized placebo-controlled trial. Dev Med Child Neurol. Oct. 1988;30(5):626-31. [pmid: 3229560].
389 Meckling SK, Becker WJ, Rose MS, et al. Sumatriptan responsiveness and clinical, psychiatric and psychologic features in migraine patients. Canadian Journal of Neurological Sciences. Nov. 2001;28(4):313-8. [pmid: 11766775].
390 Mehrotra S, Vanmolkot KRJ, Frants RR, et al. The phe-124-Cys and A-161T variants of the human 5-HT1B receptor gene are not major determinants of the clinical response to sumatriptan. Headache. May. 2007;47(5):711-6. [pmid: 17501853].
391 Mehvari J, Rafieian-Kopaei M. Prophylactic activity of cyproheptadine and Bellergal on migraine headache. Iranian Journal of Medical Sciences. 2005:84-7.
392 Melchart D, Hager S, Hager U, et al. Treatment of patients with chronic headaches in a hospital for traditional Chinese medicine in Germany. A randomised, waiting list controlled trial. Complementary therapies in medicine. 2004:71-8. [pmid: 15561516].
393 Merelle SY, Sorbi MJ, van Doornen LJ, et al. Lay trainers with migraine for a home-based behavioral training: a 6-month follow-up study. Headache. Oct. 2008;48(9):1311-25. [pmid: 19031498].
394 Merelle SY, Sorbi MJ, van Doornen LJ, et al. Migraine patients as trainers of their fellow patients in non-pharmacological preventive attack management: short-term effects of a randomized controlled trial. Cephalalgia. Feb. 2008;28(2):127-38. [pmid: 18197883].
395 Meskunas CA, Tepper SJ, Rapoport AM, et al. Medications associated with probable medication overuse headache reported in a tertiary care headache center over a 15-year period. Headache. May. 2006;46(5):766-72. [pmid: 16643579].
396 Miano S, Parisi P, Pelliccia A, et al. Melatonin to prevent migraine or tension-type headache in children. Neurol Sci. Sep. 2008;29(4):285-7. [pmid: 18810607].
397 Micieli G, Tassorelli C, Bosone D, et al. Increased cerebral blood flow velocity induced by cold pressor test in migraine: a possible basis for pathogenesis?. Cephalalgia. Dec. 1995;15(6):494-8. [pmid: 8706113].
398 Micieli G, Trucco M, Agostinis C, et al. Nimodipine vs. pizotifen in common migraine: results of a double-blind cross-over trial. Cephalalgia. 1985:532-3.
399 Millan-Guerrero RO, Isais-Millan R, Barreto-Vizcaino S, et al. Subcutaneous histamine versus sodium valproate in migraine prophylaxis: a randomized, controlled, double-blind study. Eur J Neurol. Oct. 2007;14(10):1079-84. [pmid: 17880560].
400 Millan-Guerrero RO, Pineda-Lucatero AG, Hernandez-Benjamin T, et al. Na-methylhistamine safety and efficacy in migraine prophylaxis: Phase I and Phase II studies. Headache. 2003:389-94. [pmid: 12656710].
401 Miranda H, Ortiz G, Figueroa S, et al. Depression scores following migraine treatment in patients attending a specialized center for headache and neurology. Headache. Jul–Aug. 2001;41(7):680-4. [pmid: 11554955].
402 Monro P, Swade C, Coppen A. Double blind comparative study of mianserin vs placebo in the prophylaxis of migraine. Clin Neuropharmacol. 1984;7:654-5.
403 Moore EL, Burgey CS, Paone DV, et al. Examining the binding properties of MK-0974: a CGRP receptor antagonist for the acute treatment of migraine. European Journal of Pharmacology. Jan. 14. 2009;602(2–3):250-4. [pmid: 19084002].
404 Morillo LE, Alarcon F, Aranaga N, et al. Clinical characteristics and patterns of medication use of migraneurs in Latin America from 12 cities in 6 countries. Headache. Feb. 2005;45(2):118-26. [pmid: 15705116].
405 Moschiano F, Allais G, Grazzi L, et al. Naratriptan in the short-term prophylaxis of pure menstrual migraine. Neurol Sci. May. 2005;26(Suppl 2):s162-6. [pmid: 15926020].
406 Muiesan ML, Padovani A, Salvetti M, et al. Headache: Prevalence and relationship with office or ambulatory blood pressure in a general population sample (the Vobarno Study). Blood pressure. 2006:14-9. [pmid: 16492611].
407 Mullally WJ, Hall K, Goldstein R. Efficacy of biofeedback in the treatment of migraine and tension type headaches. Pain Physician. Nov–Dec. 2009;12(6):1005-11. [pmid: 19935987].
408 Munno I, Marinaro M, Bassi A, et al. Immunological aspects in migraine: increase of IL-10 plasma levels during attack. Headache. Sep. 2001;41(8):764-7. [pmid: 11576199].
409 Murphy JJ, Heptinstall S, Mitchell JR. Randomised double-blind placebo-controlled trial of feverfew in migraine prevention. Lancet. Jul. 23. 1988;2(8604):189-92. [pmid: 2899663].
410 Mushet GR, Cady RK, Baker CC, et al. Efficacy and tolerability of subcutaneous sumatriptan administered using the IMITREX STATdose System. Clin Ther. Jul–Aug. 1996;18(4):687-99. [pmid: 8879897].
411 Nagata E, Moriguchi H, Takizawa S, et al. The middle meningial artery during a migraine attack: 3T magnetic resonance angiography study. Internal Medicine. 2009;48(24):2133-5. [pmid: 20009407].
412 Nagy AJ, Gandhi S, Bhola R, et al. Intravenous dihydroergotamine for inpatient management of refractory primary headaches. Neurology. Nov. 15. 2011;77(20):1827-32. [pmid: 22049203].
413 Naik M, Potluri R, Almasri E, et al. Sumatriptan-associated ischemic colitis. Digestive Diseases & Sciences. Sep. 2002;47(9):2015-6. [pmid: 12353847].
414 Nappi G, Sandrini G, Granella F, et al. A new 5-HT2 antagonist (ritanserin) in the treatment of chronic headache with depression. A double-blind study vs amitriptyline. Headache. Jun. 1990;30(7):439-44. [pmid: 2119355].
415 Nappi G, Sandrini G, Savoini G, et al. Comparative efficacy of cyclandelate versus flunarizine in the prophylactic treatment of migraine. Drugs. Suppl 2. 1987;33:103-9. [pmid: 3304950].
416 Nardin R. Randomized, controlled trial of telcagepant for the acute treatment of migraine. Neurology. Mar. 23. 2010;74(12):1007. author reply -8. [pmid: 20308688].
417 Natarajan S, Jabbour JT, Webster CJ, et al. Long-term tolerability of sumatriptan nasal spray in adolescent patients with migraine. Headache. Nov–Dec. 2004;44(10):969-77. [pmid: 15546259].
418 Nattero G, Biale L, Savi L. Lisuride and pizotifen in the treatment of migraine without aura. Cephalalgia. 1991:218-9.
419 Nattero G, Lisino F, Brandi G, et al. Dimethothiazine in the prevention of migraine. Minerva-Med. 1977:839-46. [pmid: 321991].
420 Nett R, Landy S, Shackelford S, et al. Pain-free efficacy after treatment with sumatriptan in the mild pain phase of menstrually associated migraine. Obstet Gynecol. Oct. 2003;102(4):835-42. [pmid: 14551015].
421 Newman L, Mannix LK, Landy S, et al. Naratriptan as short-term prophylaxis of menstrually associated migraine: a randomized, double-blind, placebo-controlled study. Headache. Mar. 2001;41(3):248-56. [pmid: 11264684].
422 Newman LC, Cady RK, Landy S, et al. Treatment satisfaction and efficacy of the rapid release formulation of sumatriptan 100 mg tablets utilising an early intervention paradigm in patients previously unsatisfied with sumatriptan. International Journal of Clinical Practice. Dec. 2008;62(12):1889-99. [pmid: 19166436].
423 Newman LC, Lipton RB, Lay CL, et al. A pilot study of oral sumatriptan as intermittent prophylaxis of menstruation-related migraine. Neurology. Jul. 1998;51(1):307-9. [pmid: 9674831].
424 Nicholson NL, Blanchard EB. A controlled evaluation of behavioral treatment of chronic headache in the elderly. Behav Ther. 1993;24:395-408. PMID.
425 Nickel AK, Hillecke T, Argstatter H, et al. Outcome research in music therapy: a step on the long road to an evidence-based treatment. Ann N Y Acad Sci. Dec. 2005;1060:283-93. [pmid: 16597777].
426 Nicolodi M, Del Bianco PL, Sicuteri F. The way to serotonergic use and abuse in migraine. International journal of clinical pharmacology research. 1997:79-84. [pmid: 9403359].
427 Nicolodi M, Galeotti N, Ghelardini C, et al. Central cholinergic challenging of migraine by testing second-generation anticholinesterase drugs. Headache. Jul–Aug. 2002;42(7):596-602. [pmid: 12482211].
428 Nicolodi M, Sicuteri F. Exploration of NMDA receptors in migraine: therapeutic and theoretic implications. Int J Clin Pharmacol Res. 1995;15(5–6):181-9. [pmid: 8835616].
429 Noronha MJ. Double-blind randomised cross-over trial of timolol in migraine prophylaxis in children. Cephalalgia. 1985:174-5.
430 Nyrke T, Kangasniemi P, Lang AH, et al. Steady-state visual evoked potentials during migraine prophylaxis by propranolol and femoxetine. Acta Neurol Scand. Jan. 1984;69(1):9-14. [pmid: 6608203].
431 Obermann M, Mueller D, Yoon MS, et al. Migraine with isolated facial pain: a diagnostic challenge. Cephalalgia. Nov. 2007;27(11):1278-82. [pmid: 17850354].
432 Oedegaard KJ, Riise T, Dilsaver SC, et al. A pharmaco-epidemiological study of migraine and antidepressant medications: complete one year data from the Norwegian population. J Affect Disord. Mar. 2011;129(1–3):198-204. [pmid: 20889212].
433 Oelkers-Ax R, Leins A, Parzer P, et al. Butterbur root extract and music therapy in the prevention of childhood migraine: an explorative study. Eur J Pain. Apr. 2008;12(3):301-13. [pmid: 17659990].
434 Ohbu S, Igarashi H, Okayasu H, et al. Development and testing of the Japanese version of the migraine-specific quality of life instrument. Quality of Life Research. Oct. 2004;13(8):1489-93. [pmid: 15503844].
435 Olesen C, Steffensen FH, Sorensen HT, et al. Pregnancy outcome following prescription for sumatriptan. Headache. Jan. 2000;40(1):20-4. [pmid: 10759898].
436 Olness K, Hall H, Rozniecki JJ, et al. Mast cell activation in children with migraine before and after training in self-regulation. Headache. Feb. 1999;39(2):101-7. [pmid: 15613202].
437 Olness K, Hall H, Schmidt W, et al. Mast cell activation in child migraine patients before and after training in self regulation. Alternative therapies in health and medicine. 1997:100-1. [pmid: 8997810].
438 Olness K, MacDonald J. Self-hypnosis and biofeedback in the management of juvenile migraine. J Dev Behav Pediatr. Dec. 1981;2(4):168-70. [pmid: 7033294].
439 O'Quinn S, Jhingran P, Pait DG, et al. Relationships between productivity and clinical efficacy measures in a double-blind, placebo-controlled trial of sumatriptan in migraine. [abstract]. Neurology. 1997:A236-7.
440 Orlando LA, Matchar DB. When to stress over triptans: a Markov analysis of cardiovascular risk in migraine treatment. Headache. Jul–Aug. 2004;44(7):652-60. [pmid: 15209686].
441 Osterhaus SO, Passchier J, van der Helm-Hylkema H, et al. Effects of behavioral psychophysiological treatment on schoolchildren with migraine in a nonclinical setting: predictors and process variables. J Pediatr Psychol. Dec. 1993;18(6):697-715. [pmid: 8138865].
442 Osterman PO. A comparison between placebo, pizotifen and 1-isopropyl-3-hydroxy-5-semicarbazono-6-oxo-2.3.5.6-tetrahydroindol (Divascan) in migraine prophylaxis. Acta neurologica Scandinavica. 1977:17-28. [pmid: 327746].
443 Ottman R, Lipton RB. Is the comorbidity of epilepsy and migraine due to a shared genetic susceptibility?. Neurology. Oct. 1996;47(4):918-24. [pmid: 8857719].
444 Palevitch D, Earon G, Carasso R. Feverfew (Tanacetum parthenium) as a prophylactic treatment for migraine: A double-blind placebo-controlled study. Phytotherapy Research. 1997:508-11.
445 Panconesi A, Pavone E, Franchini M, et al. Triptans: low utilization and high turnover in the general population. Cephalalgia. May. 2010;30(5):576-81. [pmid: 19732070].
446 Panconesi A, Pavone E, Vacca F, et al. Triptans in the Italian population: a drug utilization study and a literature review. Journal of Headache & Pain. Apr. 2008;9(2):71-6. [pmid: 18317865].
447 Parker GB, Pryor DS, Tupling H. Why does migraine improve during a clinical trial? Further results from a trial of cervical manipulation for migraine. Aust N Z J Med. Apr. 1980;10(2):192-8. [pmid: 6992760].
448 Pascual J, Cabarrocas X. Within-patient early versus delayed treatment of migraine attacks with almotriptan: the sooner the better. Headache. Jan. 2002;42(1):28-31. [pmid: 12005272].
449 Pascual J, Diener H-C, Massiou H, et al. Value of postmarketing surveillance studies in achieving a complete picture of antimigraine agents: using almotriptan as an example. Journal of Headache & Pain. Feb. 2006;7(1):27-33. [pmid: 16440139].
450 Pascual J, Falk R, Docekal R, et al. Tolerability and efficacy of almotriptan in the long-term treatment of migraine. European Neurology. 2001;45(4):206-13. [pmid: 11385257].
451 Paterna S, Martino SG, Campisi D, et al. Evaluation of the effects of verapamil, flunarizine, diltiazem, nimodipine and placebo for migraine prophylaxis. A double-blind randomized cross-over study. <ORIGINAL> VALUTAZIONE DEGLI EFFETTI INDOTTI DALL'USO DI VERAPAMILE, FLUNARIZINA, DILTIAZEM, NIMODIPINA E PLACEBO NELLA PROFILASSI DELL'EMICRANIA. STUDIO A DOPPIO CIECO RANDOMIZZATO CROSS-OVER. Clin Ter. 1990:119-25. [pmid: 2147612].
452 Paterson C, Zheng Z, Xue C, et al. “Playing their parts”: the experiences of participants in a randomized sham-controlled acupuncture trial. J Altern Complement Med. Mar. 2008;14(2):199-208. [pmid: 18315508].
453 Pelka RB, Jaenicke C, Gruenwald J. Impulse magnetic-field therapy for migraine and other headaches: a double-blind, placebo-controlled study. Adv Ther. May–Jun. 2001;18(3):101-9. [pmid: 11571822].
454 Perego R. Alpiropride: A new antimigraine drug. A multicenter double-blind crossed trial. Folha Medica. 1989:405-7.
455 Peters EW, de Bruijn SFTM. Migraine treated with acyclovir. Headache. Apr. 2005;45(4):396-7. [pmid: 15836587].
456 Pfaffenrath V, Diener HC, Fischer M, et al. The efficacy and safety of Tanacetum parthenium (feverfew) in migraine prophylaxis--a double-blind, multicentre, randomized placebo-controlled dose-response study. Cephalalgia. Sep. 2002;22(7):523-32. [pmid: 12230594].
457 Pfaffenrath V, Rehm M. Migraine in pregnancy: what are the safest treatment options?. Drug Safety. Nov. 1998;19(5):383-8. [pmid: 9825951].
458 Phongphua CH. Feasibility study for a clinical trial of chiropractic care for patients with migraine headaches using different chiropractic techniques. J Chiropr Edu. 1999:75.
459 Pieterse H, Kuster JA, Van Bortel LM. Is the Migraid device an asset in the non-pharmacologic treatment of migraine?. Acta Neurol Belg. Jun. 2007;107(2):40-6. [pmid: 17710839].
460 Pilgrim AJ, Lloyd DK. Migraine. Lancet. Jul. 4. 1992;340(8810):62. [pmid: 1351649].
461 Pini LA, Fabbri L, Di P, et al. Efficacy and safety of sumatriptan 50 mg in patients not responding to standard care, in the treatment of mild to moderate migraine. International Journal of Clinical Pharmacology Research. 1999:57-64. [pmid: 10669900].
462 Pini LA, Ferrari A, Guidetti G, et al. Influence of flunarizine on the altered electronystagmographic (ENG) recordings in migraine. Cephalalgia: an international journal of headache. 1985:173-5. [pmid: 4016930].
463 Pintov S, Lahat E, Alstein M, et al. Acupuncture and the opioid system: implications in management of migraine. Pediatr Neurol. Sep. 1997;17(2):129-33. [pmid: 9367292].
464 Piovesan EJ, Young Blood MR, Kowacs PA, et al. Prevalence of migraine in Noonan syndrome. Cephalalgia. Apr. 2007;27(4):330-5. [pmid: 17376109].
465 Pothmann R. Calcium-antagonist flunarizine vs. low-dose acetylsalicylic acid in childhood migraine: a double-blind study. Cephalalgia. 1985:385-56.
466 Pothmann R, Danesch U. Migraine prevention in children and adolescents: results of an open study with a special butterbur root extract. Headache. Mar. 2005;45(3):196-203. [pmid: 15836592].
467 Powers C, Szeto S, Pangtay D, et al. Evaluation of migraineurs' preferences for naratriptan over conventional first-line agents. Archives of Family Medicine. Aug. 2000;9(8):753-8. [pmid: 10927717].
468 Pradalier A, Bakouche P, Baudesson G, et al. Failure of omega-3 polyunsaturated fatty acids in prevention of migraine: a double-blind study versus placebo. Cephalalgia. Oct. 2001;21(8):818-22. [pmid: 11737007].
469 Pradalier A, Lutz G, Vincent D. Transient global amnesia, migraine, thalamic infarct, dihydroergotamine, and sumatriptan. Headache. Apr. 2000;40(4):324-7. [pmid: 10759939].
470 Presthus J. BC 105 and methysergide (Deseril) in migraine prophylaxis. Acta neurologica Scandinavica. 1971:514-8. [pmid: 4941732].
471 Prisinzano T, Law H, Dukat M, et al. Imidazoline-modified benzylimidazolines as h5-HT(1D/1B) serotonergic ligands. Bioorganic & Medicinal Chemistry. Mar. 2001;9(3):613-9. [pmid: 11310595].
472 Putnam GP, O'Quinn S, Bolden-Watson CP, et al. Migraine polypharmacy and the tolerability of sumatriptan: a large-scale, prospective study. Cephalalgia. Sep. 1999;19(7):668-75. [pmid: 10524661].
473 Rahimtoola H, Buurma H, Tijssen CC, et al. Reduction in the therapeutic intensity of abortive migraine drug use during ACE inhibition therapy--a pilot study. Pharmacoepidemiology & Drug Safety. Jan. 2004;13(1):41-7. [pmid: 14971122].
474 Rahimtoola H, Buurma H, Tijssen CC, et al. Single use of sumatriptan: a patient interview study. Headache. Feb. 2003;43(2):109-16. [pmid: 12558764].
475 Rahimtoola H, Egberts AC, Buurma H, et al. Patterns of ergotamine and sumatriptan use in the Netherlands from 1991 to 1997. Cephalalgia. Jun. 2001;21(5):596-603. [pmid: 11472386].
476 Rahimtoola H, Egberts AC, Buurma H, et al. Reduction in the intensity of abortive migraine drug use during coumarin therapy. Headache. Sep. 2001;41(8):768-73. [pmid: 11576200].
477 Rand MK, White RG. Behavioral self-management: An application to the problem of migraine headaches. Behav-Ther. 1977:213-21.
478 Rapoport AM, Sheftell FD, Tepper SJ, et al. Levetiracetam in the preventive treatment of transformed migraine: a prospective, open-label, pilot study. Current therapeutic research. 2005;66(3):212-21. PMID. [pmid: 24672124].
479 Rapoport AM, Visser WH, Cutler NR, et al. Oral sumatriptan in preventing headache recurrence after treatment of migraine attacks with subcutaneous sumatriptan. Neurology. Aug. 1995;45(8):1505-9. [pmid: 7644049].
480 Rascol A, Montastruc JL, Rascol O. Flunarizine versus pizotifen: a double blind study in the prophylaxis of migraine. Cephalalgia. 1985:542.
481 Rascol A, Montastruc JL, Rascol O. Flunarizine versus pizotifen: a double-blind study in the prophylaxis of migraine. Headache. Feb. 1986;26(2):83-5. [pmid: 3514549].
482 Rasmussen BK, Olesen J. Migraine with aura and migraine without aura: an epidemiological study. Cephalalgia. Aug. 1992;12(4):221-8. discussion 186. [pmid: 1525797].
483 Ravindran MK, Zheng Y, Timbol C, et al. Migraine headaches in chronic fatigue syndrome (CFS): comparison of two prospective cross-sectional studies. BMC Neurol. 2011;11:30. [pmid: 21375763].
484 Reisman M. Evaluate safety/effectiveness of PFO closure with the STARFlex system to resolve refractory migraine with aura. ClinicalTrials.gov. 2006.
485 Repaka A, Wenger J, Sitaraman SV. A case of sumatriptan-induced intestinal ischemia. Journal of Gastroenterology. Feb. 2006;41(2):177-8. [pmid: 16568377].
486 Riadh H, Mohamed G, Salah Y, et al. Pediatric case of ophthalmoplegic migraine with recurrent oculomotor nerve palsy. Canadian Journal of Ophthalmology. Dec. 2010;45(6):643. [pmid: 21135898].
487 Richardson GM, McGrath PJ. Cognitive-behavioral therapy for migraine headaches: a minimal-therapist-contact approach versus a clinic-based approach. Headache. Jun. 1989;29(6):352-7. [pmid: 2759842].
488 Richter IL, McGrath PJ, Humphreys PJ, et al. Cognitive and relaxation treatment of paediatric migraine. Pain. 1986:195-203. [pmid: 3523394].
489 Ringel G, Taubert K. The efficacy of transcutaneous electrical nerve stimulation with migraine. Zeitschrift Physiotherapie. 1991:8-11.
490 Robbins L. Triptans versus analgesics. Headache. Oct. 2002;42(9):903-7. [pmid: 12390618].
491 Robbins L. Frequent triptan use: observations on safety issues. Headache. Feb. 2004;44(2):178-82. [pmid: 14756859].
492 Roebuck-Spencer T, Sun W, Cernich AN, et al. Assessing change with the Automated Neuropsychological Assessment Metrics (ANAM): issues and challenges. Archives of Clinical Neuropsychology. Feb. Suppl 1. 2007;22:S79-87. [pmid: 17118623].
493 Roon KI, Soons PA, Uitendaal MP, et al. Pharmacokinetic profile of alniditan nasal spray during and outside migraine attacks. Br J Clin Pharmacol. Mar. 1999;47(3):285-90. [pmid: 10215753].
494 Rothner A, Edwards K, Kerr L, et al. Efficacy and safety of Naratriptan Tablets in adolsecent migraine. Journal of the Neurological Sciences. 1997.
495 Rothrock J, Lopez I, Zweilfer R, et al. Borderline personality disorder and migraine. Headache. Jan. 2007;47(1):22-6. [pmid: 17355490].
496 Rothrock JF. The price of pain. Headache. Jun. 2006;46(6):1011. [pmid: 16732848].
497 Rothrock JF, Morey V. "Mixing triptans": patient satisfaction. Headache. Jan. 2011;51(1):135-40. [pmid: 21198574].
498 Rozen TD, Oshinsky ML, Gebeline CA, et al. Open label trial of coenzyme Q10 as a migraine preventive. Cephalalgia. Mar. 2002;22(2):137-41. [pmid: 11972582].
499 Ryan JRE. A clinical study of tyramine as an etiological factor in migraine. Headache. 1974:43-8. [pmid: 4599015].
500 Saberi A, Esmaeelzadeh K, Ghayeghran AR, et al. Assessment the effectiveness of omega 3 on migraine headache severity in magraineurs. Jornal of Neurology. 2010:S61. Abstract no: P190.
501 Safar HA, Alanezi KH, Cin, et al. Successful treatment of threatening limb loss ischemia of the upper limb caused by ergotamine. A case report and review of the literature. Journal of Cardiovascular Surgery. Apr. 2002;43(2):245-9. [pmid: 11887064].
502 Saiers J, Jones M, Kane K, et al. Naratriptan tablets 2.5 Mg exhibit prolonged action and are well-tolerated in non-severe migraine attacks: data from a comparator study with sumatriptan. European Journal of Neurology (Abstracts of the 4th Congress of the European Federation of Neurological Sciences). September 7–11. Lisbon, Portugal. 1999. 1999:105.
503 Salfield SA, Wardley BL, Houlsby WT, et al. Controlled study of exclusion of dietary vasoactive amines in migraine. Arch Dis Child. May. 1987;62(5):458-60. [pmid: 3038036].
504 Salmon M. Pizotifen (BC.105. Sanomigran) in the prophylaxis of childhood migraine. Cephalalgia. 1985;5(Suppl 3):178. PMID.
505 Salonen R. The sumatriptan difference. Cephalalgia. Suppl 1. 2001;21:18-20. [pmid: 11678816].
506 Sandor PS, Di Clemente L, Coppola G, et al. Efficacy of coenzyme Q10 in migraine prophylaxis: a randomized controlled trial. Neurology. Feb. 22. 2005;64(4):713-5. [pmid: 15728298].
507 Sandrini G, Savoini G, Cavallini A, et al. Efficacy of cyclandelate in migraine prophylaxis. Cephalalgia. 1987:481-2.
508 Santucci M, Cortelli P, Rossi PG, et al. L-5-hydroxytryptophan versus placebo in childhood migraine prophylaxis: a double-blind crossover study. Cephalalgia: an international journal of headache. 1986:155-7. [pmid: 3533271].
509 Saper J, Goadsby P, Dodick D, et al. Occipital nerve stiulation (ONS) for treatment of intractable chronic migraine (ICM): 3-month results from the ONSTIM feasibility study. Neurology. 2009;72:A252. Abstract no: IN4-2.005.
510 Saper JR, Lake AE, Tepper SJ. Nefazodone for chronic daily headache prophylaxis: an open-label study. Headache. May. 2001;41(5):465-74. [pmid: 11380644].
511 Sarens T, Herroelen L, Van Deyk K, et al. Patent foramen ovale closure and migraine: are we following the wrong pathway?. J Neurol. Jan. 2009;256(1):143-4. [pmid: 19172218].
512 Savani N, Martin A, Browning D. Switching patients with migraine from sumatriptan to other triptans increases primary care costs. International Journal of Clinical Practice. Aug. 2004;58(8):758-63. [pmid: 15372848].
513 Schabert E, Crow WT. Impact of osteopathic manipulative treatment on cost of care for patients with migraine headache: a retrospective review of patient records. Journal of the American Osteopathic Association. Aug. 2009;109(8):403-7. [pmid: 19706829].
514 Scharff L, Marcus DA, Masek BJ. A controlled study of minimal-contact thermal biofeedback treatment in children with migraine. J Pediatr Psychol. Mar. 2002;27(2):109-19. [pmid: 11821495].
515 Schellenberg R, Schwarz A, Niederberger U, et al. Long-time efficacy of cyclandelate and propranolol in prophylaxis of migraine following four months of treatment. <ORIGINAL> ZUR LANGZEITWIRKUNG VON CYCLANDELAT UND PROPRANOLOL BEI MIGRANE NACH BEENDIGUNG EINER VIERMONATIGEN MEDIKAMENTOSEN PROPHYLAXE. Nervenheilkunde. 1997:183-7.
516 Schellenberg R, Scwarz A, Neiderberger U, et al. 1-year-follow-up effects after migraine prophylaxis with cyclandelate and propanolol. Functional Neurology. 1996:155.
517 Scher AI, Stewart WF, Liberman J, et al. Prevalence of frequent headache in a population sample. Headache. 1998:497-506. [pmid: 15613165].
518 Schmidt R, Oestreich W. Flunarizine in migraine prophylaxis: the clinical experience. Journal of Cardiovascular Pharmacology. Suppl 8. 1991;18:S21-6. [pmid: 1726732].
519 Schoenen J, Coppola G. Headache: spreading from molecules to patients. Lancet Neurology. Jan. 2010;9(1):11-2. [pmid: 20083026].
520 Schoenen J, De Klippel N, Giurgea S, et al. Almotriptan and its combination with aceclofenac for migraine attacks: a study of efficacy and the influence of auto-evaluated brush allodynia. Cephalalgia. Oct. 2008;28(10):1095-105. [pmid: 18644036].
521 Schoenen J, Jacquy J, Lenaerts M. High-dose riboflavin is effective in migraine prophylaxis: results from a double-blind, randomised, placebo-controlled trial. [abstract]. Neurology. 1997:A86-7.
522 Schoenen J, Jacquy J, Lenaerts M. Effectiveness of high-dose riboflavin in migraine prophylaxis. A randomized controlled trial. Neurology. Feb. 1998;50(2):466-70. [pmid: 9484373].
523 Schoonman GG, van der Grond J, Kortmann C, et al. Migraine headache is not associated with cerebral or meningeal vasodilatation--a 3T magnetic resonance angiography study. Brain. Aug. 2008;131(Pt 8):2192-200. [pmid: 18502781].
524 Schulman EA, Cady RK, Henry D, et al. Effectiveness of sumatriptan in reducing productivity loss due to migraine: results of a randomized, double-blind, placebo-controlled clinical trial. Mayo Clin Proc. Aug. 2000;75(8):782-9. [pmid: 10943230].
525 Schwartz TH, Karpitskiy VV, Sohn RS. Intravenous valproate sodium in the treatment of daily headache. Headache. Jun. 2002;42(6):519-22. [pmid: 12167141].
526 Schwerzmann M, Wiher S, Nedeltchev K, et al. Percutaneous closure of patent foramen ovale reduces the frequency of migraine attacks. Neurology. Apr. 27. 2004;62(8):1399-401. [pmid: 15111681].
527 Sedighi B, Ghaderi-Sohi S, Emami S. Evaluation of self-medication prevalence, diagnosis and prescription in migraine in Kerman, Iran. Saudi Medical Journal. Mar. 2006;27(3):377-80. [pmid: 16532101].
528 Shankland WE. Nociceptive trigeminal inhibition--tension suppression system: a method of preventing migraine and tension headaches. Compend Contin Educ Dent. Dec. 2001;22(12):1075-80. 82. quiz 84. [pmid: 11887670].
529 Shankland WE 2nd. Migraine and tension-type headache reduction through pericranial muscular suppression: a preliminary report. Cranio. Oct. 2001;19(4):269-78. [pmid: 11725851].
530 Shepherd AJ. Increased visual after-effects following pattern adaptation in migraine: a lack of intracortical excitation?. Brain. Nov. 2001;124(Pt 11):2310-8. [pmid: 11673331].
531 Sherman RA, Acosta NM, Robson L. Treatment of migraine with pulsing electromagnetic fields: a double-blind, placebo-controlled study. Headache. Sep. 1999;39(8):567-75. [pmid: 11279973].
532 Sherman RA, Robson L, Marden LA. Initial exploration of pulsing electromagnetic fields for treatment of migraine. Headache. Mar. 1998;38(3):208-13. [pmid: 9563212].
533 Shrivastava R, Pechadre JC, John GW. Tanacetum parthenium and Salix alba (Mig-RL) combination in migraine prophylaxis: a prospective, open-label study. Clin Drug Investig. 2006;26(5):287-96. [pmid: 17163262].
534 Shuhaiber S, Pastuszak A, Schick B, et al. Pregnancy outcome following first trimester exposure to sumatriptan. Neurology. Aug. 1998;51(2):581-3. [pmid: 9710039].
535 Sicuteri F. Prophylactic and therapeutic properties of 1-methyl-lysergic acid butanolamide in migraine. Int Arch Allergy Appl Immunol. 1959:300-7. [pmid: 14446408].
536 Sicuteri F. The ingestion of serotonin precursors (L-5-hydroxytryptophan and L-tryptophan) improves migraine headache. Headache. 1973:19-22. [pmid: 4540474].
537 Siegel SJ, O'Neill C, Dube LM, et al. A unique iontophoretic patch for optimal transdermal delivery of sumatriptan. Pharm Res. Oct. 2007;24(10):1919-26. [pmid: 17577644].
538 Silberstein S, Elkind A, Schreiber C. Frovatriptan, a selective 5HT1B/1D Agonist, is effective for prophylaxis of menstrually associated migraine. American Academy of Neurology Annual Meeting. 29 March-5 April, 2003. 2003. S15.004.
539 Silberstein SD, Berner T, Tobin J, et al. Scheduled short-term prevention with frovatriptan for migraine occurring exclusively in association with menstruation. Headache. Oct. 2009;49(9):1283-97. [pmid: 19751371].
540 Silberstein SD, Elkind AH, Schreiber C, et al. A randomized trial of frovatriptan for the intermittent prevention of menstrual migraine. Neurology. Jul. 27. 2004;63(2):261-9. [pmid: 15277618].
541 Silberstein SD, Young WB, Hopkins MM, et al. Dihydroergotamine for early and late treatment of migraine with cutaneous allodynia: an open-label pilot trial. Headache. Jun. 2007;47(6):878-85. [pmid: 17578539].
542 Silcocks P, Whitham D, Whitehouse WP. P3MC: a double blind parallel group randomised placebo controlled trial of Propranolol and Pizotifen in preventing migraine in children. Trials. 2010;11:71. [pmid: 20553601].
543 Sillanpää M, Koponen M. Papaverine in the prophylaxis of migraine and other vascular headache in children. Acta paediatrica Scandinavica. 1978:209-12. [pmid: 343489].
544 Siniatchkin M, Gerber WD, Vein A. Clinical efficacy and central mechanisms of cyclandelate in migraine: a double-blind placebo-controlled study. Funct Neurol. Jan–Mar. 1998;13(1):47-56. [pmid: 9584874].
545 Smith M, Cros D, Sheen V. Hyperperfusion with vasogenic leakage by fMRI in migraine with prolonged aura. Neurology. Apr. 23. 2002;58(8):1308-10. [pmid: 11971111].
546 Smith T, Blumenthal H, Diamond M, et al. Sumatriptan/Naproxen sodium for migraine: efficacy, health related quality of life, and satisfaction outcomes. Headache. May. 2007;47(5):683-92. [pmid: 17501849].
547 Society NNAM. Estrogen and progestogen use in postmenopausal women: 2010 position statement of The North American Menopause Society. Menopause. 2010;27(2):242-55. PMID.
548 Solomon S. The hazards of medication refills by telephone. Headache. Sep. 2002;42(8):835. [pmid: 12390654].
549 Somerville BW, Herrmann WM. Migraine prophylaxis with Lisuride hydrogen maleate--a double blind study of Lisuride versus placebo. Headache. May. 1978;18(2):75-9. [pmid: 348647].
550 Soon YY, Siow HC, Tan CY. Assessment of migraineurs referred to a specialist headache clinic in Singapore: diagnosis, treatment strategies, outcomes, knowledge of migraine treatments and satisfaction. Cephalalgia: an international journal of headache. 2005:1122-32. [pmid: 16305601].
551 Sorbi M, Tellegen B. Differential effects of training in relaxation and stress-coping in patients with migraine. Headache. 1986:473-81. [pmid: 3536801].
552 Sorbi M, Tellegen B, Du Long A. Long-term effects of training in relaxation and stress-coping in patients with migraine: a 3-year follow-up. Headache. 1989:111-21. [pmid: 2651355].
553 Sorensen PS. Prophylactic effect of flunarizine versus metoprolol in migraine. Cephalalgia. 1989:355-6.
554 Sorensen PS, Hansen K, Olesen J. Flunarizine in common migraine prophylaxis, a double-blind cross-over study. Cephalalgia. 1985;5:540-1.
555 Sorge F, De Simone R, Marano E, et al. Efficacy of flunarizine in the prophylaxis if migraine in children: a double-blind, cross-over, controlled study. Cephalalgia. 1985:174.
556 Soyka D, Oestreich W. Therapeutic effectiveness of flunarizine and propranolol in the interval therapy of migraine. Cephalalgia. 1987;7:467-8.
557 Soyka D, Oestreich W. Flunarizine versus propranolol in interval treatment of migraine. Nervenheilkunde. 1990:45-51.
558 Spigt MG, Kuijper EC, Schayck CP, et al. Increasing the daily water intake for the prophylactic treatment of headache: a pilot trial. European journal of neurology : the official journal of the European Federation of Neurological Societies. 2005:715-8.
559 Standal JE. Pizotifen as an antidepressant. Acta psychiatrica Scandinavica. 1977:276-9. [pmid: 335788].
560 Stead M, Josephs KA. Successful treatment of status migrainosus after electroconvulsive therapy with dihydroergotamine. Headache. Apr. 2005;45(4):378-80. [pmid: 15836577].
561 Stensrud P, Sjaastad O. Clonazepam (rivotril) in migraine prophylaxis. Headache. Sep. 1979;19(6):333-4. [pmid: 511533].
562 Stensrud P, Skaug OE, Sjaastad O. Clinical trial of MY-25 (1-methyl-ergotamine-bitartrate) in migraine prophylaxis. Headache. 1971:128-31. [pmid: 4940168].
563 Stone K. NerveCenter: Sumatriptan's evolution from brand drug to best buy of 2010. Annals of Neurology. Sep. 2010;68(3):A10-1. [pmid: 20818778].
564 Stout MA. Homeostatic reconditioning in stress-related disorders: A preliminary study of migraine headaches. Psychotherapy. 1985:531-41.
565 Stovner LJ, Hagen K, Waage A, et al. Hereditary haemochromatosis in two cousins with cluster headache. Cephalalgia. May. 2002;22(4):317-9. [pmid: 12100096].
566 Straumsheim P, Borchgrevink C, Mowinckel P, et al. Homeopathic treatment of migraine: a double blind, placebo controlled trial of 68 patients. [see comment]. Br Homeopath J. Jan. 2000;89(1):4-7. [pmid: 10703903].
567 Straumsheim PA, Borchgrevink C, Mowinckel P, et al. Homoeopathic treatment of migraine. A double-blind placebo controlled trial of 68 patients. Dynamis. 1997.
568 Strom L, Pettersson R, Andersson G. A controlled trial of self-help treatment of recurrent headache conducted via the Internet. J Consult Clin Psychol. Aug. 2000;68(4):722-7. [pmid: 10965647].
569 Stronks DL, Tulen JH, Verheij R, et al. Serotonergic, catecholaminergic, and cardiovascular reactions to mental stress in female migraine patients. A controlled study. Headache. Apr. 1998;38(4):270-80. [pmid: 9595866].
570 Sulman FG, Pfeifer Y, Superstine E. Preventive treatment of migraine with enzyme induction by proxibarbal in a "double-blind" trial. Headache. 1980:269-73. [pmid: 6108941].
571 Symon DN, Russell G. Double blind placebo controlled trial of pizotifen syrup in the treatment of abdominal migraine. Arch Dis Child. Jan. 1995;72(1):48-50. [pmid: 7717738].
572 Tassorelli C, Cavallini A, Iannacchero R, et al. Treatment and prophylaxis of migraine-type headache: Effectiveness of indomethacin-caffeine-prochlorperazine (Difmetre). A double-blind controlled trial comparing indomethacin alone. Clin Trials J. 1989:345-55.
573 Teixido M, Seymour P, Kung B, et al. Otalgia associated with migraine. Otol Neurotol. Feb. 2011;32(2):322-5. [pmid: 21178808].
574 Tfelt-Hansen P, Daugaard D, Lassen LH, et al. Prednisolone reduces nitric oxide-induced migraine. Eur J Neurol. Oct. 2009;16(10):1106-11. [pmid: 19614965].
575 Tfelt-Hansen P, Steiner TJ. Sumatriptin vs dihydroergotamine: patient preference. International Journal of Clinical Practice. Mar. 2001;55(2):151. [pmid: 11321860].
576 Theeler BJ, Mercer R, Erickson JC. Prevalence and impact of migraine among US Army soldiers deployed in support of Operation Iraqi Freedom. Headache. Jun. 2008;48(6):876-82. [pmid: 18549370].
577 Thomaides T, Karapanayiotides T, Kerezoudi E, et al. Intravenous valproate aborts glyceryl trinitrate-induced migraine attacks: a clinical and quantitative EEG study. Cephalalgia. Mar. 2008;28(3):250-6. [pmid: 18201252].
578 Thompson CA. Frovatriptan approved as migraine treatment. American Journal of Health-System Pharmacy. Jan. 15. 2002;59(2):116. [pmid: 11826560].
579 Titus F, Davalos A, Alom J, et al. 5-Hydroxytryptophan versus methysergide in the prophylaxis of migraine. Randomized clinical trial. Eur Neurol. 1986;25(5):327-9. [pmid: 3536521].
580 Tokola RA, Anttila VJ, Neuvonen PJ. The effect of metoclopramide on the absorption of tolfenamic acid. International journal of clinical pharmacology, therapy, and toxicology. 1982:465-8.
581 Tokola RA, Neuvonen PJ. Effects of migraine attack and metoclopramide on the absorption of tolfenamic acid. Br J Clin Pharmacol. 1984:67-75. [pmid: 6691890].
582 Tomita M, Suzuki N, Igarashi H, et al. Evidence against strong correlation between chest symptoms and ischemic coronary changes after subcutaneous sumatriptan injection. Internal Medicine. Aug. 2002;41(8):622-5. [pmid: 12211529].
583 Torelli P, Cologno D, Manzoni GC. Weekend headache: a retrospective study in migraine without aura and episodic tension-type headache. Headache. Jan. 1999;39(1):11-20. [pmid: 15613189].
584 Torgovnick J, Sethi NK, Arsura E. Consistency of response to sumatriptan/naproxen sodium in a placebo-controlled cross-over study. Cephalalgia. Oct. 2010;30(10):1277. author reply -9. [pmid: 20855373].
585 Trentman TL, Rosenfeld DM, Vargas BB, et al. Greater occipital nerve stimulation via the Bion microstimulator: implantation technique and stimulation parameters. Clinical trial: NCT00205894. Pain Physician. May–Jun. 2009;12(3):621-8. [pmid: 19461827].
586 Trinka E, Unterrainer J, Luthringshausen G, et al. An auditory electrophysiological intervention in migraine: A randomized placebo controlled add on trial. Journal of Neurotherapy. 2002:21-30.
587 Trucco M, Meineri P, Ruiz L, et al. Preliminary results of a withdrawal and detoxification therapeutic regimen in patients with probable chronic migraine and probable medication overuse headache. Journal of Headache & Pain. Sep. 2005;6(4):334-7. [pmid: 16362704].
588 Tuchin P. The Effect of Spinal Manipulative Therapy (SMT) on the Cervical Spine for Migraine With Aura. A Randomised Control Trial. Australasian Chiropractic & Osteopathy. 1997:96-7.
589 Tuchin PJ. The Efficacy of Chiropractic Spinal Manipulative Therapy (SMT) in the Treatment of Migraine. A Pilot Study. Australasian Chiropractic & Osteopathy. 1997:41-7. [pmid: 17987148].
590 Tuchin PJ. A Twelve Month Clinical Trial of Chiropractic Spinal Manipulative Therapy for Migraine. Australasian Chiropractic & Osteopathy. 1999:61-5. [pmid: 17987194].
591 Tulen JH, Stronks DL, Bussmann JB, et al. Towards an objective quantitative assessment of daily functioning in migraine: a feasibility study. Pain. May. 2000;86(1–2):139-49. [pmid: 10779671].
592 Turin A, Johnson WG. Biofeedback therapy for migraine headaches. Arch Gen Psychiatry. Apr. 1976;33(4):517-9. [pmid: 938188].
593 Ueberall M. Sumatriptan in paediatric and adolescent migraine. Cephalalgia. Suppl 1. 2001;21:21-4. [pmid: 11678817].
594 van der Kuy PHM, Merkus FWHM, Lohman JJHM, et al. Hydroxocobalamin, a nitric oxide scavenger, in the prophylaxis of migraine: an open, pilot study. Cephalalgia. Sep. 2002;22(7):513-9. [pmid: 12230592].
595 Velentgas P, Cole JA, Mo J, et al. Severe vascular events in migraine patients. Headache. Jul–Aug. 2004;44(7):642-51. [pmid: 15209685].
596 Verspeelt J, De Locht P, Amery WK. Post-marketing cohort study comparing the safety and efficacy of flunarizine and propranolol in the prophylaxis of migraine. Cephalalgia. Aug. 1996;16(5):328-36. discussion 288. [pmid: 8869768].
597 Vickers A, Rees R, Zollman C, et al. Acupuncture for migraine and headache in primary care: A protocol for a pragmatic, randomized trial. Complementary Therapies in Medicine. 1999:3-18. [pmid: 10361566].
598 Vickers AJ, McCarney R. Use of a single global assessment to reduce missing data in a clinical trial with follow-up at one year. Control Clin Trials. Dec. 2003;24(6):731-5. [pmid: 14662279].
599 Vickers AJ, Rees RW, Zollman CE, et al. Acupuncture for chronic headache in primary care: large, pragmatic, randomised trial. BMJ. Mar. 27. 2004;328(7442):744. [pmid: 15023828].
600 Vieira JP, et al. Ophthalmoplegic migraine and infundibular dilatation of a cerebral artery. Headache. Oct. 2008;48(9):1372-4. [pmid: 18631189].
601 Vilming S, Standnes B, Hedman C. Metoprolol and pizotifen in the prophylactic treatment of classical and common migraine A double-blind investigation. Cephalalgia: an international journal of headache. 1985:17-23. [pmid: 3986895].
602 Vincent CA. A controlled trial of the treatment of migraine by acupuncture. Clin J Pain. Dec. 1989;5(4):305-12. [pmid: 2520420].
603 Visser EJ. Is migraine a complex regional pain syndrome of the brain? Migraine prophylaxis with vitamin C?. Pain Pract. Mar. 2011;11(2):199-200. [pmid: 21371256].
604 Visudtibhan A, Lusawat A, Chiemchanya S, et al. Flunarizine for prophylactic treatment of childhood migraine. Journal of the Medical Association of Thailand. Dec. 2004;87(12):1466-70. [pmid: 15822542].
605 Vogler BK, Pittler MH, Ernst E. Feverfew as a preventive treatment for migraine: a systematic review. Cephalalgia. Dec. 1998;18(10):704-8. [pmid: 9950629].
606 Vonderheid-Guth B, Todorova A, Wedekind W, et al. Evidence for neuronal dysfunction in migraine: concurrence between specific qEEG findings and clinical drug response--a retrospective analysis. European Journal of Medical Research. Nov. 30. 2000;5(11):473-83. [pmid: 11121368].
607 Vos J, Passchier J. Reduced impact of migraine in everyday life: an observational study in the Dutch Society of Headache Patients. Headache. Jun. 2003;43(6):645-50. [pmid: 12786925].
608 Wachholtz AB, Pargament KI. Migraines and meditation: does spirituality matter?. J Behav Med. Aug. 2008;31(4):351-66. [pmid: 18551362].
609 Waelkens J. Domperidone in the prevention of complete classical migraine. Br Med J (Clin Res Ed). Mar. 27. 1982;284(6320):944. [pmid: 6802362].
610 Waelkens J. Dopamine blockade with domperidone: bridge between prophylactic and abortive treatment of migraine? A dose-finding study. Cephalalgia. Jun. 1984;4(2):85-90. [pmid: 6375874].
611 Wainscott G, Sullivan FM, Volans GN, et al. The outcome of pregnancy in women suffering from migraine. Postgrad Med J. Feb. 1978;54(628):98-102. [pmid: 634879].
612 Walach H, Lowes T, Mussbach D, et al. The long-term effects of homeopathic treatment of chronic headaches: 1 Year follow up. Cephalalgia. 2000:835-7. [pmid: 11167914].
613 Walker JE. QEEG-guided neurofeedback for recurrent migraine headaches. Clinical EEG and neuroscience : official journal of the EEG and Clinical Neuroscience Society (ENCS). 2011:59-61.
614 Walling A, Woolley DC, Molgaard C, et al. Do family physicians fail to provide triptans for patients with migraine?. Journal of Family Practice. Dec. 2006;55(12):1057-62. [pmid: 17137542].
615 Wammes-van der Heijden EA, Rahimtoola H, Leufkens HGM, et al. Risk of ischemic complications related to the intensity of triptan and ergotamine use. Neurology. Oct. 10. 2006;67(7):1128-34. [pmid: 17030745].
616 Wammes-van der Heijden EA, Smidt MH, Tijssen CC, et al. Effect of low-intensity acenocoumarol on frequency and severity of migraine attacks. Headache. Feb. 2005;45(2):137-43. [pmid: 15705119].
617 Wammes-van der Heijden EA, Tijssen CC, Egberts ACG. Treatment choices and patterns in migraine patients with and without a cardiovascular risk profile. Cephalalgia. Mar. 2009;29(3):322-30. [pmid: 19220314].
618 Wang JT, Barr CE, Goldfarb SD. Impact of chest pain on cost of migraine treatment with almotriptan and sumatriptan. Headache. Jan. Suppl 1. 2002;42:38-43. [pmid: 11966863].
619 Wang JT, Barr CE, Torigoe Y, et al. Cost savings in migraine associated with less chest pain on new triptan therapy. American Journal of Managed Care. Feb. 2002;8(3 Suppl):S102-7. [pmid: 11859905].
620 Wang L. Efficacy and safety of acupuncture for migraine prophylaxis - a multicenter, randomized controlled trial. ISRCTN Register. 2007. PMID.
621 Wang W, Schoenen J. Reduction of temporalis exteroceptive suppression by peripheral electrical stimulation in migraine and tension-type headaches. Pain. Dec. 1994;59(3):327-34. [pmid: 7708406].
622 Wauquier A, McGrady A, Aloe L, et al. Changes in cerebral blood flow velocity associated with biofeedback-assisted relaxation treatment of migraine headaches are specific for the middle cerebral artery. Headache. Jun. 1995;35(6):358-62. [pmid: 7635723].
623 Weidmann E, Unger J, Blair S, et al. An open-label study to assess changes in efficacy and satisfaction with migraine care when patients have access to multiple sumatriptan succinate formulations. Clinical Therapeutics. Jan. 2003;25(1):235-46. [pmid: 12637123].
624 Weinschutz TK, Niederberger U. Relevance of acupuncture in migraine therapy. <ORIGINAL> ZUM STELLENWERT DER AKUPUNKTUR IN DER MIGRANETHERAPIE. Nervenheilkunde. 1995:295-301.
625 Welch KM. Sumatriptan and naratriptan tolerability and safety: an update of post-marketing experience. Cephalalgia. Suppl 1. 2001;21:25-8. [pmid: 11678818].
626 Westgeest HM, Akol H, Schreuder TCMA. Pure naratriptan-induced ischemic colitis: a case report. Turkish Journal of Gastroenterology. Mar. 2010;21(1):42-4. [pmid: 20533112].
627 Whitmarsh TE, Coleston-Shields DM, Steiner TJ. Double-blind randomized placebo-controlled study of homoeopathic prophylaxis of migraine. Cephalalgia. Aug. 1997;17(5):600-4. [pmid: 9251877].
628 Wilkins AJ, Patel R, Adjamian P, et al. Tinted spectacles and visually sensitive migraine. Cephalalgia. Nov. 2002;22(9):711-9. [pmid: 12421156].
629 Williams D, Cahill T, Dowson A, et al. Usage of triptans among migraine patients: an audit in nine GP practices. Current Medical Research & Opinion. 2002;18(1):1-9. [pmid: 11999139].
630 Williamson DA, Monguillot JE, Jarrell MP, et al. Relaxation for the treatment of headache. Controlled evaluation of two group programs. Behav Modif. 1984:407-24. [pmid: 6383339].
631 Winner P. Triptans for migraine management in adolescents. Headache. Jul–Aug. 2002;42(7):675-9. [pmid: 12482222].
632 Winner P, Prensky A, Linder S, et al. Adolescent migraine: efficacy and safety of sumatriptan tablets. Journal of the Neurological Sciences. 1997:S172.
633 Witt CM, Reinhold T, Jena S, et al. Cost-effectiveness of acupuncture treatment in patients with headache. Cephalalgia. Apr. 2008;28(4):334-45. [pmid: 18315686].
634 Wober C, Wober-Bingol C, Koch G, et al. Long-term results of migraine prophylaxis with flunarizine and beta-blockers. Cephalalgia. Dec. 1991;11(6):251-6. [pmid: 1790569].
635 Wolthausen J, Sternberg S, Gerloff C, et al. Are cortical spreading depression and headache in migraine causally linked?. Cephalalgia. Feb. 2009;29(2):244-9. [pmid: 19025548].
636 Wooltorton E. Triptan migraine treatments and antidepressants: risk of serotonin syndrome. CMAJ Canadian Medical Association Journal. Oct. 10. 2006;175(8):874. [pmid: 16988028].
637 Wright W. Neurostabilizers for migraine prevention. From dosage administration to patient expectations. Advance for Nurse Practitioners. Feb. 15. 2007;85(2):52-4. [pmid: 19998927].
638 Wylie KR, Jackson C, Crawford PM. Does psychological testing help to predict the response to acupuncture or massage/relaxation therapy in patients presenting to a general neurology clinic with headache?. J Tradit Chin Med. Jun. 1997;17(2):130-9. [pmid: 10437184].
639 Wyszynski DF, Nambisan M, Surve T, et al. Increased rate of major malformations in offspring exposed to valproate during pregnancy. Neurology. Mar. 22. 2005;64(6):961-5. [pmid: 15781808].
640 Xu Z, Lv JM. Efficacy analysis of qi-promoting method for migraine. Shanghai Journal of Acupuncture and Moxibustion. Shang Hai Zhen Jiu Za Zhi. 1993:97-100.
641 Yarangumeli A, Comoglu S, Koz O, et al. Effects of betaxolol and flunarizine on visual fields and intraocular pressure in patients with migraine. Documenta Ophthalmologica. May. 2003;106(3):265-70. [pmid: 12737504].
642 Young WB, Mannix L, Adelman JU, et al. Cardiac risk factors and the use of triptans: a survey study. Headache. Jul–Aug. 2000;40(7):587-91. [pmid: 10940098].
643 Zeller JA, Lindner V, Frahm K, et al. Platelet activation and platelet-leucocyte interaction in patients with migraine. Subtype differences and influence of triptans. Cephalalgia. Jul. 2005;25(7):536-41. [pmid: 15955041].
644 Zhao L, Zhang FW, Li Y, et al. Adverse events associated with acupuncture: three multicentre randomized controlled trials of 1968 cases in China. Trials. 2011;12:87. [pmid: 21435214].
645 Ziegler DK, Batnitzky S, Barter R, et al. Magnetic resonance image abnormality in migraine with aura. Cephalalgia. Jul. 1991;11(3):147-50. [pmid: 1889071].
646 Zimmermann WJ, Heinisch C, Majunke N, et al. Patent foramen ovale closure with the SeptRx device initial experience with the first "In-Tunnel" device. JACC Cardiovascular interventions. 2010:963-7. [pmid: 20850097].
647 Zsombok T, Juhasz G, Budavari A, et al. Effect of autogenic training on drug consumption in patients with primary headache: an 8-month follow-up study. Headache. Mar. 2003;43(3):251-7. [pmid: 12603644].
648 Zsombok T, Juhasz G, Budavari A, et al. Effect of autogenic training on drug consumption in patients with primary headache: an 8-month follow-up study. Headache. 2004:251-7.

## Not Eligible Target Population

1 Treatment of migraine. The Practitioner. 1971:551-4. [pmid: 4930722].
2 Treatment of migraine attacks with sumatriptan. The Subcutaneous Sumatriptan International Study Group. N Engl J Med. Aug. 1. 1991;325(5):316-21. [pmid: 1647495].
3 Self-treatment of acute migraine with subcutaneous sumatriptan using an auto-injector device. The Sumatriptan Auto-Injector Study Group. Eur Neurol. 1991;31(5):323-31. [pmid: 1653140].
4 Sumatriptan--an oral dose-defining study. The Oral Sumatriptan Dose-Defining Study Group. Eur Neurol. 1991;31(5):300-5. [pmid: 1653137].
5 Treatment of acute cluster headache with sumatriptan. The Sumatriptan Cluster Headache Study Group. The New England journal of medicine. 1991:322-6.
6 Efficacy and safety of eletriptan 20 mg, 40 mg and 80 mg in Japanese migraineurs. Cephalalgia. Jul. 2002;22(6):416-23. [pmid: 12133040].
7 MT 300. Dihydroergotamine mesylate injection - POZEN. Drugs R D. 2003;4(2):133-4. [pmid: 12718573].
8 Abstracts of the 12th International Congress on Schizophrenia Research (ICOSR). March 28-April 1, 2009. San Diego, California, USA. Schizophr Bull. Mar. Suppl 1. 2009;35:1-377. [pmid: 19252181].
9 A one-two punch to ward off migraines. Johns Hopkins Med Lett Health After. Dec. 23. 2011;50(10):4-5. [pmid: 22216467].
10 Adelman JU, Adelman LC, Freeman MC, et al. Cost considerations of acute migraine treatment. Headache. Mar. 2004;44(3):271-85. [pmid: 15012668].
11 Adelman JU, Belsey J. Meta-analysis of oral triptan therapy for migraine: number needed to treat and relative cost to achieve relief within 2 hours. J Manag Care Pharm. Jan–Feb. 2003;9(1):45-52. [pmid: 14613361].
12 Adelman JU, Lipton RB, Ferrari MD, et al. Comparison of rizatriptan and other triptans on stringent measures of efficacy. Neurology. Oct. 23. 2001;57(8):1377-83. [pmid: 11673575].
13 Adelman LC, Adelman JU, Von Seggern R, et al. Venlafaxine extended release (XR) for the prophylaxis of migraine and tension-type headache: A retrospective study in a clinical setting. Headache. Jul–Aug. 2000;40(7):572-80. [pmid: 10940096].
14 Agha-Hosseini F, Mirzaii-Dizgah I, Ghavamzadeh L, et al. Effect of pilocarpine hydrochloride on unstimulated whole saliva flow rate and composition in patients with chronic graft-versus-host disease (cGVHD). Bone Marrow Transplantation. 2007:431-4. [pmid: 17310130].
15 Ahn AH. Chronic pain and migraine. Headache. Sep. 2007;47(8):1259-61. [pmid: 17883548].
16 Ahonen K, Hamalainen ML, Rantala H, et al. Nasal sumatriptan is effective in treatment of migraine attacks in children: A randomized trial. Neurology. Mar. 23. 2004;62(6):883-7. [pmid: 15037686].
17 Ahrens SP, Farmer MV, Williams DL, et al. Efficacy and safety of rizatriptan wafer for the acute treatment of migraine. Rizatriptan Wafer Protocol 049 Study Group. Cephalalgia. Jun. 1999;19(5):525-30. [pmid: 10403069].
18 Ahrens SP, Farmer MV, Williams DL, et al. Efficacy and safety of rizatriptan wafer for the acute treatment of migraine. Cephalalgia. 1999:525-30. [pmid: 10403069].
19 Alam M, Arndt KA, Dover JS. Severe, intractable headache after injection with botulinum a exotoxin: report of 5 cases. J Am Acad Dermatol. Jan. 2002;46(1):62-5. [pmid: 11756947].
20 Albsoul-Younes AM, Salem HA, Ajlouni SF, et al. Topiramate slow dose titration: improved efficacy and tolerability. Pediatr Neurol. Nov. 2004;31(5):349-52. [pmid: 15519117].
21 Allais G, Bussone G, Airola G, et al. Oral contraceptive-induced menstrual migraine. Clinical aspects and response to frovatriptan. Neurological Sciences. May. Suppl 1. 2008;29:S186-90. [pmid: 18545931].
22 Allais G, Bussone G, D'Andrea G, et al. Almotriptan 12.5 mg in menstrually related migraine: a randomized, double-blind, placebo-controlled study. Cephalalgia. Jan. 2011;31(2):144-51. [pmid: 20660540].
23 Allais G, Sanchez del Rio M, Diener HC, et al. Perimenstrual migraines and their response to preventive therapy with topiramate. Cephalalgia. Jan. 2011;31(2):152-60. [pmid: 20650999].
24 Allais G, Tullo V, Benedetto C, et al. Efficacy of frovatriptan in the acute treatment of menstrually related migraine: analysis of a double-blind, randomized, multicenter, Italian, comparative study versus zolmitriptan. Neurol Sci. May. Suppl 1. 2011;32:S99-104. [pmid: 21533723].
25 Allen C, Dayno J, Lines C, et al. Rizatriptan wafer--sublingual vs. placebo at the onset of acute migraine. Cephalalgia. Feb. 2001;21(1):77. [pmid: 11298669].
26 Al-Shekhlee A, Reed R. Eletriptan in acute migraine: a double-blind, placebo-controlled comparison to sumatriptan. Neurology. Sep. 12. 2000;55(5):735-6. [pmid: 11041768].
27 Altinok D, Agarwal A, Ascadi G, et al. Pediatric hemiplegic migraine: susceptibility weighted and MR perfusion imaging abnormality. Pediatr Radiol. Dec. 2010;40(12):1958-61. [pmid: 20821201].
28 Al-Waili NS. Treatment of menstrual migraine with prostaglandin synthesis inhibitor mefenamic acid: double-blind study with placebo. European Journal of Medical Research. Apr. 19. 2000;5(4):176-82. [pmid: 10799353].
29 Amparán-Estrada S, et al. Management of acute migraine headache with lidocaine. Plastic & Reconstructive Surgery. Jul. 2005;116(1):335. author reply -6. [pmid: 15988292].
30 Anderson DR, Drance SM, Schulzer M, et al. Factors that predict the benefit of lowering intraocular pressure in normal tension glaucoma. American journal of ophthalmology. 2003:820-9. [pmid: 14597032].
31 Andersson PG, Hinge HH, Johansen O, et al. Double-blind study of naproxen vs placebo in the treatment of acute migraine attacks. Cephalalgia: an international journal of headache. 1989:29-32. [pmid: 2650879].
32 Andrade SE, McPhillips H, Loren D, et al. Antidepressant medication use and risk of persistent pulmonary hypertension of the newborn. Pharmacoepidemiol Drug Saf. Mar. 2009;18(3):246-52. [pmid: 19148882].
33 Andre C, Gillon J, Moulinier B, et al. Randomised placebo-controlled double-blind trial of two dosages of sodium cromoglycate in treatment of varioloform gastritis: Comparison with cimetidine. Gut. 1982:348-52. [pmid: 6804311].
34 Andreou AP, Goadsby PJ. Therapeutic potential of novel glutamate receptor antagonists in migraine. Expert Opinion on Investigational Drugs. Jun. 2009;18(6):789-803. [pmid: 19426123].
35 Treximet in acute migraine headache: assessing cognitive function. Clinicaltrials.gov. [www.clinicaltrials.gov]. 2009.
36 Prochlorperazine more effective than ketorolac for pediatric migraine. Journal of Family Practice. 2004:444.
37 Anthony M. Cervicogenic headache: prevalence and response to local steroid therapy. Clinical & Experimental Rheumatology. Mar–Apr. 2000;18(2 Suppl 19):S59-64. [pmid: 10824289].
38 Antoniazzi AL, Bigal ME, Bordini CA, et al. Headache and hemodialysis: a prospective study. Headache. 2003:99-102. [pmid: 12558762].
39 Archambault AP, Hunt RH, Cleator IGM, et al. Comparison of omeprazole with ranitidine for treatment of symptoms associated with gastroesophageal reflux disease and uncomplicated duodenal ulcer. Canadian Journal of Gastroenterology. 1996:156-62.
40 Arnold LE, Amato A, Bozzolo H, et al. Acetyl-L-carnitine (ALC) in attention-deficit/hyperactivity disorder: a multi-site, placebo-controlled pilot trial. Journal of child and adolescent psychopharmacology. 2007:791-802. [pmid: 18315451].
41 Artto V, Nissilä M, et al. Treatment of hemiplegic migraine with triptans. European Journal of Neurology. Sep. 2007;14(9):1053-6. [pmid: 17718700].
42 Asgharnejad M, DeBussey S. Clinical efficacy of sumatriptan nasal spray in the acute treatment of migraine: a review of data from clinical trials. [abstract]. Neurology. 1998:A340.
43 Ashford E, Salonen R, Saiers J, et al. Consistency of response to sumatriptan nasal spray across patient subgroups and migraine types. Cephalalgia. Jun. 1998;18(5):273-7. [pmid: 9673807].
44 Ashkenazi A, Matro R, Shaw JW, et al. Greater occipital nerve block using local anaesthetics alone or with triamcinolone for transformed migraine: a randomised comparative study. J Neurol Neurosurg Psychiatry. Apr. 2008;79(4):415-7. [pmid: 17682008].
45 Atkinson MJ, Sinha A, Hass SL, et al. Validation of a general measure of treatment satisfaction, the Treatment Satisfaction Questionnaire for Medication (TSQM), using a national panel study of chronic disease. Health & Quality of Life Outcomes. 2004:12. [pmid: 14987333].
46 Aurora SK, Rozen TD, Kori SH, et al. A randomized, double blind, placebo-controlled study of MAP0004 in adult patients with migraine. Headache. Jun. 2009;49(6):826-37. [pmid: 19545249].
47 Autret A, De Chasteigner C. DHE methane sulfonate with programmed liberation: preliminary results of a controlled study in common migraine. Cephalalgia. 1987:451-2.
48 Awidi A. Efficacy of flurbiprofen in the treatment of acute migraine attacks: A double-blind cross-over study. Curr-Ther-Res,-Clin-Exp. 1982:492-7.
49 Aydin M, Kabakus N, Bozdag S, et al. Profile of children with migraine. Indian Journal of Pediatrics. Nov. 2010;77(11):1247-51. [pmid: 20886317].
50 Baden EY, Hunter CJ. Intravenous dexamethasone to prevent the recurrence of benign headache after discharge from the emergency department: a randomized, double-blind, placebo-controlled clinical trial. CJEM. Nov. 2006;8(6):393-400. [pmid: 17209488].
51 Bakhru A, Atlas RO. A case of postpartum cerebral angiitis and review of the literature. Arch Gynecol Obstet. Mar. 2011;283(3):663-8. [pmid: 20419307].
52 Baldwin ZK, Ceraldi CC. Ergotism associated with HIV antiviral protease inhibitor therapy. Journal of Vascular Surgery. Mar. 2003;37(3):676-8. [pmid: 12618710].
53 Banerjee M, Findley L. Propranolol in the treatment of acute migraine attacks. Cephalalgia: an international journal of headache. 1991:193-6. [pmid: 1742775].
54 Banhidy F, Acs N, Horvath-Puho E, et al. Pregnancy complications and delivery outcomes in pregnant women with severe migraine. European Journal of Obstetrics, Gynecology, & Reproductive Biology. Oct. 2007;134(2):157-63. [pmid: 17097212].
55 Barbanti P, Carpay JA, Kwong WJ, et al. Effects of a fast disintegrating/rapid release oral formulation of sumatriptan on functional ability in patients with migraine. Curr Med Res Opin. Dec. 2004;20(12):2021-9. [pmid: 15701219].
56 Barbanti P, Fabbrini G, Vanacore N, et al. Sumatriptan in migraine with unilateral cranial autonomic symptoms: an open study. Headache. Apr. 2003;43(4):400-3. [pmid: 12656712].
57 Bartolini M, Giamberardino MA, Lisotto C, et al. A double-blind, randomized, multicenter, Italian study of frovatriptan versus almotriptan for the acute treatment of migraine. J Headache Pain. Jun. 2011;12(3):361-8. [pmid: 21437714].
58 Bates D, Ashford E, Dawson R, et al. Subcutaneous sumatriptan during the migraine aura. Sumatriptan Aura Study Group. Neurology. Sep. 1994;44(9):1587-92. [pmid: 7936279].
59 Beau-Salinas F, et al. Drug dependence associated with triptans and ergot derivatives: a case/non-case study. European Journal of Clinical Pharmacology. Apr. 2010;66(4):413-7. [pmid: 20024536].
60 Bell CF, Foley KA, Barlas S, et al. Time to pain freedom and onset of pain relief with rizatriptan 10 mg and prescription usual-care oral medications in the acute treatment of migraine headaches: a multicenter, prospective, open-label, two-attack, crossover study. Clinical Therapeutics. Jun. 2006;28(6):872-80. [pmid: 16860170].
61 Belsey JD. Cost effectiveness of oral triptan therapy: a trans-national comparison based on a meta-analysis of randomised controlled trials. Curr Med Res Opin. May. 2004;20(5):659-69. [pmid: 15140331].
62 Belvis R, Ramos R, Villa C, et al. Brain apparent water diffusion coefficient magnetic resonance image during a prolonged visual aura. Headache. Jun. 2010;50(6):1045-9. [pmid: 20408884].
63 Bendtsen L, Jensen R, Olesen J. A non-selective (amitriptyline), but not a selective (citalopram), serotonin reuptake inhibitor is effective in the prophylactic treatment of chronic tension-type headache. J Neurol Neurosurg Psychiatry. Sep. 1996;61(3):285-90. [pmid: 8795600].
64 Benito-Ruiz P, Camacho-Zambrano MM, Carrillo-Arcentales JN, et al. A randomized controlled trial on the efficacy and safety of a food ingredient, collagen hydrolysate, for improving joint comfort. International Journal of Food Sciences and Nutrition. 2009:99-113. [pmid: 19212858].
65 Berges A, Walls C, Lener SE, et al. Pharmacokinetics and tolerability of sumatriptan after single-dose administration of a fixed-dose combination tablet of sumatriptan/naproxen sodium 85/500 mg followed two hours later by subcutaneous sumatriptan 4- or 6-mg injection: a randomized, open-label, three-period crossover study in healthy volunteers. Clinical therapeutics. 2010:1165-77. [pmid: 20637969].
66 Biddle AK, Shih YC, Kwong WJ. Cost-benefit analysis of sumatriptan tablets versus usual therapy for treatment of migraine. Pharmacotherapy. Nov. 2000;20(11):1356-64. [pmid: 11079284].
67 Bigal M, Rapoport A, Aurora S, et al. Satisfaction with current migraine therapy: experience from 3 centers in US and Sweden. Headache. Apr. 2007;47(4):475-9. [pmid: 17445096].
68 Bigal M, Rapoport A, Sheftell F, et al. Memantine in the preventive treatment of refractory migraine. Headache. Oct. 2008;48(9):1337-42. [pmid: 19031499].
69 Bigal M, Sheftell F, Tepper S, et al. A randomized double-blind study comparing rizatriptan, dexamethasone, and the combination of both in the acute treatment of menstrually related migraine: research submission. Headache. 2008:1286-93. [pmid: 19031496].
70 Bigal ME, Bordini CA, Sheftell FD, et al. Migraine with aura versus migraine without aura: pain intensity and associated symptom intensities after placebo. Headache. Oct. 2002;42(9):872-7. [pmid: 12390612].
71 Bigal ME, Bordini CA, Speciali JG. Intravenous chlorpromazine in the emergency department treatment of migraines: a randomized controlled trial. J Emerg Med. Aug. 2002;23(2):141-8. [pmid: 12359281].
72 Bigal ME, Borucho S, Serrano D, et al. The acute treatment of episodic and chronic migraine in the USA. Cephalalgia. Aug. 2009;29(8):891-7. [pmid: 19222509].
73 Bigal ME, Ho TW. Is there an inherent limit to acute migraine treatment efficacy?. Journal of Headache & Pain. Dec. 2009;10(6):393-4. [pmid: 19820895].
74 Bigal ME, Serrano D, Buse D, et al. Acute migraine medications and evolution from episodic to chronic migraine: a longitudinal population-based study. Headache. Sep. 2008;48(8):1157-68. [pmid: 18808500].
75 Bigal ME, Sheftell FD, Tepper SJ, et al. Migraine days decline with duration of illness in adolescents with transformed migraine. Cephalalgia: an international journal of headache. 2005:482-7. [pmid: 15955034].
76 Bigal ME, Tsang A, Loder E, et al. Body mass index and episodic headaches: a population-based study. Archives of Internal Medicine. Oct. 8. 2007;167(18):1964-70. [pmid: 17923596].
77 Biton V, Edwards KR, Montouris GD, et al. Topiramate titration and tolerability. Ann Pharmacother. Feb. 2001;35(2):173-9. [pmid: 11215835].
78 Blanchard EB, Appelbaum KA, Radnitz CL, et al. A controlled evaluation of thermal biofeedback and thermal biofeedback combined with cognitive therapy in the treatment of vascular headache. J Consult Clin Psychol. Apr. 1990;58(2):216-24. [pmid: 2186067].
79 Blanchard EB, Nicholson NL, Radnitz CL, et al. The role of home practice in thermal biofeedback. J Consult Clin Psychol. Aug. 1991;59(4):507-12. [pmid: 1918553].
80 Blanchard EB, Peters ML, Hermann C, et al. Direction of temperature control in the thermal biofeedback treatment of vascular headache. Appl Psychophysiol Biofeedback. Dec. 1997;22(4):227-45. [pmid: 9595177].
81 Blanda M, Rench T, Gerson LW, et al. Intranasal lidocaine for the treatment of migraine headache: a randomized, controlled trial. Acad Emerg Med. Apr. 2001;8(4):337-42. [pmid: 11282668].
82 Blau JN, Engel HO. Individualizing treatment with verapamil for cluster headache patients. Headache. Nov–Dec. 2004;44(10):1013-8. [pmid: 15546265].
83 Block GA, Goldstein J, Polis A, et al. Efficacy and safety of rizatriptan versus standard care during long-term treatment for migraine. Rizatriptan Multicenter Study Groups. Headache. Nov–Dec. 1998;38(10):764-71. [pmid: 11284464].
84 Block GA, Smith M, Jiang K, et al. Rizatriptan (MK-0462) for the acute treatment of migraine and migraine recurrence. [abstract]. Neurology. 1997:A68.
85 Blumenthal HJ. Butterscotch masks the bitter taste of sumatriptan nasal spray. Headache. Feb. 2001;41(2):210. [pmid: 11251713].
86 Blumenthal HJ, Weisz MA, Kelly KM, et al. Treatment of primary headache in the emergency department. Headache. Nov–Dec. 2003;43(10):1026-31. [pmid: 14629236].
87 Boe MG, Mygland A, Salvesen R. Prednisolone does not reduce withdrawal headache: a randomized, double-blind study. Neurology. Jul. 3. 2007;69(1):26-31. [pmid: 17475943].
88 Bogousslavsky J, Garazi S, Jeanrenaud X, et al. Stroke recurrence in patients with patent foramen ovale: the Lausanne Study. Lausanne Stroke with Paradoxal Embolism Study Group. Neurology. 1996:1301-5. [pmid: 8628471].
89 Bollig G, Pothmann R, Thoiss W, et al. One-point-acupuncture for the treatment of acute headache - First results. Deutsche Zeitschrift fur Akupunktur. 2000:172-4.
90 Bomhof M, Paz J, Legg N, et al. Comparison of rizatriptan 10 mg vs. naratriptan 2.5 mg in migraine. Eur Neurol. 1999;42(3):173-9. [pmid: 10529545].
91 Bonuso S, Marano E, di Stasio E, et al. Source of pain and primitive dysfunction in migraine: an identical site?. J Neurol Neurosurg Psychiatry. Dec. 1989;52(12):1351-4. [pmid: 2515254].
92 Borgesen SE, Nielsen JL, Moller CE. Prophylactic treatment of migraine with propranolol. A clinical trial. Acta neurologica Scandinavica. 1974:651-6. [pmid: 4611129].
93 Bosco D, Belfiore A, Fava A, et al. Relationship between high prolactine levels and migraine attacks in patients with microprolactinoma. Journal of Headache & Pain. Apr. 2008;9(2):103-7. [pmid: 18256782].
94 Boska MD, Welch KM, Schultz L, et al. Effects of the anti-migraine drug sumatriptan on muscle energy metabolism: relationship to side-effects. Cephalalgia. Feb. 2000;20(1):39-44. [pmid: 10817445].
95 Boureau F, Chazot G, Emile J, et al. Sumatriptan vs usual acute treatment of migraine. [abstract]. Canadian Journal of Neurological Sciences. 1993.
96 Bousser MG, Loria Y. Efficacy of dihydroergotamine nasal spray in the acute treatment of migraine attacks. Cephalalgia. 1985:554-5.
97 Bowden CL, Brugger AM, Swann AC, et al. Efficacy of divalproex vs lithium and placebo in the treatment of mania. The Depakote Mania Study Group. JAMA. Mar. 23–30. 1994;271(12):918-24. [pmid: 8120960].
98 Boyce M, Dunn K, Warrington S. Hemodynamic and electrocardiographic effects of almotriptan in healthy volunteers. Journal of cardiovascular pharmacology. 2001:280-9. [pmid: 11243418].
99 Boz C, Altunayoglu V, Velioglu S, et al. Sertraline versus amitriptyline in the prophylactic therapy of non-depressed chronic tension-type headache patients. Journal of Headache & Pain. 2003;4(2):72-8. PMID.
100 Brain SD, Poyner DR, Hill RG. CGRP receptors: a headache to study, but will antagonists prove therapeutic in migraine?. Trends in Pharmacological Sciences. Feb. 2002;23(2):51-3. [pmid: 11830255].
101 Brennum J, Brinck T, Schriver L, et al. Sumatriptan has no clinically relevant effect in the treatment of episodic tension-type headache. European Journal of Neurology. 1996:23-8.
102 Brousseau D, Duffy S, Anderson A, et al. Migraines in the pediatric emergency department: A randomized, double blind trial of IV ketorolac versus IV prochlorperazine. Pediatric research. 2002:101a.
103 Brousseau DC, Duffy SJ, Anderson AC, et al. Treatment of pediatric migraine headaches: a randomized, double-blind trial of prochlorperazine versus ketorolac. Ann Emerg Med. Feb. 2004;43(2):256-62. [pmid: 14747817].
104 Bruni O, Galli F, Guidetti V. Sleep hygiene and migraine in children and adolescents. Cephalalgia. Dec. Suppl 25. 1999;19:57-9. [pmid: 10668125].
105 Burgey CS, Stump CA, Nguyen DN, et al. Benzodiazepine calcitonin gene-related peptide (CGRP) receptor antagonists: optimization of the 4-substituted piperidine. Bioorganic & Medicinal Chemistry Letters. Oct. 1. 2006;16(19):5052-6. [pmid: 16889959].
106 Burk CT, Gilderman A, Salas J, et al. The impact of an over-the-counter migraine medication program on quality of life. Headache. Mar. 2003;43(3):191-201. [pmid: 12603637].
107 Burke R, Webster C, Laurenza A, et al. Efficacy of sumatriptan injection for the acute treatment of migraine in a primarily non-caucasian group of patients. Functional Neurology. 1998:182.
108 Bussone G, D'Amico D, McCarroll KA, et al. Restoring migraine sufferers' ability to function normally: a comparison of rizatriptan and other triptans in randomized trials. European Neurology. 2002;48(3):172-7. [pmid: 12373035].
109 Bussone G, Grazzi L, D'Amico D, et al. Acute treatment of migraine attacks: Efficacy and safety of a nonsteroidal anti-inflammatory drug, diclofenac-potassium, in comparison to oral sumatriptan and placebo. Cephalalgia. 1999:232-40. [pmid: 10376168].
110 Cabarrocas X, Salva M, Pavesi M, et al. Ethanol does not significantly affect the bioavailability of almotriptan: an open, randomized, crossover, single-dose, phase I clinical trial in healthy volunteers. International journal of clinical pharmacology and therapeutics. 2006:443-8. [pmid: 16995333].
111 Cady R. Almotriptan reduces the incidence of migraine-associated symptoms: a pooled analysis. Headache. Jan. Suppl 1. 2002;42:26-31. [pmid: 11966861].
112 Cady R, Crawford G, Ahrens S, et al. Long-term efficacy and tolerability of rizatriptan wafers in migraine. MedGenMed. Jun. 1. 2001;3(3):1. [pmid: 11549974].
113 Cady R, Martin V, Adelman J, et al. Migraine treatment with rizatriptan and non-triptan usual care medications: a pharmacy-based study. Headache. Oct. 2004;44(9):900-7. [pmid: 15447699].
114 Cady R, Martin V, Mauskop A, et al. Efficacy of Rizatriptan 10 mg administered early in a migraine attack. Headache. Jun. 2006;46(6):914-24. [pmid: 16732837].
115 Cady R, Martin V, Mauskop A, et al. Symptoms of cutaneous sensitivity pre-treatment and post-treatment: results from the rizatriptan TAME studies. Cephalalgia. Sep. 2007;27(9):1055-60. [pmid: 17681023].
116 Cady RC, Ryan R, Jhingran P, et al. Sumatriptan injection reduces productivity loss during a migraine attack: results of a double-blind, placebo-controlled trial. Arch Intern Med. May. 11. 1998;158(9):1013-8. [pmid: 9588435].
117 Cady RK. Treating an acute attack of migraine. Headache. Oct. 2008;48(9):1415-6. [pmid: 19006560].
118 Cady RK, Banks J, Jones BA, et al. Postmarketing migraine survey of frovatriptan: effectiveness and tolerability vs previous triptans, NSAIDs or a combination. Current Medical Research & Opinion. Nov. 2009;25(11):2711-21. [pmid: 19778164].
119 Cady RK, Dexter J, Sargent JD, et al. Efficacy of subcutaneous sumatriptan in repeated episodes of migraine. Neurology. Jul. 1993;43(7):1363-8. [pmid: 8392150].
120 Cady RK, Diamond ML, Diamond MP, et al. Sumatriptan-naproxen sodium for menstrual migraine and dysmenorrhea: satisfaction, productivity, and functional disability outcomes. Headache. May. 2011;51(5):664-73. [pmid: 21521204].
121 Cady RK, Goldstein J, Silberstein S, et al. Expanding access to triptans: assessment of clinical outcome. Headache. Nov–Dec. 2009;49(10):1402-13. [pmid: 19817885].
122 Cady RK, Gutterman D, Saiers JA, et al. Responsiveness of non-IHS migraine and tension-type headache to sumatriptan. Cephalalgia. Aug. 1997;17(5):588-90. [pmid: 9251874].
123 Cady RK, Lipton RB, Hall C, et al. Treatment of mild headache in disabled migraine sufferers: results of the Spectrum Study. Headache. Nov–Dec. 2000;40(10):792-7. [pmid: 11135022].
124 Cady RK, Martin VT, Geraud G, et al. Rizatriptan 10-mg ODT for early treatment of migraine and impact of migraine education on treatment response. Headache. May. 2009;49(5):687-96. [pmid: 19472447].
125 Cady RK, Rubino J, Crummett D, et al. Oral sumatriptan in the treatment of recurrent headache. Arch Fam Med. Sep. 1994;3(9):766-72. [pmid: 7987510].
126 Cady RK, Schreiber CP, Beach ME, et al. Gelstat Migraine (sublingually administered feverfew and ginger compound) for acute treatment of migraine when administered during the mild pain phase. Medical Science Monitor. Sep. 2005;11(9):PI65-9. [pmid: 16127373].
127 Cady RK, Sheftell F, Lipton RB, et al. Effect of early intervention with sumatriptan on migraine pain: retrospective analyses of data from three clinical trials. Clin Ther. Sep. 2000;22(9):1035-48. [pmid: 11048903].
128 Cady RK, Vause CV, Ho TW, et al. Elevated saliva calcitonin gene-related peptide levels during acute migraine predict therapeutic response to rizatriptan. Headache. Oct. 2009;49(9):1258-66. [pmid: 19788468].
129 Caekebeke JF, Ferrari MD, Zwetsloot CP, et al. Antimigraine drug sumatriptan increases blood flow velocity in large cerebral arteries during migraine attacks. Neurology. Aug. 1992;42(8):1522-6. [pmid: 1322512].
130 Callaham M, Raskin N. A controlled study of dihydroergotamine in the treatment of acute migraine headache. Headache. 1986:168-71. [pmid: 3519528].
131 Campos L, Diaz Gomez M, Ondiviela R, et al. Naproxen sodium in the treatment of otitis. Atencion Primaria. 1992;314:6-7.
132 Canadian Glaucoma, Study G. Canadian Glaucoma Study: 1. Study design, baseline characteristics, and preliminary analyses. Canadian journal of ophthalmology. Journal canadien d'ophtalmologie. 2006:566-75.
133 Caputi L, Carriero MR, Parati EA, et al. Postural dependency of right to left shunt: role of contrast-enhanced transcranial Doppler and its potential clinical implications. Stroke. Aug. 2008;39(8):2380-1. [pmid: 18535277].
134 Carasso RL, Peled O, Yehuda S. Flufenamic acid in prostaglandin migraine. Int-J-Neurosci. 1985:67-71. [pmid: 4019063].
135 Carlsson J, Rosenhall U. Oculomotor disturbances in patients with tension headache treated with acupuncture or physiotherapy. Cephalalgia. Jun. 1990;10(3):123-9. [pmid: 2245457].
136 Carmona S, Settecase N. Use of topiramate (topamax) in a subgroup of migraine-vertigo patients with auditory symptoms. Annals of the New York Academy of Sciences. Apr. 2005;1039:517-20. [pmid: 15827012].
137 Carpay JA, Linssen WHJP, Koehler PJJ, et al. Efficacy of sumatriptan nasal spray in recurrent migrainous headache: an open prospective study. Headache. Apr. 2003;43(4):395-9. [pmid: 12656711].
138 Casale TB, Romero FA, Spierings EL. Intranasal noninhaled carbon dioxide for the symptomatic treatment of seasonal allergic rhinitis. The Journal of allergy and clinical immunology. 2008:105-9. [pmid: 18028997].
139 Cates C. Triptan medications to treat acute migraine. Lancet. Mar. 30. 2002;359(9312):1152. author reply -3. [pmid: 11943288].
140 Ceballos Hernansanz MA, Sanchez Roy R, Cano Orgaz A, et al. Migraine treatment patterns and patient satisfaction with prior therapy: a substudy of a multicenter trial of rizatriptan effectiveness. Clinical Therapeutics. Jul. 2003;25(7):2053-69. [pmid: 12946550].
141 Centonze V, Bassi A, Causarano V, et al. Simultaneous occurrence of ipsilateral cluster headache and chronic paroxysmal hemicrania: a case report. Headache. Jan. 2000;40(1):54-6. [pmid: 10759906].
142 Centonze V, Polito MB, Di BM, et al. Evaluation of the efficacy of oral sumatriptan in the therapy of acute migraine. <ORIGINAL> VALUTAZIONE DELL'EFFICACIA DI SUMATRIPTAN NELLA TERAPIA ORALE DELL'ATTACCO DI EMICRANIA. Clinica Terapeutica. 1995:721-8. [pmid: 8720348].
143 Chambers CD, Hernandez-Diaz S, Van Marter LJ, et al. Selective serotonin-reuptake inhibitors and risk of persistent pulmonary hypertension of the newborn. N Engl J Med. Feb. 9. 2006;354(6):579-87. [pmid: 16467545].
144 Chan WS, Koren G, Barrera M, et al. Neurocognitive development of children following in-utero exposure to labetalol for maternal hypertension: a cohort study using a prospectively collected database. Hypertens Pregnancy. 2010;29(3):271-83. [pmid: 20670152].
145 Chang L, Henley E. Which oral triptans are effective for the treatment of acute migraine?. Journal of Family Practice. Feb. 2002;51(2):176. [pmid: 11978220].
146 Check JH, Cohen R. Marked improvement of headaches and vasomotor symptoms with sympathomimetic amines in a woman with sympathetic hyperalgesia-edema syndrome. Clinical & Experimental Obstetrics & Gynecology. 2011;38(1):88-9. [pmid: 21485736].
147 Chen J, Jiang XG, Jiang WM, et al. Intranasal absorption of rizatriptan--in vivo pharmacokinetics and bioavailability study in humans. Die Pharmazie. 2005:39-41. [pmid: 15702515].
148 Chengappa KN, Gershon S, Levine J. The evolving role of topiramate among other mood stabilizers in the management of bipolar disorder. Bipolar disorders. 2001:215-32. [pmid: 11912568].
149 Chia Y-C, Lim S-H, Wang S-J, et al. Efficacy of eletriptan in migraineurs with persistent poor response to nonsteroidal anti-inflammatory drugs. Headache. Oct. 2003;43(9):984-90. [pmid: 14511275].
150 Chopra HK, Sambi RS, Krishna CK, et al. Peri-operative cardiac assessment & rationale for use of beta-blockers. Indian Heart J. Mar–Apr. 2010;62(2):158-67. [pmid: 21180310].
151 Christie S, Gobel H, Mateos V, et al. Crossover comparison of efficacy and preference for rizatriptan 10 mg versus ergotamine/caffeine in migraine. Eur Neurol. 2003;49(1):20-9. [pmid: 12464714].
152 Chun-Fai-Chan B, Koren G, Fayez I, et al. Pregnancy outcome of women exposed to bupropion during pregnancy: a prospective comparative study. Am J Obstet Gynecol. Mar. 2005;192(3):932-6. [pmid: 15746694].
153 Cianchetti C. Capsaicin jelly against migraine pain. Int J Clin Pract. Mar. 2010;64(4):457-9. [pmid: 20456192].
154 Citera G, Arias MA, Maldonado-Cocco JA, et al. The effect of melatonin in patients with fibromyalgia: a pilot study. Clinical rheumatology. 2000:9-13. [pmid: 10752492].
155 Cleland PG, Barnes D, Elrington GM, et al. Studies to assess if pizotifen prophylaxis improves migraine beyond the benefit offered by acute sumatriptan therapy alone. Eur Neurol. 1997;38(1):31-8. [pmid: 9252796].
156 Clements-Mann ML, Weinhold K, Matthews TJ, et al. Immune responses to human immunodeficiency virus (HIV) type 1 induced by canarypox expressing HIV-1(MN) gp120, HIV-1(SF2) recombinant gp120, or both vaccines in seronegative adults. Journal of Infectious Diseases. 1998:1230-46. [pmid: 9593008].
157 Codispoti JR, Prior MJ, Fu M, et al. Efficacy of nonprescription doses of ibuprofen for treating migraine headache. a randomized controlled trial. Headache. Jul–Aug. 2001;41(7):665-79. [pmid: 11554954].
158 Colman I, Friedman BW, Brown MD, et al. Parenteral dexamethasone for acute severe migraine headache: meta-analysis of randomised controlled trials for preventing recurrence. BMJ. Jun. 14. 2008;336(7657):1359-61. [pmid: 18541610].
159 Cologno D, Torelli P, Manzoni GC. Migraine with aura: a review of 81 patients at 10–20 years' follow-up. Cephalalgia an international journal of headache. 1998:690-6. [pmid: 9950627].
160 Comoglu T, Dogan A, Comoglu S, et al. Formulation and evaluation of diclofenac potassium fast-disintegrating tablets and their clinical application in migraine patients. Drug Dev Ind Pharm. Mar. 2011;37(3):260-7. [pmid: 20704458].
161 Conte HR, Karasu TB. Psychotherapy for medically ill patients: review and critique of controlled studies. Review 35 refs. Psychosomatics. 1981:285-90. [pmid: 7015400].
162 Corbey MP, Bach AB, Lech K, et al. Grading of severity of postdural puncture headache after 27-gauge Quincke and Whitacre needles. Acta anaesthesiologica Scandinavica. 1997:779-84. [pmid: 9241342].
163 Cortelli P, Allais G, Tullo V, et al. Frovatriptan versus other triptans in the acute treatment of migraine: pooled analysis of three double-blind, randomized, cross-over, multicenter, Italian studies. Neurol Sci. May. Suppl 1. 2011;32:S95-8. [pmid: 21533722].
164 Couch JR Jr, Saper J, Meloche JP. Treatment of migraine with BMS180048: response at 2 hours. North American BMS180048 Study Group. Headache. Oct. 1996;36(9):523-30. [pmid: 8916559].
165 Cull RE, Price WH, Dunbar A. The efficacy of subcutaneous sumatriptan in the treatment of recurrence of migraine headache. J Neurol Neurosurg Psychiatry. May. 1997;62(5):490-5. [pmid: 9153607].
166 Curro G, Baccarani U, Adani GL, et al. Transient ischemic attack after rizatriptan administration in a liver transplant recipient: a case report. Transplantation Proceedings. Nov. 2006;38(9):3138-9. [pmid: 17112920].
167 Cutler NR, Claghorn J, Sramek JJ, et al. Pilot study of MK-462 in migraine. Cephalalgia. Apr. 1996;16(2):113-6. [pmid: 8665577].
168 Dahlof C. Sumatriptan nasal spray in the acute treatment of migraine: a review of clinical studies. Cephalalgia. Nov. 1999;19(9):769-78. [pmid: 10595285].
169 Dahlöf C, Tfelt-Hansen P, Massiou H, et al. Dose finding, placebo-controlled study of oral almotriptan in the acute treatment of migraine. Neurology. 2001:1811-7. [pmid: 11723269].
170 Dahlof C, Winter P, Ludlow S. Oral GR43175, a 5HT1-like agonist, for treatment of the acute migraine attack: an international study - preliminary results. Cephalalgia. 1989:351-2.
171 Dahlof C, Winter P, Whitehouse H, et al. Randomized, double-blind, placebo-controlled comparison of oral naratriptan and oral sumatriptan in the acute treatment of migraine. [abstract]. Neurology. 1997:A85-6.
172 Dahlöf CG, Jacobs LD. Ketoprofen, paracetamol and placebo in the treatment of episodic tension-type headache. Cephalalgia: an international journal of headache. 1996:117-23. [pmid: 8665578].
173 Dahlof CG, Lipton RB, McCarroll KA, et al. Within-patient consistency of response of rizatriptan for treating migraine. Neurology. Nov. 28. 2000;55(10):1511-6. [pmid: 11094106].
174 D'Alessio C, Ambrosini A, Colonnese C, et al. Indomethacin-responsive hemicrania associated with an extracranial vascular malformation: report of two cases. Cephalalgia. Nov. 2004;24(11):997-1000. [pmid: 15482365].
175 D'Andrea G, Nordera GP, Allais G. Treatment of aura: solving the puzzle. Neurological Sciences. May. Suppl 2. 2006;27:S96-9. [pmid: 16688638].
176 Dasbach EJ, Carides GW, Gerth WC, et al. Work and productivity loss in the rizatriptan multiple attack study. Cephalalgia. Nov. 2000;20(9):830-4. [pmid: 11167913].
177 Daugaard D, Thomsen LL, Olesen J. No relation between cephalic venous dilatation and pain in migraine. J Neurol Neurosurg Psychiatry. Aug. 1998;65(2):260-2. [pmid: 9703185].
178 Davis CP, Torre PR, Williams C, et al. Ketorolac versus meperidine-plus-promethazine treatment of migraine headache: evaluations by patients. Am J Emerg Med. Mar. 1995;13(2):146-50. [pmid: 7893296].
179 De Marinis M, Giraldi JP, de Feo A, et al. Migraine and ocular pain in "glaucoma suspect". Cephalalgia: an international journal of headache. 1999:243-7. [pmid: 10376170].
180 De Sanctis S, Grieco GS, Breda L, et al. Prolonged sporadic hemiplegic migraine associated with a novel de novo missense ATP1A2 gene mutation. Headache. Mar. 2011;51(3):447-50. [pmid: 21352219].
181 de Tommaso M, Losito L, Libro G, et al. Effects of symptomatic treatments on cutaneous hyperalgesia and laser evoked potentials during migraine attack. Cephalalgia. May. 2005;25(5):359-68. [pmid: 15839851].
182 Del Bene E, Poggioni M, De Tommasi F. Video assessment of yawning induced by sublingual apomorphine in migraine. Headache. Oct. 1994;34(9):536-8. [pmid: 8002329].
183 Del Bene E, Poggioni M, Garagiola U, et al. Intramuscular treatment of migraine attacks using diclofenac sodium: a crossover clinical trial. J Int Med Res. Jan–Feb. 1987;15(1):44-8. [pmid: 3545942].
184 Demailly P, Allaire C, Bron V, et al. Effectiveness and tolerance of beta-blocker/pilocarpine combination eye drops in primary open-angle glaucoma and high intraocular pressure. Journal of Glaucoma. 1995:235-41. [pmid: 19920680].
185 Derriennic M, Voi M, Thoren LM, et al. Cefaclor AF in the treatment of streptococcal pharyngitis/tonsillitis. Postgraduate medical journal. 1992:S43-6. discussion S6–8. [pmid: 1287618].
186 Devineni T, Blanchard EB. A randomized controlled trial of an internet-based treatment for chronic headache. Behav Res Ther. Mar. 2005;43(3):277-92. [pmid: 15680926].
187 Di Monda V, Nicolodi M, Aloisio A, et al. Efficacy of a fixed combination of indomethacin, prochlorperazine, and caffeine versus sumatriptan in acute treatment of multiple migraine attacks: a multicenter, randomized, crossover trial. Headache. Sep. 2003;43(8):835-44. [pmid: 12940804].
188 Di Rosa G, Span x00F, et al. Alternating hemiplegia of childhood successfully treated with topiramate: 18 months of follow-up. Neurology. Jan. 10. 2006;66(1):146. [pmid: 16401872].
189 Diamond ML. Migraine: a diagnostic dilemma in the emergency department. Headache. Jun. 2001;41(6):533. [pmid: 11437885].
190 Diamond S, Elkind A, Jackson RT, et al. Multiple-attack efficacy and tolerability of sumatriptan nasal spray in the treatment of migraine. Arch Fam Med. May–Jun. 1998;7(3):234-40. [pmid: 9596457].
191 Diamond S, Freitag FG. Cold as an adjunctive therapy for headache. Postgrad Med. 1986:305-9. [pmid: 3941818].
192 Diamond S, Freitag FG. Analgesic efficacy and safety of TNB in the acute treatment of migraine. Clin Pharmacol Ther. 1990:135.
193 Diamond S, Freitag FG, Feoktistov A, et al. Sumatriptan 6 mg subcutaneous as an effective migraine treatment in patients with cutaneous allodynia who historically fail to respond to oral triptans. Journal of Headache & Pain. Feb. 2007;8(1):13-8. [pmid: 17221340].
194 Diamond S, Freitag FG, Gallagher RM, et al. The analgesic efficacy of transnasal butorphanol (TNB) in the acute treatment of migraine. Cephalalgia. 1989:357.
195 Diamond S, Freitag Frederick G, Diamond Merle L, et al. Transnasal butorphanol in the treatment of migraine headache pain. Headache Quarterly. 1992:164-71.
196 Dichgans M, Freilinger T, Eckstein G, et al. Mutation in the neuronal voltage-gated sodium channel SCN1A in familial hemiplegic migraine. Lancet. Jul 30–Aug 5. 2005;366(9483):371-7. [pmid: 16054936].
197 Diener HC. Consistent efficacy, tolerability, and high levels of satisfaction with almotriptan 12.5 mg when used to treat multiple migraine attacks in routine clinical practice. Headache. Jun. 2005;45(6):624-31. [pmid: 15953293].
198 Diener HC. RPR100893, a substance-P antagonist, is not effective in the treatment of migraine attacks. Cephalalgia. Apr. 2003;23(3):183-5. [pmid: 12662184].
199 Diener HC. Efficacy of almotriptan 12.5 mg in achieving migraine-related composite endpoints: a double-blind, randomized, placebo-controlled study in patients controlled study in patients with previous poor response to sumatriptan 50 mg. Curr Med Res Opin. Oct. 2005;21(10):1603-10. [pmid: 16238900].
200 Diener HC, Barbanti P, Dahlof C, et al. BI 44370 TA, an oral CGRP antagonist for the treatment of acute migraine attacks: results from a phase II study. Cephalalgia. Apr. 2011;31(5):573-84. [pmid: 21172952].
201 Diener HC, Bussone G, de Liano H, et al. Placebo-controlled comparison of effervescent acetylsalicylic acid, sumatriptan and ibuprofen in the treatment of migraine attacks. Cephalalgia. Nov. 2004;24(11):947-54. [pmid: 15482357].
202 Diener HC, Eikermann A, Gessner U, et al. Efficacy of 1,000 mg effervescent acetylsalicylic acid and sumatriptan in treating associated migraine symptoms. Eur Neurol. 2004;52(1):50-6. [pmid: 15240983].
203 Diener HC, Gendolla A, Gebert I, et al. Almotriptan in migraine patients who respond poorly to oral sumatriptan: a double-blind, randomized trial. Headache. Jul–Aug. 2005;45(7):874-82. [pmid: 15985104].
204 Diener HC, McHarg A. Pharmacology and efficacy of eletriptan for the treatment of migraine attacks. International Journal of Clinical Practice. Dec. 2000;54(10):670-4. [pmid: 11221281].
205 Diener HC, Peil H, Aicher B. The efficacy and tolerability of a fixed combination of acetylsalicylic acid, paracetamol, and caffeine in patients with severe headache: a post-hoc subgroup analysis from a multicentre, randomized, double-blind, single-dose, placebo-controlled parallel group study. Cephalalgia. Oct. 2011;31(14):1466-76. [pmid: 21908446].
206 Diener HC, Pfaffenrath V, Pageler L, et al. The fixed combination of acetylsalicylic acid, paracetamol and caffeine is more effective than single substances and dual combination for the treatment of headache: a multicentre, randomized, double-blind, single-dose, placebo-controlled parallel group study. Cephalalgia. Oct. 2005;25(10):776-87. [pmid: 16162254].
207 Diener H-C, Evers S. Effectiveness and satisfaction with zolmitriptan 5 mg nasal spray for treatment of migraine in real-life practice: results of a postmarketing surveillance study. Clinical Drug Investigation. 2007;27(1):59-66. [pmid: 17177580].
208 Diener H-C, Gendolla A. Part IV effects of zolmitriptan orally disintegrating tablet on migraine symptoms and ability to perform normal activities: a post-marketing surveillance study in Germany. Current Medical Research & Opinion. Suppl 3. 2005;21:S18-24. [pmid: 16083520].
209 Diener H-C, Ryan R, Sun W, et al. The 40-mg dose of eletriptan: comparative efficacy and tolerability versus sumatriptan 100 mg. European Journal of Neurology. Feb. 2004;11(2):125-34. [pmid: 14748774].
210 Dikel W, Olness K. Self-hypnosis, biofeedback, and voluntary peripheral temperature control in children. Pediatrics. 1980:335-40. [pmid: 7422423].
211 Dilli E, Dodick DW. Extracephalic cluster (cluster sine headache). Neurology. Apr. 15. 2008;70(16):1362-3. [pmid: 18413592].
212 Dilone E, Bergstrom D, Cabana B, et al. Rapid oral transmucosal absorption of sumatriptan, and pharmacodynamics in acute migraine. Headache. Nov–Dec. 2009;49(10):1445-53. [pmid: 19549162].
213 Dimitriou V, Iatrou C, Malefaki A, et al. Blockade of branches of the ophthalmic nerve in the management of acute attack of migraine. Middle East Journal of Anesthesiology. Jun. 2002;16(5):499-504. [pmid: 12138513].
214 Diomedi M, Sallustio F, Rizzato B, et al. Sildenafil increases cerebrovascular reactivity: a transcranial Doppler study. Neurology. Sep. 27. 2005;65(6):919-21. [pmid: 16051646].
215 DiSerio F, Patin J, Friedman A. U.S.A. trials of dihydroergotamine nasal spray in the acute treatment of migraine headache. Cephalalgia. 1989:344-5.
216 DiSerio FJ, Singer JM, Friedman AP. An evaluation of proquazone in the acute treatment of migraine headache. Cephalalgia. 1985:146-7.
217 Djupesland PG, Docekal P. Intranasal sumatriptan powder delivered by a novel breath-actuated bi-directional device for the acute treatment of migraine: A randomised, placebo-controlled study. Cephalalgia. Mar. 17. 2010;30(8):933-42. PMID. [pmid: 20656704].
218 Dodick DW. Epidemiology and acute care of migraine headache. Managed Care Interface. Suppl D. 2004;17:6-10. discussion 1–3. [pmid: 15506040].
219 Dodick DW. Introduction: cardiovascular safety and triptans in the acute treatment of migraine. Headache. May. Suppl 1. 2004;44:S1-4. [pmid: 15149487].
220 Dodick DW, Lipsy RJ. Advances in migraine management: implications for managed care organizations. Managed Care. May. 2004;13(5):45-51. [pmid: 15181689].
221 Doepp F, Schreiber SJ, Dreier JP, et al. Migraine aggravation caused by cephalic venous congestion. Headache. 2003:96-8. [pmid: 12558761].
222 d'Onofrio F, Cologno D, Petretta V, et al. Basilar-type migraine responsive to lamotrigine: three case reports. Neurological Sciences. May. Suppl 2. 2007;28:S239-41. [pmid: 17508181].
223 Dowson AJ, Charlesworth BR, Green J, et al. Zolmitriptan nasal spray exhibits good long-term safety and tolerability in migraine: results of the INDEX trial. Headache. Jan. 2005;45(1):17-24. [pmid: 15663608].
224 Dowson AJ, D'Amico D, Tepper SJ, et al. Identifying patients who require a change in their current acute migraine treatment: the Migraine Assessment of Current Therapy (Migraine-ACT) questionnaire. Neurological Sciences. Oct. Suppl 3. 2004;25:S276-8. [pmid: 15549559].
225 Dowson AJ, Gross MLP, Couch J Jr. Functional improvement and patient acceptability of BMS-180048 in the treatment of patients with acute migraine. Functional Neurology. 1996:147.
226 Dowson AJ, Massiou H, Aurora SK. Managing migraine headaches experienced by patients who self-report with menstrually related migraine: a prospective, placebo-controlled study with oral sumatriptan. J Headache Pain. Apr. 2005;6(2):81-7. [pmid: 16362647].
227 Dowson AJ, Massiou H, Lainez JM, et al. Almotriptan is an effective and well-tolerated treatment for migraine pain: results of a randomized, double-blind, placebo-controlled clinical trial. Cephalalgia. Jul. 2002;22(6):453-61. [pmid: 12133045].
228 Dowson AJ, Massiou H, Lainez JM, et al. Almotriptan improves response rates when treatment is within 1 hour of migraine onset. Headache. Apr. 2004;44(4):318-22. [pmid: 15109355].
229 Drance SM. Some clinical implications of the collaborative normal tension glaucoma study. Klinika oczna. 2004:588-92. [pmid: 15646475].
230 Drummond PD. Effect of tryptophan depletion on symptoms of motion sickness in migraineurs. Neurology. Aug. 23. 2005;65(4):620-2. [pmid: 16116130].
231 Drury RL, DeRisi WJ, Liberman RP. Temperature biofeedback treatment for migraine headache: a controlled multiple baseline study. Headache. 1979:278-84. [pmid: 381252].
232 Duley L. Pre-eclampsia, eclampsia, and hypertension. Clin Evid (Online). 2011. [pmid: 21718554].
233 Dyb G, Holmen TL, Zwart JA. Analgesic overuse among adolescents with headache: the Head-HUNT-Youth Study. Neurology. Jan. 24. 2006;66(2):198-201. [pmid: 16434653].
234 Earl NL. Clinical safety of 311C90: aggregated data from patients and volunteers to date. Eur Neurol. Suppl 2. 1996;36:8-12. [pmid: 8791026].
235 Egger J, Carter CH, Soothill JF, et al. Effect of diet treatment on enuresis in children with migraine or hyperkinetic behavior. Clin Pediatr (Phila). May. 1992;31(5):302-7. [pmid: 1582098].
236 Egger J, Carter CM, Soothill JF, et al. Oligoantigenic diet treatment of children with epilepsy and migraine. The Journal of pediatrics. 1989:51-8. [pmid: 2909707].
237 Ehrenberg BL. Acute migraine treatment with droperidol. Neurology. Dec. 23. 2003;61(12):1826. author reply. [pmid: 14694067].
238 Eikermann A, Diener HC. Effect of active treatment is lower when using placebo control in clinical trials on acute therapy of migraine. Cephalalgia. 2004:344-7.
239 Ellis GL, Delaney J, DeHart DA, et al. The efficacy of metoclopramide in the treatment of migraine headache. Ann Emerg Med. Feb. 1993;22(2):191-5. [pmid: 8427430].
240 Ensink FBM, Dahlof C, Tournilhac M, et al. Evaluation of a multiple-dose regiment of oral sumatriptan for the acute treatment of migraine. Eur Neurol. 1991:306-13. [pmid: 1653138].
241 Evans RW. Treating migraine in the emergency department. BMJ. Jun. 14. 2008;336(7657):1320. [pmid: 18541609].
242 Evans RW, Lipton RB, Ritz KA. A survey of neurologists on self-treatment and treatment of their families. Headache. Jan. 2007;47(1):58-64. [pmid: 17355495].
243 Evans RW, Young WB. Droperidol and other neuroleptics/antiemetics for the management of migraine. Headache. Jul–Aug. 2003;43(7):811-3. [pmid: 12890142].
244 Evers S, Rahmann A, Kraemer C, et al. Treatment of childhood migraine attacks with oral zolmitriptan and ibuprofen. Neurology. Aug. 8. 2006;67(3):497-9. [pmid: 16775229].
245 Evers S, Vollmer-Haase J, Schwaag S, et al. Botulinum toxin A in the prophylactic treatment of migraine--a randomized, double-blind, placebo-controlled study. Cephalalgia. Oct. 2004;24(10):838-43. [pmid: 15377314].
246 Facchinetti F, Allais G, Nappi RE, et al. Sumatriptan (50 mg tablets vs. 25 mg suppositories) in the acute treatment of menstrually related migraine and oral contraceptive-induced menstrual migraine: a pilot study. Gynecol Endocrinol. Oct. 2010;26(10):773-9. [pmid: 20528213].
247 Facchinetti F, Bonellie G, Kangasniemi P, et al. The efficacy and safety of subcutaneous sumatriptan in the acute treatment of menstrual migraine. The Sumatriptan Menstrual Migraine Study Group. Obstetrics and gynecology. 1995:911-6. [pmid: 7501338].
248 Fadeyi MO, Adams QM. Use of botulinum toxin type B for migraine and tension headaches. American Journal of Health-System Pharmacy. Oct. 1. 2002;59(19):1860-2. [pmid: 12374073].
249 Farmer K, Cady R, Bleiberg J, et al. Sumatriptan nasal spray and cognitive function during migraine: results of an open-label study. Headache. Apr. 2001;41(4):377-84. [pmid: 11318884].
250 Featherstone HJ. Low-dose propranolol therapy for aborting migraine. Western Journal of Medicine. Mar. 1983;138(3):416-7. [pmid: 6858129].
251 Feleppa M, Apice G, D'Alessio A, et al. Tolerability of acute migraine medications: influence of methods of assessment and relationship with headache attributes. Cephalalgia. Oct. 2008;28(10):1012-6. [pmid: 18727650].
252 Ferrari A, Leone S, Tacchi R, et al. The link between pain patient and analgesic medication is greater in migraine than in rheumatic disease patients. Cephalalgia. Jan. 2009;29(1):31-7. [pmid: 18771492].
253 Ferrari A, Spaccapelo L, Sternieri E. Pharmacoepidemiology of triptans in a headache centre. Cephalalgia. Jul. 2010;30(7):847-54. [pmid: 20647176].
254 Ferrari M, Bayliss EM, Ludlow S, et al. Subcutaneous Gr43175 in the treatment of acute migraine: an international study. Cephalalgia. 1989:348.
255 Ferrari MD. Subcutaneous sumatriptan in the acute treatment of migraine. [abstract]. Canadian Journal of Neurological Sciences. 1993.
256 Ferrari MD. Subcutaneous sumatriptan in the acute treatment of migraine. Can-J-Neurological-Sci. 1994:S37.
257 Ferrari MD. The clinical effectiveness of 311C90 in the acute treatment of migraine. Eur Neurol. Suppl 2. 1996;36:4-7. [pmid: 8791025].
258 Ferrari MD. Tripstar: a comprehensive patient-based approach to compare triptans. Headache. Jan. Suppl 1. 2002;42:18-25. [pmid: 11966860].
259 Ferrari MD, Gijsman H, Block GA, et al. Double-blind, placebo-controlled, dose-findingstudy of rizatriptan (MK-0462) in acute migraine. Functional Neurology. 1996:149.
260 Ferrari MD, Goadsby PJ, Roon KI, et al. Triptans (serotonin, 5-HT1B/1D agonists) in migraine: detailed results and methods of a meta-analysis of 53 trials. Cephalalgia. Oct. 2002;22(8):633-58. [pmid: 12383060].
261 Ferriere G. Flunarizine in the prophylactic treatment of paediatric migraine. Cephalalgia. 1985;5(Suppl 3):176-7. PMID.
262 Fiesseler FW, Shih R, Szucs P, et al. Steroids for migraine headaches: a randomized double-blind, two-armed, placebo-controlled trial. J Emerg Med. Apr. 2011;40(4):463-8. [pmid: 19846269].
263 Findley LJ, Abbas A, Bayliss E. The acute treatment of migraine with aura with sumatriptan. Cephalalgia. 1991:226-7.
264 Fioroni L, Sances G, Martignoni E, et al. Perimenstrual headache prophylaxis with dihydroergokriptine. Cephalalgia. 1991;11(Suppl 11):199-200. PMID.
265 Fleishaker JC, Pearson LK, Knuth DW, et al. Pharmacokinetics and tolerability of a novel 5-HT1D agonist, PNU-142633F. International journal of clinical pharmacology and therapeutics. 1999:487-92. [pmid: 10543315].
266 Fleishaker JC, Ryan KK, Carel BJ, et al. Evaluation of the potential pharmacokinetic interaction between almotriptan and fluoxetine in healthy volunteers. Journal of clinical pharmacology. 2001:217-23. [pmid: 11210405].
267 Fletcher PE, McDonald S, Lowy MT. Long-term safety, efficacy and pattern of usage of 311C90 in the acute oral treatments of migraine. Functional Neurology. 1996:153.
268 Foley KA, Cady R, Martin V, et al. Treating early versus treating mild: timing of migraine prescription medications among patients with diagnosed migraine. Headache. May. 2005;45(5):538-45. [pmid: 15953272].
269 Forteza AM, Brozman B, Rabinstein AA, et al. Acetazolamide for the treatment of migraine with aura in CADASIL. Neurology. Dec. 11. 2001;57(11):2144-5. [pmid: 11739850].
270 Fox AW, Keywood C, Sheftell FD, et al. Comparison of therapeutic gain with therapeutic ratio for the assessment of selective 5HT(1B/1D) agonist efficacy in migraine. Headache. Jul–Aug. 2002;42(7):680-8. [pmid: 12482223].
271 Freitag F, Smith T, Mathew N, et al. Effect of early intervention with almotriptan vs placebo on migraine-associated functional disability: results from the AEGIS Trial. Headache. Mar. 2008;48(3):341-54. [pmid: 18302700].
272 Freitag FG, Cady R, DiSerio F, et al. Comparative study of a combination of isometheptene mucate, dichloralphenazone with acetaminophen and sumatriptan succinate in the treatment of migraine. Headache. Apr. 2001;41(4):391-8. [pmid: 11318886].
273 Freitag-Frederick G. The acute treatment of migraine with transnasal butorphanol (TNB). Headache Quarterly. 1993:22-8.
274 Friedenberg S, Dodick DW. Migraine-associated seizure: a case of reversible MRI abnormalities and persistent nondominant hemisphere syndrome. Headache. Jun. 2000;40(6):487-90. [pmid: 10849047].
275 Friedman AP, Di SFJ, Hwang DS. Symptomatic relief of migraine: Multicenter comparison of Cafergot( (R)) P-B, Cafergot( (R)), and placebo. Clin Ther. 1989:170-82. [pmid: 2497984].
276 Friedman BW, Bijur PE, Lipton RB. Standardizing emergency department-based migraine research: an analysis of commonly used clinical trial outcome measures. Academic Emergency Medicine. Jan. 2010;17(1):72-9. [pmid: 20078439].
277 Friedman BW, Corbo J, Lipton RB, et al. A trial of metoclopramide vs sumatriptan for the emergency department treatment of migraines. Neurology. Feb. 8. 2005;64(3):463-8. [pmid: 15699376].
278 Friedman BW, Mulvey L, Esses D, et al. Metoclopramide for acute migraine: a dose-finding randomized clinical trial. Ann Emerg Med. May. 2011;57(5):475-82. e1. [pmid: 21227540].
279 Friedman BW, Solorzano C, Esses D, et al. Treating headache recurrence after emergency department discharge: a randomized controlled trial of naproxen versus sumatriptan. Ann Emerg Med. Jul. 2010;56(1):7-17. [pmid: 20303198].
280 Friedman MH. Migraine, tension-type headache and facial pain. A common intraoral etiology and treatment. New York State Dental Journal. Jun–Jul. 2002;68(6):24-6. [pmid: 12149787].
281 Friedman MH. Local inflammation as a mediator of migraine and tension-type headache. Headache. Sep. 2004;44(8):767-71. [pmid: 15330822].
282 Fulton JA, Kahn J, Nelson LS, et al. Renal infarction during the use of rizatriptan and zolmitriptan: two case reports. Clinical Toxicology: The Official Journal of the American Academy of Clinical Toxicology & European Association of Poisons Centres & Clinical Toxicologists. 2006;44(2):177-80. [pmid: 16615676].
283 Furlan AJ, Reisman M, Massaro J, et al. Study design of the CLOSURE I Trial: a prospective, multicenter, randomized, controlled trial to evaluate the safety and efficacy of the STARFlex septal closure system versus best medical therapy in patients with stroke or transient ischemic attack due to presumed paradoxical embolism through a patent foramen ovale. Stroke; a journal of cerebral circulation. 2010:2872-83.
284 Gaby AR. Intravenous nutrient therapy: the "Myers' cocktail". Alternative Medicine Review. Oct. 2002;7(5):389-403. [pmid: 12410623].
285 Gallagher RM. Acute treatment of migraine with dihydroergotamine nasal spray. Dihydroergotamine Working Group. Archives of neurology. 1996:1285-91. [pmid: 8970458].
286 Gandolfi SA, Cimino L. Shortterm effect of brimonidine and apraclonidine on central visual function and iop in humans. a cross-over study. Iovs. 1998. ARVO Abstract 2195.
287 Gauthier J, Bois R, Allaire D, et al. Evaluation of skin temperature biofeedback training at two different sites for migraine. J Behav Med. Dec. 1981;4(4):407-19. [pmid: 7338895].
288 Gendolla A. Part I what do patients really need and want from migraine treatment?. Current Medical Research & Opinion. Suppl 3. 2005;21:S3-7. [pmid: 16083517].
289 Geraud G, Olesen J, Pfaffenrath V, et al. Comparison of the efficacy of zolmitriptan and sumatriptan: issues in migraine trial design. Cephalalgia. Feb. 2000;20(1):30-8. [pmid: 10817444].
290 Geraud G, Spierings ELH, Keywood C. Tolerability and safety of frovatriptan with short- and long-term use for treatment of migraine and in comparison with sumatriptan. Headache. Apr. Suppl 2. 2002;42:S93-9. [pmid: 12028325].
291 Gerber WD, Haag G, Grotemeyer KH, et al. Differential efficacy of ergotamine, paracetamol and ergotamine-paracetamol-combination in the treatment of acute migraine attacks: A multicenter doubleblind study. Cephalalgia. 1991:174.
292 Gerhardt RT, Hermstad E, Crawford DM, et al. Postdischarge secobarbital after ED migraine treatment decreases pain and improves resolution. Am J Emerg Med. Jan. 2011;29(1):86-90. [pmid: 20825791].
293 Gerth WC, McCarroll KA, Santanello NC, et al. Patient satisfaction with rizatriptan versus other triptans: direct head-to-head comparisons. Int J Clin Pract. Oct. 2001;55(8):552-6. [pmid: 11695077].
294 Ghose K, Coppen A, Carrol D. Intravenous tyramine response in migraine before and during treatment with indoramin. Br Med J. May. 7. 1977;1(6070):1191-3. [pmid: 324566].
295 Ghossaini SN, Spitzer JB, Mackins CC, et al. High-frequency pulsed electromagnetic energy in tinnitus treatment. The Laryngoscope. 2004:495-500. [pmid: 15091224].
296 Gillman MA, Lichtigfeld FJ. Analgesic nitrous oxide: an opioid treatment for migraine. American Journal of Emergency Medicine. Jul. 2000;18(4):501. [pmid: 10919548].
297 Ginsburg R, Schroeder JS. The short and long-term efficacy of diltiazem for the treatment of variant angina pectoris. Archives des maladies du coeur et des vaisseaux. 1983:149-52. [pmid: 6407438].
298 Glauser T, Sachdeo R, Ritter F, et al. Topiramate in Lennox-Gastaut syndrome: a double blind trial. Neurology. 1997;48:1729. PMID.
299 Goadsby PJ. 311C90, a novel 5-HT1B/1D receptor agonist: the assessment of efficacy and tolerability in the acute treatment of migraine. [abstract]. Neurology. 1997:A86.
300 Goadsby PJ, Ferrari MD, Olesen J, et al. Eletriptan in acute migraine: A double-blind, placebo-controlled comparison to sumatriptan. Neurology. 2000:156-63. [pmid: 10636142].
301 Goadsby PJ, Keywood CG. Investigation of the role of mGluR5 inhibition in migraine: a proof of concept study of ADX10059 in acute treatment of migraine. Neurology. 2009:A285. Abstract no: P06.006.
302 Gobel H, Heinze A. The Migraine Intervention Score - a tool to improve efficacy of triptans in acute migraine therapy: the ALADIN study. Int J Clin Pract. Aug. 2011;65(8):879-86. [pmid: 21762313].
303 Gobel H, Heinze A, Dworschak M, et al. Analgesic efficacy and tolerability of locally applied oleum menthae piperitae preparation LI 170 in patients with migraine or tension-type headache. Zeitschrift fur Allgemeinmedizin. 2001:287-95.
304 Gobel H, Krapat S. Psychological status during migraine attack and interval before and after treatment with a selective 5-HT1-agonist. Headache. 1993:118-20. [pmid: 8387474].
305 Gobel H, Krapat S, Ensink FB, et al. Comparison of contingent negative variation between migraine interval and migraine attack before and after treatment with sumatriptan. Headache. Nov–Dec. 1993;33(10):570-2. [pmid: 8294198].
306 Gobel H, Schenkl S. Post-lumbar puncture headache: The relation between experimental suprathreshold pain sensitivity and a quasi-experimental clinical pain syndrome. Pain. 1990:267-78. [pmid: 2326093].
307 Gobel H, Winter P, Boswell D, et al. Comparison of naratriptan and sumatriptan in recurrence-prone migraine patients. Naratriptan International Recurrence Study Group. Clin Ther. Aug. 2000;22(8):981-9. [pmid: 10972634].
308 Gobel H, Winter P, Boswell D, et al. Comparison of naratriptan and sumatriptan in recurrence-prone migraine patients. Clinical Therapeutics. 2000:981-9. [pmid: 10972634].
309 Gode S, Celebisoy N, Kirazli T, et al. Clinical assessment of topiramate therapy in patients with migrainous vertigo. Headache. Jan. 2010;50(1):77-84. [pmid: 19656221].
310 Goldberg MR, Lowry RC, Musson DG, et al. Lack of pharmacokinetic and pharmacodynamic interaction between rizatriptan and paroxetine. Journal of clinical pharmacology. 1999:192-9. [pmid: 11563413].
311 Goldberg MR, Sciberras D, De Smet M, et al. Influence of beta-adrenoceptor antagonists on the pharmacokinetics of rizatriptan, a 5-HT1B/1D agonist: differential effects of propranolol, nadolol and metoprolol. British journal of clinical pharmacology. 2001:69-76. [pmid: 11453892].
312 Goldstein J, Gawel MJ, Winner P, et al. Comparison of butorphanol nasal spray and fiorinal with codeine in the treatment of migraine. Headache. Jul–Aug. 1998;38(7):516-22. [pmid: 15613167].
313 Goldstein J, Hoffman HD, Armellino JJ, et al. Successful treatment of severe, disabling migraine headache with non-prescription combination of acetaminophen, aspirin and caffeine. Results from three randomized, placebp-controlled studies. Functional Neurology. 1998:187-8.
314 Goldstein J, Hoffman HD, Armellino JJ, et al. Successful treatment of severe, disabling migraine headache with a non-prescription combination of acetaminophen, aspirin and caffeine: results from three randomised, placebo-controlled studies. [abstract]. Neurology. 1998:A377-8.
315 Goldstein J, Ryan R, Jiang K, et al. Crossover comparison of rizatriptan 5 mg and 10 mg versus sumatriptan 25 mg and 50 mg in migraine. Rizatriptan Protocol 046 Study Group. Headache. Nov–Dec. 1998;38(10):737-47. [pmid: 11284462].
316 Goldstein J, Ryan RE, Elkind AH. A double-blind trial of BMS-180048 at 75 mg, 150 mg and 200 mg in the acute treatment of migraine headaches. Functional Neurology. 1996:147.
317 Goldstein J, Silberstein SD, Saper JR, et al. Acetaminophen, aspirin, and caffeine versus sumatriptan succinate in the early treatment of migraine: results from the ASSET trial. Headache. Sep. 2005;45(8):973-82. [pmid: 16109110].
318 Gomez-Mancilla B, Cutler NR, Leibowitz MT, et al. Safety and efficacy of PNU-142633, a selective 5-HT<inf>1D</inf> agonist, in patients with acute migraine. Cephalalgia. 2001:727-32. [pmid: 11595000].
319 Gordon ML, Lipton RB, Brown SL, et al. Headache and cortisol responses to m-chlorophenylpiperazine are highly correlated. Cephalalgia. 1993:400-5. [pmid: 8313453].
320 Gross ML, Kay J, Turner AM, et al. Long-term efficacy of subcutaneous sumatriptan using a novel self-injector. Headache. Nov–Dec. 1995;35(10):601-6. [pmid: 8550361].
321 Gruppo LQ Jr. Intravenous Zofran for headache. Journal of Emergency Medicine. Aug. 2006;31(2):228-9. [pmid: 17044590].
322 Gupta R, Gernsheimer J. Treating headache in the emergency ward: avoiding the migraine-meperidine trap. Annals of Emergency Medicine. Jul. 2003;42(1):161. author reply -2. [pmid: 12852415].
323 Guttuso TJ Jr. Gabapentin's effects on hot flashes and hypothermia. Neurology. Jun. 13. 2000;54(11):2161-3. [pmid: 10851385].
324 Haake M, Boddeker IR, Decker T, et al. Side-effects of extracorporeal shock wave therapy (ESWT) in the treatment of tennis elbow. Arch Orthop Trauma Surg. May. 2002;122(4):222-8. [pmid: 12029512].
325 Haas DC, Sheehe PR. Dextroamphetamine pilot crossover trials and n of 1 trials in patients with chronic tension-type and migraine headache. Headache. Nov–Dec. 2004;44(10):1029-37. [pmid: 15546268].
326 Hagen K, Albretsen C, Vilming ST, et al. Management of medication overuse headache: 1-year randomized multicentre open-label trial. Cephalalgia. Feb. 2009;29(2):221-32. [pmid: 18823363].
327 Hakkarainen H, Gustafsson B, Stockman O. A comparative trial of ergotamine tartrate, acetyl salicylic acid and a dextropropoxyphene compound in acute migraine attacks. Headache. 1978:35-9. [pmid: 348645].
328 Hakkarainen H, Parantainen J, Gothoni G, et al. Tolfenamic acid and caffeine: a useful combination in migraine. Cephalalgia. Dec. 1982;2(4):173-7. [pmid: 6984358].
329 Hakkarainen H, Quiding H, Stockman O. Mild analgesics as an alternative to ergotamine in migraine. A comparative trial with acetylsalicylic acid, ergotamine tartrate, and a dextropropoxyphene compound. J Clin Pharmacol. 1980:590-5. [pmid: 7440766].
330 Hakkarainen H, Vapaatalo H, Gothoni G, et al. Tolfenamic acid is as effective as ergotamine during migraine attacks. Lancet. Aug. 18. 1979;2(8138):326-8. [pmid: 89390].
331 Hakkarainen H, Allonen H. Ergotamine vs. metroclopramide vs. their combination in acute migraine attacks. Headache. 1982:10-2. [pmid: 17152739].
332 Halloul Z, Meyer F, Lippert H, et al. Ergotamine-induced acute vascular insufficiency of the lower limb--a case report. Angiology. Mar. 2001;52(3):217-21. [pmid: 11269787].
333 Halpern MT, Lipton RB, Cady RK, et al. Costs and outcomes of early versus delayed migraine treatment with sumatriptan. Headache. Nov–Dec. 2002;42(10):984-99. [pmid: 12453030].
334 Hamalainen ML, Hoppu K, Santavuori P. Sumatriptan for migraine attacks in children: a randomized placebo-controlled study. Do children with migraine respond to oral sumatriptan differently from adults?. Neurology. Apr. 1997;48(4):1100-3. [pmid: 9109909].
335 Hamalainen ML, Hoppu K, Santavuori PR. Oral dihydroergotamine for therapy-resistant migraine attacks in children. Pediatr Neurol. Feb. 1997;16(2):114-7. [pmid: 9090684].
336 Harle DE, Shepherd AJ, Evans BJW. Visual stimuli are common triggers of migraine and are associated with pattern glare. Headache. Oct. 2006;46(9):1431-40. [pmid: 17040340].
337 Havanka H, Dahlof C, Pop PHM, et al. Efficacy of naratriptan tablets in the acute treatment of migraine: A dose-ranging study. Clinical Therapeutics. 2000:970-80. [pmid: 10972633].
338 Havanka-Kanniainen H. Acute migraine attack therapy: ibuprofen and placebo compared. [abstract]. International journal of clinical pharmacology and therapeutics. 1988:171.
339 Havanka-Kanniainen H. Treatment of acute migraine attack: ibuprofen and placebo compared. Headache. 1989:507-9. [pmid: 2676908].
340 Hawken ER, Delva NJ, Lawson JS. Successful use of propranolol in migraine associated with electroconvulsive therapy. Headache. Jan. 2001;41(1):92-6. [pmid: 11168610].
341 Hay E, Rodrig J, Hussain A, et al. Rizatriptan RPD for severe migraine in the emergency department--a multicenter study. Journal of Emergency Medicine. Oct. 2003;25(3):245-9. [pmid: 14585450].
342 Heikkila M. Puerperal insertion of a copper-releasing and a levonorgestrel-releasing intrauterine contraceptive device. Contraception. Jun. 1982;25(6):561-72. [pmid: 6811195].
343 Heikkinen J, Vaheri R, Timonen U. Long-term safety and tolerability of continuous-combined hormone therapy in postmenopausal women: results from a seven-year randomised comparison of low and standard doses. The journal of the British Menopause Society. 2004:95-102. [pmid: 15494100].
344 Hellings JA, Barth FX, Logan M, et al. Overnight versus progressive conversion of multiple daily-dose divalproex to once-daily divalproex extended release: which strategy is better tolerated by adults with intellectual disabilities?. Journal of clinical psychopharmacology. 2009:492-5. [pmid: 19745651].
345 Henry KA. Memantine for the prophylaxis of chronic tension-type headache. Curr Pain Headache Rep. Dec. 2009;13(6):423-4. [pmid: 19889282].
346 Henry P, Hiesse PO, Dillenschneider A, et al. Efficacy and tolerance of effervescent aspirin-metoclopramide association in the treatment of migraine attack. A randomized, double blind, placebo controlled study. Presse Medicale. 1995:254-8.
347 Hering-Hanit R, Yavetz A, Dagan Y. Effect of withdrawal of misused medication on sleep disturbances in migraine sufferers with chronic daily headache. Headache. Nov–Dec. 2000;40(10):809-12. [pmid: 11135024].
348 Hershey AD, Powers SW, LeCates S, et al. Effectiveness of nasal sumatriptan in 5- to 12-year-old children. Headache. Jul–Aug. 2001;41(7):693-7. [pmid: 11554957].
349 Hewitt DJ, Aurora SK, Dodick DW, et al. Randomized controlled trial of the CGRP receptor antagonist MK-3207 in the acute treatment of migraine. Cephalalgia. Apr. 2011;31(6):712-22. [pmid: 21383045].
350 Hirata K, Kubo J, Arai M, et al. Alternate numbness in the upper extremities as the initial symptom of basilar migraine: an electrophysiological evaluation using EEG power topography. Internal Medicine. Oct. 2000;39(10):852-5. [pmid: 11030214].
351 Hirt D, Lataste X, Taylor P. A comparison of DHE nasal spray and Cafergot(TM) in acute migraine. Cephalalgia. 1989:410-1.
352 Ho TW. Clinical profile of the novel oral CGRP receptor antagonist telcagepant for the acute treatment of migraine in phase 3 studies. Journal of the Neurological Sciences. 2009:S149. Abstract no: FP58-FR-04.
353 Ho TW, Ferrari MD, Dodick DW, et al. Clinical profile of the novel oral CGRP receptor antagonist telcagepant for the acute treatment of migraine in two phase 3 randomized placebo controlled trials. Neurology. 2009:A250. Abstract no: IN4-1.006.
354 Ho TW, Olesen J, Dodick DW, et al. Antimigraine efficacy of telcagepant based on patient's historical triptan response. Headache. Jan. 2011;51(1):64-72. [pmid: 21054362].
355 Ho TW, Rodgers A, Bigal ME. Impact of recent prior opioid use on rizatriptan efficacy. A post hoc pooled analysis. Headache. Mar. 2009;49(3):395-403. [pmid: 19222588].
356 Holroyd KA, Cordingley GE, Pingel JD, et al. Enhancing the effectiveness of abortive therapy: a controlled evaluation of self-management training. Headache. Mar. 1989;29(3):148-53. [pmid: 2496052].
357 Holroyd KA, Holm JE, Hursey KG, et al. Recurrent vascular headache: home-based behavioral treatment versus abortive pharmacological treatment. J Consult Clin Psychol. Apr. 1988;56(2):218-23. [pmid: 3286705].
358 Hsu DA, Stafstrom CE, Rowley HA, et al. Hemiplegic migraine: hyperperfusion and abortive therapy with intravenous verapamil. Brain & Development. Jan. 2008;30(1):86-90. [pmid: 17614229].
359 Hu HQ, Zhou YH, Wang XL. Clinical study on effect of Xiaoyao Nose Drops in stopping episode of migraine. Chin J Integr Med. Jun. 2006;12(2):112-7. [pmid: 16800989].
360 Hu XH, Raskin NH, Cowan R, et al. Treatment of migraine with rizatriptan: when to take the medication. Headache. Jan. 2002;42(1):16-20. [pmid: 12005270].
361 Humbert H, Cabiac MD, Dubray C, et al. Human pharmacokinetics of dihydroergotamine administered by nasal spray. Clinical pharmacology and therapeutics. 1996:265-75. [pmid: 8841149].
362 Hunninghake DB, Davidson M, Knapp HR, et al. Extended-release fluvastatin 80 mg shows greater efficacy, with comparable tolerability, versus immediate-release fluvastatin 40 mg for once daily treatment of primary hypercholesterolaemia. British Journal of Cardiology. 2002:469-75.
363 Hunt S, Russell A, Smithson WH, et al. Topiramate in pregnancy: preliminary experience from the UK Epilepsy and Pregnancy Register. Neurology. Jul. 22. 2008;71(4):272-6. [pmid: 18645165].
364 Hurtado TR, Vinson DR, Vandenberg JT. ED treatment of migraine headache: factors influencing pharmacotherapeutic choices. Headache. Sep. 2007;47(8):1134-43. [pmid: 17883518].
365 Hyson MI. Anticephalgic photoprotective premedicated mask. A report of a successful double-blind placebo-controlled study of a new treatment for headaches with associated frontalis pain and photophobia. Headache. 1998:475-7. [pmid: 9664755].
366 Ifergane G, Wirguin I, Shvartzman P. Triptans--why once?. Headache. Sep. 2006;46(8):1261-3. [pmid: 16942470].
367 Ikeda Y, Jimbo H, Shimazu M, et al. Sumatriptan scavenges superoxide, hydroxyl, and nitric oxide radicals: in vitro electron spin resonance study. Headache. Oct. 2002;42(9):888-92. [pmid: 12390615].
368 Ilacqua GE. Migraine headaches: coping efficacy of guided imagery training. Headache. Feb. 1994;34(2):99-102. [pmid: 8163375].
369 Irimia P, Palma JA, Fernandez-Torron R, et al. Refractory migraine in a headache clinic population. BMC Neurol. 2011;11:94. [pmid: 21806790].
370 Ishkanian G, Blumenthal H, Webster CJ, et al. Efficacy of sumatriptan tablets in migraineurs self-described or physician-diagnosed as having sinus headache: a randomized, double-blind, placebo-controlled study. Clin Ther. Jan. 2007;29(1):99-109. [pmid: 17379050].
371 Itil TM, Herrmann WM, Akpinar S. Prediction of psychotropic properties of lisuride hydrogen maleate by quantitative pharmaco-electroencephalogram. Int J Clin Pharmacol Biopharm. Jul. 1975;12(1–2):221-33. [pmid: 1100539].
372 Iversen HK, Olesen J. Nitroglycerin-induced headache is not dependent on histamine release: support for a direct nociceptive action of nitric oxide. Cephalalgia: an international journal of headache. 1994:437-42. [pmid: 7535192].
373 Jackson NC. Clinical measures of efficacy, safety and tolerability for the acute treatment of migraine: a comparison of eletriptan 20–80mg), sumatriptan (100mg) and placebo. [abstract]. Neurology. 1998:A376.
374 Jamieson D, Cutrer FM, Goldstein J, et al. Real-world experiences in migraine therapy with rizatriptan. Headache. Mar. 2003;43(3):223-30. [pmid: 12603640].
375 Jamieson DG. Rizatriptan. Comparative trial results. Postgraduate Medicine. Sep. 2000;108(3 Suppl):22-8. [pmid: 19667527].
376 Janssen K, Neutgens J. Autogenic training and progressive relaxation in the treatment of three kinds of headache. Behav Res Ther. 1986;24(2):199-208. [pmid: 3964184].
377 Jeavons PM, Clark JE, Maheshwari MC. Treatment of generalized epilepsies of childhood and adolescence with sodium valproate ("epilim"). Dev Med Child Neurol. Feb. 1977;19(1):9-25. [pmid: 403104].
378 Jelinski SE, Becker WJ, Christie SN, et al. Pain free efficacy of sumatriptan in the early treatment of migraine. Can J Neurol Sci. Feb. 2006;33(1):73-9. [pmid: 16583726].
379 Jensen K, Tfelt-Hansen P, Hansen EW, et al. Introduction of a novel self-injector for sumatriptan. A controlled clinical trial in general practice. Cephalalgia. Oct. 1995;15(5):423-9. [pmid: 8536304].
380 Jensen K, Tfelt-Hansen P, Lauritzen M, et al. Clinical trial of nimodipine for single attacks of classic migraine. Cephalalgia. Sep. 1985;5(3):125-31. [pmid: 3899368].
381 Jhee SS, Salazar DE, Ford NF, et al. A double-blind, randomized, crossover assessment of blood pressure following administration of avitriptan, sumatriptan, or placebo to patients with mild to moderate hypertension. Cephalalgia: an international journal of headache. 1999:95-9. [pmid: 10214534].
382 Johannessen Landmark C, Larsson PG, Rytter E, et al. Antiepileptic drugs in epilepsy and other disorders--a population-based study of prescriptions. Epilepsy Research. Nov. 2009;87(1):31-9. [pmid: 19679449].
383 Johnson CA, Sample PA, Trick GL, et al. Short Wavelength Automated Perimetry (swap) In The Ocular Hypertension Treatment Study (ohts). Iovs. 2002. ARVO E-abstract 2136.
384 Johnson ES, Ratcliffe DM, Wilkinson M. Naproxen sodium in the treatment of migraine. Cephalalgia. Mar. 1985;5(1):5-10. [pmid: 3886154].
385 Joish VN, Cady PS, Shaw JW. Health care utilization by migraine patients: a 1998 Medicaid population study. Clinical Therapeutics. Nov. 2000;22(11):1346-56. [pmid: 11117659].
386 Jouvent R. Dihydrergocryptine plus caffeine in treatment of migraine: A randomized double-blind trial against placebo. <ORIGINAL> STRATEGIES THERAPEUTIQUES. Gaz Med. 1989:41-6.
387 Jovicic A, Maric D, Ilic T. Treatment of the acute migraine attacks. Vojnosanitetski Pregled. 1995:44-8. [pmid: 7638950].
388 Jurish SE, Blanchard EB, Andrasik F, et al. Home- versus clinic-based treatment of vascular headache. J Consult Clin Psychol. Oct. 1983;51(5):743-51. [pmid: 6630689].
389 Kabbouche MA, Powers SW, Segers A, et al. Inpatient treatment of status migraine with dihydroergotamine in children and adolescents. Headache. Jan. 2009;49(1):106-9. [pmid: 19125879].
390 Kabbouche MA, Powers SW, Vockell A-LB, et al. Carnitine palmityltransferase II (CPT2) deficiency and migraine headache: two case reports. Headache. May. 2003;43(5):490-5. [pmid: 12752755].
391 Kabbouche MA, Vockell AL, LeCates SL, et al. Tolerability and effectiveness of prochlorperazine for intractable migraine in children. Pediatrics. Apr. 2001;107(4):E62. [pmid: 11335783].
392 Kallen B, Nilsson E, Otterblad Olausson P. Delivery outcome after maternal use of drugs for migraine: a register study in Sweden. Drug Safety. Aug. 1. 2011;34(8):691-703. [pmid: 21751829].
393 Kaniecki R, Ruoff G, Smith T, et al. Prevalence of migraine and response to sumatriptan in patients self-reporting tension/stress headache. Curr Med Res Opin. Aug. 2006;22(8):1535-44. [pmid: 16870078].
394 Kaniecki RG. Mixing sumatriptan: a prospective study of stratified care using multiple formulations. Headache. Oct. 2001;41(9):862-6. [pmid: 11703472].
395 Kanwar VS, Pearce J. Acute renal failure in a 17-year-old female with ALL receiving escalating intravenous methotrexate without leukovorin. Pediatric Blood & Cancer. Aug. 2007;49(2):216. author reply 9. [pmid: 16786587].
396 Kapicioglu S, Gokce E, Kapicioglu Z, et al. Treatment of migraine attacks with a long-acting somatostatin analogue (octreotide, SMS 201-995). Cephalalgia. Feb. 1997;17(1):27-30. [pmid: 9051332].
397 Karagiannis DA, Venkatesh P, Kirkpatrick N. Cessation of migraines in a woman with low-tension glaucoma following the use of latanoprost: a favourable side effect?. Eye. Feb. 2007;21(2):293-5. [pmid: 16946757].
398 Katic BJ, Rajagopalan S, Ho TW, et al. Triptan persistency among newly initiated users in a pharmacy claims database. Cephalalgia. Mar. 2011;31(4):488-500. [pmid: 20937605].
399 Katsarava Z, Limmroth V. Is a combination of tramadol and acetaminophen effective for the treatment of acute migraine pain?. Nature Clinical Practice Neurology. Jul. 2006;2(7):360-1. [pmid: 16932584].
400 Kaube H, Herzog J, et al. Aura in some patients with familial hemiplegic migraine can be stopped by intranasal ketamine. Neurology. Jul. 12. 2000;55(1):139-41. [pmid: 10891926].
401 Kaube H, Katsarava Z, Przywara S, et al. Acute migraine headache: possible sensitization of neurons in the spinal trigeminal nucleus?. Neurology. Apr. 23. 2002;58(8):1234-8. [pmid: 11971092].
402 Kellstein DE, Lipton RB, Geetha R, et al. Evaluation of a novel solubilized formulation of ibuprofen in the treatment of migraine headache: a randomized, double-blind, placebo-controlled, dose-ranging study. Cephalalgia. May. 2000;20(4):233-43. [pmid: 10999673].
403 Kelly AM, Kerr D, Clooney M. Impact of oral dexamethasone versus placebo after ED treatment of migraine with phenothiazines on the rate of recurrent headache: a randomised controlled trial. Emerg Med J. Jan. 2008;25(1):26-9. [pmid: 18156535].
404 Kelly A-M, Knott J, Bennetts S, et al. Treatment of migraine in Australian Emergency Departments. Emergency Medicine Australasia. Aug. 2009;21(4):333-4. [pmid: 19682021].
405 Kelman L, Harper SQ, Hu X, et al. Treatment response and tolerability of frovatriptan in patients reporting short- or long-duration migraines at baseline. Curr Med Res Opin. Sep. 2010;26(9):2097-104. [pmid: 20642390].
406 Kemp JP, Cook DA, Incaudo GA, et al. Salmeterol improves quality of life in patients with asthma requiring inhaled corticosteroids. Journal of Allergy and Clinical Immunology. 1998:188-95. [pmid: 9500751].
407 Keyvan G, Abolfazl MB. Comparison of treatment effect of sodium valproate, propranolol and tricyclic antidepressants in migraine. Pak J Biol Sci. Aug. 1. 2009;12(15):1098-101. [pmid: 19943469].
408 Keywood C, Baggish J, Blumenthal HJ, et al. Rapid responders to frovatriptan in acute migraine treatment: results from a long-term, open-label study. Pain Medicine. 2009:633-8. [pmid: 19453958].
409 Kishore-Kumar R, Max MB, Schafer SC, et al. Desipramine relieves postherpetic neuralgia. Clin Pharmacol Ther. Mar. 1990;47(3):305-12. [pmid: 2178851].
410 Kitley JL, Lachmann HJ, Pinto A, et al. Neurologic manifestations of the cryopyrin-associated periodic syndrome. Neurology. 2010:1267-70. [pmid: 20404307].
411 Klapper J, Stanton J. The emergency treatment of acute migraine headache: A comparison of intravenous dihydroergotamine, dexamethasone, and placebo. Cephalalgia. 1991:159-60.
412 Klapper JA, O'Connor S. Rizatriptan wafer--sublingual vs placebo at the onset of acute migraine. Cephalalgia: an international journal of headache. 2000:585-7. [pmid: 11075843].
413 Klapper JA, Stanton J. Current emergency treatment of severe migraine headaches. Headache. Nov–Dec. 1993;33(10):560-2. [pmid: 8294195].
414 Klassen A, Webster C, Laurenza A, et al. Naratriptan tablets are effective and well-tolerated in the acute treatment of migraine: results of a double-blind placebo-controlled parallel-group trial. [abstract]. Neurology. 1997:A66-7.
415 Kolodny A, Polis A, Battisti WP, et al. Comparison of rizatriptan 5 mg and 10 mg tablets and sumatriptan 25 mg and 50 mg tablets. Cephalalgia. Jul. 2004;24(7):540-6. [pmid: 15196296].
416 Korostenskaja M, Pardos M, Kujala T, et al. Impaired auditory information processing during acute migraine: a magnetoencephalography study. Int J Neurosci. Jul. 2011;121(7):355-65. [pmid: 21425948].
417 Koudstaal PJ, Algra A, Pop GA, et al. Risk of cardiac events in atypical transient ischaemic attack or minor stroke. The Dutch TIA Study Group. Lancet. 1992:630-3. [pmid: 1355211].
418 Kozubski W. Metamizole and hydrocortisone for the interruption of a migraine attack--preliminary study. Headache Quarterly. 1992:326-8.
419 Krämer HH, Lundblad L, Birklein F, et al. Activation of the cortical pain network by soft tactile stimulation after injection of sumatriptan. Pain. 2007:72-8. [pmid: 17449179].
420 Kramer MS, Matzura-Wolf D, Getson A, et al. Placebo-controlled double-blind study of Rizatriptan in multiple attacks of acute migraine. [abstract]. Neurology. 1997:A68-9.
421 Kramer MS, Matzura-Wolfe D, Polis A, et al. A placebo-controlled crossover study of rizatriptan in the treatment of multiple migraine attacks. Rizatriptan Multiple Attack Study Group. Neurology. Sep. 1998;51(3):773-81. [pmid: 9748025].
422 Krusz JC, Scott V, Belanger J. Intravenous propofol: unique effectiveness in treating intractable migraine. Headache. Mar. 2000;40(3):224-30. [pmid: 10759925].
423 Kruuse C, Thomsen LL, Birk S, et al. Migraine can be induced by sildenafil without changes in middle cerebral artery diameter. Brain. Jan. 2003;126(Pt 1):241-7. [pmid: 12477710].
424 Krymchantowski AV. Naproxen sodium decreases migraine recurrence when administered with sumatriptan. Arq Neuropsiquiatr. Jun. 2000;58(2B):428-30. [pmid: 10920403].
425 Krymchantowski AV. Monitoring patients' response to acute migraine treatment: a headache attack report form. Headache. Feb. 2006;46(2):346-7. [pmid: 16492255].
426 Krymchantowski AV, Barbosa JS. Dexamethasone decreases migraine recurrence observed after treatment with a triptan combined with a nonsteroidal anti-inflammatory drug. Arquivos de Neuro-Psiquiatria. Sep. 2001;59(3-B):708-11. [pmid: 11593269].
427 Krymchantowski AV, Silva MTT. Intravenous Lysine Clonixinate for the acute treatment of severe migraine attacks: a double-blind, randomized, placebo-controlled study. Current Therapeutic Research, Clinical & Experimental. 2003:505-13.
428 Kunka RL, Hussey EK, Shaw S, et al. Safety, tolerability, and pharmacokinetics of sumatriptan suppositories following single and multiple doses in healthy volunteers. Cephalalgia: an international journal of headache. 1997:532-40. [pmid: 9209775].
429 Kwong WJ. Determinants of migraine emergency department utilization in the georgia medicaid population. Headache. Oct. 2007;47(9):1326-33. [pmid: 17927649].
430 Lainez MJA, Lopez A, Pascual AM. Effects on productivity and quality of life of rizatriptan for acute migraine: a workplace study. Headache. Jul–Aug. 2005;45(7):883-90. [pmid: 15985105].
431 Laloux P, Vakaet A, Monseu G, et al. Subcutaneous sumatriptan compared with usual acute treatments for migraine: clinical and pharmacoeconomic evaluation. Acta Neurol Belg. Dec. 1998;98(4):332-41. [pmid: 9922821].
432 Lampl C, Marecek S, May A, et al. A prospective, open-label, long-term study of the efficacy and tolerability of topiramate in the prophylaxis of chronic tension-type headache. Cephalalgia. Oct. 2006;26(10):1203-8. [pmid: 16961787].
433 Lampl C, Voelker M, Diener HC. Efficacy and safety of 1,000 mg effervescent aspirin: individual patient data meta-analysis of three trials in migraine headache and migraine accompanying symptoms. J Neurol. Jun. 2007;254(6):705-12. [pmid: 17406776].
434 Lance JW, Fine RD, Curran DA. An evaluation of methysergide in the prevention of migraine and other vascular headaches. Med J Aust. 1963:814-8. [pmid: 13928400].
435 Landy SH. Oral transmucosal fentanyl citrate for the treatment of migraine headache pain in outpatients: a case series. Headache. Sep. 2004;44(8):762-6. [pmid: 15330821].
436 Landy SH, McGinnis JE, McDonald SA. Pilot study evaluating preference for 3-mg versus 6-mg subcutaneous sumatriptan. Headache. Apr. 2005;45(4):346-9. [pmid: 15836571].
437 Lane PL, McLellan BA, Baggoley CJ. Comparative efficacy of chlorpromazine and meperidine with dimenhydrinate in migraine headache. Ann Emerg Med. Apr. 1989;18(4):360-5. [pmid: 2705667].
438 Lanteri-Minet M, Diaz-Insa S, Leone M, et al. Efficacy of almotriptan in early intervention for treatment of acute migraine in a primary care setting: the START study. Int J Clin Pract. Jun. 2010;64(7):936-43. [pmid: 20584227].
439 Lantéri-Minet M, Radat F, Chautard MH, et al. Anxiety and depression associated with migraine: influence on migraine subjects' disability and quality of life, and acute migraine management. Pain. 2005:319-26. [pmid: 16289799].
440 Lanzi G, D'Arrigo S, Termine C, et al. The effectiveness of hospitalization in the treatment of paediatric idiopathic headache patients. Psychopathology. 2007:1-7. [pmid: 17057418].
441 Larkin GL, Prescott JE. A randomized, double-blind, comparative study of the efficacy of ketorolac tromethamine versus meperidine in the treatment of severe migraine. Ann Emerg Med. Aug. 1992;21(8):919-24. [pmid: 1497157].
442 Latsko M, Silberstein S, Rosen N. Frovatriptan as preemptive treatment for fasting-induced migraine. Headache. Mar. 2011;51(3):369-74. [pmid: 21269298].
443 Levin M, Ward TN, Larson E. Migraine-tic syndrome: a case report of a new headache type. Cephalalgia. Jan. 2004;24(1):72-3. [pmid: 14687017].
444 Lewis DW, Winner P, Hershey AD, et al. Efficacy of zolmitriptan nasal spray in adolescent migraine. Pediatrics. Aug. 2007;120(2):390-6. [pmid: 17671066].
445 Li Q, Tan G, Zhou J. Basilar-type migraine with coma: case reports and literature review. Pain Med. Apr. 2011;12(4):654-6. [pmid: 21463463].
446 Limmroth V, May A, Auerbach P, et al. Changes in cerebral blood flow velocity after treatment with sumatriptan or placebo and implications for the pathophysiology of migraine. J Neurol Sci. Jun. 1996;138(1–2):60-5. [pmid: 8791240].
447 Linder SL, Dowson AJ. Zolmitriptan provides effective migraine relief in adolescents. International Journal of Clinical Practice. Sep. 2000;54(7):466-9. [pmid: 11070573].
448 Linder SL, Mathew NT, Cady RK, et al. Efficacy and tolerability of almotriptan in adolescents: a randomized, double-blind, placebo-controlled trial. Headache. Oct. 2008;48(9):1326-36. [pmid: 18484981].
449 Lindkvist J, Airaksinen M, Kaukonen AM, et al. Evolution of paediatric off-label use after new significant medicines become available for adults: a study on triptans in Finnish children 1994–2007. Br J Clin Pharmacol. Jun. 2011;71(6):929-35. [pmid: 21564161].
450 Lines CR, Vandormael K, Malbecq W. A comparison of visual analog scale and categorical ratings of headache pain in a randomized controlled clinical trial with migraine patients. Pain. Aug. 2001;93(2):185-90. [pmid: 11427330].
451 Lipton RB, Baggish JS, Stewart WF, et al. Efficacy and safety of acetaminophen in the treatment of migraine: results of a randomized, double-blind, placebo-controlled, population-based study. Arch Intern Med. Dec. 11–25. 2000;160(22):3486-92. [pmid: 11112243].
452 Lipton RB, Bigal ME. Opioid therapy and headache: a cause and a cure. Neurology. May. 25. 2004;62(10):1662-3. [pmid: 15159457].
453 Lipton RB, Cutrer FM, Goadsby PJ, et al. How treatment priorities influence triptan preferences in clinical practice: perspectives of migraine sufferers, neurologists, and primary care physicians. Current Medical Research & Opinion. Mar. 2005;21(3):413-24. [pmid: 15811210].
454 Lipton RB, Dodick DW, Silberstein SD, et al. Single-pulse transcranial magnetic stimulation for acute treatment of migraine with aura: a randomised, double-blind, parallel-group, sham-controlled trial. Lancet Neurol. Apr. 2010;9(4):373-80. [pmid: 20206581].
455 Lipton RB, Pascual J, Goadsby PJ, et al. Effect of rizatriptan and other triptans on the nausea symptom of migraine: a post hoc analysis. Headache. Sep. 2001;41(8):754-63. [pmid: 11576198].
456 Lipton RB, Stewart WF, Ryan RE Jr, et al. Efficacy and safety of acetaminophen, aspirin, and caffeine in alleviating migraine headache pain: three double-blind, randomized, placebo-controlled trials. Arch Neurol. Feb. 1998;55(2):210-7. [pmid: 9482363].
457 Lipton RB, Stewart WF, Stone AM, et al. Stratified care vs step care strategies for migraine: the Disability in Strategies of Care (DISC) Study: A randomized trial. JAMA. Nov. 22–29. 2000;284(20):2599-605. [pmid: 11086366].
458 Liu AS, Wang JN, Zhang JY. Treatment of migraine by "head triple needle" acupuncture: a report of 30 Cases. New Journal of Traditional Chinese Medicine. 1997:25-6.
459 Lloyd DK, Pilgrim AJ. Sumatriptan and recurrence of migraine. Lancet. Oct. 31. 1992;340(8827):1110. [pmid: 1357515].
460 Loder E, Boyle D, Wang L, et al. Comparison of preference for rizatriptan 10 mg or sumatriptan 50 mg tablet for the acute treatment of migraine. Jns. 2001.
461 Loder E, Brandes JL, Silberstein S, et al. Preference comparison of rizatriptan ODT 10-mg and sumatriptan 50-mg tablet in migraine. Headache. Sep. 2001;41(8):745-53. [pmid: 11576197].
462 Loder E, Goldstein R, Biondi D. Placebo effects in oral triptan trials: the scientific and ethical rationale for continued use of placebo controls. Cephalalgia. Feb. 2005;25(2):124-31. [pmid: 15658949].
463 Loder E, Silberstein SD, Abu-Shakra S, et al. Efficacy and tolerability of oral zolmitriptan in menstrually associated migraine: a randomized, prospective, parallel-group, double-blind, placebo-controlled study. Headache. Feb. 2004;44(2):120-30. [pmid: 14756849].
464 Loder EW, Dowson AJ, Spierings ELH. Part II clinical efficacy and tolerability of zolmitriptan orally disintegrating tablet in the acute treatment of migraine. Current Medical Research & Opinion. Suppl 3. 2005;21:S8-12. [pmid: 16083518].
465 Lofland JH, Kim SS, Batenhorst AS, et al. Cost-effectiveness and cost-benefit of sumatriptan in patients with migraine. Mayo Clinic Proceedings. Nov. 2001;76(11):1093-101. [pmid: 11702897].
466 Loisy C, Beorchia S, Centonze V, et al. Effects on migraine headache of MDL 72,222, an antagonist at neuronal 5-HT receptors Double-blind, placebo-controlled study. Cephalalgia: an international journal of headache. 1985:79-82. [pmid: 3893732].
467 Lomia M, Tchelidze T, Pruidze M. Bronchial asthma as neurogenic paroxysmal inflammatory disease: a randomized trial with carbamazepine. Respiratory medicine. 2006:1988-96. [pmid: 16597501].
468 Longmore J, Hargreaves RJ, Boulanger CM, et al. Comparison of the vasoconstrictor properties of the 5-HT(1D)-receptor agonists rizatriptan (MK-462) and sumatriptan in human isolated coronary artery: Outcome of two independent studies using different experimental protocols. Functional Neurology. 1997:3-9. [pmid: 9127118].
469 Lowy MT. 2.5 mg 311C in the acute treatment of migraine: efficacy and safety. [abstract]. European Journal of Neurology. 1996:152.
470 Lu SR, Fuh JL, Juang KD, et al. Migraine prevalence in adolescents aged 13–15 a student population-based study in Taiwan. Cephalalgia. Jun. 2000;20(5):479-85. [pmid: 11037745].
471 Lumme P, Tuulonen A, Airaksinen PJ. Treatment and no treatment in low-tension glaucoma. Investigative Ophthalmology and Visual Science. 1990. Abstract number 2467.
472 Luthringer R, Djupesland PG, Sheldrake CD, et al. Rapid absorption of sumatriptan powder and effects on glyceryl trinitrate model of headache following intranasal delivery using a novel bi-directional device. J Pharm Pharmacol. Sep. 2009;61(9):1219-28. [pmid: 19703372].
473 Maas HJ, Danhof M, Della Pasqua O. A model-based approach to treatment comparison in acute migraine. British Journal of Clinical Pharmacology. Nov. 2006;62(5):591-600. [pmid: 17061965].
474 Maas HJ, Danhof M, Della Pasqua OE. Prediction of headache response in migraine treatment. Cephalalgia. Apr. 2006;26(4):416-22. [pmid: 16556242].
475 MacGregor EA, Dowson A, Davies PT. Mouth-dispersible aspirin in the treatment of migraine: a placebo-controlled study. Headache. Apr. 2002;42(4):249-55. [pmid: 12010380].
476 MacGregor EA, Frith A, Ellis J, et al. Incidence of migraine relative to menstrual cycle phases of rising and falling estrogen. Neurology. Dec. 26. 2006;67(12):2154-8. [pmid: 16971700].
477 MacGregor EA, Frith AA, Hackshaw A. Efficacy, safety, and tolerability of sertraline on depressive symptoms in women with comorbid migraine: an open-label study. Journal of Clinical Psychopharmacology. Jun. 2011;31(3):392-3. [pmid: 21532361].
478 Maggioni F, Mainardi F, Dainese F, et al. Migraine secondary to superior oblique myokymia. Cephalalgia. Nov. 2007;27(11):1283-5. [pmid: 17692104].
479 Maizels M. Headache evaluation and treatment by primary care physicians in an emergency department in the era of triptans. Archives of Internal Medicine. Sep. 10. 2001;161(16):1969-73. [pmid: 11525699].
480 Maizels M. Rizatriptan 5mg is not efficacious for migraine in adolescents. Headache. Sep. 2002;42(8):839-40. author reply 40. [pmid: 12390657].
481 Maizels M, Geiger AM. Intranasal lidocaine for migraine: a randomized trial and open-label follow-up. Headache. Sep. 1999;39(8):543-51. [pmid: 11279969].
482 Maizels M, Scott B, Cohen W, et al. Intranasal lidocaine for treatment of migraine: a randomized, double-blind, controlled trial. JAMA. Jul. 24–31. 1996;276(4):319-21. [pmid: 8656545].
483 Malik SN, Hopkins M, Young WB, et al. Acute migraine treatment: patterns of use and satisfaction in a clinical population. Headache. May. 2006;46(5):773-80. [pmid: 16643580].
484 Malmberg I. Evaluation of the cost effectiveness of zolmitriptan for the acute treatment of migraine. [abstract]. 15th Annual Meeting of the International Society of Technology Assessment in Health Care. 1999 Jun 20–23. 1999:145.
485 Mandema JW, Cox E, Alderman J. Therapeutic benefit of eletriptan compared to sumatriptan for the acute relief of migraine pain--results of a model-based meta-analysis that accounts for encapsulation. Cephalalgia. Sep. 2005;25(9):715-25. [pmid: 16109054].
486 Manna V. Effects of piroxicam-beta-cyclodextrin in the treatment of spontaneous migraine attacks and reserpine-induced headache: Putative serotoninergic involvement in antinociceptive drug activity. Advances in Therapy. 1998:75-84.
487 Marcus DA, Scharff L, Turk D, et al. A double-blind provocative study of chocolate as a trigger of headache. Cephalalgia: an international journal of headache. 1997:855-62. discussion 00. [pmid: 9453274].
488 Mariano Da, Silva H, Alcantara MC, Bordini CA, et al. Strictly unilateral headache reminiscent of hemicrania continua resistant to indomethacin but responsive to gabapentin. Cephalalgia. Jun. 2002;22(5):409-10. [pmid: 12110117].
489 Marino C. Acute migraine treatment guideline. Annals of Internal Medicine. Oct. 7. 2003;139(7):603. author reply -4. [pmid: 14530242].
490 Marschner NW, Adler M, Nagel GA, et al. Double-blind randomised trial of the antiemetic efficacy and safety of ondansetron and metoclopramide in advanced breast cancer patients treated with epirubicin and cyclophosphamide. European journal of cancer (Oxford, England: 1990). 1991:1137-40.
491 Martin C, Bonneru JJ, Brun JP, et al. Vecuronium or suxamethonium for rapid sequence intubation: which is better?. Br J Anaesth. Oct. 1987;59(10):1240-4. [pmid: 2890365].
492 Martin PR, Seneviratne HM. Effects of food deprivation and a stressor on head pain. Health Psychol. Jul. 1997;16(4):310-8. [pmid: 9237082].
493 Martin PR, Todd J, Reece J. Effects of noise and a stressor on head pain. Headache. Nov–Dec. 2005;45(10):1353-64. [pmid: 16324168].
494 Marty J, Benhamou D, Chassard D, et al. Effects of single-dose injectable paracetamol versus propacetamol in pain management after minor gynecologic surgery: a multicenter, randomized, double-blind, active-controlled, two-parallel-group study. Current Therapeutic Research, Clinical & Experimental. 2005:294-306.
495 Massiou H. A comparison os sumatriptan nasal spray and intranasal dhiydroergotamine (DHE) in the acute treatment of migraine. Functional Neurology. 1996:151.
496 Massiou H, Jamin C, Hinzelin G, et al. Efficacy of oral naratriptan in the treatment of menstrually related migraine. Eur J Neurol. Oct. 2005;12(10):774-81. [pmid: 16190915].
497 Massiou H, et al. Evaluation of efficacy, tolerability, and treatment satisfaction with almotriptan in 3 consecutive migraine attacks. The migraine--satisfaction with treatment: reality with Almogran study. European Neurology. 2006;55(4):198-203. [pmid: 16772716].
498 Matharu MS, Cohen AS, McGonigle DJ, et al. Posterior hypothalamic and brainstem activation in hemicrania continua. Headache. Sep. 2004;44(8):747-61. [pmid: 15330820].
499 Mathew NT. Indomethacin responsive headache syndromes. Headache. 1981:147-50. [pmid: 7021474].
500 Mathew NT. Early intervention with almotriptan improves sustained pain-free response in acute migraine. Headache. Nov–Dec. 2003;43(10):1075-9. [pmid: 14629242].
501 Mathew NT, Finlayson G, Smith TR, et al. Early intervention with almotriptan: results of the AEGIS trial (AXERT Early Migraine Intervention Study). Headache. Feb. 2007;47(2):189-98. [pmid: 17300358].
502 Mathew NT, Kailasam J, Meadors L, et al. Intravenous valproate sodium (depacon) aborts migraine rapidly: a preliminary report. Headache. Oct. 2000;40(9):720-3. [pmid: 11091289].
503 Mathew NT, Landy S, Stark S, et al. Fixed-dose sumatriptan and naproxen in poor responders to triptans with a short half-life. Headache. Jul. 2009;49(7):971-82. [pmid: 19486178].
504 Mathew NT, Schoenen J, Winner P, et al. Comparative efficacy of eletriptan 40 mg versus sumatriptan 100 mg. Headache. Mar. 2003;43(3):214-22. [pmid: 12603639].
505 Matta AP, Ribas MC, Moreira Filho PF. Postmeningitis headache: case report. Arquivos de Neuro-Psiquiatria. Jun. 2007;65(2B):521-3. [pmid: 17665028].
506 Mauskop A, Farkkila M, Hering-Hanit R, et al. Zolmitriptan is effective for the treatment of persistent and recurrent migraine headache. Curr Med Res Opin. 1999;15(4):282-9. [pmid: 10640260].
507 May A, Gijsman HJ, Wallnöfer A, et al. Endothelin antagonist bosentan blocks neurogenic inflammation, but is not effective in aborting migraine attacks. Pain. 1996:375-8. [pmid: 8951932].
508 Mazza A, Zamboni S, Cuppini S, et al. Internal carotid artery fibromuscular dysplasia in arterial hypertension: management in clinical practice. Blood Pressure. 2008;17(5–6):274-7. [pmid: 18825547].
509 McBeath JG, Nanda A. Roller coaster migraine: an underreported injury?. Headache. Oct. 2000;40(9):745-7. [pmid: 11091294].
510 McCall RB, Huff R, Chio CL, et al. Preclinical studies characterizing the anti-migraine and cardiovascular effects of the selective 5-HT1D receptor agonist PNU-142633. Cephalalgia. Dec. 2002;22(10):799-806. [pmid: 12485205].
511 McCarty J, Ruoff GE, Jacobson KD. Loracarbef (LY163892) versus cefaclor in the treatment of bacterial skin and skin-structure infections in an adult population. The American journal of medicine. 1992:80s-5s. [pmid: 1621751].
512 McCrory P, Heywood J, Ugoni A. Open label study of intranasal sumatriptan (Imigran) for footballer's headache. British Journal of Sports Medicine. Aug. 2005;39(8):552-4. [pmid: 16046342].
513 McEwen JI, O'Connor HM, Dinsdale HB. Treatment of migraine with intramuscular chlorpromazine. Ann Emerg Med. Jul. 1987;16(7):758-63. [pmid: 3592329].
514 McEwen JI, O'Connor HM, Dinsdale HB. Treating migraine with chlorpromazine. Nurses Drug Alert. 1987:87.
515 McGrath PJ, Humphreys P, Keene D, et al. The efficacy and efficiency of a self-administered treatment for adolescent migraine. Pain. Jun. 1992;49(3):321-4. [pmid: 1408297].
516 Melchart D, Thormaehlen J, Hager S, et al. Acupuncture versus placebo versus sumatriptan for early treatment of migraine attacks: a randomized controlled trial. J Intern Med. Feb. 2003;253(2):181-8. [pmid: 12542558].
517 Melchart De. Acupuncture versus sumatriptan for earrly treament of acute migraine attacks - a randomised controlled clinical trial. Deutsche Zeitschrift Fur Akupunktur. 2000:39.
518 Mellick LB, Mellick GA. Treatment of primary headache in the emergency department. Headache. Sep. 2004;44(8):840-1. [pmid: 15330841].
519 Mendhekar DN, Andrade C. Prochlorperazine-induced tardive dystonia and its worsening with clozapine in a non-mentally ill patient with migraine. Ann Pharmacother. Apr. 2011;45(4):545-6. [pmid: 21487079].
520 Mercer AJ, Lamb RJ, Rolan PE, et al. Lack of an effect of zolmitriptan (Zomig, 311C90) on psychometric task performance: results of a placebo-controlled study in healthy volunteers. Psychopharmacology. 1998:398-404. [pmid: 9888613].
521 Meredith JT, Wait S, Brewer KL. A prospective double-blind study of nasal sumatriptan versus IV ketorolac in migraine. Am J Emerg Med. May. 2003;21(3):173-5. [pmid: 12811706].
522 Micieli G, Piazza D, Sinforiani E, et al. Antimigraine drugs in the management of daily chronic headaches: clinical profiles of responsive patients. Cephalalgia: an international journal of headache. 1985:219-24. [pmid: 4016938].
523 Miller FG. Treatment of acute migraine. Lancet. Mar. 2. 2002;359(9308):802. [pmid: 11888631].
524 Miller MA, Levsky ME, Enslow W, et al. Randomized evaluation of octreotide vs prochlorperazine for ED treatment of migraine headache. Am J Emerg Med. Feb. 2009;27(2):160-4. [pmid: 19371522].
525 Million R, Finlay BR, Whittington JR. Clinical trial of flupirtine maleate in patients with migraine. Curr Med Res Opin. 1984;9(3):204-12. [pmid: 6389014].
526 Millson D, Frischer M, Croft P, et al. Are triptans with enhanced lipophilicity used for the acute treatment of migraine associated with an increased consulting rate for depressive illness?. Cephalalgia. Oct. 2000;20(8):732-7. [pmid: 11167903].
527 Milton KA, Kleinermans D, Scott N, et al. The bioequivalence of standard sumatriptan tablets and two encapsulated forms of sumatriptan. International Journal of Pharmaceutical Medicine. 2001:21-6.
528 Miner JR, Smith SW, Moore J, et al. Sumatriptan for the treatment of undifferentiated primary headaches in the ED. American Journal of Emergency Medicine. Jan. 2007;25(1):60-4. [pmid: 17157685].
529 Misra UK, Jose M, Kalita J. Rofecoxib versus ibuprofen for acute treatment of migrainne: a randomised placebo controlled trial. Postgraduate Medical Journal. 2004:720-3. [pmid: 15579612].
530 Misra UK, Kalita J, Yadav RK. Rizatriptan vs. ibuprofen in migraine: a randomised placebo-controlled trial. J Headache Pain. Jun. 2007;8(3):175-9. [pmid: 17563841].
531 Mitsikostas DD, Vikelis M, Kodounis A, et al. Migraine recurrence is not associated with depressive or anxiety symptoms Results of a randomized controlled trial. Cephalalgia: an international journal of headache. 2010:690-5. [pmid: 20511208].
532 Mjaset C, Russell MB. Intravenous nimodipine worsening prolonged attack of familial hemiplegic migraine. Journal of Headache & Pain. Dec. 2008;9(6):381-4. [pmid: 18846413].
533 Moghadam AH, Zarei H, Seifaddini R, et al. Outpatient treatment of migraine headache, can we use a dexamethasone containing regimen?. Journal of Research in Medical Sciences. 2008:264-7.
534 Molaie M, Olson CM, Koch J. The effect of intravenous verapamil on acute migraine headache. Headache. 1987:51-3. [pmid: 3549629].
535 Moldofsky H, Lue FA, Mously C, et al. The effect of zolpidem in patients with fibromyalgia: a dose ranging, double blind, placebo controlled, modified crossover study. The Journal of rheumatology. 1996:529-33. [pmid: 8832997].
536 Montouris G. Gabapentin exposure in human pregnancy: results from the Gabapentin Pregnancy Registry. Epilepsy & Behavior. Jun. 2003;4(3):310-7. [pmid: 12791334].
537 Moore KH, Leese PT, McNeal S, et al. The pharmacokinetics of sumatriptan when administered with clarithromycin in healthy volunteers. Clinical therapeutics. 2002:583-94. [pmid: 12017403].
538 Moorjani BI, Rothner AD. Indomethacin-responsive headaches in children and adolescents. Seminars in Pediatric Neurology. Mar. 2001;8(1):40-5. [pmid: 11332865].
539 Morello F, Ronzani G, Cappellari F. Migraine, cortical blindness, multiple cerebral infarctions and hypocoagulopathy in celiac disease. Neurological Sciences. Jun. 2003;24(2):85-9. [pmid: 12827546].
540 Morrato EH, Nicol GE, Maahs D, et al. Metabolic screening in children receiving antipsychotic drug treatment. Arch Pediatr Adolesc Med. Apr. 2010;164(4):344-51. [pmid: 20368487].
541 Mortimer PS, Badger C, Clarke I, et al. A double-blind, randomized, parallel-group, placebo-controlled trial of O-(beta-hydroxyethyl)-rutosides in chronic arm oedema resulting from breast cancer treatment. Phlebology. 1995:51-5.
542 Mullins CD, Subedi PR, Healey PJ, et al. Economic analysis of triptan therapy for acute migraine: a Medicaid perspective. Pharmacotherapy. Aug. 2007;27(8):1092-101. [pmid: 17655509].
543 Mullins CD, Weis KA, Perfetto EM, et al. Triptans for migraine therapy: a comparison based on number needed to treat and doses needed to treat. Journal of Managed Care Pharmacy. Jun. 2005;11(5):394-402. [pmid: 15934798].
544 Musson DG, Birk KL, Panebianco DL, et al. Pharmacokinetics of rizatriptan in healthy elderly subjects. International journal of clinical pharmacology and therapeutics. 2001:447-52. [pmid: 11680669].
545 Myers DE, Myers RA. A preliminary report on hyperbaric oxygen in the relief of migraine headache. Headache. Apr. 1995;35(4):197-9. [pmid: 7775175].
546 Nagtegaal JE, Smits MG, Swart AC, et al. Melatonin-responsive headache in delayed sleep phase syndrome: preliminary observations. Headache. Apr. 1998;38(4):303-7. [pmid: 9595871].
547 Nappi G, Micieli G, Tassorelli C, et al. Effectiveness of a piroxicam fast dissolving formulation sublingually administered in the symptomatic treatment of migraine without aura. Headache. 1993:296-300. [pmid: 8349471].
548 Nappi RE, Cagnacci A, Granella F, et al. Course of primary headaches during hormone replacement therapy. Maturitas. Apr. 20. 2001;38(2):157-63. [pmid: 11306204].
549 Nappi RE, Sances G, Brundu B, et al. Estradiol supplementation modulates neuroendocrine response to M-chlorophenylpiperazine in menstrual status migrainosus triggered by oral contraception-free interval. Human Reproduction. Dec. 2005;20(12):3423-8. [pmid: 16123089].
550 Nestvold K. Naproxen and naproxen sodium in acute migraine attacks. Cephalalgia. 1986:81-4. [pmid: 3539361].
551 Nett RB, Tiseo PJ, Almas M, et al. Patient satisfaction with eletriptan in the acute treatment of migraine in primary care. International Journal of Clinical Practice. Oct. 2007;61(10):1677-85. [pmid: 17877653].
552 Neuhauser H, Radtke A, von Brevern M, et al. Zolmitriptan for treatment of migrainous vertigo: a pilot randomized placebo-controlled trial. Neurology. Mar. 11. 2003;60(5):882-3. [pmid: 12629256].
553 Newman LC, Harper S, Jones BA, et al. Frovatriptan for acute treatment of migraine associated with menstruation: results from an open-label postmarketing surveillance study. Journal of Women's Health. Aug. 2009;18(8):1265-73. [pmid: 19627225].
554 Newman LC, Lipton RB. Migraine MLT-down: an unusual presentation of migraine in patients with aspartame-triggered headaches. Headache. Oct. 2001;41(9):899-901. [pmid: 11703479].
555 Nezvalovä-Henriksen K, et al. Triptan exposure during pregnancy and the risk of major congenital malformations and adverse pregnancy outcomes: results from the Norwegian Mother and Child Cohort Study. Headache. Apr. 2010;50(4):563-75. [pmid: 20132339].
556 Ng TM, Kohli A, Fagan SC, et al. The effect of intravenous verapamil on cerebral hemodynamics in a migraine patient with hemiplegia. Annals of Pharmacotherapy. Jan. 2000;34(1):39-43. [pmid: 10669185].
557 Ng-Mak DS, Hu XH, Bigal M. Migraine treatment with rizatriptan and almotriptan: a crossover study. Headache. May. 2009;49(5):655-62. [pmid: 19456878].
558 Ng-Mak DS, Hu XH, Chen Y, et al. Times to pain relief and pain freedom with rizatriptan 10 mg and other oral triptans. International Journal of Clinical Practice. Jul. 2007;61(7):1091-111. [pmid: 17537184].
559 Niño-Maldonado AI, et al. Efficacy and tolerability of intravenous methylergonovine in migraine female patients attending the emergency department: a pilot open-label study. Head & Face Medicine. 2009;5:21. [pmid: 19895705].
560 Nicolodi M, Sicuteri F. Fibromyalgia and migraine, two faces of the same mechanism. Serotonin as the common clue for pathogenesis and therapy. Adv Exp Med Biol. 1996;398:373-9. [pmid: 8906292].
561 Nicolodi M, Sicuteri F. L-5-hydroxytryptophan can prevent nociceptive disorders in man. Adv Exp Med Biol. 1999;467:177-82. [pmid: 10721054].
562 Norman BA, Block GA, Jiang K, et al. Two-period crossover comparison of rizatriptan 5 mg and 10 mg to sumatriptan 25 mg and 50 mg for the acute treatment of migraine. [abstract]. Neurology. 1998:A341.
563 Norton J. Use of intravenous valproate sodium in status migraine. Headache. Oct. 2000;40(9):755-7. [pmid: 11091297].
564 O’Byrne P, Cuddy L, Taylor DW, et al. Efficacy and cost benefit of inhaled corticosteroids in patients considered to have mild asthma in primary care practice. Canadian Respiratory Journal. 1996:169-75.
565 Odergren T, Hjaltason H, Kaakkola S, et al. A double blind, randomised, parallel group study to investigate the dose equivalence of Dysport (R) and Botox (R) in the treatment of cervical dystonia. Journal of Neurology Neurosurgery and Psychiatry. 1998:6-12.
566 Okuma H, Kitagawa Y, Takagi S. Clinical efficacy of rizatriptan for patients with migraine: efficacy of drug therapy for migraine accompanied by tension headache-like symptoms, focusing on neck stiffness. Journal of Headache & Pain. Dec. 2005;6(6):455-8. [pmid: 16388340].
567 Okuyucu E, Melek IM, Duman T, et al. Hypomania complicating topiramate therapy for migraine prophylaxis. European Journal of Neurology. Mar. 2007;14(3):e6. [pmid: 17355539].
568 Olesen J. 5-Hydroxyptryptamine 1F (5-HT1F) receptor agonism. A possible new treatment principle for acute migraine attacks. Cephalalgia. Oct. 2010;30(10):1157-8. [pmid: 20855360].
569 Olesen J, Diener HC, Schoenen J, et al. No effect of eletriptan administration during the aura phase of migraine. Eur J Neurol. Oct. 2004;11(10):671-7. [pmid: 15469451].
570 Olson AD, Li BUK. The diagnostic evaluation of children with cyclic vomiting: a cost-effectiveness assessment. Journal of Pediatrics. Nov. 2002;141(5):724-8. [pmid: 12410206].
571 Omata T, Takanashi J, Wada T, et al. Genetic diagnosis and acetazolamide treatment of familial hemiplegic migraine. Brain & Development. Apr. 2011;33(4):332-4. [pmid: 20542393].
572 Ondo WG, Vuong KD, Derman HS. Botulinum toxin A for chronic daily headache: a randomized, placebo-controlled, parallel design study. Cephalalgia. Jan. 2004;24(1):60-5. [pmid: 14687015].
573 O'Quinn S, DeBussey S, Saiers JA. Sumatriptan injection and nasal spray: onset of efficacy in the acute treatment of migraine. [abstract]. Neurology. 1998:A264-5.
574 O'Quinn S, Ephross SA, Williams V, et al. Pregnancy and perinatal outcomes in migraineurs using sumatriptan: a prospective study. Arch Gynecol Obstet. Nov. 1999;263(1–2):7-12. [pmid: 10728620].
575 Oral Sumatriptan International Multiple-Dose Study Group. Evaluation of a multiple-dose regimen of oral sumatriptan for the acute treatment of migraine. Eur Neurol. 1991:306-13. [pmid: 1653138].
576 Orlikowski CE, Dickinson JE, Paech MJ, et al. Intrapartum analgesia and its association with post-partum back pain and headache in nulliparous women. Aust N Z J Obstet Gynaecol. Oct. 2006;46(5):395-401. [pmid: 16953853].
577 Ozkul Y, Bozlar S. Effects of fluoxetine on habituation of pattern reversal visually evoked potentials in migraine prophylaxis. Headache. Jul–Aug. 2002;42(7):582-7. [pmid: 12482209].
578 Padma MV, Jain S, Maheshwari MC, et al. Efficacy and tolerability of oral Sumatriptan in Indian patients with acute migraine; a multicentre study. Neurology India. 1998:105-8.
579 Pakalnis A, Kring D, Paolicchi J. Parental satisfaction with sumatriptan nasal spray in childhood migraine. Journal of Child Neurology. Nov. 2003;18(11):772-5. [pmid: 14696905].
580 Palikh GM, Vaughn BV. Topiramate responsive exploding head syndrome. Journal of Clinical Sleep Medicine. Aug. 15. 2010;6(4):382-3. [pmid: 20726288].
581 Panagiotopoulos C, Ronsley R, Elbe D, et al. First do no harm: promoting an evidence-based approach to atypical antipsychotic use in children and adolescents. J Can Acad Child Adolesc Psychiatry. May. 2010;19(2):124-37. [pmid: 20467549].
582 Panerai AE, Monza G, Movilia P, et al. A randomized, within-patient, cross-over, placebo-controlled trial on the efficacy and tolerability of the tricyclic antidepressants chlorimipramine and nortriptyline in central pain. Acta Neurol Scand. Jul. 1990;82(1):34-8. [pmid: 2239134].
583 Parisi P, Kasteleijn-Nolst Trenité DG, et al. A case with atypical childhood occipital epilepsy "Gastaut type": an ictal migraine manifestation with a good response to intravenous diazepam. Epilepsia. Nov. 2007;48(11):2181-6. [pmid: 17711460].
584 Parisi P, Pagani J, Galiffa S, et al. Migrainous vertigo unresponsive to antimigraine therapy in a child with "asymptomatic" cerebellar lesion: casual or causal association?. Cephalalgia. Oct. 2005;25(10):831-5. [pmid: 16162262].
585 Parker GB, Tupling H, Pryor DS. A controlled trial of cervical manipulation of migraine. Aust N Z J Med. Dec. 1978;8(6):589-93. [pmid: 373735].
586 Pascual J. Clinical benefits of early triptan therapy for migraine. Headache. Jan. Suppl 1. 2002;42:10-7. [pmid: 11966859].
587 Pascual J, Bussone G, Hernandez JF, et al. Comparison of preference for rizatriptan 10-mg wafer versus sumatriptan 50-mg tablet in migraine. Eur Neurol. 2001;45(4):275-83. [pmid: 11385269].
588 Pascual J, Diener HC. Use of almotriptan in triptan-experienced and triptan-naïve patients. Current Medical Research & Opinion. Oct. 2007;23(10):2433-40. [pmid: 17723158].
589 Pascual J, Falk RM, Piessens F, et al. Consistent efficacy and tolerability of almotriptan in the acute treatment of multiple migraine attacks: results of a large, randomized, double-blind, placebo-controlled study. Cephalalgia. Jul. 2000;20(6):588-96. [pmid: 11075844].
590 Pascual J, Fité B, et al. Comparison of triptan tablet consumption per attack: a prospective study of migraineurs in Spain. Headache. Feb. 2002;42(2):93-8. [pmid: 12005301].
591 Pascual J, García-Moncó C, et al. Rizatriptan 10-mg wafer versus usual nontriptan therapy for migraine: analysis of return to function and patient preference. Headache. Oct. 2005;45(9):1140-50. [pmid: 16178944].
592 Pascual J, Muñoz P, et al. Correlation between lipophilicity and triptan outcomes. Headache. Jan. 2005;45(1):3-6. [pmid: 15663606].
593 Pascual J, Vega P, Diener HC, et al. Comparison of rizatriptan 10 mg vs. zolmitriptan 2.5 mg in the acute treatment of migraine. Cephalalgia. 2000:455-61. [pmid: 11037741].
594 Patrick DL, Hurst BC, Hughes J. Further development and testing of the migraine-specific quality of life (MSQOL) measure. Headache. Jul–Aug. 2000;40(7):550-60. [pmid: 10940093].
595 Patten JP. Clinical experience with oral sumatriptan: a placebo-controlled, dose-ranging study. Oral Sumatriptan Dose-defining Study Group. Journal of neurology. 1991:S62-5. [pmid: 1646290].
596 Peck RW, Seaber EJ, Dixon R, et al. The interaction between propranolol and the novel antimigraine agent zolmitriptan (311C90). British journal of clinical pharmacology. 1997:595-9. [pmid: 9431839].
597 Peck RW, Seaber EJ, Dixon RM, et al. The pharmacodynamics and pharmacokinetics of the 5HT1B/1D-agonist zolmitriptan in healthy young and elderly men and women. Clinical pharmacology and therapeutics. 1998:342-53. [pmid: 9542478].
598 Penzien D, Johnson C, Carpenter D, et al. Drug vs. behavioral treatment of migraine: long-acting propranolol vs. home-based self-management training. Headache. 1990:300.
599 Perfetto EM, Weis KA, Mullins CD, et al. An economic evaluation of triptan products for migraine. Value in Health. Nov–Dec. 2005;8(6):647-55. [pmid: 16283865].
600 Perino M, Famularo G, Tarroni P. Acquired transient stuttering during a migraine attack. Headache. Feb. 2000;40(2):170-2. [pmid: 10759918].
601 Peroutka SJ, Lyon JA, Swarbrick J, et al. Efficacy of diclofenac sodium softgel 100 mg with or without caffeine 100 mg in migraine without aura: a randomized, double-blind, crossover study. Headache. Feb. 2004;44(2):136-41. [pmid: 14756851].
602 Perrin VL, Farkkila M, Goasguen J, et al. Overview of initial clinical studies with intravenous and oral GR43175 in acute migraine. Cephalalgia. 1989:63-72. [pmid: 2544286].
603 Perrotta A, Serrao M, Tassorelli C, et al. Oral nitric-oxide donor glyceryl-trinitrate induces sensitization in spinal cord pain processing in migraineurs: a double-blind, placebo-controlled, cross-over study. Eur J Pain. May. 2011;15(5):482-90. [pmid: 20965755].
604 Pfadenhauer K, Sch x00F, et al. The risks of sumatriptan administration in patients with unrecognized subarachnoid haemorrhage (SAH). Cephalalgia. Mar. 2006;26(3):320-3. [pmid: 16472339].
605 Pfaffenrath V. Efficacy and safety of sumatriptan tablets (25mg, 50mg, 100mg) in the acute treatment of migraine: Defining the optimum doses of oral sumatriptan. Journal of the Neurological Sciences. 1997:S41.
606 Pfaffenrath V, Diener HC, Isler H, et al. Efficacy and tolerability of amitriptylinoxide in the treatment of chronic tension-type headache: a multi-centre controlled study. Cephalalgia. Apr. 1994;14(2):149-55. [pmid: 8062354].
607 Pichard-Garcia L, Hyland R, Baulieu J, et al. Human hepatocytes in primary culture predict lack of cytochrome P-450 3A4 induction by eletriptan in vivo. Drug Metab Dispos. Jan. 2000;28(1):51-7. [pmid: 10611140].
608 Pini LA, Sternieri E, Fabbri L, et al. High efficacy and low frequency of headache recurrence after oral sumatriptan. The Oral Sumatriptan Italian Study Group. J Int Med Res. Mar–Apr. 1995;23(2):96-105. [pmid: 7601299].
609 Plosker GL, McTavish D. Sumatriptan. A reappraisal of its pharmacology and therapeutic efficacy in the acute treatment of migraine and cluster headache. Drugs. Apr. 1994;47(4):622-51. [pmid: 7516861].
610 Poston S, Dickson M, Johnsrud M, et al. Topiramate prescribing patterns among medicaid patients: diagnosis, comorbidities, and dosing. Clinical Therapeutics. Mar. 2007;29(3):504-18. [pmid: 17577471].
611 Pothmann R, Lobisch M. Acute treatment of episodic childhood tension-type headache with flupirtine and paracetamol - A double-blind crossover-study. Schmerz. 2000:1-4. [pmid: 12799904].
612 Poungvarin N. The first world report of botulinum A toxin injection for status migrainosus. Journal of the Medical Association of Thailand. Aug. 2001;84(8):1199-203. [pmid: 11758858].
613 Pradalier A, Guerard DLA, Scheck F, et al. The association of calcium carbasalate-metoclopramide versus dihydroergotamine in the treatment of migraine attacks. Pathologie Biologie. 1995:806-13. [pmid: 8746103].
614 Pradel FG, Subedi P, Varghese AA, et al. Does earlier headache response equate to earlier return to functioning in patients suffering from migraine?. Cephalalgia. Apr. 2006;26(4):428-35. [pmid: 16556244].
615 Pryse-Phillips W. Oral eletriptan (40–80 mg) versus oral sumatriptan (50–100 mg) for the treatment of acute migraine in sumatriptan-na&acute;ve patients. European Journal of Neurology (Abstracts of the 4th Congress of the European Federation of Neurological Sciences). September 7–11. Lisbon, Portugal. 1999. 1999:21.
616 Rabinowitz JD, Lloyd PM, Munzar P, et al. Ultra-fast absorption of amorphous pure drug aerosols via deep lung inhalation. Journal of pharmaceutical sciences. 2006:2438-51. [pmid: 16886198].
617 Ragot JP, Giorgi M, Marinoni M, et al. Acute activity of nimesulide in the treatment of pain after oral surgery - Double blind, placebo and mefenamic acid controlled study. European Journal of Clinical Research. 1994:39-50.
618 Rahimdel A, Eslami MH, Zeinali A. A randomized controlled study of magnesium sulfate versus dihydroergotamine in the management of acute migraine attacks. Pak J Neurological Sci. 2007:92-5.
619 Rahman A, Yildiz M, Dadas E, et al. Reversal of ergotamine-induced vasospasm following methylprednisolone. Clinical Toxicology: The Official Journal of the American Academy of Clinical Toxicology & European Association of Poisons Centres & Clinical Toxicologists. Dec. 2008;46(10):1074-6. [pmid: 18763151].
620 Rahmann A, Wienecke T, Hansen JM, et al. Vasoactive intestinal peptide causes marked cephalic vasodilation, but does not induce migraine. Cephalalgia. Mar. 2008;28(3):226-36. [pmid: 18254893].
621 Rampello L, Alvano A, Chiechio S, et al. Evaluation of the prophylactic efficacy of amitriptyline and citalopram, alone or in combination, in patients with comorbidity of depression, migraine, and tension-type headache. Neuropsychobiology. 2004;50(4):322-8. [pmid: 15539864].
622 Ramsberg J, Henriksson M. The cost-effectiveness of oral triptan therapy in Sweden. Cephalalgia. Jan. 2007;27(1):54-62. [pmid: 17212684].
623 Rankin LM. Migraine in the emergency department: not a win-win situation. Headache. Nov–Dec. 2003;43(10):1032-3. [pmid: 14629237].
624 Reches A. Comparison of the efficacy, safety and tolerability of oral eletriptan and cafergot(r) in the acute treatment of migraine. European Journal of Neurology (Abstracts of the 4th Congress of the European Federation of Neurological Sciences). September 7–11. Lisbon, Portugal. 1999. 1999:57.
625 Rederich G, Rapoport A, Cutler N, et al. Oral sumatriptan for the long-term treatment of migraine: clinical findings. Neurology. Aug. 1995;45(8 Suppl 7):S15-20. [pmid: 7644080].
626 Regan LA, Hoffman RS, Nelson LS. Slower infusion of metoclopramide decreases the rate of akathisia. The American journal of emergency medicine. 2009:475-80. [pmid: 19555621].
627 Reutens D, Fatovich D, Stewart-Wynne E, et al. Is intravenous lignocaine clinically effective in acute migraine?. [abstract]. Australian & New Zealand Journal of Medicine. 1991:172.
628 Richer LP, Laycock K, Millar K, et al. Treatment of children with migraine in emergency departments: national practice variation study. Pediatrics. Jul. 2010;126(1):e150-5. [pmid: 20530076].
629 Rimaitis K, Svitojute A, Macas A. The influence of dexamethasone and ketolgan on postoperative nausea and vomiting and estimation of risk factors in women undergoing gynecologic laparoscopic surgeries. Medicina (Kaunas). 2010;46(4):261-7. [pmid: 20571294].
630 Roberts RB, Shirley MA. The obstetrician's role in reducing the risk of aspiration pneumonitis. With particular reference to the use of oral antacids. Am J Obstet Gynecol. Mar. 15. 1976;124(6):611-7. [pmid: 943944].
631 Rodgers AJ, Hustad CM, Cady RK, et al. Total migraine freedom, a potential primary endpoint to assess acute treatment in migraine: comparison to the current FDA requirement using the complete rizatriptan study database. Headache. Mar. 2011;51(3):356-68. [pmid: 21039453].
632 Roon KI, Olesen J, Diener HC, et al. No acute antimigraine efficacy of CP-122,288, a highly potent inhibitor of neurogenic inflammation: results of two randomized, double-blind, placebo-controlled clinical trials. Ann Neurol. Feb. 2000;47(2):238-41. [pmid: 10665496].
633 Rossi P, Di Lorenzo C, Faroni J, et al. Advice alone vs. structured detoxification programmes for medication overuse headache: a prospective, randomized, open-label trial in transformed migraine patients with low medical needs. Cephalalgia. Sep. 2006;26(9):1097-105. [pmid: 16919060].
634 Ross-Lee LM, Eadie MJ, Heazlewood V, et al. Aspirin pharmacokinetics in migraine. The effect of metoclopramide. Eur J Clin Pharmacol. 1983;24(6):777-85. [pmid: 6884416].
635 Rostoff P, Gajos G, Latacz P, et al. Ergotamine-induced cardiovascular toxicity: mechanisms and clinical significance. International Journal of Cardiology. May. 14. 2010;141(1):111-4. [pmid: 19135734].
636 Roth T, White D, Schmidt-Nowara W, et al. Effects of armodafinil in the treatment of residual excessive sleepiness associated with obstructive sleep apnea/hypopnea syndrome: a 12-week, multicenter, double-blind, randomized, placebo-controlled study in nCPAP-adherent adults. Clinical therapeutics. 2006:689-706. [pmid: 16861091].
637 Rothner AD, Wasiewski W, Winner P, et al. Zolmitriptan oral tablet in migraine treatment: high placebo responses in adolescents. Headache. Jan. 2006;46(1):101-9. [pmid: 16412157].
638 Rothner AD, Winner P, Nett R, et al. One-year tolerability and efficacy of sumatriptan nasal spray in adolescents with migraine: results of a multicenter, open-label study. Clinical Therapeutics. Dec. 2000;22(12):1533-46. [pmid: 11192144].
639 Rothrock JF. Compound medications for acute migraine treatment. Headache. Sep. 2008;48(8):1283. [pmid: 18808510].
640 Rothrock JF. Treatment-refractory migraine: the case for opioid therapy. Headache. Jun. 2008;48(6):850-4. [pmid: 18549362].
641 Rothrock JF. Injectable sumatriptan: now needle-based or needle-free. Headache. Feb. 2010;50(2):343-4. [pmid: 20456140].
642 Rothrock JF. Opiate and opioid ("narcotic") therapy for acute migraine headache. Headache. Jul. 2010;50(7):1255-6. [pmid: 20649661].
643 Rothrock JF. Membership survey: use of oral triptans and injectable sumatriptan within the same 24-hour period. Headache. Jan. 2011;51(1):141. [pmid: 21198575].
644 Rothrock JF, Cady RK, Aurora SK, et al. Needle-free subcutaneous sumatriptan for triptan users requiring a change in migraine therapy: efficacy and impact on patient-rated functionality, satisfaction, and confidence. Curr Med Res Opin. 2011. Sep. 26. [pmid: 21942531].
645 Rowe BH, Colman I, Edmonds ML, et al. Randomized controlled trial of intravenous dexamethasone to prevent relapse in acute migraine headache. Headache. Mar. 2008;48(3):333-40. [pmid: 18047499].
646 Rozen T. Cessation of hemiplegic migraine auras with greater occipital nerve blockade. Headache. Jun. 2007;47(6):917-9. [pmid: 17578545].
647 Ruiz C, Gener B, Garaizar C, et al. Episodic spontaneous hypothermia: a periodic childhood syndrome. Pediatric Neurology. Apr. 2003;28(4):304-6. [pmid: 12849886].
648 Ruiz RS, Saathoff K, Villanueva M, et al. Red Contact Lens Therapy for the Reduction of Migraine Severity. Iovs. 2004. ARVO E-abstract 5610.
649 Russell MB, Holm TOE, Nielsen MR, et al. Subcutaneous sumatriptan in general practice: A randomized double- blind placebo-controlled cross-over study. Ugeskrift for Laeger. 1995:2320-3. [pmid: 7652970].
650 Russell MB, Holm-Thomsen OE, Rishoj Nielsen M, et al. A randomized double-blind placebo-controlled crossover study of subcutaneous sumatriptan in general practice. Cephalalgia. Aug. 1994;14(4):291-6. [pmid: 7954759].
651 Ryan R, Geraud G, Goldstein J, et al. Clinical efficacy of frovatriptan: placebo-controlled studies. Headache. Apr. Suppl 2. 2002;42:S84-92. [pmid: 12028324].
652 Ryan RE Jr, Diamond S, Giammarco RAM, et al. Efficacy of zolmitriptan at early time-points for the acute treatment of migraine and treatment of recurrence: A randomised, placebo-controlled trial. CNS Drugs. 2000:215-26.
653 Ryan RE, Elkind AH, Goldstein J. Twenty four haur response rate and incidence of recurrence of BMS-180048 in the acute treatment of migraine headaches. Functional Neurology. 1996:148.
654 Sakai F, Diener HC, Ryan R, et al. Eletriptan for the acute treatment of migraine: results of bridging a Japanese study to Western clinical trials. Curr Med Res Opin. Mar. 2004;20(3):269-77. [pmid: 15025836].
655 Sakai F, Iwata M, Tashiro K, et al. Zolmitriptan is effective and well tolerated in Japanese patients with migraine: a dose-response study. Cephalalgia. Jun. 2002;22(5):376-83. [pmid: 12110113].
656 Sakai Y, Dobson C, Diksic M, et al. Sumatriptan normalizes the migraine attack-related increase in brain serotonin synthesis. Neurology. Feb. 5. 2008;70(6):431-9. [pmid: 18250288].
657 Salazar G, Fragoso M, Vergez L, et al. Metoclopramide as an analgesic in severe migraine attacks: an open, single-blind, parallel control study. Recent Pat CNS Drug Discov. May. 1. 2011;6(2):141-5. [pmid: 21585330].
658 Salonen R. Speed of onset of sumatriptan injection, nasal spray, and tablets in the acute treatment of migraine. Functional Neurology. 1998:179.
659 Salonen R, Dawson R. Intranasal sumatriptan in the acute treatment of migraine. [abstract]. Canadian Journal of Neurological Sciences. 1993.
660 Sandrini G, Farkkila M, Burgess G, et al. Eletriptan vs sumatriptan: a double-blind, placebo-controlled, multiple migraine attack study. Neurology. Oct. 22. 2002;59(8):1210-7. [pmid: 12391349].
661 Sanger MD. The treatment of anxiety and depression in the allergic patient. Annals of allergy. 1969:506-10. [pmid: 4918116].
662 Santanello NC, Davies G, Allen C, et al. Determinants of migraine-specific quality of life. Cephalalgia. Oct. 2002;22(8):680-5. [pmid: 12383065].
663 Santanello NC, Polis AB, Hartmaier SL, et al. Improvement in migraine-specific quality of life in a clinical trial of rizatriptan. Cephalalgia. Dec. 1997;17(8):867-72. discussion 00. [pmid: 9453276].
664 Santone G, Ricchi G, Rocchetti D, et al. Is the exposure to antidepressant drugs in early pregnancy a risk factor for spontaneous abortion? A review of available evidences. Epidemiol Psichiatr Soc. Jul–Sep. 2009;18(3):240-7. [pmid: 20034202].
665 Saracco MG, Valfre W, Cavallini M, et al. Greater occipital nerve block in chronic migraine. Neurol Sci. Jun. Suppl 1. 2010;31:S179-80. [pmid: 20464617].
666 Savani N, Pfaffenrath V, Rice L, et al. Efficacy, tolerability, and patient satisfaction with 50- and 100-mg sumatriptan tablets in those initially dissatisfied with the efficacy of 50-mg sumatriptan tablets. Clin Ther. Feb. 2001;23(2):260-71. [pmid: 11293559].
667 Schmitt WJ, Slowey E, Fravi N, et al. Effect of botulinum toxin A injections in the treatment of chronic tension-type headache: a double-blind, placebo-controlled trial. Headache. Jul–Aug. 2001;41(7):658-64. [pmid: 11554953].
668 Schoenen J, Bulcke J, Caekebeke J, et al. Self-treatment of acute migraine with subcutaneous sumatriptan using an auto-injector device: comparison with customary treatment in an open, longitudinal study. Cephalalgia. 1994:55-63. [pmid: 8200027].
669 Schoenen J, Pascual J, Rasmussen S, et al. Patient preference for eletriptan 80 mg versus subcutaneous sumatriptan 6 mg: results of a crossover study in patients who have recently used subcutaneous sumatriptan. Eur J Neurol. Feb. 2005;12(2):108-17. [pmid: 15679698].
670 Scholpp J, Schellenberg R, Moeckesch B, et al. Early treatment of a migraine attack while pain is still mild increases the efficacy of sumatriptan. Cephalalgia. Nov. 2004;24(11):925-33. [pmid: 15482353].
671 Schradi A, Bene J. Results in the therapy of bronchial asthma using histaglobine Zeitschrift fur Erkrankungen der Atmungsorgane. Mit Folia Bronchologica. 1972:337-45.
672 Schreiber CP, Cady RK. Diagnosis of menstrual headache and an open-label study among those with previously undiagnosed menstrually related migraine to evaluate the efficacy of sumatriptan 100 mg. Clinical Therapeutics. Suppl. 2007;29:2511-9. [pmid: 18164918].
673 Schulman EA, Dermott KF. Sumatriptan plus metoclopramide in triptan-nonresponsive migraineurs. Headache. Jul–Aug. 2003;43(7):729-33. [pmid: 12890127].
674 Schulte-Mattler WJ, Krack P. Treatment of chronic tension-type headache with botulinum toxin A: a randomized, double-blind, placebo-controlled multicenter study. Pain. May. 2004;109(1–2):110-4. [pmid: 15082132].
675 Seaber E, On N, Dixon RM, et al. The absolute bioavailability and metabolic disposition of the novel antimigraine compound zolmitriptan (311C90). Br J Clin Pharmacol. Jun. 1997;43(6):579-87. [pmid: 9205817].
676 Seaber EJ, Peck RW, Smith DA, et al. The absolute bioavailability and effect of food on the pharmacokinetics of zolmitriptan in healthy volunteers. British journal of clinical pharmacology. 1998:433-9. [pmid: 9833595].
677 Seeburger JL, Taylor FR, Friedman D, et al. Efficacy and tolerability of rizatriptan for the treatment of acute migraine in sumatriptan non-responders. Cephalalgia. May. 2011;31(7):786-96. [pmid: 21078681].
678 Seidel WT, Mitchell WG. Cognitive and behavioral effects of carbamazepine in children: data from benign rolandic epilepsy. Journal of child neurology. 1999:716-23. [pmid: 10593548].
679 Shadle CR, Liu G, Goldberg MR. A double-blind, placebo-controlled evaluation of the effect of oral doses of rizatriptan 10 mg on oral contraceptive pharmacokinetics in healthy female volunteers. Journal of clinical pharmacology. 2000:309-15. [pmid: 10709161].
680 Shah A, Johnson BF, Milton KA. The pharmacokinetics of eletriptan - a new oral agent for the acute treatment of migraine. [abstract]. Neurology. 1998:A377.
681 Shahien R, Saleh SA, Bowirrat A. Intravenous sodium valproate aborts migraine headaches rapidly. Acta Neurol Scand. Apr. 2011;123(4):257-65. [pmid: 20569223].
682 Shankland WE. Nociceptive trigeminal inhibition--tension suppression system: a method of preventing migraine and tension headaches. Compend Contin Educ Dent. Feb. 2002;23(2):105-8. 10. 12. 3. quiz 14. [pmid: 11915652].
683 Sharma A, Jusko WJ, Fulmor IE, et al. Pharmacokinetics and pharmacodynamics of avitriptan during intravenous administration in healthy subjects. Journal of clinical pharmacology. 1999:685-94. [pmid: 10392323].
684 Sheftell F, Almas M, Weeks R, et al. Quantifying the return of headache in triptan-treated migraineurs: an observational study. Cephalalgia. Jul. 2010;30(7):838-46. [pmid: 20647175].
685 Sheftell F, O'Quinn S, Watson C, et al. Low migraine headache recurrence with naratriptan: clinical parameters related to recurrence. Headache. Feb. 2000;40(2):103-10. [pmid: 10759909].
686 Sheftell FD, Byer J, Couch J, et al. Dihydroergotamine nasal spray in the acute treatment of migraine headache. Headache. 1989:314.
687 Sheftell FD, Feleppa M, Tepper SJ, et al. Patterns of use of triptans and reasons for switching them in a tertiary care migraine population. Headache. Jul–Aug. 2004;44(7):661-8. [pmid: 15209687].
688 Sheftell FD, Fox AW, Weeks RE, et al. Differentiating the efficacy of 5-HT(1B/1D) agonists. Headache. Mar. 2001;41(3):257-63. [pmid: 11264685].
689 Sheftell FD, Rapoport AM, Marriott J, et al. Comparison of meclomen, ergotamine tartrate with caffeine and placebo for the treatment of acute headaches: a double-blind parallel-group multi-center study. Headache. 1988:299.
690 Shrikanth V, Vanderheiden A, Simha V. Spontaneous intracerebral hemorrhage associated with ingestion of isometheptine containing anti-migraine medication. Clin Neurol Neurosurg. Feb. 2011;113(2):167-9. [pmid: 21075510].
691 Shuster LT, Faubion SS, Sood R, et al. Hormonal manipulation strategies in the management of menstrual migraine and other hormonally related headaches. Curr Neurol Neurosci Rep. Apr. 2011;11(2):131-8. [pmid: 21207200].
692 Sicuteri F, Del Bene E. The influence of tryptophan and parachlorophenylalanine on the sexual activity in man. Acta vitaminologica et enzymologica. 1975:100-2. [pmid: 146411].
693 Siitonen S, Uusitalo A. Angiotensin converting enzyme activity and blood pressure during treatment and after discontinuation of Ramipril and Enalapril in hypertensive patients. Journal of Clinical Research. 1998:63-74.
694 Silberstein SD. Rizatriptan versus usual care in long-term treatment of migraine. Neurology. 2000;55(9 Suppl 2):S25-8. [pmid: 11089516].
695 Silberstein SD. Pharmacological profile and clinical characteristics of frovatriptan in the acute treatment of migraine: introduction. Headache. Apr. Suppl 2. 2002;42:S45-6. [pmid: 12028319].
696 Silberstein SD, Cady RK, Sheftell FD, et al. Efficacy of eletriptan in migraine-related functional impairment: functional and work productivity outcomes. Headache. May. 2007;47(5):673-82. [pmid: 17501848].
697 Silberstein SD, Gobel H, Jensen R, et al. Botulinum toxin type A in the prophylactic treatment of chronic tension-type headache: a multicentre, double-blind, randomized, placebo-controlled, parallel-group study. Cephalalgia. Jul. 2006;26(7):790-800. [pmid: 16776693].
698 Siniatchkin M, Hierundar A, Kropp P, et al. Self-regulation of slow cortical potentials in children with migraine: an exploratory study. Applied Psychophysiology and Biofeedback. 2000:13-32. [pmid: 10832507].
699 Smith DA, Cleary EW, Watkins S, et al. Pharmacokinetics and pharmacodynamics of zolmitriptan in patients with mild to moderate hypertension: a double-blind, placebo-controlled study. Journal of clinical pharmacology. 1998:685-93. [pmid: 9725543].
700 Smith DA, Cleary EW, Watkins S, et al. Zolmitriptan (311C90) does not interact with fluoxetine in healthy volunteers. International journal of clinical pharmacology and therapeutics. 1998:301-5. [pmid: 9660035].
701 Smith M, Golwala H, Lozano P. Zolmitriptan induced acute coronary syndrome: a unique case. Am J Ther. Sep. 2011;18(5):e153-6. [pmid: 21869671].
702 Smythe GA, Lazarus L. Suppression of human growth hormone secretion by melatonin and cyproheptadine. J Clin Invest. Jul. 1974;54(1):116-21. [pmid: 4600047].
703 Sobaniec W, Kulak W, Smigielska-Kuzia J, et al. A multicenter, placebo-controlled, double-blind study of efficacy of a new form of carbamazepine (CarbatrolR) in refractory epileptic patients. Polish Journal of Pharmacology. 2004:195-201. [pmid: 15156070].
704 Solbach MP, Waymer RS. Treatment of menstruation-associated migraine headache with subcutaneous sumatriptan. Obstet Gynecol. Nov. 1993;82(5):769-72. [pmid: 8414324].
705 Solomon S, Frishberg B, Hu XH, et al. Migraine treatment outcomes with rizatriptan in triptan-naive patients: a naturalistic study. Clinical Therapeutics. Jun. 2001;23(6):886-900. [pmid: 11440288].
706 Somerville BW. Treatment of migraine attacks with an analgesic combination (Mersyndol). The Medical journal of Australia. 1976:865-6. [pmid: 787738].
707 Soriani S, Battistella PA, Naccarella C, et al. Nimesulide and acetaminophen for the treatment of juvenile migraine: A study for comparison of efficacy, safety, and tolerability. Headache Quarterly. 2001:233-6.
708 Soyka D. Treatment of acute migraine attacks with intravenous flunarizine. Cephalalgia. 1987:529.
709 Soyka D, Taneri Z, Oestreich W, et al. Flunarizine iv in the acute treatment of the migraine attack A double-blind placebo-controlled study. Cephalalgia: an international journal of headache. 1988:35-40. [pmid: 3180201].
710 Spears RC. Is gabapentin an effective treatment choice for hemicrania continua?. Journal of Headache & Pain. Aug. 2009;10(4):271-5. [pmid: 19437100].
711 Spierings EL. Electriptan in acute migraine: A double-blind, placebo-controlled comparison to sumatriptan. Neurology. Sep. 12. 2000;55(5):735. author reply 6. [pmid: 10980753].
712 Spierings ELH, Keywood C. Rapid responders to frovatriptan in acute migraine treatment: results from a long-term, open-label study. Pain Medicine. May–Jun. 2009;10(4):633-8. [pmid: 19453958].
713 Spira PJ, Beran RG. Gabapentin in the prophylaxis of chronic daily headache: a randomized, placebo-controlled study. Neurology. Dec. 23. 2003;61(12):1753-9. [pmid: 14694042].
714 Sramek JJ, Hussey EK, Clements B, et al. Oral sumatriptan pharmacokinetics in the migraine state. Clinical Drug Investigation. 1999:137-44.
715 Srinivasu P, Rambhau D, Rao BR, et al. Lack of pharmacokinetic interaction between sumatriptan and naproxen. Journal of clinical pharmacology. 2000:99-104. [pmid: 10631628].
716 Sriraman R, Indu S, Chari P. Is granisetron-dexamethasone combination better than ondansetron - dexamethasone in the prevention of postoperative nausea and vomiting in outpatient gynaecological laparoscopy?. Journal of Anaesthesiology Clinical Pharmacology. 2007:365-72.
717 Stark S, Spierings EL, McNeal S, et al. Naratriptan efficacy in migraineurs who respond poorly to oral sumatriptan. Headache. Jul–Aug. 2000;40(7):513-20. [pmid: 10940089].
718 Stegall MD, Simon M, Wachs ME, et al. Mycophenolate mofetil decreases rejection in simultaneous pancreas-kidney transplantation when combined with tacrolimus or cyclosporine. Transplantation. 1997:1695-700. [pmid: 9422404].
719 Steiner TJ, Lange R, Voelker M. Aspirin in episodic tension-type headache: placebo-controlled dose-ranging comparison with paracetamol. Cephalalgia: an international journal of headache. 2003:59-66. [pmid: 12534583].
720 Sternieri E, Pinetti D, Coccia CPR, et al. Pharmacokinetics of sumatriptan in non-respondent and in adverse drug reaction reporting migraine patients. Journal of Headache & Pain. Sep. 2005;6(4):319-21. [pmid: 16362699].
721 Stiell IG, Dufour DG, Moher D, et al. Methotrimeprazine versus meperidine and dimenhydrinate in the treatment of severe migraine: a randomized, controlled trial. Ann Emerg Med. Nov. 1991;20(11):1201-5. [pmid: 1952306].
722 Stillman MJ, Zajac D, Rybicki LA. Treatment of primary headache disorders with intravenous valproate: initial outpatient experience. Headache. Jan. 2004;44(1):65-9. [pmid: 14979885].
723 Striano P, Zara F, Santorelli FM, et al. Topiramate-associated worsening symptoms in a patient with familial hemiplegic migraine. Journal of the Neurological Sciences. Sep. 15. 2008;272(1–2):194-5. [pmid: 18603263].
724 Sullivan JT, Preston KL, Testa MP, et al. Psychoactivity and abuse potential of sumatriptan. Clinical pharmacology and therapeutics. 1992:635-42. [pmid: 1333934].
725 Sunshine A, Mulhern SA, Olson N, et al. Comparative sensitivity of stopwatch methodology and conventional pain assessment measures for detecting early response to triptans in migraine: results of a randomized, open-label pilot study. Clin Ther. Aug. 2006;28(8):1107-15. [pmid: 16982287].
726 Syrett N, Abu-Shakra S, Yates R. Zolmitriptan nasal spray: advances in migraine treatment. Neurology. Oct. 28. 2003;61(8 Suppl 4):S27-30. [pmid: 14581655].
727 Szekely B, Merryman S, Croft H, et al. Prophylactic effects of naproxen sodium on perimenstrual headache: a double-blind, placebo-controlled study. Cephalalgia. 1989;9(Suppl 10):452-3. PMID.
728 Tamayo-Sarver JH, Dawson NV, Cydulka RK, et al. Variability in emergency physician decision making about prescribing opioid analgesics. Annals of Emergency Medicine. Apr. 2004;43(4):483-93. [pmid: 15039692].
729 Tamayo-Sarver JH, Dawson NV, Hinze SW, et al. The effect of race/ethnicity and desirable social characteristics on physicians' decisions to prescribe opioid analgesics. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. 2003:1239-48. [pmid: 14597500].
730 Tamayo-Sarver JH, Dawson NV, Hinze SW, et al. The effect of race/ethnicity and desirable social characteristics on physicians' decisions to prescribe opioid analgesics. Academic emergency medicine : official journal of the Society for Academic Emergency Medicine. 2004:1239-48.
731 Tamura BM, Chang B. Botulinum toxin: application into acupuncture points for migraine. Dermatologic Surgery. Jul. 2003;29(7):749-54. [pmid: 12828700].
732 Taylor FR, Heiring JO, Messina E, et al. Sumatriptan/naproxen sodium as early intervention for migraine: Effects on functional ability, productivity, and satisfaction in 2 randomized controlled trials. Journal of Clinical Outcomes Management. 2007:195-204.
733 Taylor M, Silva S, Cottrell C. Botulinum toxin type-A (BOTOX) in the treatment of occipital neuralgia: a pilot study. Headache. Nov–Dec. 2008;48(10):1476-81. [pmid: 19076646].
734 Tedeschi G, Casucci G, Di Costanzo A, et al. Acute effect of flunarizine on saccadic eye movements. Acta neurologica. 1992:326-32. [pmid: 1293975].
735 Teixeira AL, Meira FC, Maia DP, et al. Migraine headache in patients with Sydenham's chorea. Cephalalgia: an international journal of headache. 2005:542-4. [pmid: 15955042].
736 Tek D, Mellon M. The effectiveness of nalbuphine and hydroxyzine for the emergency treatment of severe headache. Annals of emergency medicine. 1987:308-13. [pmid: 3544982].
737 Tek DS, McClellan DS, Olshaker JS, et al. A prospective, double-blind study of metoclopramide hydrochloride for the control of migraine in the emergency department. Ann Emerg Med. Oct. 1990;19(10):1083-7. [pmid: 2221512].
738 ten Berg K, van Oppen ACC, Nikkels PGJ, et al. Complex cardiac defect with hypoplastic right ventricle in a fetus with valproate exposure. Prenatal Diagnosis. Feb. 2005;25(2):156-8. [pmid: 15712340].
739 Tepper SJ, Bigal ME, Sheftell FD, et al. Botulinum neurotoxin type A in the preventive treatment of refractory headache: a review of 100 consecutive cases. Headache. Sep. 2004;44(8):794-800. [pmid: 15330826].
740 Tepper SJ, Cochran A, Hobbs S, et al. Sumatriptan suppositories for the acute treatment of migraine. International Journal of Clinical Practice. 1998:31-5. [pmid: 9536565].
741 Tepper SJ, Donnan GA, Dowson AJ, et al. A long-term study to maximise migraine relief with zolmitriptan. Curr Med Res Opin. 1999;15(4):254-71. [pmid: 10640258].
742 Terrazzino S, Viana M, Floriddia E, et al. The serotonin transporter gene polymorphism STin2 VNTR confers an increased risk of inconsistent response to triptans in migraine patients. European Journal of Pharmacology. Sep. 1. 2010;641(2–3):82-7. [pmid: 20488209].
743 Terwindt GM, Ophoff RA, Haan J, et al. Familial hemiplegic migraine: a clinical comparison of families linked and unlinked to chromosome 19.DMG RG. Cephalalgia: an international journal of headache. 1996:153-5. [pmid: 8734765].
744 Tfelt-Hansen P. Pain freedom at 2 hours in migraine after telcagepant 300 mg. CNS Drugs. Mar. 1. 2011;25(3):269-70. [pmid: 21323397].
745 Tfelt-Hansen P. Low efficacy of transdermal sumatriptan in migraine. CNS Drugs. Feb. 1. 2011;25(2):171. author reply -3. [pmid: 21254793].
746 Tfelt-Hansen P, Bach FW, Daugaard D, et al. Treatment with sumatriptan 50 mg in the mild phase of migraine attacks in patients with infrequent attacks: a randomised, double-blind, placebo-controlled study. J Headache Pain. Dec. 2006;7(6):389-94. [pmid: 17164991].
747 Tfelt-Hansen P, Goadsby PJ. Naratriptan is effective and well tolerated in the acute treatment of migraine. [comment]. Neurology. 1999:1300-1. [pmid: 10214771].
748 Tfelt-Hansen P, Henry P, Mulder LJ, et al. The effectiveness of combined oral lysine acetylsalicylate and metoclopramide compared with oral sumatriptan for migraine. Lancet. Oct. 7. 1995;346(8980):923-6. [pmid: 7564725].
749 Tfelt-Hansen P, Jensen K, Vendsborg P, et al. Chlormezanone in the treatment of migraine attacks: A double blind comparison with diazepam and placebo. Cephalalgia. 1982:205-10. [pmid: 6760981].
750 Tfelt-Hansen P, Olesen J, Aebelholt-Krabbe A, et al. A double blind study of metoclopramide in the treatment of migraine attacks. J Neurol Neurosurg Psychiatry. 1980:369-71. [pmid: 7373338].
751 Tfelt-Hansen P, Ryan RE Jr. Oral therapy for migraine: comparisons between rizatriptan and sumatriptan. A review of four randomized, double-blind clinical trials. Neurology. 2000;55(9 Suppl 2):S19-24. [pmid: 11089515].
752 Tfelt-Hansen P, Seidelin K, Stepanavage M, et al. The effect of rizatriptan, ergotamine, and their combination on human peripheral arteries: a double-blind, placebo-controlled, crossover study in normal subjects. Br J Clin Pharmacol. Jul. 2002;54(1):38-44. [pmid: 12100223].
753 Tfelt-Hansen PC. Unpublished clinical trials with sumatriptan. Lancet. Oct. 31. 2009;374(9700):1501-2. [pmid: 19880018].
754 Than M, Bidwell S, Davison C, et al. Evidence-based emergency medicine at the 'coal face'. Emergency Medicine Australasia. Aug. 2005;17(4):330-40. [pmid: 16091095].
755 The SBMSG. The efficacy, tolerability and safety of oral sumatriptan 50 mg in the acute treatment of migraine. [abstract]. European Journal of Neurology. 1996:149.
756 The SBMSG. A study comparing the efficiency, safety and tolerability of oral sumatriptan 25, 50 and 100 mg doses in the acute treatment of migraine. [abstract]. European Journal of Neurology. 1996:149-50.
757 Thomas J, Tomb E, Thomas E, et al. Migraine treatment by oral magnesium intake and correction of the irritation of buccofacial and cervical muscles as a side effect of mandibular imbalance. Magnes Res. Jun. 1994;7(2):123-7. [pmid: 7999526].
758 Thompson I, Williams G, Caldwell B, et al. Randomised double-blind, placebo-controlled trial of the effects of the 'party pills' BZP/TFMPP alone and in combination with alcohol. Journal of psychopharmacology (Oxford, England). 2010:1299-308.
759 Thompson M, Gawel M, Desjardins B, et al. An economic evaluation of rizatriptan in the treatment of migraine. Pharmacoeconomics. 2005;23(8):837-50. [pmid: 16097844].
760 Tiller JW, Johnson GF, Burrows GD. Moclobemide for depression: an Australian psychiatric practice study. Journal of clinical psychopharmacology. 1995:31s-4s. [pmid: 7593727].
761 Titus F, Escamilla C, Gomes Da, Costa Palmeira MM, et al. A double-blind comparison of lysine acetylsalicylate plus metoclopramide vs ergotamine plus caffeine in migraine: Effects on nausea, vomiting and headache symptoms. Clinical Drug Investigation. 2001:87-94.
762 Tobin J, Flitman S. Treatment of migraine with occipital nerve blocks using only corticosteroids. Headache. Jan. 2011;51(1):155-9. [pmid: 21198577].
763 Tokola R, Hokkanen E. Propranolol for acute migraine. Br Med J. Oct. 14. 1978;2(6144):1089. [pmid: 709242].
764 Tokola RA. Tolfenamic acid in combination with caffeine: absorption during acute migraine. Methods and findings in experimental and clinical pharmacology. 1985:545-50. [pmid: 3878441].
765 Tokola RA. The effect of metoclopramide and prochlorperazine on the absorption of effervescent paracetamol in migraine. Cephalalgia: an international journal of headache. 1988:139-47. [pmid: 3197094].
766 Tokola RA, Kangasniemi P, Neuvonen PJ, et al. Tolfenamic acid, metoclopramide, caffeine and their combinations in the treatment of migraine attacks. Cephalalgia. Dec. 1984;4(4):253-63. [pmid: 6394143].
767 Troconiz IF, Wolters JM, Tillmann C, et al. Modelling the anti-migraine effects of BIBN 4096 BS: a new calcitonin gene-related peptide receptor antagonist. Clin Pharmacokinet. 2006;45(7):715-28. [pmid: 16802852].
768 Tronvik E, Stovner LJ, Bovim G, et al. Angiotensin-converting enzyme gene insertion/deletion polymorphism in migraine patients. BMC Neurology. 2008;8:4. [pmid: 18366776].
769 Trottier ED, Bailey B, Dauphin-Pierre S, et al. Practice variation after implementation of a protocol for migraines in children. European Journal of Emergency Medicine. Oct. 2010;17(5):290-2. [pmid: 19864956].
770 Trottier ED, Bailey B, Dauphin-Pierre S, et al. Clinical outcomes of children treated with intravenous prochlorperazine for migraine in a pediatric emergency department. J Emerg Med. Aug. 2010;39(2):166-73. [pmid: 19150192].
771 Tuchin PJ, Pollard H, Bonello R. A randomized controlled trial of chiropractic spinal manipulative therapy for migraine. J Manipulative Physiol Ther. Feb. 2000;23(2):91-5. [pmid: 10714533].
772 Tuchman M, Edvinsson L, Geraud G, et al. Zolmitriptan provides consistent migraine relief when used in the long-term. Curr Med Res Opin. 1999;15(4):272-81. [pmid: 10640259].
773 Turcani P, Farkasova D, Marcek T, et al. Real-life experiences in migraine therapy. Bratislavske Lekarske Listy. 2010;111(2):74-8. [pmid: 20429318].
774 Türk U, Ilhan S, Alp R, et al. Botulinum toxin and intractable trigeminal neuralgia. Clinical neuropharmacology. 2005:161-2. [pmid: 16062093].
775 Turner IM, Agrillo T. Migraine, botulinum toxin type-A, and the disappearing sebaceous cyst. Headache. Feb. 2005;45(2):166-7. [pmid: 15705125].
776 Tvedskov JF, Iversen HK, Olesen J. A double-blind study of SB-220453 (Tonerbasat) in the glyceryltrinitrate (GTN) model of migraine. Cephalalgia. Oct. 2004;24(10):875-82. [pmid: 15377319].
777 Tvedskov JF, Iversen HK, Olesen J, et al. Nitroglycerin provocation in normal subjects is not a useful human migraine model?. Cephalalgia. Aug. 2010;30(8):928-32. [pmid: 19740120].
778 Tvedskov JF, Thomsen LL, Iversen HK, et al. The prophylactic effect of valproate on glyceryltrinitrate induced migraine. Cephalalgia. Jul. 2004;24(7):576-85. [pmid: 15196300].
779 U.S. Food and Drug Administration. Clinical Pharmacology Review of Inderal® (propranolol hydrochloride). 1-18. PMID.
780 U.S. Food and Drug Administration. Public Health Advisory: treatment challenges of depression in pregnancy and the possibility of persistent pulmonary hypertension in newborns. Public Health Advisories. 2006. 2006 Public Health Advisories. PMID.
781 U.S. Food and Drug Administration. Office of Clinical Pharmacology and Biopharmaceutics/Pharmacometrics Review of Olanzapine October 30, 2006. 2006.
782 U.S. Food and Drug Administration. Clinical Executive Summary of Olanzapine 10/31/06. 2006.
783 U.S. Food and Drug Administration. Clinical Pharmacology/Biopharmaceutics. Review of Divalproex Sodium. 2007:1-10. NDA21-168/SE5-015.
784 U.S. Food and Drug Administration. Clinical Pharmacology/Biopharmaceutics. Review of Aripiprazole. 2007:1-73. NDA21436/S018.
785 U.S. Food and Drug Administration. Clinical Pharmacology Review of Guanfacine Hydrochloride. 2007.
786 U.S. Food and Drug Administration. Clinical Review of Guanfacine Hydrochloride. 2007.
787 U.S. Food and Drug Administration. Clinical Review of Combigan (brimonidine tartrate-timolol maleate). 2007.
788 U.S. Food and Drug Administration. Clinical Pharmacology Review of Combigan May 3, 2007. 2007.
789 U.S. Food and Drug Administration. Statistical Review and Evaluation of Combigan: Clinical Studies. 2007.
790 U.S. Food and Drug Administration. Clinical Pharmacology Review of Simvastatin. 2007.
791 U.S. Food and Drug Administration. Clinical Review of Olanzapine 4/06/2007. 2007.
792 U.S. Food and Drug Administration. Clinical Pharmacology/Biopharmaceutics Review of AXERT® (almotriptan malate). 2008.
793 U.S. Food and Drug Administration. Clinical Pharmacology Review of KEPPRA® (levetiracetam). 2008.
794 US Food and Drug Administration. Safety Review: sNDA for Levetiracetam Use in Pediatric Patients With Refractory Partial Onset Seizures. 2008.
795 U.S. Food and Drug Administration. Clinical Review of Divalproex Sodium. 2008.
796 U.S. Food and Drug Administration. Clinical Pharmacology/Biopharmaceutics Review of Escitalopram. 2008.
797 U.S. Food and Drug Administration. Clinical Review of Abilify® (aripiprazole). 2008.
798 U.S. Food and Drug Administration. Memorandum of Lamictal XR July 10, 2008. 2008.
799 U.S. Food and Drug Administration. Clinical Review of Divalproex Sodium. 2008.
800 U.S. Food and Drug Administration. Joint Clinical and Statistical Review of Levetiracetam. March. 18. 2008.
801 U.S. Food and Drug Administration. Clinical Review of Simvastatin. 2008.
802 U.S. Food and Drug Administration. Clinical Pharmacology and Biopharmaceutics Review of Zolmitriptan. 2008.
803 U.S. Food and Drug Administration. Clinical Review of Olanzapine 7/14/2008. 2008.
804 U.S. Food and Drug Administration. Clinical Review of Candesartan Cilexetil. 2009.
805 U.S. Food and Drug Administration. Clinical Review of Almotriptan. 2009.
806 U.S. Food and Drug Administration. Statistical Review of Almotriptan. 2009.
807 U.S. Food and Drug Administration. Clinical Review of Escitalopram. 2009.
808 U.S. Food and Drug Administration. Memorandum of Guanfacine September 1, 2009. 2009.
809 U.S. Food and Drug Administration. Memorandum of Lamotrigine. May. 6. 2009. 2009:1-4. NDA 22-115.
810 U.S. Food and Drug Administration. Statistical Review and Evaluation of CLONICEL® (clonidine HCI modified release). Clinical Studies. 2009:1-32. NDA 22-331/S-001.
811 U.S. Food and Drug Administration. Clinical Review of Lamotrigine XR March 6, 2009. 2009.
812 U.S. Food and Drug Administration. Statistical Review and Evaluation of Lamotrigine March 31, 2009. 2009.
813 U.S. Food and Drug Administration. Clinical Review of Topiramate. 2009.
814 U.S. Food and Drug Administration. Clinical Pharmacology Review of Topiramate. 2009.
815 U.S. Food and Drug Administration. Clinical Review of Quetiapine 8/10/2009. 2009.
816 U.S. FOod and Drug Administration. Clinical Pharmacology and Biopharmaceutics Review of Quetiapine. 2009.
817 U.S. Food and Drug Administration. Statistical Review and Evaluation of Seroquel (quetiapine fumarate): Clinical Studies. 2009.
818 U.S. Food and Drug Administration. Clinical Pharmacology Review of Guanfacine. 2010.
819 U.S. Food and Drug Administration. Statistical Review and Evaluation of Guanfacine: Clinical Studies. 2010.
820 U.S. Food and Drug Administration. Statistical Review and Evaluation of Guanfacine. 2010.
821 U.S. Food and Drug Administration. Clinical Review of Clonidine Hydrochloride. 2010.
822 U.S. Food and Drug Administration. Pharmacometrics Review of Clonidine. 2010.
823 U.S. Food and Drug Administration. Clinical Review of Norethindrone October 4, 2010. 2010.
824 US Food and Drug Administration. Clinical Review: Second Review of Prenatal Valproic Acid Exposure and Neurdevelopmental Delay. 2010.
825 U.S. Food and Drug Administration. Clinical Review of Guanfacine. 2011.
826 U.S. Food and Drug Administration. Clinical Review of Lamotrigine. 2011.
827 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Clinical Review of Topamax (topiramate): Division of Neuropharmacological Drug Products. 1998.
828 U.S. Food and Drug Administration, Center for Drug Evaluation and Research. Statistical Review and Evaluation of Topiramate: The R.W. Johnson Pharmaceutical Research Institute. 1998.
829 US Food and Drug Administration, Department of Health and Human Service, Public Health Service, et al. Memorandum of Divalproex Sodium. 2008.
830 US Food and Drug Administration, Department of Health and Human Services, Public Health Service, et al. Memorandum of Olanzapine April 29, 2007. 2007.
831 US Food and Drug Administration, Department of Health and Human Services, Public Health Service, et al. Memorandum of Olanzapine July 18, 2008. 2008.
832 US Food and Drug Administration, Department of Health and Human Services, Public Health Service, et al. Memorandum of Guanfacine July 27, 2009. 2009.
833 U.S. Food and Drug Administration, Johnson and Johnson Pharmaceutical Research and Development L.L.C. Clinical Review of Topiramate: Johnson and Johnson Pharmaceutical Research and Development L.L.C. 2009.
834 U.S. Food and Drug Administration, Office of Clinical Pharmacology Review. Clinical Pharmacology Review of Candesartan Cilexitil. 2009.
835 US Food and Drug Administration, U.S. Department of Health and Human Services, Center For Drug Evaluation and Research, et al. Statistical Review and Evaluation of Zomig® (zolmitriptan nasal spray) October 14, 2008. 2008.
836 US Food and Drug Administration, U.S. Department of Health and Human Services, Center for Drug Evaluation and Research, et al. Statistical Review and Evaluation of Olanzapine: Clinical Studies December 29, 2006. 2006.
837 US Food and Drug Administration, U.S. Department of Health and Human Services, Center for Drug Evaluation and Research, et al. Statistical Review and Evaluation: Antiepileptic Drugs and Suicidality. 2008.
838 US Food and Drug Administration, U.S. Department of Health and Human Services, Center for Drug Evaluation and Research, et al. Statistical Review and Evaluation of Escitalopram: Clinical Studies. 2008.
839 US Food and Drug Administration, U.S. Department of Health and Human Services, Center for Drug Evaluation and Research, et al. Statistical Review and Evaluation of Aripiprazole: Clinical Studies. 2008:1-13. NDA 21-463/S-021.
840 US Food and Drug Administration, U.S. Department of Health and Human Services, Center for Drug Evaluation and Research, et al. Statistical Review and Evaluation of Simvastatin: Pediatric Study. 2008.
841 US Food and Drug Administration, U.S. Department of Health and Human Services, Center for Drug Evaluation and Research, et al. Statistical Review and Evaluation of Candesartan Cilexetil: Clinical Studies. 2009.
842 Uldall P, Bulteau C, Pedersen S, et al. Single-blind study of safety, tolerability, and preliminary efficacy of tiagabine as adjunctive treatment of children with epilepsy. Epilepsia. 1995;36(Suppl 3):S147-S8. PMID.
843 Utiger D, Eichenberger U, Bernasch D, et al. Transient minor improvement of high altitude headache by sumatriptan. High altitude medicine & biology. 2002:387-93. [pmid: 12631424].
844 Uzogara E, Sheehan DV, Manschreck TC, et al. A combination drug treatment for acute common migraine. Headache. 1986:231-6. [pmid: 3522481].
845 Vachharajani NN, Shyu WC, Nichola PS, et al. A pharmacokinetic interaction study between butorphanol and sumatriptan nasal sprays in healthy subjects: importance of the timing of butorphanol administration. Cephalalgia: an international journal of headache. 2002:282-7. [pmid: 12100090].
846 Vakil N, Kianifard F, Bottoli I. Exploratory study of tegaserod for dyspepsia in women receiving PPIs for heartburn. Archives of Drug Information. 2008. 79-88TN: NCT00171470/ClinicalTrials.gov.
847 Van Haarst AD, Van Gerven JM, Cohen AF, et al. The effects of moclobemide on the pharmacokinetics of the 5-HT1B/1D agonist rizatriptan in healthy volunteers. British journal of clinical pharmacology. 1999:190-6. [pmid: 10417495].
848 Vasconcellos E, Pina-Garza JE, Millan EJ, et al. Analgesic rebound headache in children and adolescents. J Child Neurol. Sep. 1998;13(9):443-7. [pmid: 9733291].
849 Vasudeva S, Claggett AL, Tietjen GE, et al. Biofeedback-assisted relaxation in migraine headache: relationship to cerebral blood flow velocity in the middle cerebral artery. Headache. Mar. 2003;43(3):245-50. [pmid: 12603643].
850 Vaughan D, Speed J, Medve R, et al. Safety and pharmacokinetics of NXN-188 after single and multiple doses in five phase I, randomized, double-blind, parallel studies in healthy adult volunteers. Clinical therapeutics. 2010:146-60. [pmid: 20171420].
851 Vernon H, Jansz G, Goldsmith CH, et al. A randomized, placebo-controlled clinical trial of chiropractic and medical prophylactic treatment of adults with tension-type headache: results from a stopped trial. J Manipulative Physiol Ther. Jun. 2009;32(5):344-51. [pmid: 19539116].
852 Vestergaard P, Hermann AP, Gram J, et al. Improving compliance with hormonal replacement therapy in primary osteoporosis prevention. Maturitas. 1997:137-45. [pmid: 9522321].
853 Vikelis M, Rapoport AM. New drug delivery options for migraine. Expert Rev Neurother. Jun. 2011;11(6):771-3. [pmid: 21651323].
854 Vinson DR. Emergency department treatment of migraine headaches. Archives of Internal Medicine. Apr. 8. 2002;162(7):845. author reply 6. [pmid: 11926869].
855 Vinson DR. Treatment patterns of isolated benign headache in US emergency departments. Annals of Emergency Medicine. Mar. 2002;39(3):215-22. [pmid: 11867972].
856 Vinson DR, Hurtado TR, Vandenberg JT, et al. Variations among emergency departments in the treatment of benign headache. Annals of Emergency Medicine. Jan. 2003;41(1):90-7. [pmid: 12514688].
857 Visser WH, Ferrari MD, Bayliss EM, et al. Treatment of migraine attacks with subcutaneous sumatriptan: first placebo-controlled study. The Subcutaneous Sumatriptan International Study Group. Cephalalgia. Oct. 1992;12(5):308-13. [pmid: 1330318].
858 Visser WH, Winner P, Strohmaier K, et al. Rizatriptan 5 mg for the acute treatment of migraine in adolescents: results from a double-blind, single-attack study and two open-label, multiple-attack studies. Headache. Oct. 2004;44(9):891-9. [pmid: 15447698].
859 Vollono C, Capuano A, Mei D, et al. Multiple attack study on the available triptans in Italy versus placebo. Eur J Neurol. Jul. 2005;12(7):557-63. [pmid: 15958097].
860 Vollono C, Ferraro D, Miliucci R, et al. The abnormal recovery cycle of somatosensory evoked potential components in children with migraine can be reversed by topiramate. Cephalalgia. Jan. 2010;30(1):17-26. [pmid: 19489886].
861 Vukovic-Cvetkovic V, Plavec D, Lovrencic-Huzjan A, et al. Is iron deficiency anemia related to menstrual migraine? Post hoc analysis of an observational study evaluating clinical characteristics of patients with menstrual migraine. Acta Clin Croat. Dec. 2010;49(4):389-94. [pmid: 21830449].
862 Walach H, Betz HD, Schweickhardt A. Sferics and headache: a prospective study. Cephalalgia. Jul. 2001;21(6):685-90. [pmid: 11531901].
863 Walker Z, Walker RW, Robertson MM, et al. Antidepressant treatment of chronic tension-type headache: a comparison between fluoxetine and desipramine. Headache. Jul–Aug. 1998;38(7):523-8. [pmid: 15613168].
864 Wallasch TM. Frovatriptan in the practice of office-based neurologists/pain therapists: Results of postmarketing surveillance study ALADIN. Advances in Therapy. Jan. 2010;27(1):56-62. [pmid: 20140543].
865 Wang SJ, Fuh JL, Wu ZA. Intranasal sumatriptan study with high placebo response in Taiwanese patients with migraine. J Chin Med Assoc. Feb. 2007;70(2):39-46. [pmid: 17339143].
866 Wasiak J, Anderson JN. Is dexamethasone effective in treating acute migraine headache?. Medical Journal of Australia. Jan. 21. 2002;176(2):83. [pmid: 11936293].
867 Watanabe Y, Tanaka H, Dan I, et al. Monitoring cortical hemodynamic changes after sumatriptan injection during migraine attack by near-infrared spectroscopy. Neurosci Res. Jan. 2011;69(1):60-6. [pmid: 20875464].
868 Waters WE. Controlled clinical trial of ergotamine tartrate. Br Med J. May. 9. 1970;2(5705):325-7. [pmid: 4913961].
869 Weaver MB, Mackowiak JI, Solari PG. Triptan therapy impacts health and productivity. Journal of Occupational & Environmental Medicine. Aug. 2004;46(8):812-7. [pmid: 15300133].
870 Weder CR, Schneemann M. Triptans and troponin: a case report. Orphanet Journal Of Rare Diseases. 2009;4:15. [pmid: 19538745].
871 Wells NE, Steiner TJ. Effectiveness of eletriptan in reducing time loss caused by migraine attacks. Pharmacoeconomics. Dec. 2000;18(6):557-66. [pmid: 11227394].
872 Wheeler SD. Donepezil treatment of topiramate-related cognitive dysfunction. Headache. Feb. 2006;46(2):332-5. [pmid: 16492246].
873 White JR, Bell WL. Dysphonia associated with carotidynia and migraine responding to dihydroergotamine. Headache. Jan. 2003;43(1):69-71. [pmid: 12864762].
874 Wiklund IK, Mattsson LA, Lindgren R, et al. Effects of a standardized ginseng extract on quality of life and physiological parameters in symptomatic postmenopausal women: A double-blind, placebo-controlled trial. International Journal of Clinical Pharmacology Research. 1999:89-99. [pmid: 10761538].
875 Wilkinson M. L-ASA compared to sumatriptan and parenteral placebo in the acute treatment of migraine. Cephalalgia. 1999:542.
876 Willer L, Jensen RH, Juhler M. Medication overuse as a cause of chronic headache in shunted hydrocephalus patients. J Neurol Neurosurg Psychiatry. Nov. 2010;81(11):1261-4. [pmid: 20660917].
877 Wilson AJ, Baum M, Brinkley DM, et al. Six-year results of a controlled trial of tamoxifen as single adjuvant agent in management of early breast cancer. World-J-Surg. 1985:756-64. [pmid: 3904233].
878 Wilson JR, Foresman BH, Gamber RG, et al. Hyperbaric oxygen in the treatment of migraine with aura. Headache. Feb. 1998;38(2):112-5. [pmid: 9529766].
879 Winner P, Adelman J, Aurora S, et al. Efficacy and tolerability of sumatriptan injection for the treatment of morning migraine: two multicenter, prospective, randomized, double-blind, controlled studies in adults. Clinical therapeutics. 2006:1582-91. [pmid: 17157114].
880 Winner P, Dalessio D, Mathew N, et al. Concomitant administration of antiemetics is not necessary with intramuscular dihydroergotamine. The American journal of emergency medicine. 1994:138-41. [pmid: 8161382].
881 Winner P, Landy S, Richardson M, et al. Early intervention in migraine with sumatriptan tablets 50 mg versus 100 mg: a pooled analysis of data from six clinical trials. Clin Ther. Nov. 2005;27(11):1785-94. [pmid: 16368449].
882 Winner P, Mannix LK, Putnam DG, et al. Pain-free results with sumatriptan taken at the first sign of migraine pain: 2 randomized, double-blind, placebo-controlled studies. Mayo Clin Proc. Oct. 2003;78(10):1214-22. [pmid: 14531480].
883 Winner P, Rothner AD, Wooten JD, et al. Sumatriptan nasal spray in adolescent migraineurs: a randomized, double-blind, placebo-controlled, acute study. Headache. Feb. 2006;46(2):212-22. [pmid: 16492230].
884 Winner P, Saper JR, Nett R, et al. Sumatriptan nasal spray in the acute treatment of migraine in adoselcent migraineurs. Pediatrics. 1999:694-5.
885 Wober C, Wober-Bingol C. Intranasal sumatriptan for the acute treatment of migraine in children. Neurology. Mar. 14. 2000;54(5):1209-10. [pmid: 10720311].
886 Wonderling D, Vickers AJ, Grieve R, et al. Cost effectiveness analysis of a randomised trial of acupuncture for chronic headache in primary care. BMJ (Clinical research ed.). 2004:747.
887 Wynn RL. The sugar-loaded fentanyl lollipop (Actiq) and the risk for tooth decay. Gen Dent. May–Jun. 2011;59(3):168-70. [pmid: 21903538].
888 Wynne AG, Romanski SA, Klee GG, et al. Nifedipine, but not verapamil, acutely elevates parathyroid hormone levels in premenopausal women. Clinical endocrinology. 1995:9-15. [pmid: 7889637].
889 Yamaki T, Nozaki M, Sakurai H, et al. Multiple small-dose injections can reduce the passage of sclerosant foam into deep veins during foam sclerotherapy for varicose veins. European journal of vascular and endovascular surgery : the official journal of the European Society for Vascular Surgery. 2009:343-8.
890 Yang TY, Jang TY. The effects of one botulinum toxin type A (BTX-A) injection after UPPP. European archives of oto-rhino-laryngology : official journal of the European Federation of Oto-Rhino-Laryngological Societies (EUFOS) : affiliated with the German Society for Oto-Rhino-Laryngology - Head and Neck Surgery. 2008:1269-73.
891 Yurekli VA, Akhan G, Kutluhan S, et al. The effect of sodium valproate on chronic daily headache and its subgroups. J Headache Pain. Feb. 2008;9(1):37-41. [pmid: 18231713].
892 Zafeiriou DI, Vargiami E. Childhood steroid-responsive painful opthalmoplegia: clues to opthalmoplegic migraine. Journal of Pediatrics. Dec. 2006;149(6):881. [pmid: 17137913].
893 Zangaladze A, Asadi-Pooya AA, Ashkenazi A, et al. Sporadic hemiplegic migraine and epilepsy associated with CACNA1A gene mutation. Epilepsy & Behavior. Feb. 2010;17(2):293-5. [pmid: 20071244].
894 Zank R, Strehl U, Larbig W, et al. Effects of rizatriptan on the contingent negative variation in healthy women. Cephalalgia: an international journal of headache. 2008:922-32. [pmid: 18513259].
895 Zhao YB, Zhang GP, Chen QT, et al. A clinical trial with sumatriptan in patients with acute migraine. The Chinese Journal of Clinical Pharmacology. 1994:143-7.
896 Zito G, Jull G, Story I. Clinical tests of musculoskeletal dysfunction in the diagnosis of cervicogenic headache. Manual therapy. 2006:118-29. [pmid: 16027027].
897 Zukerman E, Negro MHS, Nothen MR. Comparative study on the efficacy and tolerability of different formulations for Tonopan versus placebo in migraine. <ORIGINAL> ESTUDO COMPARATIVO DA EFICACIA E TOLERABILIDADE DE DIFERENTES FORMULACOES DO TONOPAN VERSUS PLACEBO NAS ENXAQUECAS. Rev Bras Neurol. 1990:57-60.
898 Zwart JA, Dyb G, Hagen K, et al. Analgesic use: a predictor of chronic pain and medication overuse headache: the Head-HUNT Study. Neurology. Jul. 22. 2003;61(2):160-4. [pmid: 12874392].

## Not Eligible Outcomes

1 Alberici A, Borroni B, Manelli F, et al. Topiramate weight loss in migraine patients. Journal of the Neurological Sciences. Mar. 15. 2009;278(1–2):64-5. [pmid: 19084843].
2 Bigal ME, Kolodner KB, Lafata JE, et al. Patterns of medical diagnosis and treatment of migraine and probable migraine in a health plan. Cephalalgia. Jan. 2006;26(1):43-9. [pmid: 16396665].
3 Binder WJ, Brin MF, Blitzer A, et al. Botulinum toxin type A (BOTOX) for treatment of migraine headaches: an open-label study. Otolaryngology - Head & Neck Surgery. Dec. 2000;123(6):669-76. [pmid: 11112955].
4 Bowyer SM, Mason KM, Moran JE, et al. Cortical hyperexcitability in migraine patients before and after sodium valproate treatment. J Clin Neurophysiol. Jan–Feb. 2005;22(1):65-7. [pmid: 15689715].
5 Brown JS, Papadopoulos G, Neumann PJ, et al. Cost-effectiveness of topiramate in migraine prevention: results from a pharmacoeconomic model of topiramate treatment. Headache. Sep. 2005;45(8):1012-22. [pmid: 16109115].
6 Brown JS, Papadopoulos G, Neumann PJ, et al. Cost-effectiveness of migraine prevention: the case of topiramate in the UK. Cephalalgia. Dec. 2006;26(12):1473-82. [pmid: 17116098].
7 Brown JS, Rupnow MFT, Neumann P, et al. Cost effectiveness of topiramate in the prevention of migraines in the United States: an update. Managed Care Interface. Dec. 2006;19(12):31-8. [pmid: 17274479].
8 Busch V, Kaube S, Schulte-Mattler W, et al. Sumatriptan and corneal reflexes in headache-free migraine patients: a randomized and placebo-controlled crossover study. Cephalalgia. Feb. 2007;27(2):165-72. [pmid: 17257238].
9 Caproni S, Corbelli I, Pini LA, et al. Migraine preventive drug-induced weight gain may be mediated by effects on hypothalamic peptides: the results of a pilot study. Cephalalgia. Apr. 2011;31(5):543-9. [pmid: 21216871].
10 Caruso JM, Brown WD, Exil G, et al. The efficacy of divalproex sodium in the prophylactic treatment of children with migraine. Headache. Sep. 2000;40(8):672-6. [pmid: 10971664].
11 Cassidy EM, Tomkins E, Sharifi N, et al. Differing central amine receptor sensitivity in different migraine subtypes? A neuroendocrine study using buspirone. Pain. Feb. 2003;101(3):283-90. [pmid: 12583871].
12 Chang CL, Donaghy M, Poulter N. Migraine and stroke in young women: case-control study. The World Health Organisation Collaborative Study of Cardiovascular Disease and Steroid Hormone Contraception. BMJ (Clinical research ed.). 1999:13-8.
13 Charles JA, Jotkowitz S. Observations of the "carry-over effect" following successful termination of chronic migraine in the adolescent with short-term dihydroergotamine, dexamethasone and hydroxyzine: a pilot study. Journal of Headache & Pain. Feb. 2005;6(1):51-4. [pmid: 16362192].
14 Christensen ML, Eades SK, Fuseau E, et al. Pharmacokinetics of naratriptan in adolescent subjects with a history of migraine. Journal of Clinical Pharmacology. Feb. 2001;41(2):170-5. [pmid: 11210397].
15 Christensen ML, Mottern RK, Jabbour JT, et al. Pharmacokinetics of sumatriptan nasal spray in children. Journal of Clinical Pharmacology. Apr. 2004;44(4):359-67. [pmid: 15051742].
16 Claustrat B, Brun J, Chiquet C, et al. Melatonin secretion is supersensitive to light in migraine. Cephalalgia. Feb. 2004;24(2):128-33. [pmid: 14728708].
17 Colucci D'Amato C, Pizza V, Marmolo T, et al. Migraine prophylactic therapy: citalopram versus flunarizine. Headache Quarterly. 2000;11(3):213-5. PMID.
18 Crooks J, Stephen SA, Brass W. Clinical trial of inhaled ergotamine tartrate in migraine. Br Med J. 1964:221-4. [pmid: 14074180].
19 De Ciantis A, Muti M, Piccolini C, et al. A functional MRI study of language disturbances in subjects with migraine headache during treatment with topiramate. Neurological Sciences. May. Suppl 1. 2008;29:S141-3. [pmid: 18545916].
20 Dey R, Khan S, Akhouri V, et al. Labetalol for prophylactic treatment of intractable migraine during pregnancy. Headache. Jul–Aug. 2002;42(7):642-5. [pmid: 12482217].
21 Diener HC, Scholz E, Dichgans J, et al. Central effects of drugs used in migraine prophylaxis evaluated by visual evoked potentials. Ann Neurol. Feb. 1989;25(2):125-30. [pmid: 2645824].
22 Dowson AJ. Analysis of the patients attending a specialist UK headache clinic over a 3-year period. Headache. Jan. 2003;43(1):14-8. [pmid: 12864753].
23 Duquesnoy C, Mamet JP, Sumner D, et al. Comparative clinical pharmacokinetics of single doses of sumatriptan following subcutaneous, oral, rectal and intranasal administration. European journal of pharmaceutical sciences : official journal of the European Federation for Pharmaceutical Sciences. 1998:99-104. [pmid: 9795022].
24 Elkind AH, Wade A, Ishkanian G. Pharmacokinetics of frovatriptan in adolescent migraineurs. Journal of Clinical Pharmacology. Oct. 2004;44(10):1158-65. [pmid: 15342617].
25 Ergun H, Gulmez SE, Tulunay FC. Cost-minimization analysis comparing topiramate with standard treatments in migraine prophylaxis. Eur Neurol. 2007;58(4):215-7. [pmid: 17827966].
26 Evers S, Heuel T, Frese A, et al. The impact of different antimigraine compounds on platelet and erythrocyte aggregation. Cephalalgia. Aug. 2006;26(8):920-4. [pmid: 16886927].
27 Fanciullacci M, Alessandri M, Nicolodi M, et al. Possible long-lasting inhibition of converting enzyme by enalapril in human cerebrospinal fluid. Clin Sci (Lond). Mar. 1993;84(3):313-7. [pmid: 8384953].
28 Feliu AL, Rupnow MFT, Blount A, et al. Resource use associated with topiramate in migraine prophylaxis. American Journal of Health-System Pharmacy. Jul. 15. 2007;64(14):1483-91. [pmid: 17617498].
29 Garcia-Monco JC, Foncea N, Bilbao A, et al. Impact of preventive therapy with nadolol and topiramate on the quality of life of migraine patients. Cephalalgia. Aug. 2007;27(8):920-8. [pmid: 17645757].
30 Gerwig M, Niehaus L, Stude P, et al. Beta-blocker migraine prophylaxis affects the excitability of the visual cortex as revealed by transcranial magnetic stimulation. J Headache Pain. Jan. 2012;13(1):83-9. [pmid: 22089539].
31 Gnecchi-Ruscone T, Lorenzoni R, Anderson D, et al. Effects of ergotamine on myocardial blood flow in migraineurs without evidence of atherosclerotic coronary artery disease. Am J Cardiol. May. 1. 1998;81(9):1165-8. [pmid: 9605061].
32 Gordon CR, Kuritzky A, Doweck I, et al. Vestibulo-ocular reflex in migraine patients: the effect of sodium valproate. Headache. Mar. 1993;33(3):129-32. [pmid: 8486508].
33 Green MW, Giordano S, Jiang P, et al. Effect of divalproex on metabolic parameters is dose related in migraine prophylaxis. Headache. Sep. 2005;45(8):1031-7. [pmid: 16109117].
34 Greenlee CR, Puri V. Pediatric migraines: a case report. Journal of the Kentucky Medical Association. Nov. 2003;101(11):498-504. [pmid: 14635578].
35 Hedman C, Andersen AR. Effects of the B1-selective adrenoceptor antagonist metoprolol on the symptomatology of classic migraine attacks. Cephalalgia. 1987:461-2.
36 Hedman C, Andersen AR, Andersson PG, et al. Symptoms of classic migraine attacks: modifications brought about by metoprolol. Cephalalgia: an international journal of headache. 1988:279-84. [pmid: 3064920].
37 Hedman C, Winther K, Knudsen JB. The difference between non-selective and beta 1-selective beta-blockers in their effect on platelet function in migraine patients. Acta Neurol Scand. Dec. 1986;74(6):475-8. [pmid: 3030039].
38 Hershey AD, Powers SW, Bentti AL, et al. Effectiveness of amitriptyline in the prophylactic management of childhood headaches. Headache. Jul–Aug. 2000;40(7):539-49. [pmid: 10940092].
39 Hirfanoglu T, Serdaroglu A, Gulbahar O, et al. Prophylactic drugs and cytokine and leptin levels in children with migraine. Pediatric Neurology. Oct. 2009;41(4):281-7. [pmid: 19748048].
40 Hughes HE, Goldstein DA. Birth defects following maternal exposure to ergotamine, beta blockers, and caffeine. J Med Genet. Jun. 1988;25(6):396-9. [pmid: 3398007].
41 Iannetti P, Spalice A, Iannetti L, et al. Residual and persistent Adie's pupil after pediatric ophthalmoplegic migraine. Pediatric Neurology. Sep. 2009;41(3):204-6. [pmid: 19664538].
42 Javanmard SH, Sonbolestan SA, Heshmat-Ghahdarijani K, et al. Enalapril improves endothelial function in patients with migraine: A randomized, double-blind, placebo-controlled trial. J Res Med Sci. Jan. 2011;16(1):26-32. [pmid: 21448379].
43 Joseph R, Steiner TJ, Schultz LU, et al. Platelet activity and selective beta-blockade in migraine prophylaxis. Stroke. 1988:704-8. [pmid: 2897733].
44 Kececi H, Atakay S. Effects of topiramate on neurophysiological and neuropsychological tests in migraine patients. Journal of Clinical Neuroscience. Dec. 2009;16(12):1588-91. [pmid: 19793661].
45 Kowacs PA, Piovesan EJ, Werneck LC, et al. Critical flicker frequency in migraine. A controlled study in patients without prophylactic therapy. Cephalalgia. May. 2005;25(5):339-43. [pmid: 15839848].
46 Kung TA, Totonchi A, Eshraghi Y, et al. Review of pediatric migraine headaches refractory to medical management. Journal of Craniofacial Surgery. Jan. 2009;20(1):125-8. [pmid: 19165008].
47 Matharu MS, Boes CJ, Goadsby PJ. SUNCT syndrome: prolonged attacks, refractoriness and response to topiramate. Neurology. Apr. 23. 2002;58(8):1307. [pmid: 11971110].
48 Matthews M, Flatt S. The efficacy of hypnotherapy in the treatment of migraine. Nursing standard (Royal College of Nursing (Great Britain). 1999. 1987:33-6.
49 Mulleners WM, Chronicle EP, Vredeveld JW, et al. Visual cortex excitability in migraine before and after valproate prophylaxis: a pilot study using TMS. Eur J Neurol. Jan. 2002;9(1):35-40. [pmid: 11784374].
50 Music M, Babic N, Fajkic A, et al. Analysis of the electroencephalogram and pain characteristic in patients before and after carbamazepine treatment. Medicinski Arhiv. 2008;62(5–6):256-8. [pmid: 19469263].
51 Ortiz A, Alda M. Treatment of bipolar disorder with comorbid migraine. Journal of Psychiatry & Neuroscience. Jan. 2010;35(1):E1-2. [pmid: 20040250].
52 Owada K. Efficacy of candesartan in the treatment of migraine in hypertensive patients. Hypertension Research - Clinical & Experimental. Jun. 2004;27(6):441-6. [pmid: 15253110].
53 Paisley RD, Arora HS, Nazeri A, et al. Migraine and vasodepressor syncope in a large family. Texas Heart Institute Journal. 2009;36(5):468-9. [pmid: 19876431].
54 Palermo A, Fierro B, Giglia G, et al. Modulation of visual cortex excitability in migraine with aura: effects of valproate therapy. Neuroscience Letters. Dec. 18. 2009;467(1):26-9. [pmid: 19800389].
55 Palmer JE, Chronicle EP, Rolan P, et al. Cortical hyperexcitability is cortical under-inhibition: evidence from a novel functional test of migraine patients. Cephalalgia. Jul. 2000;20(6):525-32. [pmid: 11075834].
56 Pentland B, Anderson DA, Critchley JA. Failure of ejaculation with indoramin. Br Med J (Clin Res Ed). May. 2. 1981;282(6274):1433-4. [pmid: 6784854].
57 Pini LA, Ferrari A, Guidetti G, et al. Effectiveness of flunarizine in altering electronystagmographic patterns in migraine patients: a preliminary report. International journal of clinical pharmacology research. 1986:27-32. [pmid: 3957502].
58 Pothmann R, Winter K. Migraine prophylaxis with dihydroergotamine - A double-blind placebo-controlled study. Cephalalgia. 1989;9:428-9.
59 Rahimtoola H, Buurma H, Tijssen CC, et al. Incidence and determinants of migraine prophylactic medication in the Netherlands. European Journal of Clinical Pharmacology. May. 2002;58(2):149-55. [pmid: 12012149].
60 Rosenberg MD, Strassels SA. Serotonin-active drugs. Journal of the Massachusetts Dental Society. 2000;48(4):48-50. [pmid: 11819931].
61 Rothrock JF, Parada VA, Drinkard R, et al. Predictors of a negative response to topiramate therapy in patients with chronic migraine. Headache. Jul–Aug. 2005;45(7):932-5. [pmid: 15985112].
62 Rozen TD. Aborting a prolonged migrainous aura with intravenous prochlorperazine and magnesium sulfate. Headache. Sep. 2003;43(8):901-3. [pmid: 12940813].
63 Saper JR, Winner PK, Lake AE 3rd. An open-label dose-titration study of the efficacy and tolerability of tizanidine hydrochloride tablets in the prophylaxis of chronic daily headache. Headache. Apr. 2001;41(4):357-68. [pmid: 11318882].
64 Sargent JD, Baumel B, Peters K, et al. Aborting a migraine attack: naproxen sodium v ergotamine plus caffeine. Headache. 1988:263-6. [pmid: 3139584].
65 Scher AI, Stewart WF, Ricci JA, et al. Factors associated with the onset and remission of chronic daily headache in a population-based study. Pain. Nov. 2003;106(1–2):81-9. [pmid: 14581114].
66 Sciamanna CN, Nicholson RA, Lofland JH, et al. Effects of a Website designed to improve the management of migraines. Headache. Jan. 2006;46(1):92-100. [pmid: 16412156].
67 Serdaroglu G, Erhan E, Tekgul H, et al. Sodium valproate prophylaxis in childhood migraine. Headache. Sep. 2002;42(8):819-22. [pmid: 12390647].
68 Silberstein SD. Control of topiramate-induced paresthesias with supplemental potassium. Headache. Jan. 2002;42(1):85. [pmid: 12005283].
69 Silberstein SD, Feliu AL, Rupnow MF, et al. Topiramate in migraine prophylaxis: long-term impact on resource utilization and cost. Headache. Apr. 2007;47(4):500-10. [pmid: 17445099].
70 Silberstein SD, Winner PK, Chmiel JJ. Migraine preventive medication reduces resource utilization. Headache. Mar. 2003;43(3):171-8. [pmid: 12603635].
71 Sri-udomkajorn S, Ruangsuwan S. Short-term outcomes of tension type and migraine headache in children. Journal of the Medical Association of Thailand. Oct. Suppl 3. 2008;91:S104-8. [pmid: 19253504].
72 Storey JR, Calder CS, Potter DL. Potential role of topiramate (TPM) in the treatment of intractable daily headache: a retrospective pilot study (abstract). Neurology. 1999;52:A211. PMID.
73 Tietjen GE, Athanas K, Utley C, et al. The combination of naratriptan and prochlorperazine in migraine treatment. Headache. Jun. 2005;45(6):751-3. [pmid: 15953309].
74 Truter I. Prescribing for migraine with the focus on selective 5HT1-receptor agonists: a pharmacy database analysis. International Journal of Clinical Pharmacology & Therapeutics. May. 2010;48(5):319-26. [pmid: 20420788].
75 Velati D, Viana M, Cresta S, et al. 5-hydroxytryptamine1B receptor and triptan response in migraine, lack of association with common polymorphisms. European Journal of Pharmacology. Feb. 2. 2008;580(1–2):43-7. [pmid: 18035351].
76 Vieira DS, et al. Glutamate levels in cerebrospinal fluid and triptans overuse in chronic migraine. Headache. Jun. 2007;47(6):842-7. [pmid: 17578532].
77 Virtanen R, Aromaa M, Rautava P, et al. Changing headache from preschool age to puberty A controlled study. Cephalalgia: an international journal of headache. 2007:294-303. [pmid: 17376106].
78 Visudtibhan A, Thampratankul L, Khongkhatithum C, et al. Migraine in junior high-school students: A prospective 3-academic-year cohort study. Brain & Development. Nov. 2010;32(10):855-62. [pmid: 20060252].
79 Wang S-J, Fuh J-L, Lu S-R, et al. Outcomes and predictors of chronic daily headache in adolescents: a 2-year longitudinal study. Neurology. Feb. 20. 2007;68(8):591-6. [pmid: 17182975].
80 Warner BW, LaGrange CA, Tucker T, et al. Induction of progressive profound hypocitraturia with increasing doses of topiramate. Urology. Jul. 2008;72(1):29-32. discussion -3. [pmid: 18436283].
81 Welch BJ, Graybeal D, Moe OW, et al. Biochemical and stone-risk profiles with topiramate treatment. Am J Kidney Dis. Oct. 2006;48(4):555-63. [pmid: 16997051].
82 Wilper A, Woolhandler S, Himmelstein D, et al. Impact of insurance status on migraine care in the United States: a population-based study. Neurology. Apr. 13. 2010;74(15):1178-83. [pmid: 20385889].
83 Winther K, Hedman C, Flodgaard H. Platelet P1, P4-Di (adenosine-51) tetraphosphate (AP4A) in migraine patients before and during beta-adrenoceptor blockade. Eur J Clin Invest. Jun. 1990;20(3):336-8. [pmid: 2164477].
84 Yaldo AZ, Wertz DA, Rupnow MFT, et al. Persistence with migraine prophylactic treatment and acute migraine medication utilization in the managed care setting. Clinical Therapeutics. Dec. 2008;30(12):2452-60. [pmid: 19167603].
85 Yogendran L, Boswell D, Nacci P, et al. Effect of subcutaneous naratriptan on forearm blood flow. Cephalalgia: an international journal of headache. 1998:476-80. [pmid: 9793700].
86 Young W, Shaw J, Bloom M, et al. Correlation of increase in phosphene threshold with reduction of migraine frequency: observation of levetiracetam-treated subjects. Headache. Nov–Dec. 2008;48(10):1490-8. [pmid: 19076647].
87 Ziegler DK, Hurwitz A, Preskorn S, et al. Propranolol and amitriptyline in prophylaxis of migraine. Pharmacokinetic and therapeutic effects. Arch Neurol. Aug. 1993;50(8):825-30. [pmid: 8352668].

## Other

1 Almotriptan joins migraine market. American Journal of Health-System Pharmacy. Aug. 1. 2001;58(15):1386. [pmid: 11494779].
2 Summaries for patients. Guidelines for the treatment and prevention of migraine headaches. [Original report in Ann Intern Med. 2002 Nov 19;137(10):840–9; PMID: 12435222]. Annals of Internal Medicine. Nov. 19. 2002;137(10):150. [pmid: 12435232].
3 New medications show promise for migraine sufferers. Dentistry Today. Oct. 2002;21(10):70. [pmid: 12382492].
4 Nurse addicted to stadol sues manufacturer. Case on point: Uhiren v. Bristol-Myers Squibb Company, Inc., 346 F.3d 824--AR (2003). Nursing Law's Regan Report. Dec. 2003;44(7):2. [pmid: 14730828].
5 New drug curbs migraine pain. Health News. May. 2004;10(5):7. [pmid: 15132108].
6 Migraine drugs not linked with heart attack, stroke risk. Mayo Clinic Women's Healthsource. Jan. 2005;9(1):3. [pmid: 15592163].
7 Over-the-counter triptans--making the switch. Lancet Neurology. Oct. 2005;4(10):587. [pmid: 16168921].
8 Ibuprofen: new indication. Migraine attacks: don't begin with 400 mg!. Prescrire International. Dec. 2007;16(92):244. [pmid: 18092409].
9 Why do placebos work in some kids with migraine. Child Health Alert. Apr. 2008;26:5. [pmid: 18828187].
10 Addex starts a phase IIb trial of ADX10059 for migraine prevention. 2008.
11 Acin MP, Bono MC, Rodrigo MD, et al. Preventive analgesia with pregabalin in mesh hernia repair. Review at 1 year. Revista de la Sociedad Espanola del Dolor. 2009:215-21.
12 Adelman JU, Calhoun A. A randomized trial of frovatriptan for the intermittent prevention of menstrual migraine. Neurology. Mar. 8. 2005;64(5):931. author reply. [pmid: 15753451].
13 Aguirre Tellaeche R, Plata Toledo L, Lopez-Aguado Mario Z, et al. Reports on seven cases of migraine headache treated with biofeedback. [Spanish]. Salud Mental. 1987:77-82.
14 Ahmed DS, Fecik S. MAOIs: still here, still dangerous. American Journal of Nursing. Feb. 2000;100(2):29-30. [pmid: 10683640].
15 Alemdar M, Selekler HM. Migraine with aura triggered by citalopram. Neuropsychobiology. 2007;55(2):121-2. [pmid: 17596740].
16 Al-Hassan N. Menstrual migraine. Journal of Family Planning & Reproductive Health Care. Oct. 2007;33(4):289. author reply. [pmid: 17925127].
17 Alkhatib AA, Gangotena F, Peterson KA. Rizatriptan induced acute on top of chronic ischemic colitis. American Journal of Gastroenterology. Oct. 2009;104(10):2643-4. [pmid: 19806107].
18 Allen C, Cady R, Lines C, et al. Effect of rizatriptan in the spectrum of headache. Headache. Jun. 2001;41(6):607-8. [pmid: 11437904].
19 Allen C, Dayno J. Tolerability of sumatriptan: clinical trials and postmarketing experience. Cephalalgia. Oct. 2001;21(8):855-6. [pmid: 11737014].
20 Ambrosini A, Pierelli F, Schoenen J. Acetazolamide acts on neuromuscular transmission abnormalities found in some migraineurs. Cephalalgia. Mar. 2003;23(2):75-8. [pmid: 12603362].
21 Amelin AV, Skoromets AA, Gonchar MA, et al. Comparative efficacy of betaserc and cinnarizine of vertigo in patients with migraine. Zhurnal nevrologii i psikhiatrii imeni S.S. Korsakova / Ministerstvo zdravookhraneniia i meditsinsko&#301; promyshlennosti Rossi&#301;sko&#301; Federatsii, Vserossi&#301;skoe obshchestvo nevrologov [i] Vserossi&#301;skoe obshchestvo psikhiatrov. 2003:43-8.
22 A further step in migraine prevention. Ein weiterer schritt in der migraneprophylaxe. [German]. Fortschr Med. 1985:11-3.
23 Observation Sur L'Efficacite du Traitement Par Acupuncture de 35 Cas de Migraines. Shanghai journal of acupuncture and moxibustion. 2000:19.
24 Anselmi B, Del Bianco PL, Knor K, et al. The antihistaminic Sandomigran as the treatment of choice in anxious, thin, and anorexic patients with migraine. Schweizerische medizinische Wochenschrift. 1972:487-91. [pmid: 4401762].
25 Antonello R, Cazzato G, Capizzi A, et al. Randomized, double-blind trial on the therapeutic effect of the complex beta-cyclodextrin-piroxicam in migraine attacks. [Italian]. Giornale di Neuropsicofarmacologia. 1992:21-4.
26 Aronson SM. One man's poison. Medicine & Health, Rhode Island. Dec. 2008;91(12):359. [pmid: 19170308].
27 Artemenko AR, Kurenkov AL, Nikitin SS. Treatment of chronic migraine. Zhurnal Nevrologii i Psikhiatrii Imeni S S Korsakova. 2011;111(5):85-9. [pmid: 21905333].
28 Ault J. Teaching case: migraine and pupil dilation. Headache. Feb. 2011;51(2):324-6. [pmid: 21284618].
29 Ayata C, Jin H, Kudo C, et al. Suppression of cortical spreading depression in migraine prophylaxis. Ann Neurol. Apr. 2006;59(4):652-61. [pmid: 16450381].
30 Aylward M, Chazot G, Maddock J, et al. Treatment of morning migraine. Clinical and biokinetic correlation of programmed-release dihydroergotamine. Presse médicale (Paris, France: 1983). 1984:1617-9.
31 Bajard A, Chabaud S, Perol D, et al. Revisiting the level of evidence in randomized controlled clinical trials: A simulation approach. Contemporary Clinical Trials. Sep. 2009;30(5):400-10. [pmid: 19576298].
32 Bana DS, MacNeal PS, LeCompte PM, et al. Cardiac murmurs and endocardial fibrosis associated with methysergide therapy. Am Heart J. Nov. 1974;88(5):640-55. [pmid: 4420941].
33 Barnett R. Migraine in women. Practitioner. Jun. 2002;246(1635):455. author reply. [pmid: 12073705].
34 Bartleson JD. Triptans to the rescue: effective therapy for migraine headaches in the workplace. Mayo Clinic Proceedings. Aug. 2000;75(8):780-1. [pmid: 10943229].
35 Bartley J, Watkins LR. Comment on: excessive opioid use and the development of chronic migraine. Pain. Sep. 2009;145(1–2):262-3. [pmid: 19553017].
36 Basquin S, Dubois M, Loukakis G, et al. The treatment of headaches: an open randomized comparative therapeutic study (author's transl). La semaine des hôpitaux : organe fondé par l'Association d'enseignement médical des hôpitaux de Paris. 1979:806-9.
37 Bateman DN. Triptans and migraine. Lancet. Mar. 11. 2000;355(9207):860-1. [pmid: 10752697].
38 Baust W, Stürtzbecher KH. Management of migraine using acupuncture in a double-blind study. Die Medizinische Welt. 1978:669-73. [pmid: 347221].
39 Baxter RC, Marsden CD, Parkes JD, et al. Amantadine in migraine. Lancet. 1972:429. [pmid: 4115247].
40 Baykan B, Ertaş M, et al. Hypnic headache associated with medication overuse: case report. Agri Dergisi. Jul. 2008;20(3):40-3. [pmid: 19085181].
41 Bento MS, Esperança P, et al. Migraine with prolonged aura. Headache. Jan. 2000;40(1):52-3. [pmid: 10759905].
42 Bernik V, Maia E. The use of propranolol on prophylaxis of migraine: A double-blind clinical trial comparing propranolol with an analgesic drug (acetaminophen) and placebo. <ORIGINAL> USO DO PROPRANOLOL NA PROFILAXIA DA ENXAQUECA: ESTUDO DUPLO-CEGO COMPARANDO PROPRANOLOL A UM ANALGESICO (ACETAMINOFEN) E PLACEBO. Folha Med. 1978;77:501-8.
43 Bernik V, Maia E. The use of propranolol on prophylaxis of migraine: A double-blind clinical trial comparing propranolol with an analgesic drug (acetaminophen) and placebo. Folha Med. 1978;77:501-8.
44 Bes A, Geraud G, Guell A, et al. Dopaminergic hypersensitivity in migraine: a diagnostic test?. Nouvelle Presse Médicale. 1982:1475-8. [pmid: 7043395].
45 Bès A, Géraud G, Güell A, et al. Dopaminergic hypersensitivity in migraine: a diagnostic test? (author's transl). La Nouvelle presse médicale. 1982:1475-8. [pmid: 7043395].
46 Bhagey J, James B. Topical timolol prevented migraine attacks. Eye. Jul. 2004;18(7):751. [pmid: 14765100].
47 Bhindi R, Ormerod OJ. Letter by Bhindi and Ormerod regarding article, "Lack of association between migraine headache and patent foramen ovale: results of a case-control study". Circulation. Dec. 14. 2010;122(24):e581. author reply e3. [pmid: 21156652].
48 Bigal ME. To use or not to use dipyrone?. Sao Paulo Medical Journal = Revista Paulista de Medicina. Mar. 7. 2002;120(2):63. [pmid: 11994777].
49 Bigal ME, Lipton RB, Biondi DM, et al. Weight change and clinical markers of cardiovascular disease risk during preventive treatment of migraine. Cephalalgia. Nov. 2009;29(11):1188-96. [pmid: 19558539].
50 Bisdorff AR. Treatment of migraine related vertigo with lamotrigine an observational study. Bulletin de la Societe des Sciences Medicales du Grand-Duche de Luxembourg. 2004;(2):103-8. [pmid: 15641316].
51 Blumenfeld A. Botulinum toxin type A as an effective prophylactic treatment in primary headache disorders. Headache. Sep. 2003;43(8):853-60. [pmid: 12940806].
52 Blumenfeld A. Does single-file botox injection really work for primary headache?. Headache. Sep. 2004;44(8):838-9. [pmid: 15330839].
53 Blumenkron D, Rivera C, Cuevas C. Efficacy of botulinum toxin type A in patients with migraine. Medicina Interna de Mexico. 2006:25-31.
54 Blumenthal HJ, Diamond ML. Acetaminophen, aspirin, and caffeine versus sumatriptan succinate in the early treatment of migraine: results from the ASSET trial--a comment. Headache. Feb. 2006;46(2):340. author reply 1. [pmid: 16492249].
55 Bolay H, Reuter U, Dunn AK, et al. Intrinsic brain activity triggers trigeminal meningeal afferents in a migraine model. Nature Medicine. Feb. 2002;8(2):136-42. [pmid: 11821897].
56 Borgesen SE. Treatment of migraine with propranolol. Postgrad Med J. 1976;52(Suppl 4):163-5. [pmid: 787958].
57 Bradley DP, Smith MI, Netsiri C, et al. Diffusion-weighted MRI used to detect in vivo modulation of cortical spreading depression: comparison of sumatriptan and tonabersat. Exp Neurol. Dec. 2001;172(2):342-53. [pmid: 11716558].
58 Brain SD. Calcitonin gene-related peptide (CGRP) antagonists: blockers of neuronal transmission in migraine. British Journal of Pharmacology. Aug. 2004;142(7):1053-4. [pmid: 15237096].
59 Brannon GE, Rolland PD, Gary JM. Use of mirtazapine as prophylactic treatment for migraine headache. Psychosomatics. Mar–Apr. 2000;41(2):153-4. [pmid: 10749956].
60 Brauneis S, Marzano M, Collini S, et al. The administration of sumatriptan in the treatment of migraine and cluster headache. Confin Cephalalgica. 1994:159-64.
61 Brennan KC. Turn down the lights!: an irritable occipital cortex in migraine without aura. Neurology. Jan. 18. 2011;76(3):206-7. [pmid: 21148117].
62 Brenner SR. Mitochondrial DNA haplogroups influence the therapeutic response to riboflavin in migraineurs. Neurology. Jan. 12. 2010;74(2):182-3. author reply 3. [pmid: 20065258].
63 Brigo B. Homeopathic treatment of migraine: a sixty case double-blind controlled study. Journal of Liga Medicorum Homoeopathica Internationalis. 1987:18-25.
64 Brügger A. Differential diagnosis of headache and experiences with a new preparation in the treatment of migraine. Schweizerische Rundschau für Medizin Praxis = Revue suisse de médecine Praxis. 1970:1360-5. [pmid: 5519088].
65 Burstein R, Dodick D, Silberstein S. Migraine prophylaxis with botulinum toxin A is associated with perception of headache. Toxicon. Oct. 2009;54(5):624-7. [pmid: 19344670].
66 Burstein R, Jakubowski M. Almotriptan efficacy in migraine with allodynia: a critique of Schoenen et al. Cephalalgia. Oct. 2009;29(10):1019-20. [pmid: 19366354].
67 Bussone G, Boiardi A, Merati B, et al. Tiapride in the treatment of chronic headache (author's transl). Rivista di patologia nervosa e mentale. 1981:247-53. [pmid: 7323625].
68 Canario JR Jr, Shenenberger DW. Sumatriptan use in patients with migraine. Mayo Clinic Proceedings. Feb. 2002;77(2):201. [pmid: 11838657].
69 Canepari C, Riva M, Erminio F. Effectiveness of flunarizine in chronic headache A double-blind comparison with placebo and amitriptyline. <ORIGINAL> EFFICACIA DELLA FLUNARIZINA NELLE CEFALEE CRONICHE STUDIO IN DOPPIO CIECO VERSO PLACEBO E AMITRIPTILINA. Clin Ter. 1985:463-8. [pmid: 3913563].
70 Cano A, Sanz P, Fossas P. Comparison between flunarizine, nicardipine and nimodipine in the preventive treatment of migraine. Neurología. 1997:486.
71 Caputi CA. Effectiveness of BoNT-A in the treatment of migraine and its ability to repress CGRP release. Headache. Sep. 2004;44(8):837-8. [pmid: 15330838].
72 Carpay HA, Dowson AJ. Sumatriptan fast-disintegrating/rapid-release tablets: viewpoints. Drugs. 2006;66(6):891-2. [pmid: 16706566].
73 Carvalho DDS, Rabello GD, Figueiro JAB. Dipyrone plus caffeine versus dipyrone alone to acute treatment of mild to moderate primary headache attacks: A double blind, randomized, compared clinical study. Revista Brasileira de Medicina. 2007:273-8.
74 Cattin T. Botulinum toxin as a preventive treatment for migraine and chronic tension headache. New Zealand Medical Journal. May. 16. 2003;116(1174):U440. [pmid: 12766786].
75 Celiker A, Bir LS, Ardic N. Effects of valproate on vestibular symptoms and electronystagmographic findings in migraine patients. Clin Neuropharmacol. Jul–Aug. 2007;30(4):213-7. [pmid: 17762318].
76 Centonze V, Macinagrossa G, Attolini E, et al. Migraine prophylaxis: Flunarizine vs. verapamil. <ORIGINAL> TERAPIA PREVENTIVA DELL'EMICRANIA: FLUNARIZINA VERSUS VERAPAMIL. Clin. Ter. 1985:333-9. [pmid: 3830537].
77 Centonze V, Polito MB, Di Bari M, et al. Evaluation of the efficacy of oral sumatriptan in the management of migraine attacks. Clinical results. La Clinica terapeutica. 1995:721-8. [pmid: 8720348].
78 Cerbo R, Casacchia M, Formisano R, et al. Double-blind clinical study: flunarizine versus pizotifen in a single nightly dose in hemicrania patients. Rivista di neurologia. 1985:139-46. [pmid: 4012191].
79 Chang JJ, Liu X, Fai CP, et al. Lysine-aspirin plus metoclopramide in treatment of migraine. Chinese Journal of New Drugs and Clinical Remedies. 2000:387-8.
80 Charles A, Brennan KC. A touch of increased pain: cutaneous allodynia in migraine. Annals of Neurology. Feb. 2008;63(2):130-2. [pmid: 18306413].
81 Charles JA, Peterlin BL, Rapoport AM, et al. Chronic daily headache in adolescents: an 8-year follow-up study. Neurology. Mar. 2. 2010;74(9):780. author reply -1. [pmid: 20194921].
82 Charles JA, Pullicino PM, Stoopack PM, et al. Ischemic colitis associated with naratriptan and oral contraceptive use. Headache. Apr. 2005;45(4):386-9. [pmid: 15836580].
83 Chazot G, Chauplannaz G, Biron A, et al. Migraine: treatment by lithium (letter). Nouv-Presse-Med. 1979:2836-7. [pmid: 503820].
84 Chen FJ, Ye CS, Zhang H, et al. 74 cases of vascular migraine treated by low frequency square-wave pulse current therapy. Chinese Journal of Physical Therapy. 1993:92-3.
85 Chen WT, Fuh JL, Lu SR, et al. Persistent migrainous visual phenomena might be responsive to lamotrigine. Headache. Sep. 2001;41(8):823-5. [pmid: 11576209].
86 Chen Z. Migraine treated by acupuncture with the points on both the upper and lower body parts. Shaanxi journal of tcm. 2004:155.
87 Christiani K. The interval treatment of migraine with nocertone. Die Medizinische Welt. 1978:1293-5. [pmid: 672606].
88 Christie SN, Giammarco R, Gawel M, et al. Botulinum toxin type A and acute drug costs in migraine with triptan overuse. Can J Neurol Sci. Sep. 2010;37(5):588-94. [pmid: 21059503].
89 Chronicle E, Mulleners W. Anticonvulsant drugs for migraine prophylaxis. Cochrane Database Syst Rev. 2004;(3):CD003226. [pmid: 15266476].
90 Cochran JW. Levetiracetam as migraine prophylaxis. Clinical Journal of Pain. May–Jun. 2004;20(3):198-9. [pmid: 15100599].
91 Cohen D, Huinink S. Atypical antipsychotic-induced diabetes mellitus in child and adolescent psychiatry. CNS Drugs. 2007;21(12):1035-8. [pmid: 18020482].
92 Cohen GL. Dubious about Depakote. Headache. May. 2001;41(5):515-7. [pmid: 11380652].
93 Corbat F. Clonidin in the treatment of migraine (author's transl). Schweizerische Rundschau für Medizin Praxis = Revue suisse de médecine Praxis. 1976:82-3. [pmid: 1257204].
94 Cortelli P, Sacquegna T, Albani F, et al. Propranolol plasma levels and relief of migraine. Relationship between plasma propranolol and 4-hydroxypropranolol concentrations and clinical effects. Arch Neurol. Jan. 1985;42(1):46-8. [pmid: 3966884].
95 Couch JR, Bearss CM, Verhulst S. Fenoprofen in migraine prophylaxis. Headache. 1987:289.
96 Couch JR, Ziegler DK, Hassanein R. Amitriptyline in the prophylaxis of migraine. Effectiveness and relationship of antimigraine and antidepressant effects. Neurology. Feb. 1976;26(2):121-7. [pmid: 943066].
97 Cruz A, Bühling M, Seibel K. Double blind study of migraine therapy with etilefrine pivalate. Arzneimittel-Forschung. 1985:1086-9. [pmid: 2864937].
98 Cucherat M, Dib M. Letter to the editor concerning: Pascual J, Mateos V, Roig C, Sanchez-Del-Rio M, Jimenez D. Marketed oral triptans in the acute treatment of migraine: a systematic review on efficacy and tolerability. Headache. 2007;47(8):1152–1168. Headache. Oct. 2008;48(9):1379-80. [pmid: 19031501].
99 Curtis-Brown R. A PROTEIN POISON THEORY: Its Application to the Treatment of Headache and Especially Migraine. Br Med J. Jan. 24. 1925;1(3343):155-6. [pmid: 20771881].
100 Curtiss FR. Clinical, service, and cost outcomes of drug coverage edits and quantity limits. Journal of Managed Care Pharmacy. Jul–Aug. 2003;9(4):368-9. [pmid: 14613458].
101 Curtiss FR. Best value for money in triptans. Journal of Managed Care Pharmacy. Jun. 2005;11(5):419-21. [pmid: 15934803].
102 Dahlöf C. Assessing patient preference in migraine treatment. Cephalalgia. Oct. 2001;21(8):791-5. [pmid: 11737002].
103 Dalsgaard-Nielsen T, Trautmann J. Prophylactic treatment of migraine with vitamin B 12. Ugeskrift for laeger. 1970:339-41. [pmid: 4913223].
104 Damen L, Bruijn JK, Verhagen AP, et al. Symptomatic treatment of migraine in children: a systematic review of medication trials. Pediatrics. Aug. 2005;116(2):e295-302. [pmid: 16061583].
105 D'Amico D. Pharmacological prophylaxis of chronic migraine: a review of double-blind placebo-controlled trials. Neurological Sciences. Jun. Suppl 1. 2010;31:S23-8. [pmid: 20464578].
106 D'Amico D, Solari A, Usai S, et al. Improvement in quality of life and activity limitations in migraine patients after prophylaxis A prospective longitudinal multicentre study. Cephalalgia: an international journal of headache. 2006:691-6. [pmid: 16686908].
107 Danesch U, Rittinghausen R. Safety of a patented special butterbur root extract for migraine prevention. Headache. 2003:76-8. [pmid: 12864764].
108 Danilov AB, Glembotskaia GT, Kozub OV. Pharmacoeconomic aspects of migraine. Zhurnal Nevrologii i Psikhiatrii Imeni S S Korsakova. 2011;111(4):79-81. [pmid: 21898951].
109 Davis JS. High-dose riboflavin for the prevention of migraine: can we afford to ignore it?. Internal Medicine Journal. Jun. 2004;34(6):372-3. author reply 3. [pmid: 15228409].
110 De Simone R, Marano E, Di Stasio E, et al. Acetazolamide efficacy and tolerability in migraine with aura: a pilot study. Headache. Apr. 2005;45(4):385-6. [pmid: 15836579].
111 DeDea L. Metoclopramide for migraines; how to stock a first aid kit. JAAPA. Nov. 2010;23(11):16. [pmid: 21086883].
112 Degnan AP, Chaturvedula PV, Conway CM, et al. Discovery of (R)-4-(8-fluoro-2-oxo-1,2-dihydroquinazolin-3(4H)-yl)-N-(3-(7-methyl-1H-indazol-5-yl)-1-oxo-1-(4-(piperidin-1-yl)piperidin-1-yl)propan-2-yl)piperidine-1-carboxamide (BMS-694153): a potent antagonist of the human calcitonin gene-related peptide receptor for migraine with rapid and efficient intranasal exposure. Journal of Medicinal Chemistry. Aug. 28. 2008;51(16):4858-61. [pmid: 18665579].
113 Deleu D, Hanssens Y. Eletriptan vs sumatriptan: a double-blind, placebo-controlled, multiple migraine attack study. Neurology. Apr. 8. 2003;60(7):1221-2. author reply -2. [pmid: 12682349].
114 Delva NJ, Horgan SA, Hawken ER. Valproate prophylaxis for migraine induced by selective serotonin reuptake inhibitors. Headache. Mar. 2000;40(3):248-51. [pmid: 10759929].
115 Derosier FJ, Kori SH. Acetaminophen, aspirin, and caffeine versus sumatriptan succinate in the early treatment of migraine: results from the ASSET trial--a comment. Headache. Apr. 2007;47(4):623. author reply -5. [pmid: 17445117].
116 Devor WN, Napoli R, Sacc, et al. Vascular smooth muscle cell dysfunction in patients with migraine. Neurology. Jan. 5. 2010;74(1):94. author reply. [pmid: 20038783].
117 Di Legge S, Bruti G, Di Piero V, et al. Topiramate versus migraine: which is the cause of glaucomatous visual field defects?. Headache. Sep. 2002;42(8):837-8. [pmid: 12390655].
118 Di Lorenzo C, Pierelli F, Coppola G, et al. Mitochondrial DNA haplogroups influence the therapeutic response to riboflavin in migraineurs. Neurology. May. 5. 2009;72(18):1588-94. [pmid: 19414726].
119 Di Sabato F. Comparison of treatment with STRESSEN and arginine glutamate on homocysteine blood levels. La Clinica terapeutica. 2004:17-20. [pmid: 15147076].
120 Diamond S, Kudrow L, Stevens J, et al. Long-term study of propranolol in the treatment of migraine. Headache. 1982:268-71. [pmid: 7174304].
121 Diamond S, Solomon GD, Freitag FG, et al. Long-acting propranolol in the prophylaxis of migraine. Headache. Feb. 1987;27(2):70-2. [pmid: 3553068].
122 Diener HC. Placebo effects in treating migraine and other headaches. Current Opinion in Investigational Drugs. Jul. 2010;11(7):735-9. [pmid: 20597189].
123 Diener HC, Pfaffenrath V, Pageler L, et al. Triple combination (Thomapyrin) is more efficient for the treatment of headache than mono substances and dual combination. Nervenheilkunde. 2005:626-39.
124 Dimitriadou V, Buzzi MG, Theoharides TC, et al. Ultrastructural evidence for neurogenically mediated changes in blood vessels of the rat dura mater and tongue following antidromic trigeminal stimulation. Neuroscience. 1992;48(1):187-203. [pmid: 1374861].
125 Dodick DW, Turkel CC, DeGryse RE, et al. OnabotulinumtoxinA for treatment of chronic migraine: pooled results from the double-blind, randomized, placebo-controlled phases of the PREEMPT clinical program. Headache. Jun. 2010;50(6):921-36. [pmid: 20487038].
126 Doerr-Proske H, Wittchen HU. A muscle and vascular oriented relaxation program for the treatment of chronic migraine patients. A randomized clinical comparative study. Zeitschrift für Psychosomatische Medizin und Psychoanalyse. 1985:247-66. [pmid: 3898645].
127 Dowson AJ, Cady RK, Tepper SJ, et al. Pharmacologic management of migraine. Annals of Internal Medicine. Mar. 16. 2004;140(6):W26. [pmid: 15023737].
128 Drillisch C, Girke W. Results of treatment of migraine patients with cinnarizine and flunarizine. Die Medizinische Welt. 1980:1870-2. [pmid: 6110158].
129 Dufresne JJ. Double-blind study of oxetorone in patients with migraine or migrainous headache (author's transl). Schweizerische Rundschau für Medizin Praxis = Revue suisse de médecine Praxis. 1978:1148-52. [pmid: 674095].
130 Dufresne JJ, Muggler J. Trials with the new preparation cephatac in the attack treatment of migraine (author's transl). Schweizerische Rundschau für Medizin Praxis = Revue suisse de médecine Praxis. 1975:1514-8. [pmid: 1215311].
131 Dukat M. Donitriptan (Pierre Fabre). Current Opinion in Investigational Drugs. Mar. 2001;2(3):415-8. [pmid: 11575714].
132 Durham PL. CGRP-receptor antagonists--a fresh approach to migraine therapy?. New England Journal of Medicine. Mar. 11. 2004;350(11):1073-5. [pmid: 15014178].
133 Ebihara A, Ohashi K, Fujimura A, et al. Phase I Study of Sumatriptan Tablet (The 1st Report): Single- and Multiple-Oral Dose Study in Japanese Subjects. Rinsho Iyaku (Journal of Clinical Therapeutics and Medicines). 1993:757-65.
134 Ebihara A, Ohashi K, Fujimura A, et al. Phase I Study of Sumatriptan Injection (The 2nd Report): Single- and Multiple-Subcutaneous Dose Study in Japanese Healthy Subjects. Rinsho Iyaku (Journal of Clinical Therapeutics and Medicines). 1993:767-76.
135 Edvinsson L. CGRP-receptor antagonism in migraine treatment. Lancet. Dec. 20. 2008;372(9656):2089-90. [pmid: 19036426].
136 Edvinsson L. CGRP blockers in migraine therapy: where do they act?. British Journal of Pharmacology. Dec. 2008;155(7):967-9. [pmid: 18776915].
137 Egger J, Carter C, Wilson J, et al. Food allergies and migraine in children. Monatsschrift fur Kinderheilkunde. 1983:686.
138 Egger J, McEwen L. Controlled study on the effectivity of hyposensitisation in children with food-induced migraine. Monatsschrift fur Kinderheilkunde. 1997:S21.
139 Egger J, Stolla A, McEwen L. Controlled study on the effectivity of hyposensibilisation due to enzyme potency in children with food-induced migraine. Monatsschrift fur Kinderheilkunde. 1992:707.
140 Eom KS, Kim TY. Greater occipital nerve block by using transcranial Doppler ultrasonography. Pain Physician. Jul. 2010;13(4):395-6. [pmid: 20648209].
141 Erbguth F, Brittner W, Fogel W, et al. Botulinum toxin in migraine. Journal of Neurology. Feb. Suppl 1. 2004;251:I31-2. [pmid: 14991340].
142 Erdemoglu AK, Ozbakir S. Valproic acid in prophylaxis of refractory migraine. Acta Neurol Scand. Dec. 2000;102(6):354-8. [pmid: 11125749].
143 Eross EJ. Patient page. Chronic migraine and medication-overuse headache. Neurology. Jun. 27. 2006;66(12):E43-4. [pmid: 16801636].
144 Eross EJ, Gladstone JP, Lewis S, et al. Duration of migraine is a predictor for response to botulinum toxin type A. Headache. Apr. 2005;45(4):308-14. [pmid: 15836566].
145 Evans RW. Rizatriptan. Convenience and consistency. Postgraduate Medicine. Sep. 2000;108(3 Suppl):10-5. [pmid: 19667525].
146 Evans RW. The non-nocebo response: can migraine medication efficacy be enhanced?. Headache. Jun. 2003;43(6):693. [pmid: 12786934].
147 Evans RW. Triptans and serotonin syndrome. Cephalalgia. May. 2008;28(5):573-4. author reply 4–5. [pmid: 18355351].
148 Evans RW, Atriham AR. QT prolongation with migraine medications. Headache. Jul–Aug. 2003;43(7):809-10. [pmid: 12890141].
149 Evans RW, Blumenfeld A. Botulinum toxin injections for headache. Headache. Jun. 2003;43(6):682-5. [pmid: 12786931].
150 Evans RW, Dahlöf CG, et al. Determining triptan preference for the individual patient. Headache. Jul–Aug. 2004;44(7):723-5. [pmid: 15209698].
151 Evans RW, Johnston JC. Migraine and medical malpractice. Headache. Mar. 2011;51(3):434-40. [pmid: 21352217].
152 Evans RW, Linde M. Expert opinion: adherence to prophylactic migraine medication. Headache. Jul. 2009;49(7):1054-8. [pmid: 19583596].
153 Evans RW, Loder E, Biondi DM. When can successful migraine prophylaxis be discontinued?. Headache. Nov–Dec. 2004;44(10):1040-2. [pmid: 15546270].
154 Evans RW, Rosen N. Expert opinion: migraine, psychiatric comorbidities, and treatment. Headache. Jun. 2008;48(6):952-8. [pmid: 18572433].
155 Farinelli I, Coloprisco G, De Filippis S, et al. Long-term benefits of botulinum toxin type A (BOTOX) in chronic daily headache: a five-year long experience. J Headache Pain. Dec. 2006;7(6):407-12. [pmid: 17149565].
156 Feng SHU, He XIN, Li SUH. Clinical observation of migraine by the temporal three acupoints. Journal of clinical acupuncture and moxibustion. 2003:23.
157 Fern, x00E, ndez de las P, et al. Exploding vs. imploding headache in migraine prophylaxis with Botulinum Toxin A. Pain. Jun. 2007;129(3):363-4. author reply 4–5. [pmid: 17360120].
158 Fernandez D, Wilkins AJ. Uncomfortable images in art and nature. Perception. 2008;37(7):1098-113. [pmid: 18773732].
159 Fernandez-Rodriguez CM, Lledo JL, Lopez-Serrano P, et al. Effect of pentoxiphylline on survival, cardiac function, and portal and systemic hemodynamics in advanced alcoholic cirrhosis. Revista Espanola de Enfermedades Digestivas. 2008:481-9. [pmid: 18942901].
160 Ferrante E. Ophthalmoplegic migraine. Cephalalgia. Mar. 2006;26(3):357. author reply -8. [pmid: 16472350].
161 Ferrari MD. Re: Gomez-Mancilla et al. Safety and efficacy of PNU-142633, a selective 5-HT(1D) agonist, in patients with acute migraine. Cephalalgia 2001;21:727–32. Cephalalgia. Sep. 2001;21(7):711. [pmid: 11603382].
162 Ferrari MD. Should we advise patients to treat migraine attacks early?. Cephalalgia. Nov. 2004;24(11):915-7. [pmid: 15482351].
163 Ferrari MD, Farkkila M, Reuter U, et al. Acute treatment of migraine with the selective 5-HT1F receptor agonist lasmiditan--a randomised proof-of-concept trial. Cephalalgia. Oct. 2010;30(10):1170-8. [pmid: 20855362].
164 Fitch MT, Jones AE. Adjunctive therapy for migraine headaches: can we teach an old dog a new trick?. Academic Emergency Medicine. Dec. 2008;15(12):1310-1. [pmid: 18945233].
165 Florence J. Clinical study of oxetorone in catamenial migraine. Comparison of two posological diagrams (author's transl). Schweizerische Rundschau für Medizin Praxis = Revue suisse de médecine Praxis. 1978:1323-7. [pmid: 683962].
166 Fox AW. 5HT1B/1D agonists. Journal of Clinical Pharmacology. Nov. 2002;42(11):1281-2. author reply 2–3. [pmid: 12412829].
167 Fox AW. Metoclopramide and sumatriptan. Headache. May. 2004;44(5):446-7. [pmid: 15147257].
168 Fox AW. Revised estimates for probability of successful outcome of pregnancy after sumatriptan exposure. Headache. Mar. 2004;44(3):293-4. [pmid: 15012675].
169 Fox AW. Clinical trial ethics. Headache. Sep. 2005;45(8):1090-1. author reply 1. [pmid: 16109130].
170 Fox AW. 5-HT 1B/1D agonists, oral contraceptives, and ischemic colitis. Headache. Jun. 2006;46(6):1021-2. author reply 2–3. [pmid: 16732852].
171 Fox AW, Spierings EL. Sumatriptan and pregnancy outcome. Headache. Nov–Dec. 2000;40(10):860-1. [pmid: 11135036].
172 Fragoso YD. Low dose of sodium divalproate for the treatment of migraine. Medgenmed [Computer File]: Medscape General Medicine. Mar. 12. 2003;5(1):32. [pmid: 12827093].
173 Freitag FG. Importance of botulinum toxin for prevention of migraine. Expert Review of Neurotherapeutics. Mar. 2010;10(3):339-40. [pmid: 20187855].
174 Freitag FG, Diamond S, Diamond ML, et al. Divalproex in the long-term treatment of chronic daily headache. Headache. Mar. 2001;41(3):271-8. [pmid: 11264687].
175 Frenken CW, Nuijten ST. Flunarizine--a new agent for migraine prevention. Results of a double-blind comparison with placebo. Fortschritte der Medizin. 1984:349-51. [pmid: 6370811].
176 Frenken CW, Nuijten ST. Flunarizine - a new agent for migraine prevention Results of a double blind comparison with placebo. Flunarizin - ein neues Mittel zur Migraneprophylaxe Ergebnisse eines Doppelblindvergleichs mit Plazebo. [German]. Fortschr Med. 1984:349-51. [pmid: 6370811].
177 Friedrich MJ. Studies suggest new approaches to pain. JAMA. Jul. 4. 2007;298(1):27-8. [pmid: 17609482].
178 Fujita M, Fujiwara J, Maki T, et al. The efficacy of sodium valproate and a MRA finding in confusional migraine. Brain & Development. Apr. 2007;29(3):178-81. [pmid: 16973324].
179 Fukuuchi Y, et al. Clinical Evaluation of BAY e 9736 (Nimodipine) on Migraine: Pilot Study and Open Study. Yakuri to Chiryo (Japanese Pharmacology and Therapeutics). 1986:1561-86.
180 Fumal A, Laureys S, Di Clemente L, et al. Orbitofrontal cortex involvement in chronic analgesic-overuse headache evolving from episodic migraine. Brain. Feb. 2006;129(Pt 2):543-50. [pmid: 16330505].
181 Fumal A, Schoenen J. Effectiveness of lamotrigine in the prophylaxis of migraine with aura: an open study. [abstract]. Cephalalgia. 2006;26:1369-70. PMID.
182 Gallagher RM, Mueller LL, Freitag FG. Divalproex sodium in the treatment of migraine and cluster headaches. Journal of the American Osteopathic Association. Feb. 2002;102(2):92-4. [pmid: 11866398].
183 Galvez-Jimenez N, Hanson MR. Re: “Botulinum toxin type A as a migraine preventive treatment”. (Silberstein S, Mathew N, Saper J, Jenkins S, for the BOTOX Migraine Clinical Research Group. Headache 2000;40:445–450). Headache. Jun. 2001;41(6):607. [pmid: 11437903].
184 Garaizar C, Prats JM, Zuazo E. Results of prophylactic treatment for common childhood headaches. Revista de Neurología. 1998.
185 Garaizar C, Prats JM, Zuazo E. Response to prophylactic treatment of benign headache in children. Revista de neurologia. 1998:380-5. [pmid: 9585947].
186 Garcia Garcia C, Casanovas N, Recasens L, et al. Spontaneous coronary artery dissection in ergotamine abuse. International Journal of Cardiology. Jun. 12. 2007;118(3):410-1. [pmid: 17049384].
187 Garcia GD, Goff JM Jr, Hadro NC, et al. Chronic ergot toxicity: A rare cause of lower extremity ischemia. Journal of Vascular Surgery. Jun. 2000;31(6):1245-7. [pmid: 10842162].
188 Gasbarri A, Arnone B, Pompili A, et al. Emotional memory and migraine: effects of amitriptyline and sex related difference. Behav Brain Res. May. 16. 2008;189(1):220-5. [pmid: 18242724].
189 Gebauer R, Hoffmann J, Kuhl ED, et al. About migraine therapy. Die Medizinische Welt. 1985:550-6.
190 Genefke IK, Bryndum B, Dalsgaard-Nielsen T, et al. The action of reserpine on the concentration of 5-hydroxytryptamine, epinephrine and norepinephrine in the venous blood of migraine patients. Minerva medica. 1976:1876-82. [pmid: 934535].
191 Gerber WD, Kropp P, Speckenbach U, et al. BVP and MCA training in migraine: sensible procedures for acute treatment. Verhaltenstherapie. 1995:A28.
192 Gerhards F, Florin I, Rojahn J. Biofeedback in vasomotor control and cognitive overcoming of stress in the treatment of migraine. Comparison of 2 training programs. Fortschritte der Medizin. 1985:861-4. [pmid: 4065785].
193 Gherpelli J, Gherpelli JLD. New migraine prophylactic drug options. Revista do Hospital das Clinicas; Faculdade de Medicina Da Universidade de Sao Paulo. Nov–Dec. 2002;57(6):249-50. [pmid: 12612755].
194 Ghose K, Niven B. Prophylactic sodium valproate therapy in patients with drug-resistant migraine. Methods Find Exp Clin Pharmacol. May. 1998;20(4):353-9. [pmid: 9658386].
195 Gilbert GJ. Cerebral vasoconstriction and stroke after use of serotonergic drugs. Neurology. Aug. 27. 2002;59(4):651-2. author reply 2. [pmid: 12196679].
196 Goadsby PJ. Migraine: selecting treatments now and making requests for the future?. Current Medical Research & Opinion. 2001;17(Suppl 1):s98-9. [pmid: 12463287].
197 Goadsby PJ. Squeezing life into botulinum toxin A in migraine: imploding versus exploding pain. Pain. Dec. 5. 2006;125(3):206-7. [pmid: 17069974].
198 Goadsby PJ. Calcitonin gene-related peptide (CGRP) antagonists and migraine: is this a new era?. Neurology. Apr. 15. 2008;70(16):1300-1. [pmid: 18413584].
199 Goadsby PJ, Edvinsson L. Joint 1994 Wolff Award Presentation. Peripheral and central trigeminovascular activation in cat is blocked by the serotonin (5HT)-1D receptor agonist 311C90. Headache. Jul–Aug. 1994;34(7):394-9. [pmid: 7928323].
200 Goadsby PJ, Ferrari MD, Lipton RB. Therapeutic gain or therapeutic ratio?. Headache. Jul–Aug. 2003;43(7):814-5. author reply 5–6. [pmid: 12890143].
201 Gobel H, Heinze A, Dworschak M, et al. Oleum menthae piperitae in the acute therapy of migraine and tension-type headache. Zeitschrift fur Phytotherapie. 2004:129-39.
202 Gobel H, Pothmann R, Bauer R, et al. Migraine prevention with Petasites (Butterbur): Clinic and pharmacology of a special root extract. [German] [References]. Nervenheilkunde: Zeitschrift fur interdisziplinaere Fortbildung. 2005:211-6.
203 Goldman MD, Login IS. Misdiagnosis of migraine. Headache. Jan. 2003;43(1):85-6. author reply 6. [pmid: 12864768].
204 Goldstein J, Tiseo PT, Albert KS, et al. Eletriptan in migraine patients reporting unsatisfactory response to rizatriptan. Headache. Jul–Aug. 2006;46(7):1142-50. [pmid: 16866718].
205 Gonzalez-Espinosa LE, Gomez-Viera N, Olivera-Leal I, et al. Treatment of an acute attack if migraine headache with sumatriptan. Revista De Neurologia. 1997:1672-5. [pmid: 9484515].
206 González-Espinosa LE, Gómez-Viera N, Olivera-Leal I, et al. Treatment of acute attack of migraine with sumatriptan. Revista de neurologia. 1997:1672-5. [pmid: 9484515].
207 Gorman C, Park A. The new science of headaches. Time. Oct. 7. 2002;160(15):76-82. [pmid: 12389453].
208 Graham JR. Cardiac and pulmonary fibrosis during methysergide therapy for headache. Am J Med Sci. Jul. 1967;254(1):1-12. [pmid: 6027684].
209 Granado L, Guillen G. Treatment options for ophthalmoplegic migraine. Journal of Postgraduate Medicine. Jul–Sep. 2009;55(3):231. author reply -2. [pmid: 19884756].
210 Grigor'eva VN, Gustov AV, Kornilova LE, et al. Efficacy of combined kineso- and psychotherapy in the treatment of patients with migraine. Zhurnal nevrologii i psikhiatrii imeni S.S. Korsakova / Ministerstvo zdravookhraneniia i meditsinsko&#301; promyshlennosti Rossi&#301;sko&#301; Federatsii, Vserossi&#301;skoe obshchestvo nevrologov [i] Vserossi&#301;skoe obshchestvo psikhiatrov. 2003:20-5.
211 Grotemeyer KH, Husstedt IW, Schlake HP. Betablocker vs placebo in vasomotor headache. A double-blind crossover study. Deutsche medizinische Wochenschrift. 1946;1987:1740-3.
212 Grotemeyer KH, Scharafinski HW, Schlake HP, et al. Acetylsalicylic acid versus metroprolol in migraine prophylaxis. A double-blind crossover study. Nervenheilkunde. 1991:44-7.
213 Grotemeyer KH, Schlake HP, Husstedt IW. Prevention of migraine with metoprolol and flunarizine. A double-blind crossover study. Der Nervenarzt. 1988:549-52. [pmid: 3054595].
214 Grzesk G, Szadujkis-Szadurski L, Witkowski W, et al. The effectiveness of ergotamine treatment in chronic headache disorders: a double-blind, randomized, crossover, placebo controlled trial. Przegla&#807;d lekarski. 2003:471-4.
215 Guariso G, Bertoli S, Cernetti R, et al. Migraine and food intolerance: a controlled study in pediatric patients. La Pediatria medica e chirurgica : Medical and surgical pediatrics. 1993:57-61. [pmid: 8488128].
216 Gunner KB, Smith HD, Ferguson LE. Practice guideline for diagnosis and management of migraine headaches in children and adolescents: Part two. J Pediatr Health Care. Jan–Feb. 2008;22(1):52-9. [pmid: 18174091].
217 Guo S, Chen C, Xue G. Variation of female migraine after menopause and its prophylaxis and treatment. Zhonghua nei ke za zhi. Chinese journal of internal medicine. 1997:454-6. [pmid: 10436945].
218 Gupta S. How to prevent a migraine. Time. Jul. 1. 2002;160(1):69. [pmid: 12119734].
219 Gupta VK. Magnesium therapy for migraine: do we need more trials or more reflection?. Headache. May. 2004;44(5):445-6. [pmid: 15147256].
220 Gupta VK. De novo headache and analgesic consumption: pathophysiological insights from nosologic complexity?. Headache. Apr. 2004;44(4):375. [pmid: 15109365].
221 Gupta VK. Pharmacotherapeutics of migraine and the blood-brain barrier: serendipity, empiricism, hope, and hype. Medgenmed [Computer File]: Medscape General Medicine. 2006;8(2):89. [pmid: 16926828].
222 Gupta VK. Orbitofrontal cortex hypometabolism, medication overuse headache, substance abuse and migraine: key pathophysiological issues. Brain. Jul. 2006;129(Pt 7):E52. author reply E3. [pmid: 16803837].
223 Gupta VK. Letter regarding article by Law et al, "headaches and the treatment of blood pressure: results from a meta-analysis of 94 randomized placebo-controlled trials with 24,000 participants". Circulation. Feb. 21. 2006;113(7):e164-5. [pmid: 16493784].
224 Gupta VK. Antimigraine action of nicotine: theoretical basis and potential clinical application. European Journal of Emergency Medicine. Aug. 2007;14(4):243-4. [pmid: 17620924].
225 Gupta VK. Pre-emptive/early intervention with triptans in migraine: hope, hype and hazard. International Journal of Clinical Practice. Feb. 2007;61(2):350-2. [pmid: 17263726].
226 Gysin T. Clinical hypnotherapy/self-hypnosis for unspecified, chronic and episodic headache without migraine and other defined headaches in children and adolescents. Forschende Komplementärmedizin. 1999:44-6. [pmid: 10077718].
227 Haag G. A review of evidence-based medicine and meta-analytic reviews in migraine. Cephalalgia. Jul. 2007;27(7):862-3. author reply 3. [pmid: 17598773].
228 Haag GGWD. The interaction of behavioural treatment and drug reduction in migraine patients. Clin Pharmacol Ther. 1987:202.
229 Haan J, Sluis P, Sluis LH, et al. Acetazolamide treatment for migraine aura status. Neurology. Nov. 28. 2000;55(10):1588-9. [pmid: 11094126].
230 Hakkarainen H, Viukari M. (Sulpiride in the treatment of migraine, tension headache, and associated psychosomatic symptoms). Duodecim. 1973:1504-9. [pmid: 4587835].
231 Hanchanale VS, Biyani CS, Browning AJ, et al. Topiramate and the risk of urolithiasis. BJU Int. Feb. 2011;107(3):352-4. [pmid: 21265983].
232 He WZ, Chen M, Zheng JZ. Curative effect of fluoxetine for adjuvant treatment of migraine and its effect on serum lipid. Zhongguo Linchuang Kangfu. 2004:5254-5.
233 Henneicke-von Zepelin H-H. Feverfew for migraine prophylaxis. Headache. Mar. 2006;46(3):531. [pmid: 16618282].
234 Henry P, Hiesse-Provost O, Dillenschneider A, et al. Efficacy and tolerance of an effervescent aspirin-metoclopramide combination in the treatment of a migraine attack. Randomized double-blind study using a placebo. Presse médicale (Paris, France : 1983). 1995:254-8.
235 Herman LY. The efficacy of a safe, effective non-narcotic treatment of migraine headache. Journal of Emergency Medicine. Oct. 2003;25(3):322-3. [pmid: 14585464].
236 Hershey AD. Adolescents with migraine: nature vs nurture. Neurology. Jul. 3. 2007;69(1):12-3. [pmid: 17606876].
237 Hettiarachchi J, Sikes C. Eletriptan issues. Headache. Jul–Aug. 2003;43(7):816-8. author reply 8–9. [pmid: 12945540].
238 Heuser B, Middendorf E. Migraine prevention with dihydroergotamine. Fortschritte der Medizin. 1985:966-70. [pmid: 3905548].
239 Heydenreich A. Punctate transcutaneous electrical nerve stimulation in functional vertebragenic disorders and in migraine. Zeitschrift für die gesamte innere Medizin und ihre Grenzgebiete. 1988:651-3. [pmid: 3064454].
240 Heydenreich A. Single-point transcutaneous electric nerve stimulation in a simple placebo comparison in migraine (a prospective randomized study). Zeitschrift für ärztliche Fortbildung. 1989:881-3. [pmid: 2686215].
241 Heydenreich A, Thiessen M. Comparison of the effectiveness of drug therapy, invasive and non-invasive acupuncture in migraine. Zeitschrift für ärztliche Fortbildung. 1989:877-9. [pmid: 2686214].
242 Hill KP, Hope O. Combination of sumatriptan and naproxen for migraine. JAMA. Sep. 19. 2007;298(11):1276. author reply -7. [pmid: 17878418].
243 Hirata K. Sumatriptan-induced chest symptoms in Japanese. Internal Medicine. Aug. 2002;41(8):599-600. [pmid: 12211521].
244 Hochman MS. The interrelations of migraine, vertigo, and migrainous vertigo. Neurology. Oct. 23. 2001;57(8):1522. [pmid: 11673611].
245 Hoernecke R, Doenicke A. Treatment of migraine attacks: combination of dihydroergotamine tartrate and paracetamol in comparison with individual drugs and placebo. Medizinische Klinik (Munich, Germany: 1983). 1993:642-8.
246 Holdorff B, Sinn M, Roth G. Propranolol for prophylaxis of migraine (author's transl). Medizinische Klinik. 1977:1115-8. [pmid: 329085].
247 Holroyd KA, Penzien DB. Pharmacological versus non-pharmacological prophylaxis of recurrent migraine headache: a meta-analytic review of clinical trials. Pain. Jul. 1990;42(1):1-13. [pmid: 2146583].
248 Holroyd KA, Penzien DB, Cordingley GE. Propranolol in the management of recurrent migraine: a meta-analytic review. Headache. May. 1991;31(5):333-40. [pmid: 1830566].
249 Holtmann M, Opp J, Tokarzewski M, et al. Human epilepsy, episodic ataxia type 2, and migraine. Lancet. Jan. 12. 2002;359(9301):170-1. [pmid: 11809294].
250 Hu GC. The effect of sapogenins from leaves of panox notoginseng on migraine. Chinese Journal of Integrated Traditional and Western Medicine. 1988:726-7.
251 Huang JJ, Pang J, Lei LM, et al. Observation on therapeutic effect of Jingjin therapy on migraine. Zhongguo zhen jiu = Chinese acupuncture & moxibustion. 2006:322-4. [pmid: 16739842].
252 Hussar DA. New drugs 04, part 1. Nursing. Feb. 2004;34(2):56-62. quiz 3–4. [pmid: 14758333].
253 Hwang IK, Shih WJ, De Cani JS. Group sequential designs using a family of type I error probability spending functions. Statistics in Medicine. Dec. 1990;9(12):1439-45. [pmid: 2281231].
254 Jackson M, Barbuto JP. Botox, migraine, and the American Academy of Neurology an antidote to anecdote. Journal of Managed Care Pharmacy. Jun. 2008;14(5):465-7. [pmid: 18597576].
255 Jakubowski M, McAllister PJ, Bajwa ZH, et al. Exploding vs. imploding headache in migraine prophylaxis with Botulinum Toxin A. Pain. Dec. 5. 2006;125(3):286-95. [pmid: 17069972].
256 Janssen van Doorn K, Van der Niepen P, van Tussenbroeck F, et al. Acute tubulo-interstitial nephritis and renal infarction secondary to ergotamine therapy. Nephrology Dialysis Transplantation. Nov. 2000;15(11):1877-9. [pmid: 11071983].
257 Jia CS, Shi J, Ma XS, et al. Study on the therapeutic effect of electroacupuncture on migraine and influencing factors. Zhongguo zhen jiu = Chinese acupuncture & moxibustion. 2007:557-61. [pmid: 17853749].
258 Jiménez MD, Friera G, Morales A, et al. Gabapentine in the prophylaxis of migraine. A pilot study. Neurología. 1999:478.
259 Jin DX, Chen XY, Huang H, et al. The cerebral hemodynamics in cerebral autosomal dominant arteriopathy with subcortical infarcts and leukoencephalopathy. Zhonghua nei ke za zhi. Chinese journal of internal medicine. 2006:996-9. [pmid: 17326998].
260 Jindeel A. Are we ignoring the elephant in the room?. Archives of Internal Medicine. Nov. 12. 2007;167(20):2263-4. [pmid: 17998505].
261 Johnsen SV, Kropp P, Niederberger U, et al. Acupuncture in migraine therapy - Methodological considerations and results of two randomisied, controlled clinical and electrophysical studies. Akupunktur. 1998:72-82.
262 Jorgensen RS. BC 105, a new preparation for migraine. Ugeskrift for laeger. 1972:2266-8. [pmid: 4564231].
263 Jovici A, Mari, et al. Treatment of acute migraine attacks. Vojnosanitetski pregled Military-medical and pharmaceutical review. 1995:44-8. [pmid: 7638950].
264 Jurgens TP. Update migraine therapy. MMW Fortschritte der Medizin. Apr. 7. 2011;153(14):49-52. [pmid: 21966870].
265 Kaniecki RG. Musing on Mathew et al. Headache. Sep. 2003;43(8):922. author reply 4–8. [pmid: 14562838].
266 Kanner AM. Are antiepileptic drugs used in the treatment of migraine associated with an increased risk of suicidality?. Curr Pain Headache Rep. Jun. 2011;15(3):164-9. [pmid: 21479999].
267 Kapoor K, Willems EW, Maassen VanDenBrink A, et al. Assessment of anti-migraine potential of a novel alpha-adrenoceptor agonist S19014: effects on porcine carotid and regional haemodynamics and human coronary artery. Cephalalgia. Jun. 2004;24(6):425-38. [pmid: 15154852].
268 Karceski SC. How migraines affect cognitive function. [Original report in Neurology. 2007 Apr 24; 68(17):1417–24; PMID: 17452587]. Neurology. Apr. 24. 2007;68(17):E23-4. [pmid: 17452572].
269 Kawamura S, Sakai A, Endo T, et al. Atypical depression as a premonitory symptom of migraine managed by an oral contraceptive. Psychiatry & Clinical Neurosciences. Jun. 2008;62(3):365. [pmid: 18588602].
270 Kawase Y, Ikeda K, Iwasaki Y. Amantadine for migraine. Headache. Oct. 2008;48(9):1380. [pmid: 18547263].
271 Khromov A, Segal M, Nissinoff J, et al. Migraines linked to interferon-beta treatment of multiple sclerosis. American Journal of Physical Medicine & Rehabilitation. Aug. 2005;84(8):644-7. [pmid: 16034235].
272 Kim CC, Bogart MM, Wee SA, et al. Predicting migraine responsiveness to botulinum toxin type A injections. Archives of Dermatology. Feb. 2010;146(2):159-63. [pmid: 20157026].
273 Kirby M. The importance of getting treatment for headache right. International Journal of Clinical Practice. Dec. 2006;60(12):1519-21. [pmid: 17109658].
274 Klapetek J. Neosal, ergotamine tartrate caffeine and placebo in acute migraine attack. Die Medizinische Welt. 1973:745-7. [pmid: 4574382].
275 Klapetek J. Antidepressive effect of sandomigran. Der Nervenarzt. 1974:213-4. [pmid: 4602182].
276 Klapetek J. On the effect of the dynamics of Neosal, ergotamintartrate caffeine and placebo in an acute migraine attack. Acta Univpalackiolomucfacmed. 1975:235-45.
277 Klapper JA. An open label cross-over comparison of divalproex sodium and propranolol HCl in the prevention of migraine headaches. Headache Q. 1994:50-3.
278 Klimek A, Niewodniczy A, Pozniak-Patewicz E, et al. Propranolol in the treatment of migraine and similar headaches. Pol Tyg Lek. Jul. 10. 1978;33(28):1109-11. [pmid: 704408].
279 Kmie T, Kami, et al. Usefulness of cerebral SPECT in the children with migraine. Neurologia i neurochirurgia polska. 2005:S36-41. [pmid: 16419568].
280 Koehler PJ, Isler H. The early use of ergotamine in migraine. Edward Woakes' report of 1868, its theoretical and practical background and its international reception. Cephalalgia. Oct. 2002;22(8):686-91. [pmid: 12383066].
281 Koella WP. CNS-related (side-)effects of beta-blockers with special reference to mechanisms of action. Eur J Clin Pharmacol. 1985;28(Suppl):55-63. [pmid: 2865151].
282 Kornblau DH. Treatment of childhood migraine attacks with oral zolmitriptan and ibuprofen. Neurology. Apr. 24. 2007;68(17):1441. [pmid: 17452599].
283 Kozubski W, Prusiński A. Controlled study of iprazochrome effectiveness (Divascan) in prophylactic treatment of migraine. Neurologia i neurochirurgia polska. 1999:369-76. [pmid: 10463251].
284 Kozubski W, Prusinski A. Sodium valproate versus propranolol in the prophylactic treatment of migraine. Neurologia i Neurochirurgia Polska. Nov–Dec. 1995;29(6):937-47. [pmid: 8714731].
285 Krabbe AA, Olesen J. Ferrum quartz in the prevention of migraine. A double-blind study. Ugeskrift for laeger. 1980:516-8. [pmid: 6989074].
286 Krusz JC, Albright JP. Lacosamide in the treatment of chronic headache and migraine disorders. Headache. 2010;50(Supplement 1):48. PMID.
287 Kumar S. Preventive therapy of migraine. Neurology India. Jun. 2005;53(2):243. author reply. [pmid: 16010078].
288 Kurth T, Hernandez-Diaz S. Commentary: Triptan use during pregnancy: a safe choice?. Headache. Apr. 2010;50(4):576-8. [pmid: 20456148].
289 La PS, Mandarini A, Majello L, et al. Migraine prophylaxis: A new approach. Preliminary results of a double-blind study: Flunarizine/versus/placebo. <ORIGINAL> PROFILASSI DELLA EMICRANIA: UN NUOVO APPROCCIO. RISULTATI PRELIMINARI DI UNO STUDIO DOPPIO-CIECO: FLUNARIZINA v/s PLACEBO. Osp Ital Pediatr Spec Chir. 1985:969-79.
290 Lambru G, Manzoni GC, Torelli P, et al. Reversible cerebral vasoconstriction phenomena following indomethacin administration. Headache. May. 2011;51(5):813-8. [pmid: 21521211].
291 Lampl C, Katsarava Z, Diener HC, et al. Lamotrigine reduces migraine aura and migraine attacks in patients with migraine with aura. Journal of Neurology, Neurosurgery & Psychiatry. Dec. 2005;76(12):1730-2. [pmid: 16291905].
292 Lance JW. Paper bullets of the brain. A neurologist's story. Medical Journal of Australia. Dec. 1–15. 2003;179(11–12):620-3. [pmid: 14636134].
293 Land ST. 20 years ago: British Homoeopathic Journal, January 1984. Homeopathy: the Journal of the Faculty of Homeopathy. Jan. 2004;93(1):54-5. [pmid: 14960105].
294 Landy S, Richardson M, O'Quinn S. Migraine, Midrin, and Imitrex. Headache. Apr. 2002;42(4):322-3. author reply 3–4. [pmid: 12010397].
295 Langohr HD, Reinecke M, Gerber WD, et al. Migraine prophylaxis with dihydroergotamine and flunarizine. Fortschritte der Medizin. 1988:65-70. [pmid: 3278960].
296 Langohr HD, Reinecke M, Gerber WD, et al. Dihydroergotamine and flunarizine in the prevention of migraine. A comparative double-blind study. Fortschritte der Medizin. 1988:65-6. 9. 70. [pmid: 3278960].
297 Lastilla M, Achille P, Savarese MA, et al. Verapamil versus flunarizine in the preventive therapy of hemicrania. La Clinica terapeutica. 1990:401-4. [pmid: 2139385].
298 Lastimosa AC. Treatment of sporadic hemiplegic migraine with calcium-channel blocker verapamil. Neurology. Sep. 9. 2003;61(5):721-2. author reply 2. [pmid: 12963781].
299 Lastra L, Herranz J, Arteaga R. Flunarizine or dihydroergotamine in the treatment of migraine in childhood. A randomised study of 50 patients. Anales Espa±oles de Pediatrfa. 1990:213-18.
300 Lastra Martinez L, Herranz Fernandez J, Arteaga Manjon Cabez R. Flunarizine and dihydroergotamine in the treatment of migraine in children (published erratum appears in An Esp Pediatr 1990 Jun;32(6):566)]. An-Esp-Pediatr. 1990:213-8. [pmid: 2189328].
301 Lastra Martínez L, Herranz Fernández J, Arteaga Manjón-Cabez R. Flunarizine and dihydroergotamine in the treatment of migraine in children. Anales espanoles de pediatría. 1990:213-8. [pmid: 2189328].
302 Lehmann V, Banzhaf E, Kunze E, et al. Randomized clinically controlled study of the efficacy of acupuncture in comparison with electroacupuncture as well as drug therapy with propanolol in patients with recurrent migraine. Deutsche Zeitschrift Für Akupunktur. 1991:27-30.
303 Lehmann V, Banzhaf E, Kunze E, et al. Randomized clinically controlled study of the efficacy of acupuncture in comparison with electroacupuncture as well as drug therapy with propranolol in patients with recurrent migraine. Dtsch. Z. Akupunktur. 1991:27-30.
304 Lehrer JF. Cyproheptadine's antiserotonin effects are responsible for its antimigraine activity. Headache. Oct. 2004;44(9):935. [pmid: 15447711].
305 Lenaerts M, Bastings E, Sianard J, et al. Sodium valproate in severe migraine and tension-type headache: an open study of long-term efficacy and correlation with blood levels. Acta neurologica Belgica. 1996:126-9. [pmid: 8711985].
306 Leniger T, Wiemann M, Bingmann D, et al. Different effects of GABAergic anticonvulsants on 4-aminopyridine-induced spontaneous GABAergic hyperpolarizations of hippocampal pyramidal cells--implication for their potency in migraine therapy. Cephalalgia. Jul. 2000;20(6):533-7. [pmid: 11075835].
307 Leonard L, Phillips WJ. Near-complete migraine prophylaxis with amlodipine: a case report. Journal of Pain & Symptom Management. Dec. 2007;34(6):571-3. [pmid: 18053876].
308 Levy D, Burstein R. The vascular theory of migraine: leave it or love it?. Ann Neurol. Apr. 2011;69(4):600-1. [pmid: 21520229].
309 Lewis D, Ashwal S, Hershey A, et al. Practice parameter: pharmacological treatment of migraine headache in children and adolescents: report of the American Academy of Neurology Quality Standards Subcommittee and the Practice Committee of the Child Neurology Society. Neurology. Dec. 28. 2004;63(12):2215-24. [pmid: 15623677].
310 Lewis DW. Please don't let her suffer like I did!. Expert Review of Neurotherapeutics. May. 2005;5(3):291-4. [pmid: 15938660].
311 Lewis DW. Headaches in children and adolescents. Pediatric Annals. Jul. 2010;39(7):388-90. [pmid: 20666342].
312 Li Y, Liang F, Yu S, et al. Randomized controlled trial to treat migraine with acupuncture: design and protocol. Trials. 2008;9:57. [pmid: 18928574].
313 Li Z, Wang D, Cui Y. The clinical observation of Suxiao Jiuxin pellet on migraine for 42 cases. Chinese Journal of Integrated Traditional and Western Medicine. (Zhong Guo Zhong Xi Yi Jie He Za Zhi). 1996:15.
314 Li ZX, Li XG, Xiong XJ, et al. A clinical study of sibelium combining topiramate in prophylactic treatment of migraine. The Chinese Journal of Modern Applied Pharmacy. 2002:419-21.
315 Linde K, Rossnagel K. Propranolol for migraine prophylaxis. Cochrane Database of Systematic Reviews. 2004;(2):CD003225. [pmid: 15106196].
316 Lines C, Allen C, McCarroll K. Evidence-based migraine therapy. Cephalalgia. Nov. 2001;21(9):932-3. author reply 3–4. [pmid: 11903292].
317 Lines C, Visser WH. Patients with migraine prefer zolmitriptan orally disintegrating tablet to sumatriptan conventional oral tablet. International Journal of Clinical Practice. Mar. 2004;58(3):322. author reply -3. [pmid: 15117106].
318 Lionetto L, Fiorillo M, Martelletti P. Efficacy and tolerability of almotriptan in menstrual migraine: a comment. Expert Opinion on Pharmacotherapy. Oct. 2011;12(15):2279-81. [pmid: 21916785].
319 Lipton RB, Cady R. Mixing sumatriptan. Headache. Apr. 2002;42(4):325-6. [pmid: 12010399].
320 Liu HC. Botulinum toxin type a as a prophylactic treatment for chronic daily headache: time to conduct a large clinical trial in Taiwan?. Journal of the Chinese Medical Association: JCMA. Dec. 2007;70(12):519-20. [pmid: 18194891].
321 Liu HJ, Huang YQ, Wang XP. Effects of yanxue qingnao granules on headache symptoms and hemorheology in patients with migraine. Zhongguo Linchuang Kangfu. 2005:108-9.
322 Liu Y, Zhang X-P, Chen J-L. Observations on the curative effect of acupuncture on migraine. Shanghai journal of acupuncture and moxibustion. 2002:24.
323 Liu Y-C, Fuh J-L, Chen R-C, et al. Botulinum toxin type a in the prophylactic treatment of transformed migraine in Taiwanese patients: a review of 30 consecutive cases. [Erratum appears in J Chin Med Assoc. 2008 Oct;71(10):549]. Journal of the Chinese Medical Association: JCMA. Dec. 2007;70(12):535-40. [pmid: 18194894].
324 Loder E. Menstrual migraine: timing is everything. Neurology. Jul. 27. 2004;63(2):202-3. [pmid: 15277607].
325 Loder E. Fixed drug combinations for the acute treatment of migraine : place in therapy. CNS Drugs. 2005;19(9):769-84. [pmid: 16142992].
326 Loftus BD. Unilateral time-delayed encapsulation does not make for a fair race. Headache. Sep. 2003;43(8):921. author reply 4–8. [pmid: 12940818].
327 Logroscino G, Lipton RB. Migraine is associated with chest symptoms but not cardiac events: a reassuring paradox. Neurology. Dec. 28. 2004;63(12):2209-10. [pmid: 15623674].
328 Loisy C. Chenodeoxycholic acid and the Vichy cure. Médecine & chirurgie digestives. 1981:547-8. [pmid: 7311644].
329 Longo G, Rudoi I, Iannuccelli M, et al. Treatment of essential headache in developmental age with L-5-HTP (cross over double-blind study versus placebo). La Pediatria medica e chirurgica : Medical and surgical pediatrics. 1984:241-5. [pmid: 6397729].
330 Lopez-Gil A. Evaluating triptan usage: a rebuttal. Headache. Oct. 2004;44(9):934-5. [pmid: 15447710].
331 Louis P. Migraine prophylaxis: Double-blind trials with flunarizine. <ORIGINAL> BERICHT ZUR MIGRANEPROPHYLAXE: DOPPELBLINDVERSUCHE MIT FLUNARIZIN. Therapiewoche. 1984;34:5661-6.
332 Lu SL, Ma YL, Shan SQ. Blocking astroid sympathetic ganglion to treat migraine by bupivacaine and morphine combined solution. Chinese Journal of Anesthesiology. 1992:120-1.
333 Ludvigsson J. Letter: Propranolol in treatment of migraine in children. Lancet. Oct. 6. 1973;2(7832):799. [pmid: 4126507].
334 Lutschg J, Vassella F. Flunarizine and propranolol in the treatment of migraine in children. Schweizerische Medizinische Wochenschrift. 1990:1731-6. [pmid: 2251492].
335 Lütschg J, Vassella F. The treatment of juvenile migraine using flunarizine or propranolol. Schweizerische medizinische Wochenschrift. 1990:1731-6. [pmid: 2251492].
336 Lynggaard F, Ostergaard F. Clonidine in prevention of migraine. Report of a double-blind study of 38 patients referred for neurological assessment. Ugeskrift for laeger. 1975:149-51. [pmid: 1094661].
337 Maggioni F. Revisiting the role of ergots in the treatment of migraine and headache: a comment. Headache. May. 2011;51(5):819-20. [pmid: 21453328].
338 Mahmood T, Silverstone T. Twin concordance for bipolar disorder and migraines. American Journal of Psychiatry. Dec. 2000;157(12):2057. [pmid: 11097985].
339 Maissen CP, Ludin HP. Comparison of the effect of 5-hydroxytryptophan and propranolol in the interval treatment of migraine. Schweizerische medizinische Wochenschrift. 1991:1585-90. [pmid: 1947955].
340 Maissen CP, Ludin HP. Comparative efficacy of 5-hydroxytryptophan and propranolol in interval treatment of migraine. Schweiz Med Wochenschr. 1991:1585-90. [pmid: 1947955].
341 Malone TD, Kori SH. Ischemic colitis associated with naratriptan and oral contraceptive use: a response. Headache. Nov–Dec. 2005;45(10):1418-9. author reply 9–20. [pmid: 16324179].
342 Mann JD, Faurot KR, Wilkinson L, et al. Craniosacral therapy for migraine: protocol development for an exploratory controlled clinical trial. BMC Complement Altern Med. 2008;8:28. [pmid: 18541041].
343 Mansoor Q, Jain S. Bilateral angle-closure glaucoma following oral topiramate therapy. Acta Ophthalmologica Scandinavica. Oct. 2005;83(5):627-8. [pmid: 16188011].
344 Manzoni GC, Martucci N, Agnoli A, et al. Multicentric, double-blind, randomized study on the efficacy and tolerance of dothiepin and amitriptyline for the prophylaxis of chronic migraine. [Italian]. Giornale di Neuropsicofarmacologia. 1990:179-84.
345 Marcus DA. Pregnancy and chronic headache. Expert Opinion on Pharmacotherapy. Apr. 2002;3(4):389-93. [pmid: 11934341].
346 Martelletti P. Dispute settlement understanding on the use of Botox in chronic migraine. J Headache Pain. Feb. 2011;12(1):1-2. [pmid: 21246242].
347 Martikainen MH, Roine S. Rapid improvement of a complex migrainous episode with sodium valproate in a patient with CADASIL. J Headache Pain. Jan. 2012;13(1):95-7. [pmid: 22065121].
348 Martinez Collado JH, Alvarado Gay FJ, Danel Beltran JA, et al. Glucose screening test in pregnant women. A comparison between the traditional glucose load and diet. Medicina Interna de Mexico. 2003:286-8.
349 Martinez LL, Fernandez JH, Manjon-Cabeza RA. Flunarizine or dihydroergotamine in the treatment of migraine in childhood. A randomised study of 50 patients. <ORIGINAL> FLUNARIZINA O DIHIDROERGOTAMINA EN EL TRATAMIENTO DE LA MIGRANA EN LA INFANCIA. ESTUDIO RANDOMIZADO DE 50 PACIENTES. An Esp Pediat. 1990:213-8.
350 Masdrakis VG, Oulis P, Karakatsanis NA, et al. Remission of migraine attacks in a patient with depression who is taking pregabalin. Clinical Neuropharmacology. Jul–Aug. 2008;31(4):238-40. [pmid: 18670248].
351 Massiou H. What is lacking in the treatment of paediatric and adolescent migraine?. Cephalalgia. 1997;17(Suppl 17):21-4. [pmid: 9218882].
352 Mathew NT, Ali S. Valproate in the treatment of persistent chronic daily headache. An open label study. Headache. Feb. 1991;31(2):71-4. [pmid: 2030076].
353 Mathew NT, Saper JR, Silberstein SD. Safety and efficacy of divalproex sodium in the prophylaxis of migraine headache: a multicenter, double-blind, placebo-controlled trial. [abstract]. Canadian Journal of Neurological Sciences. 1993.
354 Matsumaru Y, Hayakawa M. Endovascular treatment for carotid artery stenosis. Brain & Nerve / Shinkei Kenkyu no Shinpo. Dec. 2010;62(12):1291-300. [pmid: 21139182].
355 Matthews SC, Miller BP. Auditory hallucinations associated with topiramate. Journal of Clinical Psychiatry. Aug. 2001;62(8):653. [pmid: 11561939].
356 Mattsson P. Migraine: preventive treatment. Cephalalgia. Oct. 2004;24(10):908. author reply -9. [pmid: 15377326].
357 Maubach KA, Davis RJ, Clark DE, et al. BGC20-1531, a novel, potent and selective prostanoid EP receptor antagonist: a putative new treatment for migraine headache. British Journal of Pharmacology. Jan. 2009;156(2):316-27. [pmid: 19154437].
358 Mauksop A, Basdeo R. Botulinum toxin A is an effective prophylactic therapy for migraines. [abstract]. Cephalalgia. 2000;20:422. abstract 387. PMID.
359 McCrory DC. Report on gabapentin (Neurontin®) for migraine prophylaxis. 2008. PMID.
360 McDevitt DG. The assessment of beta-adrenoceptor blocking drugs in man. Br J Clin Pharmacol. Aug. 1977;4(4):413-25. [pmid: 20123].
361 McIntosh E. Anti-emetics, NSAIDs and opiates in migraine. Practitioner. Sep. 2006;250(1686):60. author reply. [pmid: 17036920].
362 McQuay H, Carroll D, Jadad AR, et al. Anticonvulsant drugs for management of pain: a systematic review. BMJ (Clinical research ed.). 1995:1047-52.
363 Medvedeva LA, Zagorul'ko OI, Gnezdilov AV, et al. Use of anesthesiological technologies in the complex treatment of cervicocranial pain syndromes. Anesteziologiia i reanimatologiia. 2008:92-6. [pmid: 19102241].
364 Mehrotra S, Gupta S, Garrelds IM, et al. Effects of current and prospective antimigraine drugs on the porcine isolated meningeal artery. Naunyn-Schmiedebergs Archives of Pharmacology. Dec. 2006;374(3):163-75. [pmid: 17103145].
365 Menault F. Maintenance therapy in craniofacial pain: a controlled trial with tiapride (author's transl). [French]. Sem Hop. 1981:1015-6. [pmid: 6266020].
366 Mendizabal JE. Extended-release divalproex sodium improves the quality of life of adolescent migraineurs. Headache. Apr. 2002;42(4):327-8. [pmid: 12010402].
367 Messerich J. EMA 3--a phenacetin-free combination with analgesic action. Schweizerische Rundschau für Medizin Praxis = Revue suisse de médecine Praxis. 1973:774-6. [pmid: 4576437].
368 Michel H. Migraine and tiapride. A controlled study (author's transl). [French]. Sem Hop. 1980:1931-5. [pmid: 6256904].
369 Midelfart E, Winnem M. Sumatriptan in the treatment of migraine in general practice. Tidsskrift for den Norske lægeforening : tidsskrift for praktisk medicin, ny række. 1994:3430-2.
370 Mierzwiński J, Pawlak O, et al. The vestibular system and migraine in children. Otolaryngologia polska. The Polish otolaryngology. 2000:537-40. [pmid: 11202339].
371 Mitchell MP, Schaecher K, Cannon HE, et al. Humanistic, utilization, and cost outcomes associated with the use of botulinum toxin for treatment of refractory migraine headaches in a managed care organization. Journal of Managed Care Pharmacy. Jun. 2008;14(5):442-50. [pmid: 18597573].
372 Mnie-Filali O, Lambas-Senas L, Scarna H, et al. Therapeutic potential of 5-HT7 receptors in mood disorders. Current Drug Targets. Nov. 2009;10(11):1109-17. [pmid: 19702552].
373 Moore KL. Valproate in the treatment of refractory recurrent headaches. Headache Quarterly. 1992;3(3):323-5. PMID.
374 Moreno MJ, Abounader R, et al. Efficacy of the non-peptide CGRP receptor antagonist BIBN4096BS in blocking CGRP-induced dilations in human and bovine cerebral arteries: potential implications in acute migraine treatment. Neuropharmacology. Mar. 2002;42(4):568-76. [pmid: 11955527].
375 Morey SS. Guidelines on migraine: Part 3. Recommendations for individual drugs. American Family Physician. Nov. 1. 2000;62(9):2145-8. [pmid: 11087191].
376 Morey SS. Guidelines on migraine: Part 2. General principles of drug therapy. American Family Physician. Oct. 15. 2000;62(8):1915-7. [pmid: 11057843].
377 Morren JA, Galvez-Jimenez N. Where is dihydroergotamine mesylate in the changing landscape of migraine therapy?. Expert Opinion on Pharmacotherapy. Dec. 2010;11(18):3085-93. [pmid: 21080856].
378 Moses LL. Botulinum toxin A. An alternative treatment for migraine. Advance for Nurse Practitioners. Dec. 2009;17(12):40-1. [pmid: 20014704].
379 Mucke HA. Robalzotan AstraZeneca. Current Opinion in Investigational Drugs. Oct. 2000;1(2):236-40. [pmid: 11249580].
380 Mulleners WM, Chronicle EP. Anticonvulsants in migraine prophylaxis: a Cochrane review. Cephalalgia. Jun. 2008;28(6):585-97. [pmid: 18454787].
381 Müller KH, Haarmann K, Neff K. Effect of BC 105 on the depressed mood in migraine. Therapeutische Umschau Revue thérapeutique. 1972:628-35. [pmid: 5078775].
382 Naess K. Short piece on a double blind study with Demigran. Tidsskrift for den Norske lægeforening : tidsskrift for praktisk medicin, ny række. 1969:1658.
383 Nair KG. A pilot study of the value of propranolol in migraine. Journal of Postgraduate Medicine. Jul. 1975;21(3):111-3. [pmid: 1107526].
384 Nair P. Recent developments in health law. Wyeth v. Levine: challenging implied pre-emption for drugs. Journal of Law, Medicine & Ethics. 2009;37(3):527-30. [pmid: 19791315].
385 Naprienko MV, Oknin V, Kremenchugskaia MR, et al. Use of acupuncture in the therapy of chronic daily headache. Zhurnal nevrologii i psikhiatrii imeni S.S. Korsakova / Ministerstvo zdravookhraneniia i meditsinsko&#301; promyshlennosti Rossi&#301;sko&#301; Federatsii, Vserossi&#301;skoe obshchestvo nevrologov [i] Vserossi&#301;skoe obshchestvo psikhiatrov. 2003:40-4.
386 Nascimento ED. Prophylaxis of migraine: open study with venlafaxine in 42 patients. Arq Neuropsiquiatr. Dec. 1998;56(4):744-6. [pmid: 10029876].
387 Nattero G, Lisino F, Brandi G, et al. Use of dimethothiazine in the prevention of hemicrania. Minerva medica. 1977:839-45. [pmid: 321991].
388 Nattero G, Lisino F, Brandi G, et al. Reserpine in the prevention of migraine and in the therapy of tension-vascular headache. Minerva medica. 1976:1871-5. [pmid: 934534].
389 Ni C. 32 cases of non-premonitory migraine treated by opening "four gates". Acta universitatis traditionis medicalis sinensis pharmacologiaeque shanghai. 2002:24.
390 Nørrelund N, Christiansen LV, Plantener S. Tolfenamic acid versus paracetamol in migraine attacks. A double-blind study in general practice. Ugeskrift for laeger. 1989:2436-8. [pmid: 2678652].
391 Novembre E, Dini L, Bernardini R, et al. Unusual reactions to food additives. La Pediatria medica e chirurgica : Medical and surgical pediatrics. 1992:39-42. [pmid: 1579515].
392 Ogose T, Manabe T, Abe T. Childhood steroid-responsive painful ophthalmoplegia: clues to ophthalmoplegic migraine. Journal of Pediatrics. Aug. 2007;151(2):e8-9. author reply e. [pmid: 17643751].
393 Olesen C, Olsen J. Sumatriptan: what do we know about fetal risks?. Headache. Feb. 2001;41(2):206-7. [pmid: 11251709].
394 O'Quinn S, Saiers J, Mansbach H, et al. Comparison of rizatriptan and sumatriptan: a reply to Tfelt-Hansen et al. Headache. Jul–Aug. 2000;40(7):605-9. [pmid: 10940103].
395 Oshinsky ML, Luo J. Neurochemistry of trigeminal activation in an animal model of migraine. Headache. Jun. Suppl 1. 2006;46:S39-44. [pmid: 16927963].
396 Oterino A, Ramon C, Pascual J. Experience with onabotulinumtoxinA (BOTOX) in chronic refractory migraine: focus on severe attacks. J Headache Pain. Apr. 2011;12(2):235-8. [pmid: 21298315].
397 Overbeek WA, de Vroede MA, Lahuis BE, et al. Antipsychotics and metabolic abnormalities in children and adolescents: a review of the literature and some recommendations. Tijdschr Psychiatr. 2010;52(5):311-20. [pmid: 20458678].
398 Pakalnis A, Couch J. Headache therapy with botulinum toxin: form over substance. Archives of Neurology. Jan. 2008;65(1):149-51. [pmid: 18195156].
399 Pakalnis A, Kring D. Zonisamide prophylaxis in refractory pediatric headache. Headache. May. 2006;46(5):804-7. [pmid: 16643584].
400 Palmer JB, Salonen R. Migraine revolution and sumatriptan. Lancet. Jun. 24. 2000;355(9222):2250-1. [pmid: 10881915].
401 Parisi P. Migraine and suicidal ideation in adolescents aged 13 to 15 years. Neurology. Nov. 17. 2009;73(20):1713. author reply -4. [pmid: 19918001].
402 Pascual J. Good news for chronic migraine. Journal of Headache & Pain. Sep. 2006;7(4):169-71. [pmid: 16897616].
403 Paterna S, di Pasquale P, Martino S, et al. Captopril versus placebo in the prevention of hemicrania without aura. A randomized double-blind study. La Clinica terapeutica. 1992:475-81. [pmid: 1493669].
404 Paterna S, Martino S, Ingurgio NC, et al. The effects of terazosin hydrochloride and buflomedil in patients with hemicrania without aura. La Clinica terapeutica. 1994:307-19. [pmid: 7911406].
405 Paterna S, Martino SG, Campisi D, et al. Evaluation of the effects of verapamil, flunarizine, diltiazem, nimodipine and placebo in the prevention of hemicrania. A double-blind randomized cross-over study. La Clinica terapeutica. 1990:119-25. [pmid: 2147612].
406 Peatfield RC. Importance of headache. Current Medical Research & Opinion. 2001;17(Suppl 1):s1-3. [pmid: 12463269].
407 Pedersen E, Moller CE. Methysergide in migraine prophylaxis. Clinical pharmacology and therapeutics. 1966:520-6. [pmid: 5328472].
408 Pellock JM, Willmore LJ. A rational guide to routine blood monitoring in patients receiving antiepileptic drugs. Neurology. Jul. 1991;41(7):961-4. [pmid: 2067658].
409 Perrotta A. The importance of early symptomatic treatment of the migraine attack. Confinia Cephalalgica. 2006:83-7.
410 Pfaffenrath V, Diener HC, Isler H, et al. Effectiveness and tolerance of amitriptyline oxide in chronic tension headache--a multicenter double-blind study versus amitriptyline versus placebo. Der Nervenarzt. 1993:114-20. [pmid: 8450893].
411 Philipp M. Therapy of migraine. Clinical experience with Migraeflux, a new migraine drug. Fortschritte der Medizin. 1977:107-10. [pmid: 832830].
412 Pichler E, Strauss A, Wunderlich E. Ophthalmodynamographic studies in spontaneous and pharmacologically induced vascular headache. [German]. Wiener Klinische Wochenschrift. 1968:855-61. [pmid: 5708945].
413 Pini LA. Future drugs for migraine. Internal & Emergency Medicine. Oct. 2009;4(5):361-2. [pmid: 19707844].
414 Piovesan EJ, Werneck LC, Kowacs PA, et al. Anesthetic blockade of the greater occipital nerve in migraine prophylaxis. Arquivos de neuro-psiquiatria. 2001:545-51. [pmid: 11588633].
415 Pita E, Higueras A, Bolanos J, et al. Propranolol and migraine. A clinical trial. Archivos de farmacología y toxicología. 1977:273-8. [pmid: 350168].
416 Pluvinage R. The treatment of migraine and tension headaches with amitriptyline (author's transl). La semaine des hôpitaux : organe fondé par l'Association d'enseignement médical des hôpitaux de Paris. 1978:713-6.
417 Poch GF. BC 105 in migraine. Prensa médica argentina. 1972:563-7. [pmid: 4403208].
418 Polisca R, Signoretti P, Marchi P. Fluoxetine in the treatment of migraine with interval headache. Rassegna Internazionale di Clinica e Terapia. 1992:408-15.
419 Pothmann R. Migraine prophylaxis in children with low dose aspirin and flunarzin. Journal of Neurology. 1985:219. [pmid: 2864402].
420 Pothmann R. Prevention of migraine with flunarizine and acetylsalicylic acid. A double-blind study. Monatsschrift Kinderheilkunde : Organ der Deutschen Gesellschaft für Kinderheilkunde. 1987:646-9. [pmid: 3313023].
421 Pothmann R. Childhood migraine prophylaxis with calcium antagonist flunarizine and acetylsalicylic acid. A double blind study. Monatsschrift fur Kinderheilkunde. 1987:646-9.
422 Pradalier A, Dry J, Loisy B, et al. Comparative study of indoramin versus dihydroergotamine in the preventive treatment of migraine. Thérapie. 1988:293-7. [pmid: 3055407].
423 Pradalier A, Dry J, Maininger V, et al. Comparative study of indoramin vs dihydroergotamine in in-depth treatment of migraine (with or without aura). Therapie. 1990:364.
424 Pradalier A, Guérard des Lauriers A, Scheck F, et al. Calcium carbasalate-metoclopramide combination versus dihydroergotamine in the treatment of migraine attacks. Pathologie-biologie. 1995:806-13. [pmid: 8746103].
425 Pradalier A, Serratrice G, Collard M, et al. Beta-blockers and migraine. Efficacy of time-release propranolol versus placebo. Thérapie. 1990:441-5. [pmid: 2260046].
426 Pradalier A, Serratrice G, Collard M, et al. Betablockers and migraine: Long-acting propranolol in migraine prophylaxis, against placebo. <ORIGINAL> BETA-BLOQUANTS ET MIGRAINE. EFFICACITE, CONTRE PLACEBO, DU PROPRANOLOL A LIBERATION PROLONGEE. Therapie. 1990:441-5. [pmid: 2260046].
427 Pradalier A, Vincent D. Migraine and non-steroidal anti-inflammatory agents. Pathologie-biologie. 1992:397-405. [pmid: 1495823].
428 Prusinski A, Kozubski W. Use of verapamil in the treatment of migraine. Wiadomosci Lekarskie. Jun. 1. 1987;40(11):734-8. [pmid: 3673084].
429 Puzich R, Girke W, Heidrich H, et al. Doppler ultrasound studies of the extracranial cerebral vessels in migraine patients after ergotamine tartrate administration. Deutsche medizinische Wochenschrift. 1946;1983:457-61.
430 Rabe K, Katsarava Z, Pageler L, et al. Efficacy of oral prednisone in the treatment of medication withdrawal headache following medication overuse headache: A placebo-controlled, double-blind and randomised study. Aktuelle Neurologie. 2007:526-9.
431 Rahimtoola H, Buurma H, Tijssen CC, et al. Migraine prophylactic medication usage patterns in The Netherlands. Cephalalgia. May. 2003;23(4):293-301. [pmid: 12716348].
432 Ramchandren S, Liebeskind DS. Headache in a patient with Klinefelter's syndrome and hyperostosis frontalis interna. Journal of Headache & Pain. Dec. 2007;8(6):342-4. [pmid: 18071629].
433 Ramos-Reyna E, Figueroa-Medina MJ, Garcia-Hurtado JP. Clinical trial of intranasal tetracaine and placebo in an acute migrane a tac at the Central Military Hospital. Archivos de Neurociencias. 2008:237-41.
434 Rapoport A. Antimigraine drugs: new frontiers. Neurol Sci. May. Suppl 1. 2009;30:S49-54. [pmid: 19415426].
435 Raveau-Landon C, Bousser MG. Metoprolol, a new effective antimigraine agent. Presse médicale (Paris, France: 1983). 1988:1805-9.
436 Ravishankar K. Botulinum toxin--role in headache prophylaxis. Journal of the Association of Physicians of India. Sep. 2003;51:851-2. [pmid: 14710967].
437 Recober A, Russo AF. Olcegepant, a non-peptide CGRP1 antagonist for migraine treatment. Idrugs. Aug. 2007;10(8):566-74. [pmid: 17665333].
438 Regidor PA, Speer K, Regidor M, et al. Long-term side-effects following cyproterone acetate containing therapy in gynecology. Zentralblatt für Gynäkologie. 2000:268-73. [pmid: 10857213].
439 Richardson MS, Bowers BW, Petrie JL. The comparative clinical and economic benefits of drugs should be established and discussed as part of any formulary decision process. American Journal of Managed Care. Aug. 2002;8(8):693-4. author reply 4–5. [pmid: 12212757].
440 Ridley-Smith RM. A fatal error. New Zealand Medical Journal. 2007;120(1255):U2570. [pmid: 17546115].
441 Rieder MJ. Comparison of rizatriptan and other triptans on stringent measures of efficacy. Neurology. Sep. 10. 2002;59(5):787. author reply 8. [pmid: 12229911].
442 Riopelle R, McCans JL. A pilot study of the calcium channel antagonist diltiazem in migraine syndrome prophylaxis. Can J Neurol Sci. 1982;9(2):269. PMID. [pmid: 7104892].
443 Roach ES. Questioning botulinum toxin for headache: reality or illusion. Archives of Neurology. Jan. 2008;65(1):151-2. [pmid: 18195157].
444 Robbins L. Stadol nasal spray for headache. Headache. May. 2002;42(5):386. [pmid: 12047344].
445 Rodgers A, Hustad CM, Ramsey KE, et al. Comment on eletriptan in migraine patients reporting unsatisfactory response to rizatriptan. Headache. Mar. 2007;47(3):452. author reply -3. [pmid: 17371373].
446 Rollet J. More than skin deep. Botox applications go beyond frown lines. Advance for Nurse Practitioners. Dec. 2004;12(12):33-4. [pmid: 15615218].
447 Rothrock JF. Clinical studies of valproate for migraine prophylaxis. Cephalalgia. Apr. 1997;17(2):81-3. [pmid: 9137842].
448 Rothrock JF. Oral triptan therapy. Headache. Jun. 2006;46(6):1038. [pmid: 16732854].
449 Rothrock JF. Topiramate for chronic migraine. Headache. Jan. 2007;47(1):139. [pmid: 17355514].
450 Rothrock JF. Lagniappe. Headache. Sep. 2007;47(8):1232-3. [pmid: 17883544].
451 Rothrock JF. Patient information regarding subcutaneous self-administration of dihydroergotamine (DHE). Headache. May. 2007;47(5):740. [pmid: 17501862].
452 Rothrock JF. Patient information regarding subcutaneous self-administration of sumatriptan (imitrex). Headache. Apr. 2007;47(4):639. [pmid: 17445120].
453 Rothrock JF. Chronic migraine: medication overuse headache. Headache. Mar. 2007;47(3):467-8. [pmid: 17371376].
454 Rothrock JF. BOTOX for headache treatment. Headache. Feb. 2007;47(2):345-6. [pmid: 17300388].
455 Rothrock JF. Images from headache: a costly attack of migraine. Headache. Jun. 2008;48(6):951. [pmid: 18549373].
456 Rothrock JF. Preventive (prophylactic) therapy. Headache. Sep. 2009;49(8):1253-5. [pmid: 19719547].
457 Rothrock JF. In this issue. Headache. Nov–Dec. 2009;49(10):1401. [pmid: 19912345].
458 Rothrock JF. Triptans, SSRIs/SNRIs and serotonin syndrome. [Original report in Headache. 2010 Jun;50(6):1089–99; PMID: 20618823]. Headache. Jun. 2010;50(6):1101-2. [pmid: 20618824].
459 Rothrock JF. Non-steroidal anti-inflammatory drugs (NSAIDs) for acute migraine treatment. Headache. Nov. 2010;50(10):1635-6. [pmid: 21198567].
460 Rothrock JF, Mendizabal JE. An analysis of the "carry-over effect" following successful short-term treatment of transformed migraine with divalproex sodium. Headache. Jan. 2000;40(1):17-9. [pmid: 10759897].
461 Rozen TD. Worsening of headaches on topiramate? A low cerebrospinal fluid pressure syndrome?. Headache. Jul–Aug. 2003;43(7):819-20. [pmid: 12945541].
462 Russell MB, Holm-Thomsen OE, Nielsen MR, et al. Sumatriptan treatment of migraine in general practice. A randomized, double-blind, placebo-controlled cross-over study. Ugeskrift for laeger. 1995:2320-3. [pmid: 7652970].
463 Sacré A, et al. Topiramate induces type 3 renal tubular acidosis by inhibiting renal carbonic anhydrase. Nephrology Dialysis Transplantation. Oct. 2006;21(10):2995-6. [pmid: 16735391].
464 Sánchez-Pérez R, Asensio M, Melchor A, et al. Clinical features of migraine according to the questionnaire 'Alcoi-92' in the Comtat area. Revista de neurologia. 1999:459-63. [pmid: 10229957].
465 Sandor PS, Morath GP, Hess K, et al. Prosopagnosia as symptom of migraine with aura: a case report. Cephalalgia. Mar. 2006;26(3):345-8. [pmid: 16472345].
466 Sartory G, Muller B, Metsch J, et al. Psychological and medicinal treatment of migraine in children and adolescents. Verhaltenstherapie. 1995:A25.
467 Sattin JA, Login IS. Buspirone challenge is not a valid probe of central 5-HT1A receptor function. Cephalalgia. Jun. 2004;24(6):510. author reply 1–2. [pmid: 15154863].
468 Saurugg D, Hodkewitsch E. Clinical experiences with an analgesic-acting infusion solution in neurological painful conditions. Wiener medizinische Wochenschrift. 1946;1977:490-2.
469 Saxena P, Tesar PJ. Vascular obstruction related to mediastinal fibrosis: an interesting clinical entity. Journal of Thoracic & Cardiovascular Surgery. Nov. 2007;134(5):1379. author reply -80. [pmid: 17976493].
470 Schaerlinger B, Hickel P, Etienne N, et al. Agonist actions of dihydroergotamine at 5-HT2B and 5-HT2C receptors and their possible relevance to antimigraine efficacy. British Journal of Pharmacology. Sep. 2003;140(2):277-84. [pmid: 12970106].
471 Schnorrenberger CC, Baust W. Acupuncture therapy of migraine in a double-blind trial. Die Medizinische Welt. 1979:425-8. [pmid: 431377].
472 Schoenen J, Vandenheede M. Almotriptan efficacy in migraine with allodynia: a rebuttal to Burstein and Jakubowski's critique of Schoenen et al. Cephalalgia. Sep. 2010;30(9):1147-8. [pmid: 20713568].
473 Schreiber CP. Building a migraine toolkit for patients: successful management of migraine headache. Postgraduate Medicine. Nov. 2003;114(5 Suppl Understanding):27-35. [pmid: 19667647].
474 Schulz HD, Taubert K, Falkner R. Migraine therapy with shortwave. Zeitschrift für ärztliche Fortbildung. 1991:41-2. [pmid: 2028651].
475 Schurks M. Common mechanisms in migraine and epilepsy: a comment. Archives of Neurology. Nov. 2008;65(11):1546. author reply -7. [pmid: 19001180].
476 Seidel S, x00F, ber C. Numb chin syndrome, migraine-like headache and leptomeningeal spread of a B-cell lymphoma. Headache. Jan. 2010;50(1):150-1. [pmid: 19804399].
477 Sercl M, Vrcha L. Clinical experiences with polyantiaminic BC-105 Sandoz in the prevention of vasomotor headaches. Schweizerische Rundschau für Medizin Praxis = Revue suisse de médecine Praxis. 1970:679-83. [pmid: 4396441].
478 Sewell RA, Gottschalk CH. Problem child is no headache. Headache. Feb. 2011;51(2):306. author reply -7. [pmid: 21083559].
479 Shaffer CR. Triptan therapy in migraine. New England Journal of Medicine. Sep. 30. 2010;363(14):1377. author reply 8. [pmid: 20886673].
480 Shank RP, Gardocki JF, Vaught JL, et al. Topiramate: preclinical evaluation of structurally novel anticonvulsant. Epilepsia. Mar–Apr. 1994;35(2):450-60. [pmid: 8156972].
481 Sharifi M, Burks J. Efficacy of clopidogrel in the treatment of post-ASD closure migraines. Catheterization & Cardiovascular Interventions. Oct. 2004;63(2):255. [pmid: 15390244].
482 Shimony A, Romem A, Horowitz S, et al. Acute coronary syndrome associated with myocardial bridging due to ergotamine treatment for migraine. International Journal of Cardiology. Oct. 26. 2006;113(1):E7-8. [pmid: 16887217].
483 Shin JI, Lee JS. Can chronic fatigue symptoms associated with nutcracker phenomenon be treated with aspirin?. Medical Hypotheses. 2007;69(3):704-5. [pmid: 17329037].
484 Shulman ST. Headaches!. Pediatric Annals. Jul. 2010;39(7):386-7. [pmid: 20666341].
485 Siegmeth W, Placheta P. Double-blind comparative trial of lonazolac-Ca versus naproxen in spinal osteoarthrosis, coxarthrosis and gonarthrosis (author's transl). Wiener klinische Wochenschrift. 1982:145-7. [pmid: 7048748].
486 Silberstein SD. Divalproex sodium in headache: literature review and clinical guidelines. Headache. Oct. 1996;36(9):547-55. [pmid: 8916563].
487 Stovner LJ. Migraine prophylaxis with drugs influencing the renin-angiotensin system. European Journal of Neurology. Jul. 2007;14(7):713-4. [pmid: 17594324].
488 Strunge P. MY 25, a peroral prophylactic for migraine. Ugeskrift for laeger. 1971:1209-13. [pmid: 5560739].
489 Sulman FG, Pfeifer Y, Tal E. Migraine therapy by enzyme induction with proxibarbital. Therapie der Gegenwart. 1976:2088-103. [pmid: 14412].
490 Sun Zhong-Ren ET. Research Into Clinical Curative Effect of Acupuncture on Migraine and Its Biochemical Mechanism. Shanghai journal of acupuncture and moxibustion. 2002:16.
491 Tan LR, Huang SH, Zheng BL. Observation on integrated Chinese and western medicine therapy on intractable migraine. Hubei Journal of Tradional Chinese Medicine. 2005:28-9.
492 Taneri Z, Petersen-Braun M. Double blind study of intravenous aspirin vs placebo in the treatment of acute migraine attacks. <ORIGINAL> THERAPIE DES AKUTEN MIGRANEANFALLS MIT INTRAVENOS APPLIZIERTER ACETYLSALICYLSAURE. EINE PLAZEBOKONTROLLIERTE DOPPELBLINDSTUDIE. Schmerz. 1995:124-9. [pmid: 18415546].
493 Taneri Z, Petersen-Braun M. Double blind study of intravenous aspirin vs placebo in the treatment of acute migraine attacks. Schmerz. 1995:124-9. [pmid: 18415546].
494 Taubert K. Magnesium in migraine. Results of a multicenter pilot study. Fortschritte der Medizin. 1994:328-30. [pmid: 7959501].
495 Taylor MT. Cautions concerning botox therapy. Journal of the American Osteopathic Association. May. 2007;107(5):172-3. author reply 3–4. [pmid: 17596584].
496 Tazaki Y, Sakai F, Tashiro K, et al. Clinical Evaluation of SN-308 (Sumatriptan) Tablet on Migraine: Early Phase II Study. Rinsho Iyaku (Journal of Clinical Therapeutics and Medicines). 1997:5547-65.
497 Tazaki Y, Sakai F, Tashiro K, et al. Clinical Evaluation of SN-308 (Sumatriptan) Tablet on Migraine: Double-Blind Parallel-Group Study. Rinsho Iyaku (Journal of Clinical Therapeutics and Medicines). 1993:2147-65.
498 Tazaki Y, Sakai F, Tashiro K, et al. Clinical Evaluation of SN-308 (Sumatriptan) Tablet on Migraine: Dose Finding Study by Double-Blind Cross-Over Method. Rinsho Iyaku (Journal of Clinical Therapeutics and Medicines). 1993:1539-66.
499 Tazaki Y, Sakai F, Tashiro K, et al. Clinical Evaluation of SN-308 (Sumatriptan) Tablet on Migraine: Dose Finding Study by Double-Blind Cross-Over Method. Rinsho Iyaku (Journal of Clinical Therapeutics and Medicines). 1997:5567-94.
500 Tazaki Y, Sakai F, Tashiro K, et al. Study on Clinical Usefulness of SN-308 (Sumatriptan) Subcutaneous Injection in Migraine: Dose Finding Study by Envelope Method. Rinsho Iyaku (Journal of Clinical Therapeutics and Medicines). 1993:1077-93.
501 Temple RJ, Meyer R. Continued need for placebo in many cases, even when there is effective therapy. Archives of Internal Medicine. Feb. 10. 2003;163(3):371-3. author reply 3. [pmid: 12578526].
502 Tfelt-Hansen P. Sumatriptan nasal spray in the acute treatment of migraine: a review of clinical studies. Cephalalgia. Mar. 2000;20(2):137. [pmid: 10961773].
503 Tfelt-Hansen P. Oral triptans vs. other classes of acute migraine medication. Cephalalgia. May. 2006;26(5):628. [pmid: 16674775].
504 Tfelt-Hansen P. Gastric emptying in migraine. Headache. Jun. 2007;47(6):929. author reply -30. [pmid: 17578550].
505 Tfelt-Hansen P. Frovatriptan and data publication. Headache. Oct. 2008;48(9):1382-3. [pmid: 19006553].
506 Tfelt-Hansen P. Maximum effect of triptans in migraine? A comment. Cephalalgia. Jul. 2008;28(7):767-8. [pmid: 18547214].
507 Tfelt-Hansen P. Early responses in randomized clinical trials of triptans in acute migraine treatment. Are they clinically relevant? A comment. Headache. Jul. 2010;50(7):1198-200. [pmid: 19178578].
508 Tfelt-Hansen P, Henry P, Mulder LJ, et al. The combination of oral lysine-acetylsalicylate and metoclopramide compared with oral sumatriptan in the treatment of migraine attacks. A randomized, double-blind, placebo-controlled clinical trial. Ugeskrift for laeger. 1996:6435-9. [pmid: 8992678].
509 Tfelt-Hansen P, Olesen J. Increasing the effect of triptans in migraine. Lancet. Oct. 14. 2006;368(9544):1313-4. [pmid: 17046449].
510 Tfelt-Hansen P, Steiner T. The truth about frovatriptan. Headache. Jun. 2003;43(6):699-700. author reply 697–9. [pmid: 12786937].
511 Tfelt-Hansen PC. When to use frovatriptan in migraine?. J Headache Pain. Jun. 2011;12(3):393-4. author reply 5–6. [pmid: 21512776].
512 Tfelt-Hansen PC, Koehler PJ. History of the use of ergotamine and dihydroergotamine in migraine from 1906 and onward. Cephalalgia. Aug. 2008;28(8):877-86. [pmid: 18460007].
513 Thygesen P, Klee A, Fog M. Prophylactic treatment of migraine patients with 6-alpha-trifluoromethyl-17-alpha-acetoxyprogesterone (Demigran Leo, WG 537). Ugeskrift for laeger. 1969:144-9. [pmid: 4892187].
514 Torgovnick J. OnabotulinumtoxinA for the treatment of chronic migraine not quite there. Cephalalgia. Feb. 2011;31(3):377. author reply 8–9. [pmid: 21098110].
515 Uzar E, Kutluhan S, et al. Topiramate-induced reversible auditory hallucination. Epileptic Disorders. Sep. 2008;10(3):240. [pmid: 18833667].
516 Vale S. How migraines impact cognitive function: findings from the Baltimore ECA. Neurology. Aug. 21. 2007;69(8):810. [pmid: 17709720].
517 van de Velde K, Cras P, Helsen G. Acute chorea caused by valproate in an elderly. Acta Neurol Belg. Sep. 2011;111(3):220-1. [pmid: 22141287].
518 van den Maagdenberg AMJM, Plomp JJ. Neuromuscular synapse function in typical migraine. Cephalalgia. Mar. 2003;23(2):73-4. [pmid: 12603361].
519 Varkey BM, Varkey LM. Topiramate induced somnabulism and automatic behaviour. Indian Journal of Medical Sciences. Nov. 2003;57(11):508-10. [pmid: 14646161].
520 Vas J, Rebollo A, Perea-Milla E, et al. Study protocol for a pragmatic randomised controlled trial in general practice investigating the effectiveness of acupuncture against migraine. BMC Complement Altern Med. 2008;8:12. [pmid: 18410686].
521 Vedula SS, Bero L, Scherer RW, et al. Outcome reporting in industry-sponsored trials of gabapentin for off-label use. New England Journal of Medicine. Nov. 12. 2009;361(20):1963-71. [pmid: 19907043].
522 Victor S, Ryan SW. Drugs for preventing migraine headaches in children. Cochrane Database of Systematic Reviews. 2003;(4):CD002761. [pmid: 14583952].
523 Vitols S, Vetr A, Tomson T. It's possible to influence prescriptions patterns by producer-independent information. [Swedish]. Lakartidningen. 2004:2573-5. [pmid: 15446696].
524 Wang B. Nape Multiple Acupuncture Plus Surrounding Acupuncture for Migraine. (in Chinese). Shanghai journal of acupuncture and moxibustion. 2004:14-5.
525 Wang QM, Wang JJ, Hu J, et al. Study on the best solution of immediate analgesia of acupuncture for migraine. Zhongguo zhen jiu = Chinese acupuncture & moxibustion. 2010:798-801. [pmid: 21058472].
526 Wang S, Cai YY. The Clinical Effect of Point-through-Point Acupuncture on Migraine and the Investigation into its Mechanism. (in Chinese). Shanghai journal of acupuncture and moxibustion. 2003:18-20.
527 Wang Sa. Clinical Observation on Treatment of Migraine with Acupuncture Matching Chuanju Capsule. Journal of clinical acupuncture and moxibustion. 2002:11.
528 Wang Z, Guo ZX, Ma W. Clinical Observations on Pricking Blood Treatment of Migraine with Three-Edged Needle. Shanghai journal of acupuncture and moxibustion. 2002:11.
529 Wang ZY, Ma L, Yue CY, et al. Cold treatment for 77 cases with migraine. Chinese Journal of Physical Therapy. 1995:166-7.
530 Wasserfallen JM. Double-blind study with oxetorone in cephalalgia (author's transl). Schweizerische Rundschau für Medizin Praxis = Revue suisse de médecine Praxis. 1976:1021-4. [pmid: 794862].
531 Waters WE. A randomized controlled trial of ergotamine tartrate. Br J Prev Soc Med. Feb. 1970;24(1):65. [pmid: 4908199].
532 Watson DB, Torres-Trejo A, Gutmann L. Altitude induced migraine. W V Med J. Jan–Feb. 2011;107(1):22-3. [pmid: 21322468].
533 Wears RL. Headaches from practice guidelines. Annals of Emergency Medicine. Mar. 2002;39(3):334-7. [pmid: 11867993].
534 Weerasuriya K, Patel L, Turner P. Beta-adrenoceptor blockade and migraine. Cephalalgia. Mar. 1982;2(1):33-45. [pmid: 6126280].
535 Weinschutz TK. Acupuncture in headache therapy. [German]. Schmerz. 1996:149-55. [pmid: 12799862].
536 Weinschutz TK, Niederberger U. Relevance of acupuncture in migraine therapy. Nervenheilkunde. 1995:295-301.
537 Weinschutz TN. Zum stellenwert der akupunktur in der migranetherapie. Nervenheilkunde. 1995:295-301.
538 Welch KMA. Botulinum toxin type A for the treatment of headache: con. Headache. Sep. 2004;44(8):831-3. [pmid: 15330835].
539 Wenzel RG. A comment on acetaminophen, aspirin, and caffeine versus sumatriptan succinate in the early treatment of migraine: results from the ASSET trial. Headache. Feb. 2006;46(2):341. author reply -3. [pmid: 16492251].
540 Wilkinson F. Migraine, eating disorders, and triptans: an unrecognized risk?. Headache. Oct. 2001;41(9):914-5. [pmid: 11703486].
541 Williams P, Dowson AJ, Rapoport AM, et al. The cost effectiveness of stratified care in the management of migraine. Pharmacoeconomics. 2001;19(8):819-29. [pmid: 11596834].
542 Winett B. There is value in anecdotal reports of relief from migraine with botulinum toxin. Journal of Managed Care Pharmacy. Jan–Feb. 2009;15(1):78. author reply -9. [pmid: 19125554].
543 Worz R, Drillisch C. Migraine prevention by a calcium channel blocker. Results of a double-blind study of flunarizine vs. pizotifen. [German]. MMW Munch Med Wochenschr. 1983:711-14. [pmid: 6415411].
544 Worz R, Reinhardt-Benmalek B, Foh M, et al. Migraine prophylaxis by bisoprolol. Results of a double-blind study in comparison with metoprolol. <ORIGINAL> MIGRANEPROPHYLAXE DURCH BISOPROLOL. ERGEBNISSE EINER DOPPELBLINDSTUDIE VERSUS METOPROLOL. Fortschr Med. 1992:80-90. [pmid: 1555803].
545 Wörz R, Reinhardt-Benmalek B, Föh M, et al. Prevention of migraine using bisoprolol. Results of a double-blind study versus metoprolol. Fortschritte der Medizin. 1992:268-72. [pmid: 1351025].
546 Wu WD, Liu YL, Li YQ, et al. Lithium carbonate in the treatment of migraine. Chinese Journal of New Drugs. 1997:370-1.
547 Xu CY, et al. Analysis of the curative effect of Qi-promoting acupuncture manipulation on migraine. Shanghai Journal of Acupuncture and Moxibustion. 1993:97-103.
548 Yan XX, Bian SK, Huo JH, et al. Impulse current therapy for migraine. Chinese Journal of Physical Therapy. 1993:142.
549 Yang G. Observation of Curative Effect of 42 Cases of Migraine Treated by Points Injection. Yunnan journal of tcm and materia medica. 2000:42.
550 Ye Deba FJSYa. The Effect of Tens of Pc6 on Acute Migraine Attacked Patients'Tcd. Journal of zhejiang college of tcm. 2003:68.
551 Yetkin E, Turhan H. Is it worthwhile to test statin in migraine?. Headache. Mar. 2007;47(3):448-50. [pmid: 17371368].
552 Young WB. Cessation of hemiplegic migraine auras with greater occipital nerve blockade: a comment. Headache. Mar. 2008;48(3):481. [pmid: 18205798].
553 Yuan C, Wang JX, Yu JP, et al. A double-blind trial of 5 calcium channel blockers in prophylaxis of migraine. The Chinese Journal of Clinical Pharmacology. 1998:14-7.
554 Zgorzalewicz M. Visual evoked potentials in children and school adolescents with migraine and tension-type headache. Clinical and neurophysiological correlations. Neurologia i neurochirurgia polska. 2005:S26-35. [pmid: 16419567].
555 Zhang JT, Kuang PG, Lang SY, et al. Clinical study of the efficacy of flupenthixol/melitracen in treatment of migraine with depression and/or anxiety. Chinese Journal of New Drugs. 2001:605-7.
556 Zhang JT, Lang SY, Wu WP, et al. A randomized controlled trial: Deanxit in treatment of migraine complicated with depression and/or anxiety. Chinese Journal of Clinical Rehabilitation. 2003:2720-21.
557 Zhang Y, Wang L, Liu H, et al. The design and protocol of acupuncture for migraine prophylaxis: a multicenter randomized controlled trial. Trials. 2009;10:25. [pmid: 19389262].
558 Zhang Y, Zhang L, Li B, et al. Effects of acupuncture preventive treatment on the quality of life in patients of no-aura migraine. Zhongguo zhen jiu = Chinese acupuncture & moxibustion. 2009:431-5. [pmid: 19563186].
559 Zhong GW, Li W, Luo YH, et al. Herbs for calming liver and suppresing liver-yang in treatment of migraine with hyperactive liver-yang syndrome and its effects on lymphocyte protein expression: a randomized controlled trial. Journal of Chinese Integrative Medicine. 2009:25-33. [pmid: 19134454].
560 Zhong GW, Li W, Luo YH, et al. [Acupuncture at points of the liver and gallbladder meridians for treatment of migraine: a multi-center randomized and controlled study]. Zhongguo zhen jiu = Chinese acupuncture & moxibustion. 2009:259-63. [pmid: 19565729].
561 Zhou JW, Li J, Li N, et al. Transient analgesic effect of electroacupuncture at Taiyang (EX-HN 5) for treatment of migraine with hyperactivity of the liver-yang. Zhongguo zhen jiu = Chinese acupuncture & moxibustion. 2007:159-63. [pmid: 17432637].
562 Zhu YH, Ju LZ, Dong J. Current impulse therapy for migraine. Chinese Journal of Physical Therapy. 1992:110.
563 Zlotnik G. Ischemic stroke and active migraine. Neurology. Jul. 9. 2002;59(1):149. author reply 50. [pmid: 12105331].
564 Zwozdziak W. Treatment of migraine with migristin. Wiadomo&#347;ci lekarskie (Warsaw, Poland: 1960). 1973:1617-20.
565 Zwozdziak W. BC-105 preparation in treatment of migraine. Wiadomo&#347;ci lekarskie (Warsaw, Poland: 1960). 1973:2207-9.
566 Silberstein SD. Analyses of cost-effectiveness of migraine therapies should consider multiple measures. Journal of Managed Care Pharmacy. May–Jun. 2003;9(3):279-80. author reply 80–1. [pmid: 14613476].
567 Silberstein SD. Association between restless legs syndrome and migraine. Journal of Neurology, Neurosurgery & Psychiatry. May. 2010;81(5):473-5. [pmid: 20460586].
568 Silberstein SD. Predicting the probability of relapse after discontinuation of migraine preventive treatment with topiramate. Cephalalgia. Nov. 2010;30(11):1283. [pmid: 20921027].
569 Silberstein SD, Aoki KR. Botulinum toxin type A: myths, facts, and current research. Headache. Jul–Aug. 2003;43(Suppl 1):S1. [pmid: 12887387].
570 Silberstein SD, Marmura MJ, Shaw J, et al. Headache prophylaxis with BoNTA: patient characteristics. Headache. Jan. 2010;50(1):63-70. [pmid: 19549156].
571 Silberstein SD, Rosenberg J. Multispecialty consensus on diagnosis and treatment of headache. Neurology. Apr. 25. 2000;54(8):1553. [pmid: 10762491].
572 Smith DG. Cost-effectiveness of migraine treatment: a commentary. Value in Health. Jul–Aug. 2003;6(4):436-7. [pmid: 12859584].
573 Smith R, Schwartz A. Diltiazem prophylaxis in refractory migraine. N Engl J Med. May. 17. 1984;310(20):1327-8. [pmid: 6144044].
574 Smuts JA, Schultz D, Barnard A. Mechanism of action of botulinum toxin type A in migraine prevention: a pilot study. Headache. Sep. 2004;44(8):801-5. [pmid: 15330827].
575 Sold-Darseff J, Leydhecker W. Acupuncture for pain in the cranial region and for blepharospasm without organic cause. [German]. Klin Monatsbl Augenheilkd. 1986:167-9. [pmid: 3761996].
576 Solomon GD. Verapamil in migraine prophylaxis--a five-year review. [Review] [16 refs]. Headache. 1989:425-7. [pmid: 2668225].
577 Soyka D, Oestreich W. Flunarizine versus propranolol in migraine prophylaxis - A multicenter double-blind study in 12 hospitals. Nervenheilkunde. 1987:177-83.
578 Spierings EL. The (suma)triptan history revisited. Headache. Oct. 2000;40(9):766-7. [pmid: 11091302].
579 Spierings ELH. Triptan meta-analysis. Headache. Oct. 2002;42(9):948. [pmid: 12390627].
580 Spierings ELH, Sjaastad O. Hemicrania continua is not that rare. Neurology. Aug. 13. 2002;59(3):476-7. author reply 7. [pmid: 12177400].
581 Steiner T. Triptans vs other drugs for acute migraine. Headache. Oct. 2008;48(9):1378-9. [pmid: 18793208].
582 Steiner TJ, Cook GE, Joseph R, et al. Double-blind dose-ranging comparison of metoprolol with placebo in the prophylaxis of classical and common migraine. Cephalalgia. 1985;5:558-9.
583 Storer RJ, Goadsby PJ. Microiontophoretic application of serotonin (5HT)1B/1D agonists inhibits trigeminal cell firing in the cat. Brain. Dec. 1997;120(Pt 12):2171-7. [pmid: 9448572].