# Analytical Framework

## PICOTS Framework

### Population(s)

Adults with episodic migraine, chronic daily headache, or chronic migraine as defined by the Headache Classification Subcommittee of the International Headache Society1 (see below for definitions).

Patient characteristics that can modify the effects of pharmacological treatments for preventing migraine attacks in children and adults:

– Age
– Sex
– Pregnancy
– Hormone-based birth control and hormone replacement
– The onset of menarche and menopause
– Race and ethnicity
– Socioeconomic status
– Education
– Family history
– Access to care, type of care, and residence in rural or urban areas
– Definition of migraine
– Presence of aura
– Headache frequency
– Prior treatments; overuse of drugs for acute migraine
– Obesity
– Nutritional and dietary factors, specifically caffeine
– Aerobic fitness
– Previous head injury
– Psychological factors and social/family support system
– Comorbidities (depression, bipolar disorder, anxiety, diabetes, hypertension, cardiovascular diseases, others)
– Concomitant medications for comorbid conditions

### Interventions

Drugs approved by the FDA (such as propranolol, timolol, topiramate, and divalproex sodium) to prevent episodic migraine and to treat chronic migraine (such as Botox).

Off-label medications available in the United States and previously examined in clinical trials for preventing migraine.

Monotherapy.

Multidrug interventions.

Combined pharmacological with nonpharmacological modalities: behavioral interventions with education, exercise, biofeedback, relaxation techniques, yoga, massage, acupuncture, and dietary supplements.

### Comparators

Placebo.

Drug treatments (comparative effectiveness).

Nonpharmacological treatments: behavioral interventions with education, exercise, biofeedback, relaxation techniques, yoga, massage, acupuncture, and dietary supplements.

### Outcomes

Patient-centered outcomes:

- Reduction of migraine attacks by >50 percent from baseline; primary outcome for the review.
- Quality of life.
- Patient satisfaction.
- Composite patient centered outcomes defined as an aggregate improvement of the aforementioned outcomes.
- Emergency visits, loss of work days; treatment failure.

Intermediate outcomes:

- Number of headache days.
- Number of moderate to severe headache days.
- Improvement in associated symptoms.
- Use of drugs for acute migraine (prescribed or over-counter).
- Physician/healthcare professional (HCP) visits.

Harms:

- All reported adverse reactions and effects (such as anxiety, nausea, vomiting, sleep time reduction, drowsiness, or weakness).
- Treatment discontinuation due to adverse effects.
- Additional medical resource utilization to manage adverse effects (e.g., prescription medication, urgent care/emergency services, physician/HCP visits).

### Timing

6 months or more; optimally 12 months.

Any time of occurrence for the harms.

### Setting

Outpatient settings

## Definition of Terms

[underlined: Migraine] (as defined by the Headache Classification Subcommittee of the International Headache Society):1

[underlined: Repeate]d attacks of headache lasting 4 to 72 hours in patients with a normal physical examination, no other reasonable cause for the headache, and:

- At least two of the following features:
  – Unilateral pain
  – Throbbing pain
  – Aggravation by movement
  – Moderate or severe intensity
- Plus at least one of the following features:
  – Nausea/vomiting
  – Photophobia and phonophobia

Episodic migraine as an indication for preventive treatment:

- Five or more attacks a month2
- Three or more attacks a month2

Definitions of chronic migraine (can be chronic from onset or transformed from episodic migraine):

- FDA:
  – Chronic migraine is defined as having a history of migraine and experiencing a headache on most days of the month.3
- Revised International Headache Society criteria for chronic migraine:1
  1.5.1 Chronic migraine
    A. Headache (tension-type and/or migraine) on ≥15 days per month for at least 3 months
      ^*^ Characterization of a frequently recurring headache generally requires a headache diary to record information on pain and associated symptoms day by day for at least 1 month.
    B. Occurring in a patient who has had at least five attacks.
    C. On ≥8 days per month for at least 3 months headache has fulfilled C.1 and/or C.2 below, that is, has fulfilled criteria for pain and associated symptoms of migraine without aura.
      1. Has at least two of a–d
        a. Unilateral location
        b. Pulsating quality
        c. Moderate or severe pain intensity
        d. Aggravation by or causing avoidance of routine physical activity (e.g., walking or climbing stairs) and at least one of (1) or (2):
          1. Nausea and/or vomiting
          2. Photophobia and phonophobia
      2. Treated and relieved by triptan(s) or ergot before the expected development of C.1 above
    D. No medication overuse^†^ and not attributed to another causative disorder
      ^†^Headache Classification Committee criteria for a medication overuse headache (A8.2)1

Table 1 Pharmacological classes for migraine prevention

Drug, ATC Code^*^ | Class of Drug
ANTIEPILEPTICS
Topiramate, N03AX11 | N03 ANTIEPILEPTICS N03AX Other antiepileptics
Lamotrigine, N03AX09 | N03A ANTIEPILEPTICS
Levetiracetam, N03AX14 | N03A ANTIEPILEPTICS
Pregabalin, N03AX16 | N03A ANTIEPILEPTICS alpha2-delta agonist
Carbamazepine, N03AF01 | N03A ANTIEPILEPTICS N03AF Carboxamide derivatives
Valproic acid, N03AG01 | N03A ANTIEPILEPTICS N03AG Fatty acid derivatives, Gamma-aminobutyric acid (GABA) enhancer and analog
Vigabatrin, N03AG04 | N03A ANTIEPILEPTICS N03AG Fatty acid derivatives, GABA transaminase inhibitor
Tiagabine, N03AG06 | N03A ANTIEPILEPTICS N03AG Fatty acid derivatives, gamma aminobutyric acid (GABA) enhancer
Zonisamide, N03AX15 | N03A ANTIEPILEPTICS N03AX Other antiepileptics
Valproate | N03A ANTIEPILEPTICS N03AG Fatty acid derivatives
Divalproex | Gamma-aminobutyric acid (GABA) enhancer and analog
Gabapentin, N03AX12 | N03A ANTIEPILEPTICS
Acetazolamide, S01EC01 | S01EC, carbonic anhydrase inhibitor
ANTIDEPRESSANTS
Nortriptyline, N06AA10 | N06A ANTIDEPRESSANTS N06AA nonselective monoamine reuptake inhibitors
Clomipramine, N06AA04 | N06A ANTIDEPRESSANTS N06AA nonselective monoamine reuptake inhibitors
Citalopram, N06AB04 | N06A ANTIDEPRESSANTS N06AB selective serotonin reuptake inhibitors
Venlafaxine, N06AX16 | N06A ANTIDEPRESSANTS N06AX Other antidepressants
Amitriptyline | N06A ANTIDEPRESSANTS N06AA nonselective monoamine reuptake inhibitors
Mirtazapine, N06AX11 | N06A ANTIDEPRESSANTS tricyclic antidepressants
BETA BLOCKERS
Timolol, C07AA06 | C07AA, Beta blocking agents, nonselective
Nadolol, C07AA12 | C07AA Beta blocking agents, nonselective
Propranolol,C07AA05 | C07AA Beta blocking agents, nonselective
Metoprolol,C07AB02 | C07AB Beta blocking agents, selective
Atenolol, C07AB03 | C07AB Beta blocking agents, selective
Bisoprolol,C07AB07 | C07AB Beta blocking agents, selective
Acebutolol,C07AB04 | C07AB Beta blocking agents, selective
Alprenolol, C07AA01 | C07A BETA BLOCKING AGENTS
Oxprenolol, C07AA02 (discontinued in the FDA) | C07AA Beta blocking agents, nonselective
Pindolol, C07AA03 | C07AA Beta blocking agents, nonselective
ACE INHIBITORS
Trandolapril, C09AA10 | C09AA ACE inhibitors
Enalapril,C09AA02 | C09AA ACE inhibitors
Captopril,C09AA01 | C09AA ACE inhibitors
Lisinopril, C09AA03 | C09AA ACE inhibitors
ANGIOTENSIN II ANTAGONISTS
Telmisartan,C09CA07 | C09CA Angiotensin II antagonists
Candesartan, C09CA06 | C09CA Angiotensin II antagonists
CALCIUM CHANNEL ANTAGONIST
Dotarizine | SELECTIVE CALCIUM CHANNEL ANTAGONIST; 5-HT receptors ANTAGONIST
Flunarizine, N07CA03; Sibelium | SELECTIVE CALCIUM CHANNEL ANTAGONISTN07C ANTIVERTIGO PREPARATIONS
SELECTIVE CALCIUM CHANNEL BLOCKERS
Nimodipine,C08CA06 | C08C SELECTIVE CALCIUM CHANNEL BLOCKERS WITH MAINLY VASCULAR EFFECTS C08CA Dihydropyridine derivatives
Verapamil,C08DA01 | C08D SELECTIVE CALCIUM CHANNEL BLOCKERS WITH DIRECT CARDIAC EFFECTS C08DA Phenylalkylamine derivatives
Nicardipine,C08CA04 | C08C SELECTIVE CALCIUM CHANNEL BLOCKERS WITH MAINLY VASCULAR EFFECTS C08CA Dihydropyridine derivatives
Nifedipine,C08CA05 | C08C SELECTIVE CALCIUM CHANNEL BLOCKERS WITH MAINLY VASCULAR EFFECTS C08CA Dihydropyridine derivatives
ANTIADRENERGICS
Clonidine,C02AC01 | C02A ANTIADRENERGIC AGENTS, CENTRALLY ACTING C02AC Imidazoline receptor agonists
Labetalol, C07AG01 | C07AG, Alpha and beta blocking agents
Dixarit (clonidine, C02AC01) Guanfacine, C02AC02 | C02A ANTIADRENERGIC AGENTS, CENTRALLY ACTING C02A ANTIADRENERGIC AGENTS, CENTRALLY ACTING C02AC Imidazoline receptor agonists
ANTI-DEMENTIA
Donepezil, N06DA02 | N06 PSYCHOANALEPTICS
Memantine, N06DX01 | N06D ANTI-DEMENTIA DRUGS N-methyl-D-aspartate (NMDA) receptor inhibitor
ANTIPSYCHOTICS
Aripiprazole,N05AX12 | N05A ANTIPSYCHOTICS
Olanzapine,N05AH03 | N05A ANTIPSYCHOTICS N05AH Diazepines, oxazepines, thiazepines and oxepines
Quetiapine,N05AH04 | N05A ANTIPSYCHOTICS N05AH Diazepines, oxazepines, thiazepines and oxepines
Deanxit (Flupentixol, N05AF01) | N05A ANTIPSYCHOTICS N05AF Thioxanthene derivatives
Sulpiride, N05AL01 (antipsychotic) | N05A ANTIPSYCHOTICS N05AL Benzamides
Prochlorperazine, N05AB04 | N05A ANTIPSYCHOTICS
DOPAMINERGIC AGENTS
Amantadine, N04BB01 | N04B DOPAMINERGIC AGENTS N04BB Adamantane derivatives N-methyl-D-aspartate (NMDA) receptor inhibitor
Dihydroergocryptine, N04BC03 | N04B DOPAMINERGIC AGENTS N04BC Dopamine agonists
ERGOT ALKALOIDS
Dihydroergotamine, N02CA01 | N02C ANTIMIGRAINE PREPARATIONS N02CA Ergot alkaloids
Lisuride, N02CA07 Ergotamine, N02CA02 | N02C ANTIMIGRAINE PREPARATIONS N02C ANTIMIGRAINE PREPARATIONS N02CA Ergot alkaloids
Methysergide, N02CA04 | N02C ANTIMIGRAINE PREPARATIONS N02CA Ergot alkaloids
MUSCLE RELAXANTS
Botulinum Toxin Type A, M03AX01 | M03A MUSCLE RELAXANTS, PERIPHERALLY ACTING AGENTS M03AX Other muscle relaxants, peripherally acting agents
Tizanidine, M03BX02 | M03B MUSCLE RELAXANTS, CENTRALLY ACTING AGENTS
SYSTEMIC DRUGS
Montelukast, R03DC03 | R03D OTHER SYSTEMIC DRUGS FOR OBSTRUCTIVE AIRWAY DISEASES R03DC Leukotriene receptor antagonists

ATC code - The Anatomical Therapeutic Chemical classification

Table 2 Bayesian models summary under the noninformative prior

Fixed effect model | Random effect model (homogeneous) | Random effect model (heterogeneous) | Random effect model (inconsistency)
[underlined: Data] | [underlined: Data] | [underlined: Data] | [underlined: Data]
r_ik_ ~ Bin(n_ik_, p_ik_) | r_ik_ ~ Bin(n_ik_, p_ik_) | r_ik_ ~ Bin(n_ik_, p_ik_) | r_ik_ ~ Bin(n_ik_, p_ik_)
i = 1, …, NS; k = 1, …, NT (NS = number of study; NT = number of trt) [underlined: Model] | [underlined: Model] | [underlined: Model] | [underlined: Model]
logit(p_ik_) = μ_iB_ + Δ_Bk_ | logit(p_ik_) = μ_iB_ + δ_iBk_ | logit(p_ik_) = μ_iB_ + δ_iBk_ | logit(p_ik_) = μ_iB_ + δ_iBk_
where B is for the baseline treatment, μ_iB_ is the log odds of the baseline treatment and Δ_Bk_ is the fixed effect of the k^th^ drug versus the baseline treatment defined by d_k_ − d_B_ with the fixed effect of the k^th^ drug versus placebo, d_k_ (d_B_ = 0) [underlined: Prior] | where δ_iBk_ is the random effect of the k^th^ drug versus the baseline treatment in the i^th^ study [underlined: Prior] | where δ_iBk_ is the random effect of the k^th^ drug versus the baseline treatment in the i^th^ study [underlined: Prior] | where δ_ik_ is the random effect of the k^th^ drug versus the placebo in the i^th^ study
| where δ_iBk_ is the random effect of the k^th^ drug versus the baseline treatment in the i^th^ study [underlined: Prior] | where δ_iBk_ is the random effect of the k^th^ drug versus the baseline treatment in the i^th^ study [underlined: Prior] | 1. d_BC_ = d_AC_ − d_AB_ + w_ABC_
| where δ_iBk_ is the random effect of the k^th^ drug versus the baseline treatment in the i^th^ study [underlined: Prior] | where δ_iBk_ is the random effect of the k^th^ drug versus the baseline treatment in the i^th^ study [underlined: Prior] | w_ABC_ is the amount of inconsistency between direct and indirect comparisons [underlined: Prior]
d_k_ ~ N(0, 10000) μ_iB_ ~ N(0, 10000) | δ_iBk_ ~ N(d_k_ − d_B_, σ^2^) d_k_ ~ N(0, 10000) μ_iB_ ~ N(0, 10000) σ ~Unif(0.01,2) | δ_iBk_ ~ N(d_k_ − d_B_, σ_Bk_^2^) d_k_ ~ N(0, 10000) μ_iB_ ~ N(0, 10000) logσ_xy_ = logσ_0_ + ν_xy_ σ_0_ ~Unif(0.01,2) ν_xy_ ~ N(0, ψ^2^) | δ_iBk_ ~ N(d_k_ − d_B_, σ^2^) d_k_ ~ N(0, 10000) μ_iB_ ~ N(0, 10000) w_ABC_ ~ N(0, σ_w_^2^) σ, σ_w_ ~Unif(0.01,2)
[Example] Study 1: Drugs 1 vs. 2 vs. 3 trial (drug 1 is the baseline treatment)
Fixed effect model | Random effect model (homogeneous) | Random effect model (heterogeneous) | Random effect model (inconsistency)
[underlined: Data] | [underlined: Model] | [underlined: Model] | Study 1: 1 vs. 2 vs. 3 trial
r_11_ ~ Bin(n_11_, p_11_) r_12_ ~ Bin(n_12_, p_12_) r_13_ ~ Bin(n_13_, p_13_) | 5. logit(p_11_) = μ_11_ 6. logit(p_12_) = μ_11_ + δ_12_ 7. logit(p_13_) = μ_11_ + δ_13_ | 8. logit(p_11_) = μ_11_ 9. logit(p_12_) = μ_11_ + δ_12_ 10. logit(p_13_) = μ_11_ + δ_13_ | 11. Study 2: 1 vs. 2 12. Study 3: 1 vs. 3
[underlined: Model] | [underlined: Prior (assume ρ=0.5)] | [underlined: Prior (assume ρ=0.5)] | → We can estimate w_123_ because the data permit estimation via the equation; d_23_ = d_13_ − d_13_ + w_123_
2. logit(p_11_) = μ_11_ 3. logit(p_12_) = μ_11_+ d_2_ 4. logit(p_13_) = μ_11_+ d_3_ | ( δ_12_ δ_13_ ) ~ M V N ( ( d_2_ d_3_ ) , σ^2^ ( 1 0.5 0.5 1 ) ) → δ_12_ ~ N ( d_2_ , σ^2^ ) → δ_13_ ∣ δ_12_ ~ N ( d_3_ + (1)/(2) ( δ_12_ - d_2_ ) , (3)/(4) σ^2^ ) | ( δ_12_ δ_13_ ) ~ M V N ( ( d_2_ d_3_ ) , ( σ_11_^2^ 0.5 σ_12_ 0.5 σ_12_ σ_22_^2^ ) ) → δ_12_ ~ N ( d_2_ , σ_1_^2^ ) → δ_13_ ∣ δ_12_ ~ N ( d_3_ + (1)/(2) ( δ_12_ - d_2_ ) , (3)/(4) σ_2_^2^ ) | Model and priors are similarly defined as in Model2. Additional prior is
[underlined: Prior] | d_2_, d_3_ ~ N(0, 10000) μ_11_ ~ N(0, 10000) σ ~Unif(0.01,2) | d_2_, d_3_ ~ N(0, 10000) μ_11_ ~ N(0, 10000) logσ_11_ = logσ_0_ + ν_11_ logσ_12_ = logσ_0_ + ν_12_ logσ_22_ = logσ_0_ + ν_22_ σ_0_ ~ Unif(0.01,2) ν_11_, ν_12_, ν_22_ ~ Unif(0.01, ψ^2^) | w_123_ ~ N(0, σ_w_^2^) σ_w_ ~ Unif(0.01,2)
d_2_, d_3_ ~ N(0, 10000) μ_11_ ~ N(0, 10000)

Table 3 Winbug Code for Bayesian network meta analysis

## References

1 Olesen J, Bousser MG, Diener HC, et al. New appendix criteria open for a broader concept of chronic migraine. Cephalalgia. Jun. 2006;26(6):742-6. [pmid: 16686915].
2 Goadsby PJ, Raskin NH. Chapter 15 Headache. Fauci AS, Braunwald E, Kasper DL, Hauser SL, Longo DL, Jameson JL, et al., editors. Harrison’s principles of internal medicine. 17th ed. New York. The McGraw-Hill Companies. 2008.
3 Administration USFaD. FDA News Release: FDA approves Botox to treat chronic migraine. http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm229782.htm. Accessed on February 1 2011.