# Literature Search

January, 2011 PubMed

# | Strings | N
8 | Search “Migraine Disorders”[Mesh] AND “Migraine Disorders”[Mesh] Limits: Humans, Meta-Analysis, English | 97
7 | Search “Migraine Disorders”[Mesh] AND “Migraine Disorders”[Mesh] Limits: Humans, Randomized Controlled Trial, English | 907

# | Strings | N
71 | Search migraine NOT acute Limits: Humans, Randomized Controlled Trial, English | 655
70 | Search migraine Limits: Humans, Randomized Controlled Trial, English | 1040
66 | Search melatonin AND migraine | 55
67 | Search melatonin AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 7
64 | Search “Brain-Derived Neurotrophic Factor”[Mesh] AND migraine | 6
63 | Search “Brain-Derived Neurotrophic Factor”[Mesh] AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 1
62 | Search “Brain-Derived Neurotrophic Factor”[Mesh] Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 94
58 | Search Risperidone AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
57 | Search Paliperidone AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
56 | Search Methiothepin AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
55 | Search Metergoline AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
53 | Search Lisuride AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 5
51 | Search Bromocriptine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 4
50 | Search Zotepine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
49 | Search Ziprasidone AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
48 | Search Trifluoperazine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
47 | Search Tenilapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
46 | Search Sulpiride AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 1
45 | Search Spiperone AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
44 | Search Sertindole AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
43 | Search Olanzapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
42 | Search Loxapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
41 | Search Ketanserin AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
40 | Search Imipramine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
39 | Search Fluperlapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
38 | Search Fluphenazine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
36 | Search Cyproheptadine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 9
35 | Search Clozapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
33 | Search Clomipramine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 2
32 | Search Aripiprazole AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
31 | Search Amoxapine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
29 | Search Amitriptyline AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 34
28 | Search Amitriptyline AND migraine Limits: Humans, English | 150
27 | Search 5-HT7 AND migraine Limits: Humans, English | 12
24 | Search 5-HT7 Limits: Humans, English | 150
13 | Search Quetiapine AND migraine Limits: Humans, English | 5
21 | Search “Antipsychotic Agents “[Pharmacological Action] AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 41
20 | Search “Antipsychotic Agents “[Pharmacological Action] AND migraine Limits: Humans, English | 206
19 | Search “Antipsychotic Agents “[Pharmacological Action] Limits: Humans, English | 51308
11 | Search 5-HT2A AND migraine Limits: Humans, English | 14
10 | Search 5-HT2A antagonists AND migraine Limits: Humans, English | 3
7 | Search 5-HT2A antagonists Limits: Humans, English | 394
5 | Search Alpha-2 agonists AND migraine Limits: Humans, English | 6
4 | Search Alpha-2 agonists AND migraine | 17

84 | Search telcagepant AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 4
83 | Search olcegepant AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
82 | Search Arachidonic cascade modulators Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
80 | Search tonabersat) AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 6
79 | Search dextromethorphan AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
78 | Search dextromethorphan AND migraine NOT acute Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
77 | Search loxapine AND migraine NOT acute Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 0
76 | Search prochlorperazine AND migraine NOT acute Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 8
75 | Search prochlorperazine AND migraine Limits: Humans, Clinical Trial, Randomized Controlled Trial, English | 20

August, 2011

# | Strings | N
15 | Search Phenelzine AND migraine Limits: Humans, Journal Article, English | 11
14 | Search Bupropion AND migraine Limits: Humans, Journal Article, English | 1
13 | Search Imipramine AND migraine Limits: Humans, Journal Article, English | 15
12 | Search Imipramine AND headache Limits: Humans, Journal Article, English | 60
11 | Search Doxepin AND headache Limits: Humans, Journal Article, English | 15
9 | Search Desipramine AND headache Limits: Humans, Journal Article, English | 13
10 | Search Desipramine AND migraine Limits: Humans, Journal Article, English | 1
7 | Search Protriptyline AND headache Limits: Humans, Journal Article, English | 4
6 | Search Protriptyline AND migraine Limits: Humans, Journal Article, English | 0

Updated search in Ovid; 1948 to November Week 3 2011

# | Searches | Results
1 | exp migraine disorders/dt | 5944
2 | exp migraine disorders/pc | 1669
3 | ad.fs. | 998247
4 | 2 and 3 | 286
5 | 1 or 4 | 6112
6 | 1 or 2 | 7065
7 | exp “off-label use”/ | 519
8 | off label.mp. | 2412
9 | 7 or 8 | 2412
10 | 6 and 9 | 14
11 | exp calcium channel blockers/ | 68976
12 | exp antihypertensive agents/ | 216956
13 | exp antidepressive agents/ | 113058
14 | exp anticonvulsants/ | 111349
15 | exp botulinum toxin type a/ | 4832
16 | exp alzheimer disease/dt | 8107
17 | 11 or 12 or 13 or 14 or 15 or 16 | 476372
18 | 6 and 17 | 1675
19 | 5 or 10 or 18 | 6489
20 | limit 19 to (humans and yr=“2000 -Current”) | 3195
21 | limit 20 to updaterange=“mesz(20111121020154–20111121091315]” | 0

Ovid MEDLINE(R) 1946 to December Week 4 2011

# | Searches | Results
1 | exp migraine disorders/dt | 5882
2 | exp migraine disorders/pc | 1659
3 | ad.fs. | 975844
4 | 2 and 3 | 284
5 | 1 or 4 | 6048
6 | 1 or 2 | 6996
7 | exp “off-label use”/ | 510
8 | off label.mp. | 2358
9 | 7 or 8 | 2358
10 | 6 and 9 | 13
11 | exp calcium channel blockers/ | 67571
12 | exp antihypertensive agents/ | 1420023
13 | exp antidepressive agents/ | 110836
14 | exp anticonvulsants/ | 1012405
15 | exp botulinum toxin type a/ | 4648
16 | exp alzheimer disease/dt | 7829
17 | 11 or 12 or 13 or 14 or 15 or 16 | 2510533
18 | 6 and 17 | 1831
19 | 5 or 10 or 18 | 6431

Database(s): Ovid MEDLINE(R) 1946 to May Week 2 2012 Search Strategy:

# | Searches | Results
1 | drug management.mp. | 467
2 | exp patient care team/ | 49789
3 | exp delivery of health care, integrated/ | 7185
4 | integrated care.mp. | 1087
5 | exp managed care programs/ | 38113
6 | (managed care or coordinated care).mp. | 28360
7 | exp Patient Education as Topic/ | 64554
8 | exp Health Education/ | 125606
9 | drug surveillance.mp. | 432
10 | exp drug monitoring/ | 12104
11 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 | 231287
12 | exp patient compliance/ | 46268
13 | exp patient satisfaction/ | 52327
14 | exp patient care management/ | 475066
15 | 12 or 13 or 14 | 555310
16 | exp migraine disorders/dt | 5965
17 | 11 and 16 | 111
18 | 15 and 16 | 360

Ovid Technologies, Inc.
- Search for: limit 19 to (humans and yr=“2000 -Current”)
  Results: 100

Database: Ovid MEDLINE(R) <1946 to May Week 2 2012> Search Strategy:
1. exp migraine disorders/dt (5965)
2. exp migraine disorders/pc (1692)
3. ad.fs. (1002489)
4. 2 and 3 (291)
5. 1 or 4 (6136)
6. 1 or 2 (7101)
7. exp “off-label use”/(628)
8. off label.mp. (2572)
9. 7 or 8 (2572)
10. 6 and 9 (14)
11. exp calcium channel blockers/(68722)
12. exp antihypertensive agents/(217035)
13. exp antidepressive agents/(113333)
14. exp anticonvulsants/(112028)
15. exp botulinum toxin type a/(4853)
16. exp alzheimer disease/dt (8211)
17. 11 or 12 or 13 or 14 or 15 or 16 (477138)
18. 6 and 17 (1689)
19. 5 or 10 or 18 (6514)
20. limit 19 to (humans and yr=“2000 -Current”) (3226)

Scientific Information Package requests and responses

Company Name | Date Responded
Abbott Laboratories | No response
Alexza Pharmaceuticals, Inc. | No response
Allergan, Inc. | No response
Almirall, S.A. | No response
AstraZeneca Pharmaceuticals, LP | No response
Beth Israel Deaconess Medical Center | No response
Boston Scientific | No response
BTG International, Ltd. | No response
Capnia, Inc. | No response
Centre Hospitalier Universitaire de Saint Etienne | No response
Cephalon, Inc | No response
Chengdu University of Traditional Chinese Medicine | No response
Clinvest | No response
CoLucid Pharmaceuticals, Inc. | No response
D-Pharm Ltd. | No response
Eisai Inc. | No response
Eli Lilly & Co | No response
Endo Pharmaceuticals | No response
eNeura | No response
Eurohead | No response
GlaxoSmithKline | Submitted
HaEmek Medical Center | No response
Ipsen Biopharm, Ltd | No response
Janssen Cilag Pharmaceutica S.A.C.I. | No response
Janssen EMEA | No response
Janssen Pharmaceutica NV | Submitted
Janssen-Ortho, Inc. | No response
Johnson & Johnson Pharmaceutical Research & Development, L.L.C. | No response
Kowa Pharmaceuticals America | No response
Lotus Pharmaceuticals, Inc. | No response
Luitpold Pharmaceuticals, Inc. | No response
Manhattan Pharmaceuticals, Inc. | No response
MAP Pharmaceuticals, Inc. | No response
Medtronic, Inc. | No response
Merck & Co., Inc. | Submitted
Nektar | Nothing to submit 11/16/2011
NeurAxon | No response
Nordlandssykehuset HF | No response
Novartis Pharmaceuticals Corporation | No response
NPS Pharmaceuticals | No response
Ortho-McNeil Janssen Scientific Affairs, LLC | No response
Ortho-McNeil Neurologics | No response
Ortho-McNeil-Janssen Pharmaceuticals, Inc | No response
Pfizer Inc | No response
Pozen | No response
PriCara® (Division of Ortho-McNeil-Janssen Pharmaceuticals, Inc.) | No response
Raptor Pharmaceutical Corp. | No response
Roxane Laboratories | No response
SK Chemicals | No response
Sorlandet Hospital HF | No response
Takeda Global Research & Development Center, Inc. | No response
Takeda Pharmaceuticals North America, Inc. | No response
The EMMES Corporation | No response
UCB, Inc. | No response
Valeant Pharmaceuticals International | No response
Zogenix | No response