# Results

## Literature Search

Of the 8409 records identified through the literature search, we limited screening to those references that contained the terms “screen* OR surveil*” in title or abstract. Of the 5279 references that did not contain the key textwords, none met eligibility criteria. Of the remaining 3130 records, 3082 were excluded at various stages of screening and 48 records were included. Of these 48 studies, 16 studies attempted to control for confounding and/or secular trends (CCS studies) and 32 studies did not attempt to control for confounding and/or secular trends (non-CCS studies). The PRISMA diagram (Figure 3) depicts the flow of search screening and study selection.

Figure 3 PRISMA diagram for identified published literature

CCS = studies controlling for confounding and/or secular trend; non-CCS = studies not controlling for confounding and/or secular trend

Figure 3 is a PRISMA diagram illustrating the review of articles identified via literature search for this systematic review. 7945 records were identified through the literature search. 5279 were excluded by limited title and abstract screening by key words. Of the 2,666 remaining records, 1,630 were excluded at various stages of screening and 48 records were included.

## Grey Literature Search

We evaluated the results of the grey literature search with results summarized in Figure 4.

- Regulatory information: The search yielded 49 studies from the 510(k) summaries obtained for MRSA; the assays included Xpert MRSA SA/SSTI, XPert MRSA SA/BC, XPert MRSA, GeneOhm MRSA assay and BBL ChromAgar MRSA. All 49 citations were excluded—28 were duplicates and 21 met one or more exclusion criterion. No new studies were identified from this source.
- Clinical trial registries: Citations for published articles linked to trials registered at ClinicalTrials.gov were included. The search yielded 168 clinical trials, of which, 167 were excluded during the title and abstract screen—86 were duplicate (literature citations already included in the reference database) and 81 met one or more exclusion criterion (e.g., did not compare MRSA screening versus an alternative or noncomparative trial). One reference was reviewed in full-text and was excluded according to the study protocol.
- Abstracts and conference papers: The search yielded 1,113 citations, of which, 1085 were excluded during the title and abstract screen—22 references were duplicate and 1063 met one or more exclusion criterion. Twenty-eight references were reviewed by a third team member in full-text and all were excluded according to the study protocol.
- Grants and federally funded research: The search yielded 15 citations and all 15 were excluded—3 were duplicates and 13 met one or more exclusion criterion.
- Manufacturer database: In response to requests, scientific information packets were received from CEPHEID. The submissions consisted of descriptive text supported by 15 citations. No abstracts or unpublished data were provided by the company. Of the 15 references, 13 were excluded during abstract and title screen—9 were duplicate and 4 met one or more exclusion criterion. The remaining two references were evidence reports—one from the Canadian Agency for Drugs and Technologies in Health (CADTH) and one from ECRI Institute. Further, the CADTH report was cross-referenced to another relevant CADTH report and hence was included in the full-text review. The full-text review of these three evidence reports yielded 80 references. Of these, all 80 were excluded—48 were duplicates and 32 met one or more exclusion criterion.

Figure 4 PRISMA diagram for identified grey literature

ACP = American College of Physicians; AHRQ = Agency for Healthcare Research and Policy; APIC = Association of Professionals in Infection Control and Epidemiology; ASID = Australasian Society of Infectious Diseases; CSA = http://www.csa.com; ESCMID = European Society of Clinical Microbiology and Infectious Diseases; ESICM = European Society of Intensive Care Medicine; FDA = Food and Drug Administration; GOLD = Grants On-Line Database; HSRPROJ = Health Services Research Projects in Progress; ICAAC = Interscience Conference on Antimicrobial Agents and Chemotherapy; IDSA = Infectious Disease Society of America; ISF = International Sepsis Forum; ISID = International Society of Infectious Diseases; PIDS = Pediatric Infectious Diseases Society; RePORTER = Research Portfolio Online Reporting Tools; SHEA = Society for Healthcare Epidemiology of America; WHO = World Health Organization

Figure 4 is a PRISMA diagram illustrating the review of articles identified via grey literature search for this systematic review. For regulatory information, the U.S. Food and Drug Administration (FDA) website was searched for 510(k) summaries for commercially FDA approved diagnostic test for MRSA that Xpert MRSA SA/SSTI, XPert MRSA SA/BC, XPert MRSA, GeneOhm MRSA assay and BBL ChromAgar MRSA. The search of these documents yielded 49 studies. Citations in the summary documents were screened against the main bibliographic databases. No new studies were identified from this source. Four clinical trial registries were searched. These were clinicaltrials.gov, current controlled trials, clinical study results and WHO clinical trials. This search yielded 168 clinical trials. Of these, 85 studies were duplicate and 81 met one or more exclusion criterion and therefore these 166 references were excluded. Remaining 1 article was excluded after a full text review. Thirteen sources for conference abstracts and papers were searched for the grey literature. They were conference papers index or CSA, Scopus, annual meetings of Interscience Conference on Antimicrobial Agents and Chemotherapy or ICAAC, the Infectious Disease Society of America or IDSA, the Society for Healthcare Epidemiology of America or SHEA, the Association of Professionals in Infection Control and Epidemiology or APIC, the American College of Physicians or ACP, the Pediatric Infectious Diseases Society or PIDS, the European Society of Clinical Microbiology and Infectious Diseases or ESCMID, the International Society of Infectious Diseases or ISID, the Australasian Society of Infectious Diseases or ASID, the International Sepsis Forum or ISF, the European Society of Intensive Care Medicine or ESICM. The search of these sources yielded 1113 citations. Of these, 20 references were duplicate and 1061 studies met one or more exclusion criterion and therefore these 1081 references were excluded. Remaining 32 references were then reviewed in full-text and all were excluded according to the study protocol. Three sources for grants and federally funded research were searched. The first was NIH RePORTER, which is a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions. The second was HSRPROJ, which is a database providing access to ongoing grants and contracts in health services research. The third was AHRQ GOLD, which is an online searchable database of AHRQ grants, working papers and HHS recovery act projects. The search of all 3 databases yielded 15 citations and all were excluded- 3 were duplicate and 13 met one or more exclusion criterion. For identifying grey literature in the manufacturer database, the scientific information packet or SIPs was reviewed. The SIPs supplied by CEPHEID contained 15 citations. Of these 9 were duplicate and 6 met one or more exclusion criterion and therefore all 15 references were excluded. Among those excluded, 2 references were evidence reports- 1 from Canadian Agency for Drugs and Technologies in Health (CADTH) and 1 from ECRI Institute. Further, the CADTH report was cross-referenced to another relevant CADTH report and hence was included in for the review. The full-text review of these 3 evidence reports yielded 80 references. Of these 80 were excluded- 48 were duplicate and 32 met one or more exclusion criterion. Remaining one study was included for full text review. Overall, the grey literature search resulted in no new relevant references to inform this review.

## Overview of Studies Included in the Present Review

Overall, 48 studies were abstracted for this review. They are summarized in Table 4. Three studies30,41,42 evaluated universal screening for MRSA carriage compared to no screening (Key Question 1), two studies30,43 evaluated universal screening for MRSA carriage compared to screening of selected patient populations (targeted screening) (Key Question 2), 14 studies29,30,44–55 evaluated screening for MRSA carriage in ICU patients compared to no screening (Key Question 3A), 18 studies31,55–69,74,81 evaluated screening for MRSA carriage in surgical patients compared to no screening (Key Question 3B), eight studies70–77 evaluated screening for MRSA carriage in high-risk populations compared to no screening (Key Question 3C), and 10 studies56,72,78–85 evaluated screening of limited populations for MRSA carriage compared to screening of expanded populations (Key Question 4).

Table 4 Overview of abstracted studies

A. CCS, Good Quality, used in SOE synthesis
Author, Year | Design | KQ1 | KQ2 | KQ3A | KQ3B | KQ3C | KQ4 | HCA Acq | HCA Inf | HCA Site Inf | HCA /Imp Acq | HCA/ Imp Inf | HCA/ Imp Site Inf
Harbarth, et al., 2008^31^ | QEX-CG, X-OVER | | | | • | | | • | • | •
Huskins, et al., 2011^46^ | RCT | | | • | | | | •
Leonhardt, et al., 2011^43^ | QEX-CG | | • | | | | | | •
Robicsek, et al., 2008^30^ | QEX-BA | • | • | • | | | | | • | •

B. CCS, Fair quality, not used in SOE synthesis
Author, Year | Design | KQ1 | KQ2 | KQ3A | KQ3B | KQ3C | KQ4 | HCA Acq | HCA Inf | HCA Site Inf | HCA /Imp Acq | HCA/ Imp Inf | HCA/ Imp Site Inf
Gould, et al., 2007^44^ | QEX-ITS | | | • | | | | | | | •

C. CCS, Poor quality, used in SOE synthesis
Author, Year | Design | KQ1 | KQ2 | KQ3A | KQ3B | KQ3C | KQ4 | HCA Acq | HCA Inf | HCA Site Inf | HCA /Imp Acq | HCA/ Imp Inf | HCA/ Imp Site Inf
Chaberny, et al., 2008^78^ | QEX-BA | | | | | | • | | • | | •
Chowers, et al., 2009^70^ | QEX-ITS | | | | | • | | | | •
Ellingson, et al., 2011^56^ | QEX-ITS | | | | • | | | • | | •
Harbarth, et al., 2000^71^ | QEX-BA | | | | | • | | | • | •
Holzmann-Pazgal, et al., 2011^45^ | QEX-BA | | | • | | | | •
Huang, et al., 2006^29^ | QEX-ITS | | | • | | | | • | | •
Jain, et al., 2011^41^ | QEX-BA | • | | | | | | • | • | •
Muder, et al.,2008^55^ | QEX-BA | | | • | • | | | | •
Raineri, et al., 2007^47^ | QEX-BA | | | • | | | | •
Rodriguez-Bano, et al.,2010^72^ | QEX-ITS | | | | | • | • | • | | •

D. CCS, Poor quality, not used in SOE synthesis
Author, Year | Design | KQ1 | KQ2 | KQ3A | KQ3B | KQ3C | KQ4 | HCA Acq | HCA Inf | HCA Site Inf | HCA /Imp Acq | HCA/ Imp Inf | HCA/ Imp Site Inf
Reilly, et al., 2012^42^ | QEX-BA | • | | | | | | | | | | •

E. Non-CCS, not used in SOE synthesis
Author, Year | Design | KQ1 | KQ2 | KQ3A | KQ3B | KQ3C | KQ4 | HCA Acq | HCA Inf | HCA Site Inf | HCA /Imp Acq | HCA/ Imp Inf | HCA/ Imp Site Inf
Blumberg and Klugman, 1994^48^ | QEX-BA | | | • | | | | | | | | | •
Bowler, et al., 2010^73^ | QEX-BA | | | | | • | | | •
Boyce, et al., 2004^49^ | QEX-BA | | | • | | | | | •
Clancy, et al., 2006^50^ | QEX-BA | | | • | | | | | •
Chen, et al., 2012^69^ | QEX-BA | | | | • | | | | | •
de la Cal, et al., 2004^51^ | QEX-BA | | | • | | | | • | | •
Enoch, et al., 2011^85^ | QEX-BA | | | | | | • | | | | •
Eveillard, et al., 2006^79^ | QEX-BA | | | | | | • | •
Girou, et al., 2000^80^ | QEX-BA | | | | | | • | •
Jog, et al., 2008^58^ | QEX-BA | | | | • | | | | | •
Kelly, et al., 2012^68^ | QEX-BA | | | | • | | | | | | | •
Keshtgar, et al., 2008^74^ | QEX-BA | | | | | • | | | | •
Kim DH, et al., 2010^59^ | QEX-BA | | | | • | | | | | •
Kurup, et al., 2010^52^ | QEX-BA | | | • | | | | | •
Lipke and Hyott 2010^60^ | QEX-BA | | | | • | | | | | •
Malde, et al., 2006^61^ | QEX-BA | | | | • | | | | | •
Nixon, et al., 2006^62^ | QEX-BA | | | | • | | | | | •
Pan, et al., 2005^75^ | QEX-BA | | | | | • | | | | •
Pofahl, et al., 2009^63^ | QEX-BA | | | | • | | | | | •
Salaripour, et al.,2006^76^ | QEX-BA | | | | | • | | •
Sankar, et al., 2005^57^ | QEX-BA | | | | • | | | | •
Schelenz, et al., 2005^81^ | QEX-BA | | | | | | • | •
Simmons 2011^53^ | QEX-BA | | | • | | | | | •
Sott, et al., 2001^64^ | QEX-BA | | | | • | | | | | •
Souweine, et al., 2000^54^ | QEX-BA | | | • | | | | | | | •
Supriya, et al., 2009^65^ | QEX-BA | | | | • | | | | | •
Thomas, et al., 2007^66^ | QEX-BA | | | | • | | | | | •
Thompson, et al., 2009^82^ | QEX-BA | | | | | | • | • | | •
Trautmann, et al., 2007^83^ | QEX-BA | | | | | | • | • | | •
Walsh, et al., 2011^67^ | QEX-BA | | | | • | | | | | •
Wernitz, et al., 2005^77^ | QEX-BA | | | | | • | | | • | •
West, et al., 2006^84^ | QEX-BA | | | | | | • | | •

Acq = acquisition; BA= before after; CCS = attempted to control for confounding and/or secular trends; CG = control group; HCA = healthcare-associated; Imp = imported; Inf = infection; ITS = interrupted time series; KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus; QEX = quasi-experimental; RCT = randomized controlled trial; SOE = strength of evidence; X-over = cross over

Of the 48 studies abstracted for this review, 16 were CCS studies.29–31,41–47,55,56,70–72,78 Controlling for secular trends is important because the incidence of MRSA infection has been decreasing in recent years. Therefore, studies that do not adequately control for secular trends may show a decrease in the incidence of MRSA infection with screening, though that decrease may actually be attributable to a secular trend. Similarly, interventions designed to decrease healthcare-associated infection more generally (e.g., interventions to reduce SSIs or catheter-associated bloodstream infections) may also reduce MRSA infection. Studies that fail to control for these confounders may show a decrease in the incidence of MRSA infection with screening, though that decrease may actually be attributable to a confounder, rather than to screening. As a result, only the studies that adequately controlled for confounders and/or secular trends had the potential to support causal inferences about the impact of MRSA screening on health outcomes. Therefore, only these studies had the potential to be included in the SOE syntheses. The remaining 32 non-CCS studies performed simple two-group statistical analyses which cannot support causal inferences; the non-CCS studies were, therefore, excluded from the SOE syntheses.

The quality of the CCS studies was subsequently rated as good, fair, or poor. Studies that reported baseline group characteristics, considered and analyzed at least one healthcare-associated outcome, and conducted appropriate analysis (tested for trend, addressed autocorrelation, and included at least one confounder in the analysis) were rated “good.” Studies that met the criteria for good quality except that they did not report a healthcare-associated outcome were rated “fair.” Studies that failed to report baseline group characteristics and/or to conduct appropriate analysis were rated “poor.”

Of the 16 CCS studies, 14^29–31,41,43,45–47,55,56,70–72,78^ reported on a healthcare-associated outcome. Because screening for MRSA carriage in the hospital or ambulatory settings is most proximately expected to affect healthcare-associated MRSA acquisition, infection, morbidity and mortality, health-care associated outcomes are the outcomes of interest. The 14 studies29–31,41,43,45–47,55,56,70–72,78 that reported a healthcare-associated outcome were included in the SOE analysis across all four Key Questions. Two of the CCS studies42,44 did not report an outcome that was exclusively health care-associated and therefore, were excluded from the SOE analysis.

For each Key Question, the results chapter is organized as follows: overview of the literature, results of CCS studies, results of non-CCS studies, SOE assessment and comments on pattern of results for non-CCS studies.

## Key Question 1 Universal Screening for MRSA Carriage Compared With No Screening

### Overview

This section describes the literature that evaluates universal screening for MRSA carriage compared with no screening. After an overview of the literature, the results are described for each outcome: MRSA acquisition, MRSA infection, morbidity, mortality, harms, and resource utilization. The emphasis in this chapter is on outcomes describing healthcare-associated events. Healthcare-associated outcomes are the primary outcomes of interest because screening for MRSA carriage in health care facilities is most proximately expected to impact healthcare-associated MRSA transmission and infection. The study that did not report healthcare-associated outcomes is discussed in the results section below. However, because this study did not report a healthcare-associated outcome, it did not contribute to the SOE analysis. The outcome data from this study is presented in Appendix F. Table 5 summarizes the studies reviewed for Key Question 1 that presented healthcare-associated outcomes.

Table 5 KQ1: Healthcare-associated MRSA acquisition and infection

Outcome | Study | Quality | Statistical Result | Synthesis
HCA acquisition | Jain et al., 2011^41^ | Poor | SS ↓ | SOE = insufficient
HCA infection | Robicsek et al., 2008^30^ | Good | SS ↓ | SOE = low
HCA infection | Jain et al., 2011^41^ | Poor | SS ↓ | SOE = low

HCA = healthcare-associated; KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus; SOE = strength of evidence; SS = statistically significant

Three CCS studies30,41,42 compared universal screening for MRSA carriage to no screening. All three studies used quasi-experimental study designs. Table 6 displays key elements in rating of study quality. Only the Robicsek study30 reported baseline characteristics and met the required elements for appropriate analysis of results; it was judged to be of good quality. The Jain study41 was judged to be of poor quality as it had limitations in the reporting of baseline characteristics and analysis of results. Although Jain41 reported baseline characteristics for the intervention period, baseline data from the control period were not reported, precluding comparison between periods. Appropriate analysis was not accomplished because no adjustment for confounders was reported. The Reilly study42 was judged to be of poor quality because it did not report any baseline group characteristics and did not meet any of the elements required for appropriate analysis of results. Another concern with the Reilly study42 is that it did not report whether its infection outcome was exclusively health care-associated. As a result, community-acquired cases may have been included.

Table 6 KQ1: Study quality details for CCS studies

Author, Year | Reported Baseline Characteristics | Analytic Technique | Test for Trend (1) | Addressed Auto-Correlation (2) | Adjusted for at Least 1 Confounder (3) | Appropriate Analysis of Results^*^ | Quality
Robicsek et al., 2008^30^ | Sex, ethnicity, long term care residence, history hospital admission, admission-discontinuation details, medical condition | segmented Poisson regression, D-W test | Y | Tested for | Y (admitting hospital) | Y | Good
Jain et al., 2011^41^ | Reported for intervention period but not control period | Poisson regression, D-W test | Y | Tested for | NR | N | Poor
Reilly et al., 2012^42^ | NR | Poisson regression, before vs. after introduction of MRSA screening | NR | NR | NR | N | Poor

CCS = attempted to control for confounding and/or secular trends; D-W = Durbin-Watson test for autocorrelation; KQ = Key question; MRSA = methicillin-resistant Staphylococcus aureus; N = no; NR= not reported; Y = yes

* The study was judged to meet appropriate analysis if all 3 elements (1, 2, 3) were present.

All three studies were conducted in multihospital organizations of acute care hospitals. The Jain study41 occurred in Veterans Affairs hospitals, the Robicsek study30 occurred in academic and community hospitals and the Reilly study42 occurred in acute hospitals including a tertiary referral hospital, district general hospital and island hospital. All three studies had a large number of subjects. The Robicsek study30 specified the sample size for the intervention group (n=73,464) and for the control group (39,521). The Jain study41 specified the sample size for the intervention group (n=1,934,598), but not for the control group, as did the Reilly study42 (intervention group n=81,438, control group n=unspecified).

For two of the studies30,41, the interventions included at least one intervention in addition to universal screening for MRSA carriage. For the Robicsek study,30 the intervention was nasal surveillance for MRSA colonization on the first day of hospitalization for all patients, as well as decolonization (with intranasal antimicrobials and topical antimicrobial washes) for those patients who tested positive for MRSA.30 For the Jain study41, the intervention was a MRSA bundle including surveillance for nasal colonization with MRSA for all patients within 24 hours of admission to the hospital, all patients not already known to be colonized or infected with MRSA transferred from one unit to another within the hospital, and all patients not already known to be colonized or infected with MRSA on discharge from the hospital; contact precautions for patients colonized or infected with MRSA; hand hygiene; and an institutional culture change wherein infection control became the responsibility of everyone who had patient contact.41 One of the studies utilized PCR to screen patients for MRSA30 and one41 utilized either culture or PCR to screen patients for MRSA carriage. For the Reilly study,42 the intervention was surveillance of all patients on admission for MRSA carriage, except psychiatric, obstetric and pediatric admissions. Those patients who were found to be colonized with MRSA underwent isolation and decolonization. The Robicsek study utilized PCR to screen patients for MRSA30 and the Jain study41 utilized either culture or PCR to screen patients for MRSA carriage. For all three studies, the control condition consisted of no screening.

The primary outcome for the Robicsek30 and Jain41 studies was the rate of healthcare-associated MRSA infection. For the Robicsek study,30 the primary outcome was the aggregate healthcare-associated rate of MRSA infection in the hospital. For the Jain study,41 the primary outcome was the rate of healthcare-associated MRSA infections. The primary outcomes for the Reilly study42 were the rates of MRSA colonization, infection and bacteremia.

The infection control practices differed for MRSA-positive patients during the intervention and control periods. None of the studies recommended actions for patients awaiting test results for the intervention or control groups. However, all three studies recommended more intensive actions for MRSA-positive patients in the intervention group than for MRSA-positive patients in the control group. In the Robicsek study,30 the MRSA-positive intervention group received isolation or cohorting, barrier precautions, dedicated equipment for staff use, and decolonization (with intranasal antimicrobials and topical antimicrobial washes). For its MRSA-positive control group, the Robicsek study30 recommended isolation or cohorting, barrier precautions, and dedicated equipment for staff use, but no decolonization. For its MRSA-positive intervention group, the Jain study41 recommended contact precautions, hand washing, and repeat assays while it did not recommend any action for its MRSA-positive control group. For its MRSA-positive intervention group, the Reilly study42 recommended isolation and decolonization while it did not recommend any action for its MRSA-positive control group. Only the Robicsek study30 described the turnaround time for testing (0.67 day).

### Results by Outcome

The Jain study41 reported on healthcare-associated MRSA acquisition and healthcare-associated MRSA infection. The Robicsek study30 reported on healthcare-associated MRSA infection. The Reilly study reported on MRSA infection, but did not specify that this outcome was exclusively health care-associated, suggesting that the reported results might also include community associated infections. Therefore, the Reilly study42 did not contribute to the SOE assessment for universal screening for MRSA carriage compared to no screening. Outcomes data for this study is presented in the Appendix F.

#### Healthcare-Associated MRSA Acquisition

Healthcare-associated MRSA acquisition is measured by MRSA colonization or by MRSA colonization or infection that is health care-associated, rather than imported. Only one poor quality quasi-experimental study41 addressed this outcome. This study by Jain et al.,41 defined healthcare-associated MRSA colonization or infection as a positive sample for MRSA obtained more than 48 hours after admission from a patient not previously known to be colonized or infected with MRSA. Patients not known to be colonized or infected with MRSA who were readmitted to the hospital within 48 hours after discharge and were found to be positive at the time of readmission were also considered to have a transmission event. With universal screening for MRSA, this study showed a statistically significant reduction in healthcare-associated MRSA in the ICU (−17 percent relative risk reduction) and in non-ICU settings (−21 percent relative risk reduction).

##### Strength of Evidence

Overall, compared to no screening, the SOE was assessed as insufficient that universal screening for MRSA carriage decreases healthcare-associated MRSA acquisition based on the positive findings from a single, quasi-experimental before/after study.41 The risk of bias was judged to be high as only one poor quality observational study addressed this outcome. Because only one study41 evaluated this outcome, the consistency of the results was unknown. The study addressed healthcare-associated MRSA acquisition, an intermediate and therefore, indirect outcome. The effect was judged to be precise, given the statistically significant reduction in health care-associate MRSA acquisition seen in this study. Because the evidence base that addressed this outcome consisted of a single observational study, the starting level of SOE was low. SOE was lowered level based on the high risk of bias. Therefore, compared to no screening, the SOE is insufficient that universal screening for MRSA carriage decreases healthcare-associated MRSA acquisition.

#### Healthcare-Associated MRSA Infection

One good quality quasi-experimental study30 by Robicsek and one poor quality quasi-experimental study41 by Jain addressed healthcare-associated MRSA infection overall. In their definition of hospital-acquired infection, both studies included infection that had occurred more than two days after admission. The Robicsek study30 defined infection as the sum total of all bloodstream infections (positive blood culture in the absence of a positive clinical culture from another site), respiratory tract infections (positive respiratory culture, compatible chest radiograph and decision to treat), urinary tract infections (positive urine culture and decision to treat or growth of more than 100,000 colony-forming units/mL plus at least 50 leukocytes per high-power field), and SSIs (positive culture of a surgical site). Infections were considered hospital-associated if they occurred more than two days after admission and within 30 days of discharge. The Jain study41 defined healthcare-associated MRSA infection according the Center for Disease Control and Prevention’s (CDC’s) National Healthcare Safety Network guidelines with three modifications: (1) the diagnosis of MRSA infection required a positive culture; (2) a positive culture was considered to be imported if it was obtained within 48 hours after admission; (3) a positive clinical culture obtained from a patient in whom infection was not present or incubating at the time of admission as defined by National Healthcare Safety Network guidelines criteria was considered to be health care-associated if it was obtained more than 48 hours after admission.

Compared to no screening, both studies found a statistically significant reduction in healthcare-associated MRSA infection with universal screening for MRSA. For the good quality study,30 the change in the rate of MRSA infection from a Poisson regression model was −69.6 percent with broad confidence intervals (95% CI: −89.2 to −19.6). For the poor quality study,41 the relative reduction in the rate of MRSA infection was −62 percent in ICU settings and −45 percent in non-ICU settings. The p value for trend in both settings was <0.001.^41^

##### Strength of Evidence

Overall, compared to no screening, the SOE was judged to be low that universal screening for MRSA carriage decreases healthcare-associated MRSA infection. Two quasi-experimental studies30,41 reported this outcome; the Jain study was a before/after design judged to be of poor quality41 and the Robicsek study was an interrupted time series design30 judged to be of good quality. The risk of bias for the body of evidence was judged as high, as only quasi-experimental studies addressed this outcome, only one of which30 was good quality. Because both studies found a reduction in healthcare-associated MRSA infection with screening, the results were consistent. The results were also direct because healthcare-associated MRSA infection is a health outcome. The effect was judged to be precise, given the statistically significant reduction in healthcare-associated MRSA infection seen in these studies. Because the evidence base that addressed this outcome consisted of two quasi-experimental studies, the starting level of SOE was low. SOE was raised by one level based on the large effect size, though lowered one level based on the high risk of bias. Therefore, compared to no screening, the SOE is low that universal screening for MRSA carriage decreases healthcare-associated MRSA infection.

#### Morbidity, Mortality, Harms and Resource Utilization

##### Results

No studies addressed these outcomes.

##### Strength of Evidence

Because no studies addressed these outcomes, compared to no screening, the SOE is insufficient to assess the effect of universal screening for MRSA carriage on morbidity, mortality, harms or resource utilization.

### Summary Strength of Evidence Across Key Question 1

A summary of the main syntheses for this question is given in Table 7.

Table 7 Strength of evidence for studies comparing universal screening versus no screening

Strategies Compared | Outcome | No of Studies^§^ | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Universal screening vs. No screening | MRSA Acquisition | 1 QEX (N=1,934,598) Jain 2011^41^ | High | Unknown | Indirect | Precise | Insufficient
Universal screening vs. No screening | MRSA Infection | 2 QEX (N= 112,985) Robicsek 2008^30^ (N=1,934,598) Jain 2011^41^ | High | Consistent | Direct | Precise | Low^*^

QEX = quasi-experimental; MRSA = methicillin-resistant Staphylococcus aureus

§ Studies that controlled for confounding and/or trend.

* Optional domain for effect magnitude invoked, raising strength of evidence by one level due to large effect size.

## Key Question 2 Universal Screening for MRSA Carriage Compared With Screening of Selected Patient Populations (Targeted Screening)

### Overview

This section describes the literature that evaluates universal screening for MRSA carriage compared to screening of selected patient populations (targeted screening). After an overview of the literature, the body of evidence is described for each outcome measure: MRSA acquisition, MRSA infection, morbidity, mortality, harms, and resource utilization. The emphasis in this chapter is on outcomes describing healthcare-associated events. Healthcare-associated outcomes are the primary outcomes of interest because screening for MRSA carriage in health care facilities is most proximately expected to impact healthcare-associated MRSA transmission and infection. Table 8 summarizes the studies reviewed for Key Question 2.

Table 8 KQ2: Healthcare-associated MRSA infection

Outcome | Study | Quality | Statistical Result | Synthesis
HCA infection | Robicsek et al.30 | Good | SS ↓ | SOE=insufficient
HCA infection | Leonhardt et al.43 | Good | NSS↓ | SOE=insufficient

HCA = health care associated; KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus; NSS = not statistically significant; SOE = strength of evidence; SS = statistically significant

Two quasi-experimental studies compared universal screening for MRSA carriage on hospital admission to screening of selected patient populations (targeted screening).30,43 Leonhardt and colleagues (n=15,049) was a case-control study43 and the study by Robicsek and colleagues30 (n=77,856) was a limited time series design; both studies were judged to be good quality. Both studies presented baseline characteristics (Table 9) for intervention and control groups and conducted appropriate analyses (tested for trend, addressed autocorrelation and controlled for at least one confounder). Both studies reported on an important outcome, healthcare-associated MRSA infection.

Table 9 KQ2: Study quality details for CCS studies

Author, Year | Reported Baseline Characteristics | Analytic Technique | Test for Trend (1) | Addressed Auto-Correlation (2) | Adjusted for at Least 1 Confounder (3) | Appropriate Analysis of Results^*^ | Quality
Robicsek et al., 2008^30^ | Sex, ethnicity, long term care residence, history hospital admission, admission-discontinuation details, medical condition | Segmented Poisson regression, D-W test | Y | Tested for | Y (admitting hospital) | Y | Good
Leonhardt et al., 2011^43^ | Age, sex, race, case mix | Difference in difference analysis | Y | Tested for | Y (ICP) | Y | Good

CCS = attempted to control for confounding and/or secular trends; D-W = Durbin-Watson test for autocorrelation; ICP = infection control practices; KQ = Key question; MRSA = methicillin-resistant Staphylococcus aureus; Y = yes

* The study was judged to meet appropriate analysis if all 3 elements (1, 2, 3) were present.

As its comparison group, the Robicsek study30 evaluated screening of patients admitted to the ICU. The Leonhardt study43 evaluated screening of high-risk patients, including those admitted to the ICU as its comparison group. In its high-risk group, this study also included patients with a history of MRSA infection or colonization, those with a history of prior hospitalization including transfers within the past 6 months, patients from long-term care facilities and correctional institutes, patients receiving hemodialysis and selected orthopedic and cardiothoracic surgery patients.

The Robicsek study30 conducted followup for MRSA disease for 180 days after discharge, though patients in the intervention group were followed for less than 180 days if they were discharged in the final 180 days of the study period. The Leonhardt study43 did not specify the duration of followup.

Both studies utilized PCR to screen for MRSA carriage. Turnaround times for screening results were reported by the Robicsek study,30 but not by the Leonhardt study.43 The Robicsek study30 found the turnaround time to be 2.5 days for the control period and 0.67 day for the intervention period.

The Robicsek study30 cited the aggregate hospital-associated MRSA infection rate as its primary outcome. This study included several secondary outcomes including rates of healthcare-associated MRSA and methicillin-sensitive Staphylococcus aureus bacteremia, rates of aggregate MRSA infections occurring up to 180 days after discharge, and adherence to MRSA surveillance. The Leonhardt study43 cited the clinical effectiveness and the cost benefit of universal screening versus targeted screening for MRSA as its primary outcome.

The infection control practices used to care for MRSA-positive patients differed between intervention and control group patients for the Robicsek study30 but were the same for the Leonhardt study.43 For MRSA-positive patients in the intervention group, Robicsek et al.30 utilized contact isolation and decolonization (with nasal antimicrobials and topical antimicrobial washes). However, MRSA-positive patients in the control group received contact isolation without decolonization. For MRSA-positive patients in both intervention and control groups, Leonhardt et al.,43 utilized contact isolation and when appropriate, perioperative decolonization and antibiotic prophylaxis.

The infection control practices used to care for patients while waiting for screening test results were the same for intervention and control group patients for both studies. Robicsek et al.,30 utilized no interventions during this time period. Leonhardt et al.,43 recommended contact isolation for patients previously known to be MRSA positive.

### Results by Outcome

#### Healthcare-Associated MRSA Acquisition

Healthcare-associated MRSA acquisition is measured by MRSA colonization or by MRSA colonization or infection that is health care-associated, rather than imported.

##### Results

No studies addressed this outcome.

##### Strength of Evidence

No studies addressed this outcome. Therefore, the SOE to evaluate the effect of universal screening for MRSA carriage compared to targeted screening on healthcare-associated MRSA acquisition is judged to be insufficient.

#### Healthcare-Associated MRSA Infection

##### Results

Although both studies showed a reduction in hospital-acquired MRSA infection with universal screening for MRSA carriage compared to targeted screening, only the Robicsek study showed a statistically significant reduction. Using a segmented Poisson regression, Robicsek et al.,30 found that the rate of hospital-acquired MRSA infection declined by 52.4 percent (CI: 9.3 to 78.3 percent) in the universal screening group compared to the targeted screening group. Leonhardt et al.,43 showed a 0.12 percent reduction in hospital-acquired infection with universal screening compared to targeted screening, a result that is close to a null effect. However, this reduction was not statistically significant (p=0.23), nor was the difference in difference (p=0.34).

The definitions of hospital-acquired infection differed between the two studies. One study43 defined an infection as hospital acquired if it occurred on or after day 4 of hospitalization. The other study30 defined an infection as hospital acquired if it occurred more than 48 hours after admission and 30 days or less after discharge.

##### Strength of Evidence

The SOE to evaluate the effect of universal screening for MRSA carriage compared to targeted screening on healthcare-associated MRSA infection was judged to be insufficient. The risk of bias was judged to be medium as two good quality observational studies addressed this outcome.30,43 With universal screening, both studies30,43 found a reduction in healthcare-associated MRSA infection. Using a segmented Poisson regression, Robicsek et al.,30 found that the rate of hospital-acquired MRSA infection declined by 52.4 percent (CI: 9.3 to 78.3 percent) in the universal screening group compared to the targeted screening group. Leonhardt et al.,43 showed a 0.12 percent reduction in hospital-acquired infection with universal screening compared to targeted screening. However, this reduction was not statistically significant (p=0.23), nor was the difference in difference (p=0.34). Therefore, the results were consistent, because both studies showed a reduction in infection with screening. The studies evaluated MRSA infection, a health outcome. Therefore, the outcome was direct. Because the individual studies did not consistently report statistically significant results, the findings were imprecise. Because the evidence base for this outcome consisted of two observational studies, the starting level for the SOE was low. SOE was lowered by one level based on the medium risk of bias and by one level based on the imprecise results and is therefore, insufficient. In summary, the SOE is insufficient to support or refute that, compared to targeted screening, universal screening for MRSA carriage decreases healthcare-associated MRSA infection.

#### Morbidity, Mortality, Harms, and Resource Utilization

##### Results

No studies addressed these outcomes.

##### Strength of Evidence

Because no studies addressed these outcomes, the SOE to evaluate the effect of universal screening for MRSA carriage compared to targeted screening on morbidity, mortality, harms or resource utilization is judged to be insufficient.

### Summary Strength of Evidence Across Key Question 2

A summary of the main syntheses for this question follows in Table 10.

Table 10 Strength of evidence for studies comparing universal screening versus screening in selected patient population

Strategies Compared | Outcome | No of Studies^§^ | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Universal Vs Screening of Selected Patients | MRSA Acquisition | No studies | NA | NA | NA | NA | Insufficient
Universal Vs Screening of Selected Patients | MRSA Infection | 2 QEX (N=92,905) (Robicsek 2008,30 Leonhardt 2011^43^) | Medium | Consistent | Direct | Imprecise | Insufficient

MRSA = methicillin-resistant Staphylococcus aureus; NA = not applicable; QEX = quasi-experimental

§ Studies that controlled for confounding and/or trend.

## Key Question 3A Screening of ICU Patients for MRSA Carriage Compared With No Screening

### Overview

This section describes the literature that evaluates screening of ICU patients for MRSA carriage compared to no screening. After an overview of the literature, the results are described for each outcome: MRSA acquisition, MRSA infection, morbidity, mortality, harms, and resource utilization. Within the category of MRSA infection, we also included results for MRSA bacteremia or bloodstream infection and for MRSA SSI, as some studies present these outcomes rather than the broader outcome of MRSA infection irrespective of site. The emphasis in this chapter is on outcomes describing healthcare-associated events. Healthcare-associated outcomes are the primary outcomes of interest because screening for MRSA carriage in health care facilities is most proximately expected to impact healthcare-associated MRSA transmission and infection. Studies that did not report healthcare-associated outcomes are discussed in the results section below. However, because these studies did not report a healthcare-associated outcome, they did not contribute to the SOE analyses. The outcomes data from these studies is presented in the Appendix F. In addition, SOE syntheses presented here include only CCS studies. Because studies that use simple two-group statistical analyses cannot support causal inferences, the non-CCS studies were excluded from the SOE analysis. Following the SOE syntheses, we comment on the pattern of results seen in non-CCS studies. Table 11 summarizes the studies reviewed for Key Question 3A and Table 12 details the study quality ratings. Note that Table 11 does not include the studies by Gould,44 Blumberg48 and Souweine et al.,54 because they did not report outcomes that were exclusively health-care associated.

Table 11 KQ3A: Healthcare-associated MRSA acquisition, infection, bacteremia, or surgical-site infection

Outcome | Study | Quality | Statistical Result | Synthesis
HCA acquisition | Huskins et al., 2011^46^ | Good | NSS ↑ | SOE=insufficient
HCA acquisition | Huang et al., 2006^29^ | Poor | SS ↓ | Comment: Results more favorable than the good quality Huskins study, however causal inference is not possible.
HCA acquisition | Raineri et al., 2007^47^ | Poor | SS ↓ | Comment: Results more favorable than the good quality Huskins study, however causal inference is not possible.
HCA acquisition | Holzmann-Pazgal et al., 2011^45^ | Poor | SS ↓ | Comment: Results more favorable than the good quality Huskins study, however causal inference is not possible.
HCA acquisition | de la Cal et al., 2004^51^ | Non-CCS | SS ↓ | Comment: Results more favorable than the good quality Huskins study, however causal inference is not possible.
HCA infection | Robicsek et al., 2008^30^ | Good | NSS ↓ | SOE=insufficient
HCA infection | Muder et al., 2008^55^ | Poor | SS ↓ | Comment: Results more consistently favorable than Robicsek, however causal inference is not possible.
HCA infection | Clancy et al., 2006^50^ | Non-CCS | SS ↓^a^/NSS↓^b^ | Comment: Results more consistently favorable than Robicsek, however causal inference is not possible.
HCA infection | Boyce et al.,2004^49^ | Non-CCS | SS ↓ | Comment: Results more consistently favorable than Robicsek, however causal inference is not possible.
HCA infection | Kurup et al.,2010^52^ | Non-CCS | NSS ↓ | Comment: Results more consistently favorable than Robicsek, however causal inference is not possible.
HCA infection | Simmons et al.,2011^53^ | Non-CCS | SS ↓ | Comment: Results more consistently favorable than Robicsek, however causal inference is not possible.
HCA bacteremia/blood stream infection | Robicsek et al.,2008^30^ | Good | NSS ↓ | SOE=insufficient
HCA bacteremia/blood stream infection | Huang et al.,2006^29^ | Poor | SS ↓ | Comment: Results more consistently favorable than Robicsek, however causal inference is not possible.
HCA bacteremia/blood stream infection | de la Cal et al.,2004^51^ | Non-CCS | SS ↓ | Comment: Results more consistently favorable than Robicsek, however causal inference is not possible.
HCA surgical site infection | Robicsek et al.,2008^30^ | Good | NSS ↓ | SOE=insufficient

CCS = study attempted to control for confounding and/or secular trends; HCA = healthcare-associated; KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus; NSS = not statistically significant; SOE = strength of evidence; SS = statistically significant

a Reduction in hospital-acquired MRSA infection in the surgical ICU as well as in the pooled analysis of the surgical ICU, medical ICU, and wards with screening for MRSA in the ICU was statistical significant.

b Reduction in hospital-acquired MRSA infection in the medical ICU or the wards was not statistically significant.

Table 12 KQ3A: Study quality details for CCS studies

Author, Year | Reported Baseline Characteristics | Analytic Technique | Test for Trend (1) | Addressed Auto-Correlation (2) | Adjusted for at Least 1 Confounder (3) | Appropriate Analysis of Results^*^ | Quality
Gould et al., 2007^44^ | Age, sex, APACHE II, ICU deaths, length of stay | Segmented regression, D-W test | Y (also MSSA) | Accounted for | Y (number patients admitted to ICU) | Y | Fair
Huang et al., 2006^29^ | NR | Segmented regression, D-W test | Y (also MSSA) | Adjusted for | NR | N | Poor
Raineri et al., 2007^47^ | Patient-days, age, length of stay, sex, SAPS II | Segmented regression, D-W test | Y | Tested for | NR | N | Poor
Robicsek et al., 2008^30^ | Sex, ethnicity, long term care residence, history hospital admission, admission-discontinuation details, medical condition | Segmented regression, D-W test | Y | Tested for | Y (admitting hospital) | Y | Good
Holzmann-Pazgal et al., 2011^45^ | NR | Multivariable linear regression during int per only | N(inter-vention period only) | Tested for | hand hygiene compliance | N | Poor
Huskins et al., 2011^46^ | ICU length of stay, prehospital-ization residence, history hospital admission, age, sex, nonoperative primary diagnosis, APACHE III, MODS, hx MRSA/VRE colonization/infection past year | ANCOVA adjusted for BL incidence, multivariable Cox proportional hazards model regression | Y | Tested for | Y (multiple ICU-level and pt-level variables) | Y | Good
Muder et al., 2008^55^ | NR | Segmented Poisson regression | Y | NR | NR | N | Poor

ANCOVA = analysis of covariance; APACHE = Acute Physiology and Chronic Health Evaluation; BL = baseline; CCS = attempted to control for confounding and/or secular trends; D-W = Durbin-Watson test for autocorrelation; Hx = history; ICU = intensive care unit; KQ = Key Question; MODS = Multiple Organ Dysfunction Score; MRSA = methicillin-resistant Staphylococcus aureus; MSSA = methicillin-sensitive Staphylococcus aureus; N = no; NR = not reported; Pt = patient; SAPS = Simplified Acute Physiology Score; VRE = vancomycin-resistant Enterococcus; Y = yes

* The study was judged to meet appropriate analysis if all 3 elements (1, 2, 3) were present.

Fourteen studies described screening of ICU patients for MRSA carriage compared to no screening. Seven were CCS studies29,30,44–47,55 and seven48–54 were non-CCS studies. Of the CCS studies, the Robicsek30 and Huskins46 studies were judged to be of good quality overall because they presented baseline characteristics for intervention and control groups, conducted appropriate analyses (tested for trend, addressed autocorrelation and controlled for at least one confounder) and reported on an important (healthcare-associated) outcome. The Gould44 study was judged to be of fair quality because it did not report on an outcome that was exclusively health care-associated, suggesting that its outcomes may have included both community-acquired and healthcare-associated cases. The Huang,29 Muder,55 Raineri47 and Holzmann-Pazgal45 studies were judged to be of poor quality. The Huang study29 was rated as poor quality because it did not report baseline group characteristics and whether the analysis controlled for confounders. The Muder study55 was rated as poor quality because it did not report baseline group characteristics, addressing autocorrelation, and whether its analysis controlled for confounders. The Raineri study47 was rated as poor quality because it did not report adjusting for any confounders. The Holzmann-Pazgal study45 was rated as poor quality because though it controlled for the confounding influence of hand hygiene compliance and for trend during the intervention period, it did not address trend during the pre-intervention period.

Of the good quality studies, Huskins46 was a cluster RCT and Robicsek30 utilized a before/after quasi-experimental design. The Gould study, a study of fair quality, utilized a quasi-experimental interrupted time series design.44 Of the poor quality studies, all four utilized a quasi-experimental study design. The Huang study29 utilized an interrupted time series design and the other three studies45,47,55 utilized a before/after design. All seven non-CCS studies48–54 utilized a before/after design.

In terms of sample size, both good quality studies30,46 specified the sample size for the intervention group and for the control group. Among the good quality studies, the range in sample size for the intervention group was 1,615–39,521; the range in sample size for the control group was 2,441–40,392. The total sample size for the good quality studies30,46 was 83,969. For the fair quality study, the sample size for the control group was 1,232, the sample size for the intervention group was 1,421, and the total sample size was 2,653.^44,45^ Of the poor quality studies, two45,47 specified the sample size and two29,55 did not. Among the poor quality studies, the range in sample size for the intervention group was 2367–3311; the range in sample size for the control group was 667–730. The total sample size for the poor quality studies was 7,075. For the good, fair and poor quality studies combined, the total sample size was 86,622.

Of the non-CCS studies, two of seven specified the sample size for the intervention group and for the control group.48,51 Four non-CCS studies49,50,52,53 specified the sample size only for the intervention group. One54 of the non-CCS studies did not specify the sample size for any group. Of the non-CCS studies, the range in sample size for the intervention group was 351–2,605; the range in sample size for the control group was 140–2,315. For the non-CCS studies, the total sample size including patients in both the intervention and control groups was at least 9,369.

All 14 studies evaluated patients in the ICU. The Holzmann-Pazgal study45 focused its intervention on the pediatric ICU. The Blumberg study48 also evaluated patients in a pediatric oncology unit.

The MRSA screening interventions could be divided into two general categories: multicomponent MRSA screening interventions or MRSA screening alone. The interventions in both good quality studies30,46 consisted of MRSA screening alone. The fair quality study44 consisted of a multicomponent intervention including surveillance cultures of the nares, throat, axillae, and groin on admission to the ICU, decolonization for all patients (with intranasal antimicrobials and topical antimicrobials), isolation, decolonization for MRSA-positive patients, and barrier nursing for MRSA-positive patients. Of the poor quality studies, two29,47 were multicomponent interventions and one45 consisted of screening for MRSA carriage alone. The intervention from Huang and colleagues29 included four sequential interventions: (1) a campaign to increase sterile barrier precautions during central venous catheter placement; (2) the hospital wide institution of alcohol-based hand rubs; (3) a hand hygiene campaign; and (4) nasal surveillance for MRSA in all ICU patients on admission and weekly throughout the ICU stay. The intervention from Muder and colleagues55 included four components: (1) the use of standard precautions (especially hand hygiene) before and after contact with patients and their environment; (2) contact precautions for all patients infected or colonized with MRSA; (3) active surveillance cultures to identify patients colonized with MRSA; and (4) an industrial systems-engineering approach to facilitate delivery of the infection control program. The intervention from Raineri et al.,47 included two interventions. The first intervention included active surveillance for MRSA (a nasal swab on admission to the ICU and every 3 days throughout the ICU stay), contact precautions (gloves and hand hygiene, with gowns and masks reserved for procedures at risk for MRSA transmission), decolonization of carriers (with intranasal antimicrobials and topical antimicrobials), repeat testing after treatment, and additional treatment for those patients who continued to test positive. Staff education was provided throughout the intervention. The second intervention included all of the components of the first intervention, as well as the movement of the ICU to a new ward where isolation or cohorting could be performed.

Of the non-CCS studies, three48,51,54 were multicomponent interventions, and four49,50,52,53 consisted of screening for MRSA carriage alone. One51 of the non-CCS studies included two interventions. For the study by de la Cal et al.,51 the first intervention consisted of surveillance samples from the nose, throat, rectum, tracheostomy and pressure sores, on admission to the ICU and weekly throughout the ICU stay. Enteral vancomycin was administered to MRSA positive patients. The second intervention also included surveillance samples from the nose, throat, rectum, tracheostomy, and pressure sores, on admission to the ICU and weekly throughout the ICU stay. In addition, all patients expected to require mechanical ventilation for three or more days received enteral vancomycin and selective digestive decontamination with oral and intravenous antibiotics. In addition, vancomycin paste was administered topically to the oropharynx, tracheostomy site, and pressure sores 4 times a day. Vancomycin solution was administered via nasogastric tube 4 times a day. Patients were washed with a topical antimicrobial solution twice a week.

The Souweine study54 used an intervention that included surveillance cultures (on admission to the ICU, weekly throughout the ICU stay, and at discharge from the ICU), isolation procedures (handwashing, gown and gloves, cleansing patients), attempted eradication of MRSA nasal carriage with mupirocin, and staff education. The Blumberg study48 also utilized a multicomponent intervention. This intervention included screening of staff at study onset and six months later, screening of patients at study onset followed by sampling of new patients three times a week, decolonization and repeat assays.

Of the good quality studies, the Robicsek study30 utilized PCR to screen patients for MRSA and the Huskins study46 utilized culture. The fair quality study utilized culture to screen patients for MRSA.44 Of the poor quality studies, all four29,45,47,55 utilized culture to screen patients for MRSA. Of the non-CCS studies, five studies48–51,54 utilized culture to screen patients for MRSA, one53 utilized PCR to screen patients for MRSA, and one52 utilized culture to screen some patients for MRSA and PCR to screen other patients for MRSA. For all of the studies, the control condition consisted of no screening.

The primary outcomes for the majority of the studies included healthcare-associated MRSA acquisition (either colonization, infection or both colonization and infection). There were several distinctive primary outcomes of interest. For the Huskins study,46 the primary outcome was the ICU-level incidence of new events of colonization or infection with MRSA or VRE. The inclusion of VRE was unusual among the 13 studies. Almost all of the studies focused on outcomes that were documented in the ICU. However, for the Robicsek study,30 the primary outcome was the aggregate rate of MRSA infection in the hospital and for the Simmons study,53 the primary outcomes were the ICU-acquired MRSA rate, and the hospital-wide MRSA rate. The Blumberg study48 included the identification and treatment of MRSA-positive staff and patients as a primary outcome of interest. For the Huang study,29 the primary outcome was rates of MRSA bacteremia.

Of the studies of fair or good quality, the Huskins study46 and the Gould study44 recommended actions for patients in the intervention group before test results were known, but no actions for patients in the control group before test results were known. The Huskins study46 recommended universal gloving and contact precautions for those patients infected or colonized with MRSA or VRE during the prior year. The Gould study44 recommended topical and intranasal antimicrobials while awaiting test results. In contrast, the Robicsek study30 recommended no action for patients in either the intervention group or the control group before test results were known. The Muder study55 recommended contact precautions for those with a prior history of MRSA infection or colonization. None of the other poor quality studies29,45,47 recommended action before test results were known for patients in the intervention group or the control group.

The majority of non-CCS studies (four of seven) took no action before test results were known for patients in the intervention group or the control group. Two of the non-CCS studies recommended actions for patients in the intervention group while awaiting test results. The Souweine study54 recommended isolation for patients transferred from another ICU while awaiting test results. For the first half of the intervention period, the Kurup study52 recommended no action for patients while awaiting test results; in the second half of the intervention period however, this study recommended topical antimicrobial washes for patients while awaiting test results.

Once a patient was found to be MRSA-positive, all of the good quality30,46 and fair quality studies44 recommended the same action for these patients in the intervention group as for those in the control group. All of these studies30,44,46 recommended isolation and barrier precautions. In addition, the Robicsek study30 recommended dedicated equipment for staff use. Of the poor quality studies, only one45 recommended the same action for MRSA-positive patients in the intervention group as in the control group. The Holzmann-Pazgal study45 recommended isolation and barrier precautions for MRSA-positive patients in both the intervention and control groups. In contrast, three29,47,55 of the poor quality studies recommended different actions for MRSA-positive patients in the intervention and control groups. Huang et al.,29 recommended contact precautions for MRSA-positive patients in the intervention group and no action for MRSA-positive patients in the control group. Raineri et al.,47 recommended contact precautions (hand hygiene and gloves; gowns and masks when performing procedures at risk for MRSA transmission), intranasal and topical antimicrobials, and repeat assays for MRSA-positive patients in the first and second intervention groups. In addition, this study47 recommended isolation and cohorting for MRSA-positive patients in the second intervention group. No action was recommended for MRSA-positive patients in the control group.47 Muder et al.,55 recommended contact precautions for MRSA-positive patients in the intervention group, but did not specify an action for MRSA-positive patients in the control group.

Only one49 of the seven non-CCS studies recommended exactly the same action for MRSA-positive patients in the intervention group as in the control group. Boyce et al.,49 recommended contact precautions for MRSA-positive patients in both the intervention and control groups. Two of the non-CCS studies50,53 recommended similar actions for MRSA-positive patients in the intervention and control groups. The Clancy study50 recommended isolation or cohorting, barrier precautions, handwashing compliance checks, contact isolation compliance checks, and repeat assays for MRSA-positive patients in the intervention group. Isolation or cohorting and barrier precautions were recommended for MRSA-positive patients in the control group.50 In another non-CCS study, Simmons and colleagues53 recommended contact isolation, potential decolonization (with intrasnasal antimicrobials), and repeat assays for MRSA-positive patients in the intervention group. Contact isolation, potential decolonization (type unspecified), and repeat assays were recommended for MRSA-positive patients in the control group. Four48,51,52,54 of the seven non-CCS studies recommended different interventions for MRSA-positive patients in the intervention group than in the control group. de la Cal et al.,51 recommended isolation or cohorting, barrier precautions, topical antimicrobials, oral or intravenous antimicrobials, and hand washing for MRSA-positive patients in the intervention group. Isolation or cohorting, barrier precautions and hand washing were recommended for MRSA-positive patients in the control group.51

Souweine et al.,54 recommended isolation or cohorting, barrier precautions, intranasal antimicrobials, topical antimicrobial washes, hand washing, and repeat assays for MRSA-positive patients in the intervention group. In addition, all soiled articles, moist body substances, and waste were wrapped in double bags before removal from patient rooms.54 No interventions were recommended for MRSA-positive patients in the control group.54 Blumberg et al.,48 recommended isolation or cohorting for patients admitted to the ICU (not for those admitted to the pediatric oncology unit), barrier precautions, intranasal antimicrobials, topical antimicrobial washes, and alcohol-based hand rubs for MRSA-positive patients in the intervention group. In addition, cohort nursing was attempted for MRSA-positive patients in the intervention group.48 No interventions were recommended for MRSA-positive patients in the control group.48 Kurup et al.,52 recommended isolation or cohorting, topical antimicrobial washes, and repeat assays for MRSA-positive patients in the intervention group. No interventions were recommended for MRSA-positive patients in the control group.52

Of the studies of good, fair or poor quality, five of the seven reported test turnaround time.29,30,45,46,55 The Robicsek study described the turnaround time as 2.5 days30 and the Huskins study as 5.2 days ± 1.4 days.46 The Huang study,29 the Muder study55 and the Holzmann-Pazgal study45 described test turnaround time as two days. The Simmons study53 (a non-CCS study) reported test turnaround time as 12 hours.

### Results by Outcome

The Huskins study,46 the Huang study,29 the Raineri study,47 and the Holzmann-Pazgal study45 reported on healthcare-associated MRSA acquisition. The Robicsek study30 reported on healthcare-associated MRSA infection regardless of site, as did the Muder study.55 The Robicsek study30 also reported on healthcare-associated MRSA bacteremia or bloodstream infection, as did the Huang study.29 In addition, the Robicsek study30 reported on MRSA SSI. The Gould study44 reported on MRSA infection, but did not specify that this outcome was exclusively health care-associated, suggesting that the reported results might also include community associated infections. Therefore, the Gould study44 did not contribute to the SOE assessment for screening of ICU patients for MRSA carriage compared to no screening. Outcomes data for this study is presented in the Appendix F.

#### Healthcare-Associated MRSA Acquisition

Healthcare-associated MRSA acquisition is measured by MRSA colonization or by MRSA colonization or infection that is health care-associated, rather than imported. One good quality study,46 three poor quality studies,29,45,47 and one non-CCS study51 addressed this outcome. The Huskins study,46 a good quality study, was a cluster RCT and the poor quality studies29,45,47 and the non-CCS study51 utilized quasi-experimental designs.

The definitions of hospital-associated infection differed from study to study. The Huskins study46 defined hospital-associated as a positive-MRSA sample 2 or more days after admission to the ICU in a patient whose ICU length of stay was at least 3 days with no history of colonization or infection in the prior year, no positive clinical culture within two days after admission to the ICU, and a negative surveillance culture within 2 days of admission to the ICU. The Huang study29 defined hospital-associated infection as a first-ever MRSA-positive sample more than 2 days after admission if not previously hospitalized at that institution within the prior year, or at any time during the hospital admission if hospitalized at that institution in the prior year. The Raineri study47 defined ICU-associated as a MRSA-positive isolate identified at least 48 hours after admission in patients with no previous MRSA isolate documented and at least one negative screen from the ICU. The Holzmann-Pazgal study45 defined hospital-acquired as the initial isolation of MRSA in any specimen obtained more than 48 hours after admission. The non-CCS study51 defined colonization or infection as hospital-associated if the MRSA-positive sample was obtained more than 72 hours after admission.

Compared to no screening, the good quality study46 found a nonstatistically significant increase in healthcare-associated MRSA colonization or infection with screening for MRSA carriage in the ICU. However, the poor quality studies29,45,47 found a statistically significant reduction in hospital-acquired MRSA colonization or infection with screening for MRSA carriage in the ICU, as did the non-CCS study.51

##### Strength of Evidence

The SOE to evaluate the effect of screening for MRSA carriage in ICU patients compared to no screening on healthcare-associated MRSA acquisition was determined to be insufficient. Of the four CCS-studies29,45–47 that evaluated this outcome, the Huskins study was a good quality, cluster RCT,46 while the Huang study,29 the Holzmann-Pazgal study45 and the Raineri study47 were quasi-experimental before/after studies of poor quality. For the group of studies, the risk of bias was deemed to be low because of the good quality RCT that addressed this outcome. With targeted screening, the Huskins RCT46 found a nonstatistically significant increase in healthcare-associated MRSA colonization or infection. However, the Huang,29 Raineri,47 and Holzmann-Pazgal45 studies found statistically significant reductions in healthcare-associated colonization or infection. Because the estimates of effect have different directions, the results were inconsistent. The studies addressed healthcare-associated MRSA acquisition, an intermediate and therefore, indirect outcome. Because the individual studies did not consistently report statistically significant results, the findings were imprecise. The evidence base included a RCT of good quality, so the starting level for the SOE was high. However, the lack of consistency and lack of precision raised serious concerns. With targeted screening, the RCT46 found a nonstatistically significant increase in healthcare-associated MRSA colonization or infection, while the quasi-experimental studies29,45,47 found statistically significant reductions in healthcare-associated colonization or infection. Due to the very serious concern related to uncertainty about the direction of effect (opposite direction of effect with the RCT and the quasi-experimental studies), the SOE was reduced by two levels. The SOE was further reduced by one level due to lack of precision, another serious concern. In summary, the SOE to evaluate the effect of screening of ICU patients for MRSA carriage on MRSA acquisition is insufficient.

The cluster RCT46 was criticized in the literature because of lengthy turnaround time of the screening test used in the study and the failure to implement contact precautions and/or isolation while awaiting test results.86 Therefore, we conducted a sensitivity analysis, excluding the cluster RCT46 from the SOE analysis. Because the evidence base for this outcome would then include only observational studies, the starting level for the SOE would be low. SOE would be lowered by the high risk of bias (because of only three observational studies of poor quality in the evidence base). Therefore, even if the Huskins trial46 was excluded from the studies that evaluated this outcome, the SOE to evaluate the effect of screening of ICU patients for MRSA carriage on MRSA acquisition would remain insufficient.

##### Comment, Non-CCS Studies

One non-CCS study51 evaluated the impact of screening for MRSA carriage in the ICU on healthcare-associated MRSA transmission. The non-CCS study by de la Cal and colleagues51 found a statistically significant reduction in hospital-acquired MRSA colonization or infection with screening of ICU patients for MRSA carriage.

#### Healthcare-Associated MRSA Infection, Irrespective of Site

One good quality study,30 one poor quality study55 and four49,50,52,53 non-CCS studies addressed this outcome. The definitions of hospital-associated MRSA infections were diverse. The Robicsek study30 defined infection as the sum total of all bloodstream infections (positive blood culture in the absence of a positive clinical culture from another site), respiratory tract infections (positive respiratory culture, compatible chest radiograph and decision to treat), urinary tract infections (positive urine culture and decision to treat or growth of more than 100,000 colony-forming units/mL plus at least 50 leukocytes per high-power field), and SSIs (positive culture of a surgical site). Infections were considered to be hospital associated if they occurred more than 2 days after admission and within 30 days of discharge. The Muder study55 used the CDC definition of healthcare-associated infection. The Clancy study50 defined hospital-associated infection as the first clinical specimen (ordered to evaluate for infection) positive for MRSA more than 72 hours after admission. The Simmons study53 defined hospital-associated MRSA rates using the National Nosocomial Infection Surveillance system. The study by Boyce and colleagues49 utilized CDC criteria to define hospital-associated infection. Patients were considered to have a hospital-associated MRSA infection if the infection began more than 3 days after admission to the ICU in a patient with no prior history of MRSA. The Kurup study52 utilized CDC criteria to define infection. Patients were considered to have a hospital-associated MRSA infection if the first MRSA isolate from any source was recovered more than 24 hours after ICU admission in a patient with no known prior history of MRSA.52

Compared to no screening, the good quality study30 found a reduction in hospital-acquired MRSA infection with screening of ICU patients for MRSA carriage (rate difference −1.46 [95% CI: −3.43 to 0.51]); however, this reduction was not statistically significant. The poor quality study55 found a statistically significant reduction in the rate of healthcare-associated infection with screening of ICU patients for MRSA carriage (rate 5.45/1000 patient-days prior to the intervention, 1.35/1000 patient-days following the intervention, a 75 percent reduction, p=0.001). In addition, compared to no screening, one52 of the non-CCS studies found no statistically significant reduction in hospital-acquired MRSA infection with screening of ICU patients for MRSA carriage. However, two49,53 of the non-CCS studies found a statistically significant reduction in hospital-acquired MRSA infection with screening of ICU patients for MRSA carriage. In addition, compared to no screening, one50 of the non-CCS studies found a statistically significant reduction in hospital-acquired MRSA infection in the surgical ICU, as well as in the pooled analysis of the surgical ICU, medical ICU, and wards with screening for MRSA in the ICU. However, this same study50 found no statistically significant reduction in hospital-acquired MRSA infection in the medical ICU or the wards.50

##### Strength of Evidence

The SOE to evaluate the effect of screening for MRSA carriage in ICU patients compared to no screening on healthcare-associated MRSA infection was determined to be insufficient. Two CCS studies30,55 addressed this outcome. The Muder study55 utilized a before/after design and was judged to be of poor quality because it did not report baseline characteristics, addressing autocorrelation, and whether its analysis controlled for confounders. The Robicsek study30 was an interrupted time series design judged to be of good quality. The risk of bias was judged as high, as the body of evidence that evaluated this outcome included only quasi-experimental studies, only one of which was of good quality. With screening, the Robicsek study30 found a reduction in healthcare-associated MRSA infection (rate difference −1.46; 95% CI: −3.43 to 0.51); however, this reduction was not statistically significant. With segmented Poisson regression, the change in the rate of healthcare-associated infection was −36.2 percent (95% CI: −65.4 to 9.8). The Muder study55 found a statistically significant reduction in healthcare-associated MRSA infection with screening (rate 5.45/1000 patient-days prior to the intervention, 1.35/1000 patient-days following the intervention, a 75 percent reduction, p=0.001). Therefore, the results were consistent, because both studies showed a reduction in infection with screening. The studies evaluated MRSA infection, a health outcome. Therefore, the outcome was direct. Because the individual studies did not consistently report statistically significant results, the findings were imprecise. Because the evidence base for this outcome includes only observational studies, the starting level for the SOE was low. SOE was lowered by the high risk of bias and the lack of precision. In summary, the SOE is insufficient to support or refute that, compared to no screening, screening for MRSA carriage in ICU patients decreases healthcare-associated MRSA infection.

##### Comment, Non-CCS Studies

Four non-CCS studies evaluated the impact of screening for MRSA carriage in the ICU on healthcare-associated MRSA infection, regardless of site.49,50,52,53 Compared to no screening, all of these studies demonstrated a reduction in healthcare-associated MRSA infection with screening of ICU patients for MRSA carriage. For two49,53 of these studies, the reduction was statistically significant, while for one52 of the studies it was not. For another50 of the non-CCS studies, the reduction was statistically significant in some settings, but not in others.

#### Healthcare-Associated MRSA Bacteremia or Bloodstream Infection

One good quality study,30 one poor quality study,29 and one non-CCS study51 addressed this outcome. The good quality study30 by Robicsek, which also reported MRSA infection irrespective of site, defined bloodstream infection as a positive blood culture in the absence of a positive clinical culture from another site. Infections were considered to be hospital associated if they occurred more than 2 days after admission and within 30 days of discharge. The poor quality study29 defined hospital-associated cases as those with a first-ever MRSA-positive blood culture more than 2 days after admission if not previously hospitalized at that institution within the prior year, or at any time during the hospital admission if hospitalized at that institution in the prior year. The non-CCS study51 used the term “positive diagnostic sample” rather than infection to avoid bias in the definition of some infections (e.g., ventilator-associated pneumonia). Diagnostic samples (those performed for reasons other than surveillance) were considered hospital associated if the sample was obtained more than 72 hours after admission.

The good quality study30 found no statistically significant reduction in the rate of acquired MRSA bloodstream infection with screening for MRSA in the ICU compared to no screening for MRSA (absolute change in prevalence density −0.18 (95% CI: −0.99 to 0.62). Compared to no screening for MRSA, the poor quality study29 found a statistically significant reduction in the trend of the hospital-associated incidence density of MRSA bloodstream infection in the ICU, non-ICU settings, and hospital wide with screening for MRSA in the ICU. In addition, this study29 found a statistically significant reduction in the trend of the hospital-associated incidence of MRSA bloodstream infection hospital wide with screening for MRSA in the ICU. The non-CCS study51 found a statistically significant reduction in the rate of acquired MRSA bacteremia (including bloodstream infection) with screening for MRSA in the ICU compared to no screening for MRSA.

##### Strength of Evidence

The SOE for the effect of screening for MRSA carriage in ICU patients compared to no screening on healthcare-associated MRSA bacteremia or bloodstream infection was judged to be insufficient. Two CCS studies addressed this outcome; the Robicsek study was a limited time series design30 of good quality and the Huang study was a before/after study29 of poor quality because it did not report baseline group characteristics and whether its analysis controlled for confounders. The risk of bias was deemed to be high as the body of evidence was comprised of quasi-experimental studies, only one of which was good quality30. Because both studies showed a reduction in MRSA bacteremia or bloodstream infection with screening, the results were consistent. The studies evaluated healthcare-associated MRSA bacteremia or bloodstream infection, which are health outcomes. Therefore, the outcome was direct. Because the individual studies did not consistently report statistically significant results, the findings were imprecise. Because the evidence base for this outcome includes only quasi-experimental studies, the starting level for the SOE was low. SOE was lowered by the high risk of bias and the lack of precision. In summary, the SOE is insufficient to support or refute that compared to no screening, screening for MRSA carriage in ICU patients decreases healthcare-associated MRSA bacteremia or bloodstream infection.

##### Comment, Non-CCS Studies

One non-CCS study51 evaluated the impact of screening for MRSA carriage in the ICU on healthcare-associated MRSA bacteremia or bloodstream infection. Compared to no screening, this study51 found a statistically significant reduction in the rate of acquired MRSA bacteremia (including bloodstream infection) with screening for MRSA in the ICU.

#### Healthcare-Associated MRSA Surgical Site Infection

One good quality study30 addressed this outcome. The Robicsek study found a reduction in hospital-associated SSIs with screening in the ICU compared to no screening; however, this reduction was not statistically significant.30 With screening, the study found no statistically significant reduction in healthcare-associated MRSA infection (rate difference −0.77; 95% CI: −1.85 to 0.30).

##### Strength of Evidence

The SOE for the effect of screening for MRSA carriage in ICU patients compared to no screening on healthcare-associated MRSA SSI was judged to be insufficient. One CCS study addressed this outcome; it was a limited time series design of good quality.30 The risk of bias was deemed to be high as the body of evidence consisted of only a single good quality observational study.30 Because only one study addressed this outcome, the consistency was unknown. The study evaluated SSI, a health outcome. Therefore, the outcome was direct. Because the study did not report statistically significant results, the findings were imprecise. Because the evidence base for this outcome included only one observational study, the starting level for the SOE was low. SOE was lowered by the high risk of bias and lack of precision. In summary, the SOE for the effect of screening of ICU patients on healthcare-associated MRSA SSI is judged to be insufficient.

#### Morbidity, Mortality, Harms and Resource Utilization

##### Results

No studies addressed these outcomes.

##### Strength of Evidence for Screening of ICU Patients for MRSA Carriage on Morbidity, Mortality, Harms and Resource Utilization

Because no studies addressed these outcomes, the SOE to evaluate the effect of screening of ICU patients for MRSA carriage on morbidity, mortality, harms or resource utilization is judged to be insufficient.

### Summary Strength of Evidence Across Key Question 3A

A summary of the main syntheses for this question follows in Table 13.

Table 13 Strength of evidence for studies comparing screening of ICU patients versus no screening

Strategies Compared | Outcome | No of Studies^§^ | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Screening of ICU Risk Pts Vs No Screening | MRSA Acquisition | 1 RCT (N=4,056) (Huskins 2011^46^) 3 QEX (N=3097) (Holzmann-Pazgal 2011^45^) (N=Unclear) (Huang 2006^29^) (N=21,754; 166,877^‡^) (Raineri 2007^47^) | Low | Inconsistent | Indirect | Imprecise | Insufficient
Screening of ICU Risk Pts Vs No Screening | MRSA Infection | 2 QEX (N=Unclear) (Robicsek 2008^30^) (N=Unknown) Muder 2008^55^ | High | Consistent | Direct | Imprecise | Insufficient
Screening of ICU Risk Pts Vs No Screening | MRSA Bacteremia or Blood Stream Infection | 2 QEX (N=Unclear) (Robicsek 2008^30^) (N=Unclear) (Huang 2006^29^) | High | Consistent | Direct | Imprecise | Insufficient
Screening of ICU Risk Pts Vs No Screening | MRSA Surgical Site Infection | 1 QEX (N=Unclear) (Robicsek 2008^30^) | High | Unknown | Direct | Imprecise | Insufficient

ICU = intensive care unit; MRSA = methicillin-resistant Staphylococcus aureus; NA = not applicable; QEX = quasi-experimental; RCT = randomized controlled trial

§ Studies that controlled for confounding and/or trend.

‡ Patient days.

## Key Question 3B Screening of Surgical Patients for MRSA Carriage Compared With No Screening

### Overview

This section describes the literature that evaluates screening surgical patients for MRSA carriage compared to no screening. After an overview of the literature, the results are described for each outcome measure: MRSA acquisition, MRSA infection, morbidity, mortality, harms, and resource utilization. Within the category of MRSA infection, we also included results for MRSA SSI, as some studies present this outcome rather than the broader outcome of MRSA infection, irrespective of site. The emphasis in this chapter is on outcomes describing healthcare-associated events. Healthcare-associated outcomes are the primary outcomes of interest because screening for MRSA carriage in health care facilities is most proximately expected to impact healthcare-associated MRSA transmission and infection. SOE syntheses presented here include only CCS studies. Because studies that use simple two-group statistical analyses cannot support causal inferences, the non-CCS studies were excluded from the SOE analysis. Following each SOE synthesis, we comment on the results seen in non-CCS studies. Table 14 summarizes the studies reviewed for Key Question 3B. The study quality details for CCS studies are shown in Table 15.

Table 14 KQ3B: Healthcare-associated MRSA acquisition, infection, or surgical site infection

Outcome | Study | Quality | Statistical Result | Synthesis
HCA acquisition | Harbarth et al., 2008^31^ | Good | NSS ↑ | SOE = insufficient
HCA acquisition | Ellingson et al., 2011^56^ | Poor | NSS ↓
HCA infection | Harbarth et al., 2008^31^ | Good | NSS ↑ | SOE = insufficient
HCA infection | Muder et al., 2008^55^ | Poor | SS ↓ | SOE = insufficient
HCA infection | Kelly et al., 2012^68^ | Non-CCS | NSS ↓ | SOE = insufficient
HCA infection | Sankar et al., 2008^57^ | Non-CCS | SS ↓ | SOE = insufficient
HCA surgical site infection | Harbarth et al., 2008^31^ | Good | NSS ↑ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Chen et al., 2012^69^ | Non-CCS | NSS ↓ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Jog et al., 2008^58^ | Non-CCS | SS ↓ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Keshtgar et al., 2007^74^ | Non-CCS | SS ↓ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Kim et al., 2010^59^ | Non-CCS | SS ↓ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Lipke et al., 2010^60^ | Non-CCS | NSS ↓ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Malde et al., 2006^61^ | Non-CCS | SS ↓ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Nixon et al., 2006^62^ | Non-CCS | SS ↓/NSS↓^a^ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Pofahl et al., 2009^63^ | Non-CCS | SS ↓NSS ↓^b^ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Schelenz et al., 2005^81^ | Non-CCS | NSS ↓ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Sott et al., 2001^64^ | Non-CCS | NSS ↓ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Supriya et al., 2009^65^ | Non-CCS | SS ↓ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Thomas et al., 2007^66^ | Non-CCS | SS ↓ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible
HCA surgical site infection | Walsh et al., 2011^67^ | Non-CCS | SS ↓ | SOE = insufficient Comment: Results from non-CCS studies more consistently favorable than CCS studies, however causal inference is not possible

CCS = studies controlling for confounding and/or secular trend; non-CCS = studies not controlling for confounding and/or secular trend; HCA = Healthcare-associated; KQ = Key Question; NSS = not statistically significant; SOE = strength of evidence; SS = statistically significant

a The reduction in rate was statistically significant for patients admitted emergently, though not for patients admitted electively and screened prior to admission.

b The reduction in rate was statistically significant for patients who underwent joint replacement, though not for patients undergoing other surgical procedures.

Table 15 KQ3B: Study quality details for CCS studies

Author, Year | Reported Baseline Characteristics | Analytic Technique | Test for Trend (1) | Addressed Auto-Correlation (2) | Adjusted for at Least 1 Confounder (3) | Appropriate Analysis of Results^*^ | Quality
Harbarth et al., 2008^31^ | Pt-days, direct admissions, surgical procedures, length of stay, antibiotics, ABHRs | Poisson regression, ANCOVA | Y | Accounted for | Y (Colonization pressure, ABHRs, antibiotic selection pressure) | Y | Good
Muder et al., 2008^55^ | NR | Segmented Poisson regression | Y | NR | NR | N | Poor
Ellingson et al., 2001^56^ | NR | Interrupted time series analysis with Poisson model | Y | Tested for | NR | N | Poor

ABHR = alcohol-based hand rubs; ANCOVA = analysis of covariance; CCS = attempted to control for confounding and/or secular trends; D-W = Durbin-Watson test for autocorrelation; ICP = infection control practices; KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus; N = no; NR = not reported; Pt = patient; Y = yes

* The study was judged to meet appropriate analysis if all 3 elements (1, 2, 3) were present.

Eighteen studies described screening surgical patients for MRSA compared to no screening. Three31,55,56 were CCS studies; 15 were non-CCS studies. The Harbarth study31 was a prospective, interventional cohort study with crossover design. This study31 was judged to be of good quality overall because it presented baseline characteristics for the intervention and control groups, conducted appropriate analyses (tested for trend, addressed autocorrelation and controlled for at least one confounder) and reported on an important (healthcare-associated) outcome. The Muder study55 was a quasi-experimental before/after study design. This study55 was judged to be of poor quality, as it did not report baseline group characteristics, addressing autocorrelation, and whether its analysis controlled for confounders. The Ellingson study56 was a quasi-experimental study with an interrupted time series design. This study56 was determined to be of poor quality as it did not report baseline group characteristics or whether its analysis controlled for confounders. Of the 14 non-CCS studies, all employed a quasi-experimental before/after study design.

All 18 studies evaluated patients undergoing a surgical procedure. There was considerable variation in the type of surgical patient targeted for screening. Five studies31,55,60,63,74 included patients across a broad range of surgeries. Six studies57,59,62,64,68,69 focused on orthopedic surgery patients (including spine surgery) and three studies58,67,81 focused on cardiothoracic surgery patients. Three studies included very specific surgical patient populations (e.g., vascular,61 head and neck cancer,65 percutaneous endoscopic gastrostomy placement66) One study56 evaluated patients admitted to a surgical ward, but did not describe the type(s) of surgical patients included. The 18 studies were all conducted in Europe or the U.S. (one Swiss study, seven U.S. studies, and ten U.K./Ireland studies).

The MRSA screening protocol varied among studies, as did the infection control practices that accompanied screening. In terms of the MRSA screening protocol, five studies31,58,59,63,74 utilized PCR to screen for MRSA and nine studies utilized culture.55,56,61,62,64–67,69 Four studies did not specify whether PCR or culture was utilized to screen for MRSA.57,60,68,81 While waiting for screening test results, two studies55,63 utilized contact isolation for at least some patients. Four studies58,62,67,74 initiated MRSA eradication by topical antimicrobial wash and/or intranasal antibiotics. When bed availability allowed, one study68 isolated high-risk populations (e.g., health care workers, nursing home residents and those known to be previously colonized or infected with MRSA) while waiting for screening results. Eleven studies did not describe the initiation of special procedures while waiting for screening results. Ten studies57,60– 64,67– 69,74 screened at least some patients prior to hospitalization, so MRSA status was known prior to hospitalization. Once patients were found to be MRSA positive, studies varied in the number of interventions applied. The most intensive combination included four elements (contact isolation, intranasal antibiotics, topical antimicrobials, and adjustment in systemic antibiotics) at the time of surgery for four studies.31,59,62,81 Seven studies58,61,63,64,66,67,74 used a protocol with intranasal antibiotics, topical antimicrobials, and adjustment in systemic antibiotics, but did not describe contact isolation procedures. The study by Kelly68 used intranasal antimicrobials and/or topical antimicrobials, isolation and repeat swabs. The remaining six studies used two or fewer procedures in various combinations.

The control arms of each of the sixteen studies included no systematic screening for MRSA. However, the infection control practices of the control groups did vary considerably especially in cases where an individual with MRSA was identified during routine care. In the study by Harbarth et al.,31 control period patients found to have MRSA were treated just as they were in the intervention periods with a combination of isolation, intranasal antibiotics, topical antimicrobial wash, and adjusted use of systemic antibiotic prophylaxis. In the study by Nixon,62 again, intranasal antibiotics and topic antimicrobial wash were used. Walsh and colleagues67 isolated patients with MRSA and adjusted the use of systemic antibiotic prophylaxis. Three other studies58,63,65 described isolating or cohorting patients found to have MRSA during control periods. Most studies provided very little specific information about routine care for patients without MRSA during control periods.

Study durations were divided into control periods and intervention periods of varying lengths. Seven studies had observation periods of two years or more.31,55,56,61,66–68 Two studies62–65 had observation periods less than 1 year. The remaining nine studies57–60,63,66,69,74,81 had observation periods of 1 to 2 years. Six studies58–60,63,67,81 identified MRSA SSI rates as the primary endpoint of interest. Three studies31,65,66 used broader MRSA endpoints such as MRSA infection rates. Ellingson et al.,56 Sankar et al.,57 Kelly et al.,68 and Nixon et al.,62 identified the incidence of MRSA colonization or infection as the primary endpoint. Malde et al.,61 identified wound infection, major limb amputation and death as primary endpoints. Sott et al.,64 identified postoperative sepsis associated with MRSA as the primary endpoint. Muder et al.,55 identified the effectiveness of an industrial systems-engineering approach to a MRSA prevention program as its primary endpoint. Keshtgar et al.,74 described the rate of MRSA SSI and bacteremia as the primary endpoints. Chen et al,69 identified the prevalence of MRSA colonization and the rate of MRSA SSI as the primary endpoints.

### Results by Outcome

#### Healthcare-Associated MRSA Acquisition

Healthcare-associated MRSA acquisition is measured by MRSA colonization or by MRSA colonization or infection that is health care-associated, rather than imported.

##### Results

Two CCS studies addressed this outcome. The study by Harbarth et al.,31 a good quality study with a crossover design, specifically evaluated the incidence of nosocomial MRSA acquisition which included both new infection and colonization. With screening of surgical patients, Harbarth et al.,31 found an increase in the rate ratio for MRSA acquisition to 1.1, but the confidence intervals were wide and not statistically significant (95% CI: 0.8–1.4). The study by Ellingson et al,56 a poor quality study with an interrupted time series design evaluated the incidence of MRSA colonization and infection. With screening of surgical patients, Ellingson et al.,56 found the intervention resulted in an incidence rate ratio of 0.775, but the confidence intervals were wide and not statistically significant (0.371–1.617). Ellingson et al.,56 also found a reduction in the trend in the incidence of MRSA colonization or infection (incidence rate ratio 0.958), but the confidence intervals were not statistically significant (0.909–1.009).

##### Strength of Evidence

The SOE for the effect of screening surgical patients for MRSA carriage compared to no screening on healthcare-associated MRSA acquisition was judged to be insufficient. Two CCS studies addressed this outcome; the Harbarth study was a good quality quasi-experimental study31 with a crossover design and the Ellingson study56 was a poor quality study with an interrupted time series design. The Ellingson study56 was determined to be of poor quality as it did not report baseline group characteristics or whether its analysis controlled for confounders. The risk of bias was deemed to be high because the body of evidence consisted of quasi-experimental studies, only one of which was good quality. The findings were inconsistent, because one study31 found an increase in MRSA acquisition with screening and the other56 found a reduction. Thus, the direction of effect differed between the two studies. The studies addressed healthcare-associated MRSA acquisition, an intermediate and therefore, indirect outcome. The study findings were judged to be imprecise because the individual studies did not consistently report statistically significant results. Because the evidence base for this outcome included only observational studies, the starting level for the SOE was low. SOE was lowered by the high risk of bias, lack of consistency and lack of precision. In summary, the SOE for the effect of screening of surgical patients on healthcare-associated MRSA acquisition is judged to be insufficient.

#### Healthcare-Associated MRSA Infection, Irrespective of Site

Four studies reported the effect of MRSA screening in surgical wards on healthcare-associated MRSA infection. The Harbarth and Muder31,55 studies were CCS studies, while the Sankar and Kelly studies57,68 were non-CCS studies.

For the Harbarth study,31 infection was defined as hospital-acquired if it occurred more than 48 hours after admission and less than 72 hours after discharge from the surgical service. This endpoint was assessed among patients with previously known or newly identified MRSA carriage. With screening of surgical patients, Harbarth and colleagues31 found no reduction in the rate of acquired MRSA infection. In fact, the rate of MRSA infection was slightly higher in the intervention group than in the control group (1.11/1000 patient days vs. 0.91/1000 patient days) but was not statistically significant.31 This analysis adjusted for colonization pressure, antibiotic selection pressure, use of alcohol-based hand rubs, temporal trends, and clustering.

For the Muder study,55 healthcare-associated MRSA infection was based on CDC definitions. Using a segmented Poisson regression, Muder and colleagues55 found that MRSA infection steadily declined in the surgical ward (1.56/1000 patient days pre, 0.63/1000 patient days post, p=0.003).

Sankar et al.,57 did label MRSA outcomes as hospital-acquired infection but did not provide a specific definition. Sankar et al.,57 reported that the proportion of patients with MRSA infection declined from 2.4 percent (4/164) to 0.0 percent (0/231) in an unadjusted analysis. Kelly et al.,68 defined MRSA infection according to the CDC guidelines for the prevention of SSIs. With screening for MRSA, Kelly et al.,68 reported a reduction in MRSA infection from 0.49 percent prior to the intervention to 0.35 percent after the intervention. However, this reduction was not statistically significant (p=0.108).

##### Strength of Evidence

The SOE for the effect of screening for MRSA carriage in surgical patients compared to no screening on healthcare-associated MRSA infection was judged to be insufficient. Two CCS studies addressed this outcome; the Harbarth study31 was a prospective, interventional cohort study with crossover design of good quality and the Muder study55 was a before/after study of poor quality. The Muder study55 was determined to be of poor quality because it did not report baseline group characteristics, addressing autocorrelation, and whether its analysis controlled for confounders. The risk of bias was judged to be high because the body of evidence that evaluated this outcome included only quasi-experimental studies, only one of which was of good quality31. With screening in surgical patients, Harbarth and colleagues found no reduction in MRSA infection. On the contrary, the rate was slightly higher, though not statistically significant.31 On the other hand, the Muder study55 found a statistically significant reduction in MRSA SSI. The findings were inconsistent, because one study31 found an increase in MRSA acquisition with screening and the other56 found a reduction. Thus, the direction of effect differed between the two studies. Both studies31,55 evaluated healthcare-associated MRSA infection, a health outcome and therefore, a direct outcome measure. The study findings were judged to be imprecise because the individual studies did not consistently report statistically significant results. Because the evidence base for this outcome included only observational studies, the starting level for the SOE was low. SOE was lowered by the high risk of bias, lack of consistency and lack of precision. In summary, the SOE for the effect of screening for MRSA carriage in surgical patients on healthcare-associated MRSA infection is judged to be insufficient.

##### Comments, Non-CCS Studies

Two non-CCS studies57,68 evaluated the impact of screening for MRSA carriage in surgical patients on healthcare-associated MRSA infection. Compared to no screening, these studies57,68 found a statistically significant reduction in the rate of healthcare-associated MRSA infection with screening for MRSA in surgical patients.

#### MRSA Surgical Site Infection

Fourteen of 18 surgical ward studies reported on MRSA SSI. For three studies, SSI due to MRSA was attributed to surgery if it was documented within 30 days following the surgical procedure.31,59,67 In addition, the Walsh study67 attributed the SSI to surgery if the sternum or deep-organ space was involved within one year of surgery. These three studies also defined MRSA acquisition with some specificity. The Harbarth study,31 a good quality study, found no difference in the rate of MRSA SSI after adjustment for covariates. With screening in surgical patients, Harbarth and colleagues31 found an increase in MRSA SSI which was not statistically significant (rate ratio 1.2; 95% CI: 0.8–1.7). On the other hand, Kim and colleagues59 and Walsh and colleagues,67 both non-CCS studies, found significant reductions in the proportion of surgical patients experiencing MRSA SSI.

The remaining non-CCS surgical ward studies, that addressed MRSA SSI varied in their specific definition of a MRSA SSI. Four of the studies mentioned criteria for identifying MRSA SSI such as the Nosocomial Infection Surveillance System criteria.58,60,63,64 Six studies61,62,65,66,69,81 required both signs of an infected wound and a positive wound swab for MRSA to identify a MRSA SSI. The Keshtgar study74 relied on its hospital wound team to identify SSI through observation, questioning of staff, examination of medical records, and contact with patients by phone or mail.

For all of the non-CCS, the point estimates for MRSA SSI rates were lower in screening periods in comparison to control periods. In seven studies58,59,61,65–67,74 these differences in rates were statistically significant. For four studies,60,63,69,81 the reductions were not statistically significant. For the Nixon study,62 the reduction in rate was statistically significant for patients admitted emergently, though not for patients admitted electively and screened prior to admission. In the Pofahl study,63 the reduction in rate was statistically significant for patients who underwent joint replacement, though not for patients undergoing other surgical procedures.

##### Strength of Evidence

The SOE for the effect of screening for MRSA carriage in surgical patients compared to no screening on MRSA SSI was judged to be insufficient. One CCS studies addressed this outcome; the Harbarth study31 was a prospective, interventional cohort study with crossover design of good quality. The risk of bias was judged to be high because the body of evidence that evaluated this outcome included only quasi-experimental study. With screening in surgical patients, Harbarth and colleagues found no reduction in MRSA SSI; in fact the rate was slightly higher, though not statistically significant.31 The consistency of the findings is unknown, because only one study addressed this outcome. The study evaluated MRSA SSI, a health outcome and therefore, a direct outcome measure. The study findings were judged to be imprecise because the individual study did not report statistically significant results. Because the evidence base for this outcome included only one observational study, the starting level for the SOE was low. The SOE was lowered by the high risk of bias and lack of precision. In summary, the SOE for the effect of screening for MRSA carriage in surgical patients on MRSA SSI is judged to be insufficient.

##### Comment, Non-CCS Studies

Thirteen non-CCS studies evaluated the impact of screening for MRSA carriage in surgical patients on healthcare-associated MRSA infection. Compared to no screening, all of the non-CCS studies found a reduction in the rate of MRSA SSI with screening for MRSA carriage in surgical patients. For seven of these studies, the reduction was statistically significant.58,59,61,65–67,74 For one study62 the reduction was statistically significant for one outcome, but not for another; and for five studies,60,63,64,69,81 the reduction was not statistically significant.

#### Morbidity

No CCS studies evaluated the impact of screening for MRSA carriage in surgical patients on morbidity. However, one non-CCS quasi-experimental study formally evaluated MRSA morbidity. Malde and colleagues61 were specifically interested in major limb amputations among patients who were found to have MRSA colonization or infection. From the Malde study,61 amputation rates declined significantly from 27.8 percent to 9.0 percent for patients with elective admissions. For patients with emergency admissions, the rate of amputation did decline from 50.0 percent to 38.8 percent, but this was not statistically significant.

##### Strength of Evidence

Because no CCS studies addressed this outcome, the SOE to evaluate the effect of screening for MRSA carriage in surgical patients on morbidity is judged to be insufficient.

##### Comment, Non-CCS Studies

One non-CCS study addressed this outcome. With screening, Malde and colleagues61 found a statistically significant reduction in amputation rates from 27.8 percent to 9.0 percent for patients admitted electively. For patients with emergency admissions, the rate of amputation declined from 50.0 percent to 38.8 percent, but this was not statistically significant.61

#### Mortality

##### Results

No CCS studies evaluated the impact of screening for MRSA carriage in surgical patients on mortality. However, one non-CCS quasi-experimental study reported on mortality rates among patients with MRSA colonization or infection.

In the study by Malde and colleagues61 for both elective and emergency admissions, mortality rates for patients with MRSA declined with screening.61 However, these reductions were not statistically significant.

##### Strength of Evidence

Because no CCS studies addressed this outcome, the SOE to evaluate the effect of screening for MRSA carriage in surgical patients on mortality is judged to be insufficient.

##### Comment, Non-CCS Studies

One non-CCS study61 addressed this outcome. With screening, Malde and colleagues61 found reductions in mortality for patients admitted electively or emergently. However, these reductions were not statistically significant.61

#### Harms

##### Results

No studies addressed this outcome.

##### Strength of Evidence for Screening of Surgical Patients for MRSA Carriage on Harms

Because no studies addressed this outcome, the SOE to evaluate the effect of screening of surgical patients for MRSA carriage on harms is judged to be insufficient.

#### Resource Utilization

##### Results

No CCS studies evaluated the impact of screening for MRSA carriage in surgical patients on resource utilization. However, one non-CCS quasi-experimental study reported the impact of screening surgical patients for MRSA carriage on resource utilization. Sankar and colleagues57 found that with screening, the mean length of hospital stay declined by almost one day. In unadjusted analysis, this result was found to be statistically significant.57

##### Strength of Evidence

Because no CCS studies addressed this outcome, the SOE to evaluate the effect of screening for MRSA carriage in surgical patients on resource utilization is judged to be insufficient.

##### Comments, Non-CCS Studies

One non-CCS study57 addressed this outcome. With screening, Sankar and colleagues57 found a reduction in the mean length of hospital stay of almost one day. In unadjusted analysis, this result was found to be statistically significant.57

### Summary Strength of Evidence Across Key Question 3B

A summary of the main syntheses for this question follows in Table 16.

Table 16 Strength of evidence for studies comparing screening of surgical patients versus no screening

Strategies Compared | Outcome | No of Studies^§^ | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Screening of Surgical Pts Vs No Screening | MRSA Acquisition | 1 QEX -crossover design (N=21,754) (Harbarth 2008^31^) 1 QEX (N=Unclear) (Ellingson 2011^56^ | High | Inconsistent | Indirect | Imprecise | Insufficient
Screening of Surgical Pts Vs No Screening | MRSA infection | 1 QEX -crossover design (N=21,754) (Harbarth 2008^31^) 1 QEX (N=21,449^‡^) (Muder 2008^55^) | High | Inconsistent | Direct | Imprecise | Insufficient
Screening of Surgical Pts Vs No Screening | MRSA Surgical Site Infection | 1 QEX - crossover design (N=21,754) (Harbarth 2008^31^) | High | Unknown | Direct | Imprecise | Insufficient

MRSA = methicillin-resistant Staphylococcus aureus; QEX = quasi-experimental

§ Studies that controlled for confounding and/or trend.

‡ Patient days.

## Key Question 3C Screening of High-Risk Patients for MRSA Carriage Compared With No Screening

### Overview

This section describes the literature that evaluates screening of high-risk patients for MRSA carriage compared to no screening. Studies defined high risk based on the patient population (e.g., transferred from a nursing home or other health care facility) or the ward (e.g., high prevalence of MRSA transmission or infection). After an overview of the literature, the results are described for each outcome measure: MRSA acquisition, MRSA infection, morbidity, mortality, harms, and resource utilization. Within the category of MRSA infection, we also included results for MRSA bacteremia or bloodstream infection and for MRSA SSI, as some studies present these outcomes rather than the broader outcome of MRSA infection irrespective of site. The emphasis in this chapter is on outcomes describing healthcare-associated events. Healthcare-associated outcomes are the primary outcomes of interest because screening for MRSA carriage in health care facilities is most proximately expected to impact healthcare-associated MRSA transmission and infection. SOE syntheses presented here include only CCS studies. Because studies that use simple two-group statistical analyses cannot support causal inferences, the non-CCS studies were excluded from the SOE analysis. Following the SOE syntheses, we comment on the pattern of results seen in non-CCS studies. Table 17 summarizes the studies reviewed for Key Question 3C. Table 18 shows study quality details for CCS studies.

Table 17 KQ3C: Healthcare-associated MRSA acquisition, infection, bacteremia, or surgical site infection

Outcome | Study | Quality | Statistical Result | Synthesis
HCA acquisition | Rodriguez-Bano et al., 2010^72^ | Poor | NSS ↓ | SOE = insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA acquisition | Salaripour et al., 2006^76^ | Non-CCS | SS ↓ | SOE = insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA infection | Harbarth et al., 2000^71^ | Poor | SS ↓ | SOE = insufficient
HCA infection | Bowler et al., 2010^73^ | Non-CCS | SS ↓ | SOE = insufficient
HCA infection | Wernitz et al., 2005^77^ | Non-CCS | SS ↓ | SOE = insufficient
HCA bacteremia/blood stream infection | Rodriguez-Bano et al., 2010^72^ | Poor | SS ↓ | SOE = insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA bacteremia/blood stream infection | Chowers et al., 2009^70^ | Poor | SS ↓ | SOE = insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA bacteremia/blood stream infection | Wernitz et al., 2005^77^ | Non-CCS | SS ↓ | SOE = insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA bacteremia/blood stream infection | Pan et al., 2005^75^ | Non-CCS | SS ↓ | SOE = insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA surgical site infection | Harbarth et al., 2000^71^ | Poor | SS ↓ | SOE = insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA surgical site infection | Keshtgar et al., 2008^74^ | Non-CCS | SS ↓ | SOE = insufficient Comment: Causal inference is not possible based on non-CCS studies

HCA = healthcare-associated; KQ = Key Question; non-CCS = studies not controlling for confounding and/or secular trend; NSS = not statistically significant; SOE = strength of evidence; SS = statistically significant

Table 18 KQ3C: Study quality details for CCS studies

Author, Year | Reported Baseline Characteristics | Analytic Technique | Test for Trend (1) | Addressed Auto-Correlation (2) | Adjusted for at Least 1 Confounder (3) | Appropriate Analysis of Results^*^ | Quality
Harbarth et al., 2000^71^ | NR | Poisson regression | N | NR | NR | N | Poor
Chowers et al., 2009^70^ | NR | Poisson regression | Y | Tested for | NR | N | Poor
Rodriguez-Bano et al., 2010^72^ | Age, number diagnoses, antibiotics | segmented regression, D-W test | Y | Tested for | N (indirect control) | N | Poor

CCS = attempted to control for confounding and/or secular trends; D-W = Durbin-Watson test for autocorrelation; KQ = Key question; MRSA = methicillin-resistant Staphylococcus aureus; N = No; NR = not reported; Y = yes

* The study was judged to meet appropriate analysis if all 3 elements (1, 2, 3) were present.

Eight studies described screening of high-risk patients for MRSA carriage compared to no screening. Three were CCS studies70–72 and five73–77 were non-CCS studies. Of the CCS studies, all of the studies were of poor quality.70–72 The Rodriguez-Bano72 study was determined to be of poor quality because it did not perform an appropriate analysis (it performed indirect control of confounders rather than statistical adjustment within the segmented regression analysis). The study by Chowers et al.70 was judged to be of poor quality as it did not report baseline group characteristics or whether its analysis controlled for confounders. The Harbarth study71 was also determined to be of poor quality as it did not report baseline group characteristics, addressing autocorrelation, or whether its analysis controlled for confounders.

All eight studies employed a quasi-experimental study design. The study by Rodriguez-Bano and colleagues, which was of poor quality72 utilized an interrupted times series design, as did the study by Chowers and colleagues,70 another poor quality study. The other studies utilized a before/after study design. In terms of clinical setting, all eight studies evaluated hospitalized patients. Four of the studies took place in teaching hospitals, two in community hospitals, and one in a regional referral hospital.

“Screening of high-risk patients” was defined differently across studies. The study by Rodriguez-Bano and colleagues72 evaluated the screening of patients on high-risk wards as well as high-risk patients. High-risk wards were defined based on clinical epidemiology. High-risk patients were those who were readmitted or who were admitted from long-term care facilities or other hospitals. The Harbarth71 study also evaluated the screening of patients on high-risk wards as well as high-risk patients. High-risk patients were patients known to have been previously colonized or infected with MRSA or roommates of patients found to be MRSA-positive; high-risk wards were those with the highest rate of MRSA colonization or infection. The study by Chowers and colleagues70 evaluated screening of high-risk patients, defined as patients hospitalized during the prior month, receiving hemodialysis, previously known to be MRSA-positive, or transferred from another ward in the hospital, a long-term care facility or another hospital. Of the non-CCS studies, the study by Keshtgar74 evaluated screening of patients on high-risk wards; the studies by Salaripour,76 Wernitz,77 and Bowler73 evaluated screening of high-risk patients; and the study by Pan75 evaluated screening of patients on high-risk wards as well as high-risk patients. The studies varied in their execution of the MRSA screening protocol and the infection control practices that accompanied screening. Seven studies utilized culture to screen patients for MRSA. The Keshtgar study74 utilized PCR to screen patients for MRSA. The Chowers study70 first utilized culture and then utilized PCR to screen patients for MRSA.

The study by Rodriguez-Bano and colleagues72 included MRSA bacteremia as a primary outcome. The other studies reported diverse primary endpoints ranging from nosocomial MRSA76 to MRSA bloodstream infection.75

Of the CCS studies, studies by Rodriguez-Bano and colleagues72 and by Chowers and colleagues70 reported test turnaround time. For the Rodriguez-Bano study,72 the reported turnaround time was described as 37 to 51 hours after culture was performed. The Chowers study70 reported turnaround time as 2 to 4 days after culture was performed and 24 hours after PCR was performed. Of the non-CCS studies, one reported test turnaround time and four did not. The Keshtgar study74 noted the time from sample collection to receipt in lab was 13.7 hours (9.78–15.1), from receipt in the lab to obtaining the result 21.8 hours (21.0–22.5), and from obtaining result to calling the service with the result 1.03 hours (0.83–1.41).

The Pan study75 reported the compliance rate for contact precautions (203/370 patients or 55 percent overall, 62 percent for those known to be MRSA positive during the hospitalization). None of the other seven studies reported the compliance rate for contact precautions.

Beyond MRSA screening, the intervention protocols varied considerably in their infection control practices. For one of its interventions, the study by Rodriguez-Bano and colleagues72 took no specific action for patients awaiting test results in the intervention group or control group. For the other of its interventions, this study72 recommended that patients in the intervention group who were readmitted and were previously colonized with MRSA were preemptively isolated before the results of screening tests were available. The study did not specify any such actions for patients in the control group. Of the other two CCS studies, one70 took no specific action for patients awaiting test results in the intervention or control groups. The exception was the study by Harbarth et al.71 The Harbarth study71 recommended preemptive isolation of patients previously known to be colonized or infected with MRSA for the intervention group, but not for the control group. For the five non-CCS studies, three studies73,75,76 took no specific action for patients awaiting test results in the intervention or control groups. The exceptions were the studies by Wernitz et al.77 and Keshtgar et al.74 The Wernitz study77 recommended isolation, barrier precautions and topical antimicrobial wash for all potential MRSA carriers pending screening test results. The same protocol was applicable to control group patients awaiting test results. The Keshtgar study74 recommended intranasal antimicrobials and topical antimicrobial washes for patients who required emergency surgery before the screening test results were available.

Once a patient was found to be MRSA-positive, the Rodriguez-Bano study72 recommended different actions for MRSA-positive patients in the intervention group in comparison to the control group. In this study,72 MRSA-positive patients in the intervention group received contact precautions and decolonization (intranasal antimicrobials, topical antimicrobial washes) as well as dedicated patient care equipment and disinfection of surfaces and devices. MRSA-positive patients in the control group also received contact precautions, dedicated patient care equipment and disinfection of surfaces and devices, but did not receive decolonization. One of the non-CCS studies, the Wernitz study77 recommended the same action for MRSA-positive patients in the intervention group and in the control group. For the Harbarth,71 Chowers,70 Salaripour,76 and Pan studies,75 steps were taken to isolate and decolonize MRSA-positive patients in the intervention group but no interventions were recommended for MRSA-positive patients in the control group. For the Bowler73 and Keshtgar studies,74 decolonization was recommended for MRSA-positive patients in the intervention group, but not for MRSA-positive patients in the control group.

The control arms of each of the eight studies included no systematic screening for MRSA. However, the infection control practices of the control groups did vary especially in cases where an individual with MRSA was identified during routine care. As mentioned above, the Wernitz study77 decolonized patients in the control group who were found to be MRSA positive.

### Results by Outcome

#### Healthcare-Associated MRSA Acquisition

Healthcare-associated MRSA acquisition is measured by MRSA colonization or by MRSA colonization or infection that is healthcare-associated, rather than imported. Two studies72,76 evaluated healthcare-associated MRSA infection or colonization as an outcome. One72 was a CCS study and one76 was a non-CCS study. The Rodriguez-Bano study, a CCS study, was determined to be of poor quality72 because it used indirect control of confounders rather that statistical adjustment within the segmented regression analysis. Definition of this healthcare-associated MRSA acquisition differed between the studies. The Rodriguez-Bano study72 defined cases as health care-associated if the first sample yielding MRSA was obtained more than 3 calendar days after hospital admission or if the first sample yielding MRSA was obtained from an ambulatory patient with an identified association with recent health care delivery. Cases were excluded as nonincident if a positive clinical culture result could be identified anywhere in the laboratory information system (including long-term care and outpatient settings) within the prior year. The Salaripour study76 defined cases as health care-associated if a positive culture result was obtained more than 72 hours after admission.

In terms of findings, for the Rodriguez-Bano study,72 the reported change in incidence of MRSA acquisition from a segmented regression analysis was −0.065 with confidence intervals that included zero (change in incidence after second intervention −0.053 to 0.182). Considering the baseline rate of 0.55/1000 patient days, this change in incidence rate would be equivalent to a relative risk reduction of −11.8 percent. The reported change in trend in incidence of MRSA acquisition was −0.045 (95% CI: −0.062 to −0.029; p<0.001).72 In univariate analysis, compared to no screening, both interventions showed a reduction in MRSA colonization or infection, though this reduction was not statistically significant.72 The Salaripour study76 also found a statistically significant reduction in healthcare-associated MRSA infection with targeted screening (−0.18 per 1000 patient-days, a 30 percent reduction).

##### Strength of Evidence

The SOE for the effect of screening for MRSA carriage in high-risk patients compared to no screening on healthcare-associated MRSA acquisition was judged to be insufficient. One CCS study72 addressed this outcome. This study, by Rodriguez-Bano and colleagues, was an interrupted time series design of poor quality.72 The study was judged to be of poor quality because it did not conduct an appropriate analysis, using indirect control of confounders rather that statistical adjustment within its segmented regression analysis. The risk of bias for the body of evidence was deemed to be high because only a single poor quality quasi-experimental study72 evaluated this outcome. As only one study72 evaluated this outcome, the consistency of the findings was unknown. The study addressed healthcare-associated MRSA acquisition, an intermediate and therefore, indirect outcome. The study findings72 were judged to be imprecise because the study reported statistically significant findings for trend, though nonstatistically significant findings for rate. Because the evidence base for this outcome included only one quasi-experimental study, the starting level for the SOE was low. SOE was lowered by the high risk of bias and lack of precision. In summary, the SOE for the effect of screening of high-risk patients on healthcare-associated MRSA acquisition is judged to be insufficient.

##### Comment, Non-CCS Study

One non-CCS study76 addressed this outcome. With screening of high-risk patients, the Salaripour study76 demonstrated a statistically significant reduction in healthcare-associated MRSA colonization or infection.

#### Healthcare-Associated MRSA Infection, Irrespective of Site

##### Results

Three studies71,73,77 evaluated the impact of screening for MRSA carriage in high-risk patients on healthcare-associated MRSA infection. One71 was a CCS study and two73,77 were non-CCS studies. All three studies defined healthcare-associated MRSA infection as clinical signs of infection 48 hours or more after admission, with MRSA isolated as the causative pathogen. All studies showed a statistically significant reduction in healthcare-associated MRSA infection with screening of high-risk patients compared to no screening.

##### Strength of Evidence

The SOE for the effect of screening for MRSA carriage in high-risk patients compared to no screening on healthcare-associated MRSA infection was judged to be insufficient. One CCS study71 addressed this outcome. This study, by Harbarth and colleagues,71 utilized a before/after design and was judged to be of poor quality as it did not report baseline group characteristics, addressing autocorrelation, or whether its analysis controlled for confounders. The risk of bias for the body of evidence was deemed to be high because only one poor quality quasi-experimental study addressed this outcome. As only one study evaluated this outcome, the consistency of the findings was unknown. This study evaluated healthcare-associated MRSA infection, a health outcome and therefore, a direct outcome measure. The study findings were judged to be precise because they were statistically significant. Because the evidence base for this outcome included only one quasi-experimental study, the SOE was low. SOE was lowered by the high risk of bias. In summary, the SOE for the effect of screening of high-risk patients on healthcare-associated MRSA infection is judged to be insufficient.

##### Comment, Non-CCS Studies

Two non-CCS studies evaluated this outcome.73 Compared to no screening, both studies showed a statistically significant reduction in healthcare-associated MRSA infection with screening of high-risk patients.73,77

#### Healthcare-Associated MRSA Bacteremia or Bloodstream Infection

Four studies addressed the impact of screening on rates of healthcare-associated MRSA bacteremia or bloodstream infection. Two were CCS studies70,72 and two were non-CCS studies75,77. Of the CCS studies, both the Rodriguez-Bano study72 and the Chowers study70 were determined to be of poor quality. The Rodriguez-Bano study72 measured MRSA bacteremia and defined cases as health care-associated if the first sample yielding MRSA was obtained more than 3 calendar days after hospital admission or if the first sample yielding MRSA was obtained from an ambulatory patient with an identified association with recent health care delivery. The Wernitz77 and Pan75 studies defined cases as health care-associated if a positive, clinical MRSA culture result was obtained at least 48 hours after admission. The Chowers study70 defined bacteremia as health care-associated if a positive blood culture result was obtained from blood drawn 48 hours or more after admission, or from blood drawn at admission from any patient who had been admitted to the study hospital during the prior year.

With segmented regression analysis, the study by Rodriguez-Bano and colleagues72 reported that the change in incidence of MRSA bacteremia was −0.051 after the intervention (95% CI: −0.083 to −0.020, p=0.002). The change in trend in MRSA bacteremia was −0.006 after the second intervention (95% CI: −0.10 to −0.01, p=0.01). In univariate analysis, compared to no screening, both interventions showed a reduction in MRSA bacteremia, though this reduction was not statistically significant. The Chowers study70 found a reduction in the average number of bacteremia cases per 1,000 patient-days by a factor of 0.55 with one component of the intervention (95% CI: 0.36–0.83). With another component of the intervention, there was a reduction in the average number of bacteremia cases per 1,000 patient-days by a factor of 0.27 (95% CI: 0.14–0.58). The Wernitz77 and Pan75 studies also showed a statistically significant reduction in healthcare-associated MRSA bloodstream infection with screening of high-risk patients compared to no screening.

##### Strength of Evidence

The SOE for the effect of screening for MRSA carriage in high-risk patients compared to no screening on healthcare-associated MRSA bacteremia or bloodstream infection was judged to be insufficient. Two CCS studies addressed this outcome. The study by Rodriguez-Bano et al.,72 utilized a limited time series design and was judged to be of poor quality because it used indirect control of confounders rather that statistical adjustment within the segmented regression analysis. The study by Chowers et al.,70 also utilized a limited time series design and was judged to be of poor quality as it did not report baseline group characteristics or whether its analysis controlled for confounders. The risk of bias for the body of evidence was determined to be high as two quasi-experimental studies70,72 of poor quality addressed this outcome. The study findings were consistent, because both studies70, 72 showed a reduction in MRSA bacteremia or bloodstream infection with screening. The studies70,72 evaluated MRSA bacteremia or MRSA bloodstream infection, which are health outcomes and therefore, direct outcome measures. The study findings were judged to be precise because the individual studies consistently reported statistically significant results. Because the evidence base for this outcome included only observational studies, the starting level for the SOE was low. SOE was lowered by the high risk of bias. In summary, the SOE for the effect of screening for MRSA carriage in high-risk patients compared to no screening on healthcare-associated MRSA bacteremia or bloodstream infection is judged to be insufficient.

##### Comment, Non-CCS Studies

Two non-CCS studies evaluated this outcome.75,77 Compared to no screening, both studies showed a statistically significant reduction in healthcare-associated MRSA infection with screening of high-risk patients.75,77

#### MRSA Surgical Site Infection

Two studies addressed this outcome. One was a CCS study71 and one74 was a non-CCS study. Both the Harbarth71 and Keshtgar74 studies showed a statistically significant reduction in healthcare-associated MRSA SSI with screening of high-risk patients compared to no screening.

##### Strength of Evidence

The SOE for the effect of screening for MRSA carriage in high-risk patients compared to no screening on MRSA SSI was judged to be insufficient. One CCS study71 addressed this outcome. This study, by Harbarth and colleagues,71 utilized a before/after design and was judged to be of poor quality as it did not report baseline group characteristics, addressing autocorrelation, or whether its analysis controlled for confounders. The risk of bias for the body of evidence was deemed to be high because only a single poor quality quasi-experimental study71 addressed this outcome. As only one study71 evaluated this outcome, the consistency of the findings was unknown. The study71 evaluated MRSA SSI, a health outcome and therefore, a direct outcome measure. The study findings were judged to be precise because the individual study that addressed this question reported a statistically significant result. Because the evidence base for this outcome included only one quasi-experimental study, the starting level for the SOE was low. SOE was lowered by the high risk of bias. In summary, the SOE for the effect of screening of high-risk patients on MRSA SSI is judged to be insufficient.

##### Comment, Non-CCS Studies

One non-CCS study74 addressed this outcome. The Keshtgar74 study showed a statistically significant reduction in MRSA SSI with screening of high-risk patients compared to no screening.

#### Morbidity, Mortality, Harms and Resource Utilization

##### Results

No studies addressed these outcomes.

##### Strength of Evidence for Screening of High-Risk Patients for MRSA Carriage on Morbidity, Mortality, Harms and Resource Utilization

Because no studies addressed these outcomes, the SOE to evaluate the effect of screening of high-risk patients for MRSA carriage on morbidity, mortality, harms or resource utilization is judged to be insufficient.

### Summary Strength of Evidence Across Key Question 3C

A summary of the main syntheses for this question follows in Table 19.

Table 19 Strength of evidence for studies comparing screening of high risk patients versus no screening

Strategies Compared | Outcome | No of Studies^§^ | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Screening of High Risk Pts Vs No Screening | MRSA Acquisition | 1 QEX (N=Unclear) (Rodriguez-Bano 2010^72^) | High | Unknown | Indirect | Imprecise | Insufficient
Screening of High Risk Pts Vs No Screening | MRSA Infection | 1 QEX (N=506,012) (Harbarth 2000^71^) | High | Unknown | Direct | Precise | Insufficient
Screening of High Risk Pts Vs No Screening | MRSA Bacteremia/Blood Stream Infection | 2 QEX (N=Unclear) (Rodriguez-Bano 2010^72^) (N=377,945; 1,535,806^‡^) (Chowers 2009^70^) | High | Consistent | Direct | Precise | Insufficient
Screening of High Risk Pts Vs No Screening | MRSA Surgical Site Infection | 1 QEX (N=506,012) (Harbarth 2000^71^) | High | Unknown | Direct | Precise | Insufficient

MRSA = methicillin-resistant Staphylococcus aureus; NA = not applicable; QEX = quasi-experimental

§ Studies that controlled for confounding and/or trend.

‡ Patient days.

## Key Question 4 Screening of a Broader Patient Population for MRSA Carriage (Expanded Screening) Compared With Screening of a Narrower Patient Population (Limited Screening)

### Overview

This section describes the literature that evaluates expanded screening for MRSA carriage compared to limited screening. Studies described in this section conducted MRSA surveillance for a limited patient population or number of wards (e.g., screening of all patients admitted to the ICU) at baseline and then expanded MRSA surveillance to a larger population or number of wards (e.g., screening of all patients admitted to acute care units). These studies compared outcomes during the expanded screening period to those during the limited screening period. After an overview of the literature, the results are described for each outcome measure: MRSA acquisition, MRSA infection, morbidity, mortality, harms, and resource utilization. Within the category of MRSA infection, we also included results for MRSA bacteremia or bloodstream infection, as some studies present these outcomes rather than the broader outcome of MRSA infection irrespective of site. The emphasis in this chapter is on outcomes describing healthcare-associated events. Healthcare-associated outcomes are the primary outcomes of interest because screening for MRSA carriage in health care facilities is most proximately expected to impact healthcare-associated MRSA transmission and infection. SOE syntheses presented here include only CCS studies. Because studies that use simple two-group statistical analyses cannot support causal inferences, the non-CCS studies were excluded from the SOE analysis. We present the SOE assessment for MRSA acquisition, MRSA infection (considering studies that addressed either MRSA infection regardless of site together with those that addressed MRSA bacteremia or bloodstream infection), morbidity, mortality, harms and resource utilization. Following the SOE syntheses, we comment on the pattern of results seen in non-CCS studies. Table 20 summarizes the studies reviewed for Key Question 4. Note that Table 20 does not include the Enoch study85 because it did not report outcomes that were exclusively health-care associated. Table 21 shows the study quality details for CCS studies.

Table 20 KQ4: Healthcare-associated MRSA acquisition, infection, or bacteremia

Outcome | Study | Quality | Statistical Result | Synthesis
HCA acquisition | Rodriguez-Bano et al., 2010^72^ | Poor | Incidence NSS ↓ Trend SS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA acquisition | Ellingson et al., 2011^56^ | Poor | Incidence SS ↓^a^ Incidence NSS↓^b^ Trend NSS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA acquisition | Eveillard et al., 2006^79^ | Non-CCS | SS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA acquisition | Girou et al., 2000^80^ | Non-CCS | NSS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA acquisition | Schelenz et al., 2005^81^ | Non-CCS | SS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA acquisition | Thompson et al., 2009^82^ | Non-CCS | SS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA acquisition | Trautmann et al., 2007^83^ | Non-CCS | SS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA infection | Chaberny et al., 2008^78^ | Poor | SS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA infection | West et al., 2006^84^ | Non-CCS | NSS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA bacteremia/blood stream infection | Rodriguez-Bano et al., 2010^72^ | Poor | Incidence NSS ↓ Trend NSS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA bacteremia/blood stream infection | Thompson et al., 2009^82^ | Non-CCS | SS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies
HCA bacteremia/blood stream infection | Trautmann et al., 2007^83^ | Non-CCS | SS ↓ | SOE=insufficient Comment: Causal inference is not possible based on non-CCS studies

HCA = health care associated; KQ = Key Question; non-CCS = studies not controlling for confounding and/or secular trend; NSS = non statistically significant; SOE = strength of evidence; SS = statistically significant

a The reduction was statistically significant following the third intervention.

b The reduction was not statistically significant following the second intervention.

Table 21 KQ4: Study quality details for CCS studies

Author, Year | Reported Baseline Characteristics | Analytic Technique | Test for Trend (1) | Addressed Auto-Correlation (2) | Adjusted for at Least 1 Confounder (3) | Appropriate Analysis of Results^*^ | Quality
Chaberny et al., 2008^78^ | Pt-days, length of stay | Segmented regression of ITS | Y | Tested for | NR | N | Poor
Rodriguez-Bano, et al., 2010^72^ | Age, number diagnoses, antibiotics | Segmented regression, D-W test | Y | Tested for | N (indirect control ) | Y | Poor
Ellingson, et al., 2011^56^ | NR | Interrupted time series analysis with Poisson model | Y | Tested for | NR | N | Poor

CCS = attempted to control for confounding and/or secular trends; D-W = Durbin-Watson test for autocorrelation; ITS = interrupted time-series; KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus; N = no; NR = not reported; Pt = patient; Y = yes

* The study was judged to meet appropriate analysis if all 3 elements (1, 2, 3) were present.

Ten studies56,72,78–85 described limited screening for MRSA carriage compared to expanded screening. The studies by Chaberny78, Ellingson,56 and Rodriguez-Bano72 were CCS studies; the remaining seven79–85 were non-CCS studies. All ten56,72,78–85 studies employed a quasi-experimental study design.

The study by Rodriguez-Bano and colleagues72 utilized an interrupted time series design as did the study by Ellingson and colleagues.56 The eight other studies utilized a before/after study design. The study by Rodriguez-Bano72 and colleagues was judged to be of poor quality72 because it controlled for confounders indirectly, rather than employing statistical adjustment within the segmented regression analysis. The study by Ellingson and colleagues56 was determined to be of poor quality because it did not report baseline group characteristics or whether its analysis controlled for confounders. The study by Chaberny and colleagues78 was determined to be of poor quality because it did not report whether its analysis controlled for confounders.

All ten studies evaluated hospitalized adult patients. All of the CCS studies56,72,78 took place in more than one area of the hospital, as did one of the non-CCS studies.85 Three82–84 of the non-CCS studies took place in the ICU. One of the non-CCS studies was conducted on the cardiothoracic ward,81 one on the internal medicine ward,79 and one on the dermatology ward.80

The exact composition of the expanded MRSA screening intervention varied across the studies. Eight studies utilized culture to screen patients for MRSA. The study by Schelenz and colleagues81 did not specify whether screening was performed with culture or PCR. The study by Enoch and colleagues85 initially utilized culture to screen for MRSA, then introduced screening with PCR. For the study by Rodriguez-Bano and colleagues,72 the intervention was active surveillance for MRSA and decolonization in patients and health care workers in wards with documented MRSA transmission, and surveillance of all patients admitted from other hospitals or from long-term care facilities and all readmitted patients previously colonized with MRSA. For the study by Chaberny and colleagues,78 the intervention was screening of readmitted patients as well as roommates of patients with MRSA plus screening of all admitted patients on surgical wards and ICUs. For the study by Ellingson and colleagues,56 the intervention consisted of systems and behavior change strategies to promote adherence to the infection control protocol, enhanced emphasis on hand hygiene and environmental disinfection, and surveillance testing of the anterior nares and open wounds within 48 hours after admission. The intervention was begun in the surgical ward, then in the surgical ICU and ultimately, in all acute care units of the hospital. For two of the non-CCS studies, the intervention was screening of all patients admitted to a single ward. The study by Eveillard and colleagues79 screened all patients admitted to the internal medicine service. The study by Girou and colleagues80 screened all patients admitted to the dermatology ward within 48–72 hours of admission.

Two of the non-CCS studies included screening of high-risk patients as well as those admitted to the ICU. The study by West and colleagues84 defined high risk patients as those transferred from another hospital, admitted from long-term care facilities, readmitted within 30 days after discharge, or admitted to a nephrology service. The study by Trautmann and colleagues83 defined high-risk patients as (1) patients with chronic open wounds or pressure sores; (2) patients transferred from secondary or tertiary acute care hospitals; (3) bed-bound patients from chronic care facilities; (4) patients with insulin-dependent diabetes mellitus; and (5) patients with chronic renal failure on dialysis. In addition to screening, the Trautmann study83 included additional interventions including a written standard detailing hygienic precautions for MRSA, acquisition of long-sleeved isolation gowns, acquisition of carts to facilitate the use of separate supplies for MRSA patients, isolation signs, enhanced documentation of MRSA cases, feedback and staff training, and flagging of electronic charts for patients with MRSA. For the study by Thompson and colleagues,82 the intervention was screening all admissions to the ICU, daily antimicrobial washes for all patients regardless of MRSA status, scrubs for medical staff, computer keyboards with a wipeable surface, and standardized care of vascular lines.

For the study by Schelenz and colleagues,81 the intervention included multiple components: (1) preadmission, admission, and weekly screening for all admitted ward patients; (2) decolonization (intranasal antimicrobials, topical antimicrobials) for patients found to be MRSA positive; (3) admission of patients from high-risk units (ICUs, other hospitals), only after MRSA status known; (4) audit plus feedback; (5) education and support; (6) closure of operating rooms to facilitate repairs; (7) alcohol hand rub; (8) isolation on admission for patients known to be colonized with MRSA; (9) decolonization (intranasal antimicrobials, topical antimicrobials) of both MRSA carriers and those with pending screening test results 24 hours before surgery; (10) isolation and barrier precautions for MRSA-positive patients; (11) designated nurses for MRSA-positive patients; (12) a nursing care pathway for MRSA; (13) use of clippers to prepare the skin in the operating room; (14) preoperative skin disinfection with a rapidly drying solution; (15) improvements in environmental cleaning; (16) alterative in IV antibiotic prophylaxis; and (17) recovery in the operating room when possible, rather than admission to the ICU. The study by Enoch and colleagues85 also included multiple interventions including screening (first of patients with central venous catheters, then elective screening, then emergency screening along with seven-day testing), decolonization (all patients admitted to the ICU of high dependency unit regardless of test result), prosthetic device care, input from an infection control team, and enhanced environmental cleaning and space for isolation.

An important feature of this group of studies was that limited screening was already occurring at baseline, so it is important to understand the nature of screening during control periods. For the Rodriguez-Bano study72 the control condition consisted of active surveillance for MRSA and decolonization in patients and health care workers in wards with documented MRSA transmission. The Chaberny study78 screened readmitted patients as well as roommates of patients with MRSA. For the Ellingson study, an interrupted time series design, the control condition was patients in the surgical ward and subsequently patients in the surgical ICU. For five of the non-CCS studies, the control condition consisted of screening high-risk patients. The Eveillard study79 screened patients with a history of MRSA carriage, hospitalization, or institutionalization within the prior year, intra- or inter-hospital transfers, and patients with chronic skin lesions. The Girou study80 screened patients transferred from other wards, with a history of prior hospitalization in the past 3 years, with chronic wounds, or with a disease with denuded skin. The Trautmann study83 screened (1) patients with chronic open wounds or pressure sores; (2) patients transferred from secondary or tertiary acute care hospitals; (3) bed-bound patients from chronic care facilities; (4) patients with insulin-dependent diabetes mellitus; and (5) patients with chronic renal failure on dialysis. The Thompson study82 screened high-risk patients, but did not define this population group. For the West study,84 the control condition was screening upon admission to the ICU and weekly thereafter. The Enoch study85 screened patients considered to be high risk by national guidelines. For the Schelenz study,81 the control condition was pre-admission, admission, and weekly MRSA screening.

While all ten studies evaluated similar MRSA outcomes, the primary outcome of interest varied. For the Rodriguez-Bano study,72 the primary outcome was rates of MRSA colonization or infection and rates of bacteremia. For the Ellingson study,56 the primary outcome was the clinical incidence of MRSA colonization or infection. For the Chaberny and West studies,78,84 the primary outcome was incidence of nosocomial MRSA infection. For the Eveillard study79, the primary outcomes were the prevalence of MRSA carriage on admission, the efficiency of the selective screening program and the effectiveness of the screening program on controlling MRSA transmission. For the Girou study,80 the primary outcomes were the number of patients without risk factors found to screen positive for MRSA, the rate of acquired MRSA, and the rate of imported MRSA. For the Thompson study,82 the primary outcome was to detect long-term trends in the prevalence of MRSA in admissions, MRSA acquisition and bacteremia rates within the ICU, and to determine the effect of the three interventions. For the Trautmann study,83 the primary outcome was the nosocomial MRSA transmission. For the Schelenz study,81 the primary outcomes were rates of MRSA acquisition and infection. For the Enoch study,85 the primary outcome was the use of bacteremia compared with clinical isolates to determine the effectiveness of the interventions.

Infection control practices varied in the background of these studies. In terms of actions taken while awaiting test results, the study by Rodriguez-Bano and colleagues,72 a poor quality study, recommended actions for patients in the intervention group while awaiting test results. This study72 recommended preemptive isolation for readmitted patients previously colonized with MRSA. However, preemptive isolation or decolonization for patients was not recommended for patients in the control group while awaiting test results. The studies by Chaberny and colleagues78 and Ellingson and colleagues,56 both poor quality studies, did not report actions while waiting for screening test results. Similarly, the study by Enoch and colleagues,85 a non-CCS study, did not report actions for patients awaiting test results in the intervention group or in the control group. Five of the non-CCS studies utilized the same action for patients in the intervention group awaiting test results as for patients in the control group awaiting test results. The West study84 recommended preemptive isolation and barrier precautions for patients found to have MRSA colonization or infection on a prior admission. The Girou study80 recommended isolation and barrier precautions for patients at high risk of MRSA acquisition. Four studies78,79,82,83 recommended no interventions while awaiting screening test results. The Schelenz study81 utilized different actions for patients in the intervention group awaiting tests results as for patients in the control group awaiting test results. No interventions were recommended for patients in the control group while awaiting screening results. In the intervention group, patients were not admitted to the ward until their MRSA status was known. In addition, presumptive decolonization was recommended for patients in the intervention group whose test results were not available 24 hours prior to surgery.

Once a patient was found to have a MRSA positive screening test, practices were similar for patients in the intervention and control groups. The Rodriguez-Bano study72 utilized similar interventions for MRSA-positive patients in the intervention and control groups. Action consisted of isolation (including barrier precautions), decolonization (intranasal and topical antimicrobials) and follow up nasal swabs for both the groups. Hand hygiene was recommended for the care of MRSA-positive patients in both groups, but alcohol hand rubs were available only during the intervention period. In the Ellingson study,56 MRSA-positive patients in the intervention and control groups received contact precautions and unspecified hand hygiene. Similarly, the Chaberny study78 utilized the same interventions for MRSA-positive patients in the intervention group and in the control group, as did four of the non-CCS studies.79,80,82,84 Two81,83 of the non-CCS studies utilized similar interventions for MRSA-positive patients in the intervention group and in the control group. For one of these studies, MRSA-positive patients in the intervention group were isolated, but those in the control group were isolated only if an isolation room was available.

### Results by Outcome

#### Healthcare-Associated MRSA Acquisition

Healthcare-associated MRSA acquisition is measured by MRSA colonization or by MRSA colonization or infection that is health care-associated, rather than imported. Seven studies evaluated healthcare-associated MRSA infection or colonization as an outcome. The studies by Rodriguez-Bano and colleagues72 and Ellingson and colleagues56 were the CCS studies, while the studies by Eveillard and colleagues,79 Trautmann and colleagues,83 Thompson and colleagues,82 Girou and colleagues,80 and Schelenz and colleagues81 were non-CCS studies. The Rodriguez-Bano study, an interrupted time series design, was determined to be of poor quality72 because it controlled for confounders indirectly, rather than employing statistical adjustment within the segmented regression analysis. The study by Ellingson and colleagues,56 an interrupted time series design, was determined to be of poor quality because it did not report baseline group characteristics or whether its analysis controlled for confounders.

The study by Rodriguez-Bano and colleagues, a poor quality study72 defined cases as health care-associated if the first sample yielding MRSA was obtained more than 3 calendar days after hospital admission or if the first sample yielding MRSA was obtained from an ambulatory patient with an identified association with recent health care delivery. The study by Ellingson and colleagues56 defined cases as health care-associated if a positive, clinical MRSA culture result was obtained at least 48 hours after admission to an acute care unit or if the patient was transferred, within 48 hours after transfer to another unit.

The Eveillard and Trautmann studies79,83 defined colonization or infection as health care-associated if patients were identified as MRSA positive two or more days after admission. The Thompson study82 defined colonization or infection as health care-associated if growth of MRSA was noted five or more days after admission to the ICU in patients who initially screened negative for MRSA. The Girou study80 defined colonization or infection as health care-associated if the first MRSA isolate from any source was recovered more than 72 hours after admission. The Schelenz study81 defined MRSA acquisition as the isolation of MRSA from any site more than 72 hours after admission to the ward in patients who had no previous history of MRSA colonization or infection. MRSA infections were defined as the isolation of MRSA from blood culture or surgical wound sites that had evidence of clinical infection.

The Rodriguez-Bano study72 showed reductions in the incidence and trend of healthcare-associated MRSA infection or colonization with expanded screening compared to limited screening. Though the reduction in trend was statistically significant (change in trend after the third intervention 0.047; 95% CI: 0.035 to 0.059, p<0.001), the reduction in incidence was not (change in incidence after the third intervention 0.077 [NSS; 95% CI: −0.012 to 0.165]).72 Of note, for the calculation of incidences of MRSA colonization or infection, only patients who had MRSA isolated from clinical samples were included because active surveillance was not performed uniformly throughout the study periods. The Ellingson study56 showed reductions in the incidence rate ratio for MRSA colonization or infection after the second intervention (screening for MRSA carriage in the ICU, incidence rate ratio 0.913, 95% CI: 0.356 to 2.343) and after the third intervention (screening for MRSA carriage in all other acute care units, incidence rate ratio 0.656, 95% CI: 0.440 to 0.979). In addition, the Ellingson study56 showed reduction in the pre- to post-intervention trends (screening for MRSA carriage in the ICU, incidence rate ratio 0.971, 95% CI: 0.938 to 1.004) and after the third intervention (screening for MRSA carriage in all other acute care units, incidence rate ratio 0.998, 95% CI: 0.982 to 1.014). All five of the non-CCS studies showed a reduction in hospital-acquired MRSA infection with expanded targeted screening compared to limited targeted screening. The studies by Eveillard, Thompson, Trautmann, and Schelenz79,81–83 showed a statistically significant reduction and the study by Girou80 did not.

##### Strength of Evidence

The SOE for the effect of expanded screening for MRSA carriage compared to limited screening on healthcare-associated MRSA acquisition was determined to be insufficient. Two CCS studies addressed this outcome. The study by Rodriguez-Bano et al.,72 utilized a limited time series design and was judged to be of poor quality because it used indirect control of confounders rather than statistical adjustment within the segmented regression analysis. The study by Ellingson et al.,56 also utilized a limited time series design, and was judged to be of poor quality as it did not report baseline group characteristics or whether its analysis controlled for confounders. The risk of bias for the body of evidence was determined to be high as two quasi-experimental studies56,72 of poor quality addressed this outcome. The study findings were consistent, because both studies found a reduction in healthcare-associated MRSA acquisition with screening. The studies addressed healthcare-associated MRSA acquisition, an intermediate and therefore, indirect outcome. The study findings were judged to be imprecise because the individual studies did not consistently report statistically significant results. Because the evidence base for this outcome included only quasi-experimental studies, the starting level for the SOE was low. SOE was lowered by the high risk of bias. In summary, the SOE for the effect of expanded screening for MRSA carriage compared to limited screening on healthcare-associated MRSA acquisition is judged to be insufficient.

##### Comments, Non-CCS Studies

Five non-CCS studies addressed this outcome.79–83 With expanded screening compared to limited screening, all five studies showed a reduction in MRSA infection. The reduction was statistically significant for four of the non-CCS studies,79,81–83 though not for one80 of the non-CCS studies.

#### Healthcare-Associated MRSA Infection, Irrespective of Site

Two studies78,84 addressed this outcome. The study by Chaberny and colleagues78 was a CCS-study while the study by West and colleagues84 was a non-CCS study. The study by Chaberny and colleagues78 was determined to be of poor quality because it did not report whether its analysis controlled for confounders. Both studies defined hospital-acquired infection as an infection detected at least 72 hours after admission. Chaberny et al.,78 showed a statistically significant reduction in hospital-acquired MRSA infection (based on the change in level and slope of the incidence density) with expanded screening compared to limited screening. West et al.,84 showed a reduction in hospital-acquired MRSA infection with expanded screening compared to limited screening; however, this reduction was not statistically significant.

##### Strength of Evidence

The SOE for the effect of expanded screening for MRSA carriage compared to limited screening on healthcare-associated MRSA infection irrespective of site was determined to be insufficient. One CCS study addressed this outcome. The study by Chaberny et al.,78 utilized a before/after study design and was judged to be of poor quality as it did not report whether its analysis controlled for confounders. The risk of bias for the body of evidence was determined to be high because only one poor quality quasi-experimental study addressed this outcome. With expanded screening, Chaberny et al.,78 found a reduction in the incidence density of healthcare-associated MRSA infection (change in level −0.122, 95% CI: −0.204 to −0.040, p=0.004). In addition, Chaberny et al.,78 found a reduction in the monthly change in incidence density of healthcare-associated MRSA infection (change in slope −0.008, 95% CI: −0.013 to −0.003, p=0.004). The consistency of the findings was unknown, because only one study addressed this outcome. This study evaluated MRSA infection, a health outcome and therefore, a direct outcome measure. The study findings were judged to be precise, because the single study that addressed this outcome found statistically significant results. Because the evidence base for this outcome included only one quasi-experimental study, the starting level for the SOE was low. SOE was lowered by the high risk of bias. In summary, the SOE for the effect of expanded screening for MRSA carriage compared to limited screening on healthcare-associated MRSA infection is judged to be insufficient.

#### Healthcare-Associated MRSA Bacteremia or Bloodstream Infection

Three studies addressed this outcome. The study by Rodriguez-Bano and colleagues72 was a CCS study, while the studies by Thompson and colleagues82 and by Trautmann and colleagues83 were non-CCS studies. The study by Rodriguez-Bano and colleagues was determined to be of poor quality72 because it controlled for confounders indirectly, rather than employing statistical adjustment within the segmented regression analysis. The Rodriguez-Bano study72 defined bacteremia as health care-associated if the first sample yielding MRSA had been obtained more than 3 calendar days after hospital admission or if the first sample yielding MRSA had been obtained from an ambulatory patient who had an identified association with recent health care delivery. The Thompson study82 defined bacteremia as ICU-acquired if the first positive blood culture occurred on or after the fifth day in the ICU. Patients who grew MRSA from other sites prior to or after the elucidation of MRSA from the blood were included. The Trautmann study83 defined septicemia as hospital-acquired if it was identified two or more days after admission. The CDC definition was used to define septicemia.

The Rodriguez-Bano study72 reported a reduction in hospital-acquired MRSA bacteremia with expanded targeted screening compared to limited targeted screening, but the confidence intervals included the null (change in incidence after the third intervention 0.002, 95% CI: −0.022 to 0.026; change in trend after the third intervention 0.003, 95% CI: 0.000 to 0.006). The Trautmann study83 showed a statistically significant reduction in hospital-acquired MRSA intravenous catheter-associated septicemia with expanded targeted screening compared to limited targeted screening. The Thompson study82 showed a statistically significant reduction in hospital-acquired MRSA bacteremia with expanded targeted screening compared to limited targeted screening.

##### Strength of Evidence

The SOE for the effect of expanded screening for MRSA carriage compared to limited screening on healthcare-associated MRSA bacteremia was judged to be insufficient. One CCS study addressed this outcome. The study by Rodriguez-Bano et al.,72 utilized a limited time series design and was judged to be of poor quality because it used indirect control of confounders rather that statistical adjustment within the segmented regression analysis. The risk of bias was judged to be high because only one poor quality quasi-experimental study addressed this outcome. The Rodriguez-Bano72 study reported a reduction in hospital-acquired MRSA bacteremia with expanded targeted screening compared to limited targeted screening, but the confidence intervals included the null (change in incidence after the third intervention 0.002, 95% CI: −0.022 to 0.026; change in trend after the third intervention 0.003, 95% CI: 0.000 to 0.006). The consistency of the findings was unknown, because only one study addressed this outcome. This study investigated MRSA bacteremia, a health outcome and therefore, a direct outcome. The study findings were judged to be imprecise because the study did not report statistically significant results. Because the evidence base for this outcome included only one quasi-experimental study, the starting level for the SOE was low. SOE was lowered by the high risk of bias and lack of precision. In summary, the SOE for the effect of expanded screening for MRSA carriage compared to limited screening on healthcare-associated MRSA bacteremia is judged to be insufficient.

##### Comment, Non-CCS Studies

Two studies that did not use statistical methods to attempt to control for confounders and/or secular trends (non-CCS studies) addressed this outcome.82–83 Both of the studies82,83 evaluated the effect of expanded screening for MRSA carriage compared to limited screening on healthcare-associated MRSA bacteremia or bloodstream infection, a proxy for healthcare-associated MRSA infection.

With expanded screening, both studies showed a reduction in healthcare-associated MRSA infection. For one of the studies,83 the reduction was statistically significant, while for one of the studies, it was not.82

#### Morbidity, Mortality, Harms and Resource Utilization

No studies addressed these outcomes.

##### Strength of Evidence for Expanded Screening for MRSA Carriage Compared to Limited Screening on Morbidity, Mortality, Harms and Resource Utilization

Because no studies addressed these outcomes, the SOE to evaluate the effect of expanded screening for MRSA carriage compared to limited screening on morbidity, mortality, harms or resource utilization is judged to be insufficient.

### Summary Strength of Evidence Across Key Question 4

A summary of the main syntheses for this question follows in Table 22.

Table 22 Strength of evidence for studies comparing expanded screening versus limited screening

Strategies Compared | Outcome | No of Studies^§^ | Risk of Bias | Consistency | Directness | Precision | Overall Grade
Expanded Screening vs. Limited Screening | MRSA Acquisition | 2 QEX (N=Unclear) (Rodriguez-Bano 2010^72^) (N=Unclear) (Ellingson 2011^56^) | High | Consistent | Indirect | Imprecise | Insufficient
Expanded Screening vs. Limited Screening | MRSA Infection | 1 QEX (N=219,124; 1,987,676^‡^) (Chaberny 2008^78^) | High | Unknown | Direct | Precise | Insufficient
Expanded Screening vs. Limited Screening | MRSA Bacteremia | 1 QEX (N=Unclear) (Rodriguez-Bano 2010^72^) | High | Unknown | Direct | Imprecise | Insufficient

MRSA = methicillin-resistant Staphylococcus aureus; NA = not applicable; QEX = quasi-experimental

§ Studies that controlled for confounding and/or trend.

‡ Patient days.