# References

1 Jevons MP. “Celbenin” - resistant Staphylococci. BMJ. 1961;1(5219):124-5.
2 Klein E, Smith DL, Laxminarayan R. Hospitalizations and deaths caused by methicillin-resistant Staphylococcus aureus, United States, 1999–2005. Emerg Infect Dis. Dec. 2007;13(12):1840-6. [pmid: 18258033].
3 Kallen AJ, Mu Y, Bulens S, et al. Health care-associated invasive MRSA infections, 2005–2008. JAMA. Aug. 11. 2010;304(6):641-8. [pmid: 20699455].
4 Burton DC, Edwards JR, Horan TC, et al. Methicillin-resistant Staphylococcus aureus central line-associated bloodstream infections in US intensive care units, 1997–2007. JAMA. Feb. 18. 2009;301(7):727-36. [pmid: 19224749].
5 Cosgrove SE, Sakoulas G, Perencevich EN, et al. Comparison of mortality associated with methicillin-resistant and methicillin-susceptible Staphylococcus aureus bacteremia: a meta-analysis. Clin Infect Dis. Jan. 1. 2003;36(1):53-9. [pmid: 12491202].
6 Engemann JJ, Carmeli Y, Cosgrove SE, et al. Adverse clinical and economic outcomes attributable to methicillin resistance among patients with Staphylococcus aureus surgical site infection. Clin Infect Dis. 2003;36(5):592-8. [pmid: 12594640].
7 Barton E, MacGowan A. Future treatment options for Gram-positive infections--looking ahead. Clin Microbiol Infect. Dec. Suppl 6. 2009;15:17-25. [pmid: 19917023].
8 Herold BC, Immergluck LC, Maranan MC, et al. Community-acquired methicillin-resistant Staphylococcus aureus in children with no identified predisposing risk. JAMA. Feb. 25. 1998;279(8):593-8. [pmid: 9486753].
9 Outbreaks of community-associated methicillin-resistant Staphylococcus aureus skin infections--Los Angeles County, California, 2002–2003. MMWR Morb Mortal Wkly Rep. 2003;52(5):88. [pmid: 12588006].
10 Methicillin-resistant Staphylococcus aureus among players on a high school football team--New York City, 2007. MMWR Morb Mortal Wkly Rep. 2009;58(3):52-5. [pmid: 19177039].
11 Ebert MD, Sheth S, Fishman EK. Necrotizing pneumonia caused by community-acquired methicillin-resistant Staphylococcus aureus: an increasing cause of “mayhem in the lung”. Emerg Radiol. Mar. 2009;16(2):159-62. [pmid: 18274797].
12 Daum RS, Ito T, Hiramatsu K, et al. A novel methicillin-resistance cassette in community-acquired methicillin-resistant Staphylococcus aureus isolates of diverse genetic backgrounds. J Infect Dis. Nov. 1. 2002;186(9):1344-7. [pmid: 12402206].
13 Boyle-Vavra S, Daum RS. Community-acquired methicillin-resistant Staphylococcus aureus: the role of Panton-Valentine leukocidin. Lab Invest. Jan. 2007;87(1):3-9. [pmid: 17146447].
14 McAdams RM, Ellis MW, Trevino S, et al. Spread of methicillin-resistant Staphylococcus aureus USA300 in a neonatal intensive care unit. Pediatr Int. Dec. 2008;50(6):810-5. [pmid: 19067897].
15 Huang SS, Datta R, Platt R. Risk of acquiring antibiotic-resistant bacteria from prior room occupants. Arch Intern Med. Oct. 9. 2006;166(18):1945-51. [pmid: 17030826].
16 Sheretz RJ, Reagan DR, Hampton KD, et al. A cloud adult: the Staphylococcus aureus-virus interaction revisited. Ann Intern Med. Mar. 15. 1996;124(6):539-47. [pmid: 8597316].
17 Pittet D, Hugonnet S, Harbarth S, et al. Effectiveness of a hospital-wide programme to improve compliance with hand hygiene. Infection Control Programme. Lancet. Oct. 14. 2000;356(9238):1307-12. [pmid: 11073019].
18 Sroka S, Gastmeier P, Meyer E. Impact of alcohol hand-rub use on methicillin-resistant Staphylococcus aureus: an analysis of the literature. J Hosp Infect. Mar. 2010;74(3):204-11. [pmid: 20061061].
19 Yokoe DS, Mermel LA, Anderson DJ, et al. A compendium of strategies to prevent healthcare-associated infections in acute care hospitals. Infect Control Hosp Epidemiol. Oct. Suppl 1. 2008;29:S12-21. [pmid: 18840084].
20 Jernigan JA, Titus MG, Groschel DH, et al. Effectiveness of contact isolation during a hospital outbreak of methicillin-resistant Staphylococcus aureus. Am J Epidemiol. Mar. 1. 1996;143(5):496-504. [pmid: 8610665].
21 Srinivasan A, Song X, Ross T, et al. A prospective study to determine whether cover gowns in addition to gloves decrease nosocomial transmission of vancomycin-resistant enterococci in an intensive care unit. Infect Control Hosp Epidemiol. Aug. 2002;23(8):424-8. [pmid: 12186206].
22 Mawdsley EL, Garcia-Houchins S, Weber SG. Back to basics: Four years of sustained improvement in implementation of contact precautions at a university hospital. Jt Comm J Qual Patient Saf. Sep. 2010;36(9):418-23. [pmid: 20873675].
23 Stelfox HT, Bates DW, Redelmeier DA. Safety of patients isolated for infection control. JAMA. Oct. 8. 2003;290(14):1899-905. [pmid: 14532319].
24 Weber SG, Perl TM, Cosgrove SE. Quality of care and satisfaction among patients isolated for infection control. JAMA. Jan. 28. 2004;291(4):421. author reply -2. [pmid: 14747493].
25 Vos MC, Behrendt MD, Melles DC, et al. 5 years of experience implementing a methicillin-resistant Staphylococcus aureus search and destroy policy at the largest university medical center in the Netherlands. Infect Control Hosp Epidemiol. Oct. 2009;30(10):977-84. [pmid: 19712031].
26 Montecalvo MA, Jarvis WR, Uman J, et al. Costs and savings associated with infection control measures that reduced transmission of vancomycin-resistant enterococci in an endemic setting. Infect Control Hosp Epidemiol. Jul. 2001;22(7):437-42. [pmid: 11583213].
27 Price CS, Paule S, Noskin GA, et al. Active surveillance reduces the incidence of vancomycin-resistant enterococcal bacteremia. Clin Infect Dis. Oct. 1. 2003;37(7):921-8. [pmid: 13130403].
28 Ostrowsky BE, Trick WE, Sohn AH, et al. Control of vancomycin-resistant enterococcus in health care facilities in a region. N Engl J Med. May. 10. 2001;344(19):1427-33. [pmid: 11346807].
29 Huang SS, Yokoe DS, Hinrichsen VL, et al. Impact of routine intensive care unit surveillance cultures and resultant barrier precautions on hospital-wide methicillin-resistant Staphylococcus aureus bacteremia. Clin Infect Dis. Oct. 15. 2006;43(8):971-8. [pmid: 16983607].
30 Robicsek A, Beaumont JL, Paule SM, et al. Universal surveillance for methicillin-resistant Staphylococcus aureus in 3 affiliated hospitals. Ann Intern Med. Mar. 18. 2008;148(6):409-18. [pmid: 18347349].
31 Harbarth S, Fankhauser C, Schrenzel J, et al. Universal screening for methicillin-resistant Staphylococcus aureus at hospital admission and nosocomial infection in surgical patients. JAMA. 2008;299(10):1149-57. [pmid: 18334690].
32 Farr BM. What to think if the results of the National Institutes of Health randomized trial of methicillin-resistant Staphylococcus aureus and vancomycin-resistant enterococcus control measures are negative (and other advice to young epidemiologists): a review and an au revoir. Infect Control Hosp Epidemiol. Oct. 2006;27(10):1096-106. [pmid: 17006818].
33 Bode LG, Kluytmans JA, Wertheim HF, et al. Preventing surgical-site infections in nasal carriers of Staphylococcus aureus. N Engl J Med. Jan. 7. 2010;362(1):9-17. [pmid: 20054045].
34 Weber SG, Huang SS, Oriola S, et al. Legislative mandates for use of active surveillance cultures to screen for methicillin-resistant Staphylococcus aureus and vancomycin-resistant enterococci: Position statement from the Joint. SHEA and APIC Task Force. Am J Infect Control. Mar. 2007;35(2):73-85. [pmid: 17327185].
35 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(11)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011.
36 Briss PA, Zaza S, Pappaioanou M, et al. Developing an evidence-based Guide to Community Preventive Services--methods. The Task Force on Community Preventive Services. Am J Prev Med. Jan. 2000;18(1 Suppl):35-43. [pmid: 10806978].
37 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
38 Deeks JJ, Dinnes J, D’Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].
39 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
40 Atkins D, Eccles M, Flottorp S, et al. Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches. The GRADE Working Group. BMC Health Serv Res. Dec. 22. 2004;4(1):38. [pmid: 15615589].
41 Jain R, Kralovic SM, Evans ME, et al. Veterans Affairs initiative to prevent methicillin-resistant Staphylococcus aureus infections. N Engl J Med. Apr. 14. 2011;364(15):1419-30. [pmid: 21488764].
42 Reilly JS, Stewart S, Christie P, et al. Universal screening for meticillin-resistant Staphylococcus aureus in acute care: risk factors and outcome from a multicentre study. J Hosp Infect. Jan. 2012;80(1):31-5. [pmid: 22104473].
43 Leonhardt KK, Yakusheva O, Phelan D, et al. Clinical effectiveness and cost benefit of universal versus targeted methicillin-resistant Staphylococcus aureus screening upon admission in hospitals. Infection Control and Hospital Epidemiology. 2011;32(8):797-803. [pmid: 21768764].
44 Gould IM, MacKenzie FM, MacLennan G, et al. Topical antimicrobials in combination with admission screening and barrier precautions to control endemic methicillin-resistant Staphylococcus aureus in an Intensive Care Unit. Int J Antimicrob Agents. May. 2007;29(5):536-43. [pmid: 17337163].
45 Holzmann-Pazgal G, Monney C, Davis K, et al. Active surveillance culturing impacts methicillin-resistant Staphylococcus aureus acquisition in a pediatric intensive care unit. Pediatric Critical Care Medicine. 2011;12(4):e171-e5. [pmid: 20838355].
46 Huskins WC, Huckabee CM, O’Grady NP, et al. Intervention to reduce transmission of resistant bacteria in intensive care. N Engl J Med. Apr. 14. 2011;364(15):1407-18. [pmid: 21488763].
47 Raineri E, Crema L, De Silvestri A, et al. Meticillin-resistant Staphylococcus aureus control in an intensive care unit: a 10 year analysis. J Hosp Infect. Dec. 2007;67(4):308-15. [pmid: 17945395].
48 Blumberg LH, Klugman KP. Control of methicillin-resistant Staphylococcus aureus bacteraemia in high-risk areas. Eur J Clin Microbiol Infect Dis. Jan. 1994;13(1):82-5. [pmid: 8168568].
49 Boyce JM, Havill NL, Kohan C, et al. Do infection control measures work for methicillin-resistant Staphylococcus aureus?. Infect Control Hosp Epidemiol. 2004;25(5):395-401. [pmid: 15188845].
50 Clancy M, Graepler A, Wilson M, et al. Active screening in high-risk units is an effective and cost-avoidant method to reduce the rate of methicillin-resistant Staphylococcus aureus infection in the hospital. Infect Control Hosp Epidemiol. 2006;27(10):1009-17. [pmid: 17006806].
51 de la Cal MA, Cerda E, van Saene HK, et al. Effectiveness and safety of enteral vancomycin to control endemicity of methicillin-resistant Staphylococcus aureus in a medical/surgical intensive care unit. J Hosp Infect. Mar. 2004;56(3):175-83. [pmid: 15003664].
52 Kurup A, Chlebicka N, Tan KY, et al. Active surveillance testing and decontamination strategies in intensive care units to reduce methicillin-resistant Staphylococcus aureus infections. Am J Infect Control. Jun. 2010;38(5):361-7. [pmid: 20189267].
53 Simmons S. Effects of selective patient screening for MRSA on overall MRSA hospital-acquired infection rates. Crit Care Nurs Q. Jan–Mar. 2011;34(1):18-24. [pmid: 21160296].
54 Souweine B, Traore O, Aublet-Cuvelier B, et al. Role of infection control measures in limiting morbidity associated with multi-resistant organisms in critically ill patients. J Hosp Infect. Jun. 2000;45(2):107-16. [pmid: 10860687].
55 Muder RR, Cunningham C, McCray E, et al. Implementation of an industrial systems-engineering approach to reduce the incidence of methicillin-resistant Staphylococcus aureus infection. Infect Control Hosp Epidemiol. Aug. 2008;29(8):702-8. 7 p following 8. [pmid: 18624651].
56 Ellingson K, Muder RR, Jain R, et al. Sustained reduction in the clinical incidence of methicillin-resistant Staphylococcus aureus colonization or infection associated with a multifaceted infection control intervention. Infect Control Hosp Epidemiol. Jan. 2011;32(1):1-8. [pmid: 21133794].
57 Sankar B, Hopgood P, Bell KM. The role of MRSA screening in joint-replacement surgery. Int Orthop. Jun. 2005;29(3):160-3. [pmid: 15864590].
58 Jog S, Cunningham R, Cooper S, et al. Impact of preoperative screening for meticillin-resistant Staphylococcus aureus by real-time polymerase chain reaction in patients undergoing cardiac surgery. J Hosp Infect. Jun. 2008;69(2):124-30. [pmid: 18387695].
59 Kim DH, Spencer M, Davidson SM, et al. Institutional prescreening for detection and eradication of methicillin-resistant Staphylococcus aureus in patients undergoing elective orthopaedic surgery. J Bone Joint Surg Am. Aug. 4. 2010;92(9):1820-6. [pmid: 20610773].
60 Lipke VL, Hyott AS. Reducing surgical site infections by bundling multiple risk reduction strategies and active surveillance. AORN J. Sep. 2010;92(3):288-96. [pmid: 20816102].
61 Malde DJ, Abidia A, McCollum C, et al. The success of routine MRSA screening in vascular surgery: a nine year review. Int Angiol. Jun. 2006;25(2):204-8. [pmid: 16763540].
62 Nixon M, Jackson B, Varghese P, et al. Methicillin-resistant Staphylococcus aureus on orthopaedic wards: incidence, spread, mortality, cost and control. J Bone Joint Surg Br. Jun. 2006;88(6):812-7. [pmid: 16720779].
63 Pofahl WE, Goettler CE, Ramsey KM, et al. Active surveillance screening of MRSA and eradication of the carrier state decreases surgical-site infections caused by MRSA. J Am Coll Surg. May. 2009;208(5):981-6. discussion 6–8. [pmid: 19476875].
64 Sott AH, Jones R, Davies S, et al. The value of pre-operative screening for MRSA in the reduction of sepsis in total hip replacement associated with MRSA. A prospective audit. HIP Int. 2001;11(2):102-6.
65 Supriya M, Shakeel M, Santangeli L, et al. Controlling MRSA in head and neck cancer patients: what works?. Otolaryngol Head Neck Surg. 2009;140(2):224-7. [pmid: 19201293].
66 Thomas S, Cantrill S, Waghorn DJ, et al. The role of screening and antibiotic prophylaxis in the prevention of percutaneous gastrostomy site infection caused by methicillin-resistant Staphylococcus aureus. Aliment Pharmacol Ther. Mar. 1. 2007;25(5):593-7. [pmid: 17305760].
67 Walsh EE, Greene L, Kirshner R. Sustained reduction in methicillin-resistant Staphylococcus aureus wound infections after cardiothoracic surgery. Arch Intern Med. Jan. 10. 2011;171(1):68-73. [pmid: 20837818].
68 Kelly JC, O’Briain DE, Walls R, et al. The role of pre-operative assessment and ringfencing of services in the control of methicillin resistant Staphlococcus aureus infection in orthopaedic patients. Surgeon. Apr. 2012;10(2):75-9. [pmid: 22385528].
69 Chen AF, Chivukula S, Jacobs LJ, et al. What Is the Prevalence of MRSA Colonization in Elective Spine Cases?. Clin Orthop Relat Res. 2012. Mar. 23. [pmid: 22441994].
70 Chowers MY, Paitan Y, Gottesman BS, et al. Hospital-wide methicillin-resistant Staphylococcus aureus control program: A 5-year follow-up. Infect Control Hosp Epidemiol. Aug. 2009;30(8):778-81. [pmid: 19580437].
71 Harbarth S, Martin Y, Rohner P, et al. Effect of delayed infection control measures on a hospital outbreak of methicillin-resistant Staphylococcus aureus. J Hosp Infect. Sep. 2000;46(1):43-9. [pmid: 11023722].
72 Rodriguez-Bano J, Garcia L, Ramirez E, et al. Long-term control of endemic hospital-wide methicillin-resistant Staphylococcus aureus (MRSA): the impact of targeted active surveillance for MRSA in patients and healthcare workers. Infect Control Hosp Epidemiol. Aug. 2010;31(8):786-95. [pmid: 20524852].
73 Bowler WA, Bresnahan J, Bradfish A, et al. An integrated approach to methicillin-resistant Staphylococcus aureus control in a rural, regional-referral healthcare setting. Infect Control Hosp Epidemiol. Mar. 2010;31(3):269-75. [pmid: 20102280].
74 Keshtgar MR, Khalili A, Coen PG, et al. Impact of rapid molecular screening for meticillin-resistant Staphylococcus aureus in surgical wards. Br J Surg. Mar. 2008;95(3):381-6. [pmid: 18041109].
75 Pan A, Carnevale G, Catenazzi P, et al. Trends in methicillin-resistant Staphylococcus aureus (MRSA) bloodstream infections: effect of the MRSA “search and isolate” strategy in a hospital in Italy with hyperendemic MRSA. Infect Control Hosp Epidemiol. 2005;26(2):127-33. [pmid: 15756881].
76 Salaripour M, McKernan P, Devlin R. A multidisciplinary approach to reducing outbreaks and nosocomial MRSA in a university-affiliated hospital. Healthc Q. Oct. 2006;9(Spec No):54-60. [pmid: 17087169].
77 Wernitz MH, Swidsinski S, Weist K, et al. Effectiveness of a hospital-wide selective screening programme for methicillin-resistant Staphylococcus aureus (MRSA) carriers at hospital admission to prevent hospital-acquired MRSA infections. Clin Microbiol Infect. 2005;11(6):457-65. [pmid: 15882195].
78 Chaberny IF, Schwab F, Ziesing S, et al. Impact of routine surgical ward and intensive care unit admission surveillance cultures on hospital-wide nosocomial methicillin-resistant Staphylococcus aureus infections in a university hospital: an interrupted time-series analysis. J Antimicrob Chemother. Dec. 2008;62(6):1422-9. [pmid: 18765411].
79 Eveillard M, Mortier E, Lancien E, et al. Consideration of age at admission for selective screening to identify methicillin-resistant Staphylococcus aureus carriers to control dissemination in a medical ward. Am J Infect Control. 2006;34(3):108-13. [pmid: 16630972].
80 Girou E, Azar J, Wolkenstein P, et al. Comparison of systematic versus selective screening for methicillin-resistant Staphylococcus aureus carriage in a high-risk dermatology ward. Infect Control Hosp Epidemiol. Sep. 2000;21(9):583-7. [pmid: 11001261].
81 Schelenz S, Tucker D, Georgeu C, et al. Significant reduction of endemic MRSA acquisition and infection in cardiothoracic patients by means of an enhanced targeted infection control programme. J Hosp Infect. Jun. 2005;60(2):104-10. [pmid: 15866007].
82 Thompson DS, Workman R, Strutt M. Decline in the rates of meticillin-resistant Staphylococcus aureus acquisition and bacteraemia in a general intensive care unit between 1996 and 2008. J Hosp Infect. 2009;71(4):314-9. [pmid: 19217186].
83 Trautmann M, Pollitt A, Loh U, et al. Implementation of an intensified infection control program to reduce MRSA transmissions in a German tertiary care hospital. Am J Infect Control. Dec. 2007;35(10):643-9. [pmid: 18063128].
84 West TE, Guerry C, Hiott M, et al. Effect of targeted surveillance for control of methicillin-resistant Staphylococcus aureus in a community hospital system. Infect Control Hosp Epidemiol. Mar. 2006;27(3):233-8. [pmid: 16532409].
85 Enoch DA, Cargill JS, Sismey A, et al. MRSA surveillance in a UK district hospital: measuring clinical isolates with MRSA is more useful than measuring MRSA bacteraemias. J Hosp Infect. Dec. 2011;79(4):287-91. [pmid: 21978609].
86 Platt R. Time for a culture change?. N Engl J Med. Apr. 14. 2011;364(15):1464-5. [pmid: 21488769].
87 McGinigle KL, Gourlay ML, Buchanan IB. The use of active surveillance cultures in adult intensive care units to reduce methicillin-resistant Staphylococcus aureus-related morbidity, mortality, and costs: a systematic review. Clin Infect Dis. Jun. 1. 2008;46(11):1717-25. [pmid: 18494098].
88 Tacconelli E, De Angelis G, de Waure C, et al. Rapid screening tests for meticillin-resistant Staphylococcus aureus at hospital admission: systematic review and meta-analysis. Lancet Infect Dis. Sep. 2009;9(9):546-54. [pmid: 19695491].
89 Siegel JD, Rhinehart E, Jackson M, et al. Management of multidrug-resistant organisms in health care settings, 2006. Am J Infect Control. Dec. 2007;35(10 Suppl 2):S165-93. [pmid: 18068814].
90 Muto CA, Jernigan JA, Ostrowsky BE, et al. SHEA guideline for preventing nosocomial transmission of multidrug-resistant strains of Staphylococcus aureus and enterococcus. Infect Control Hosp Epidemiol. May. 2003;24(5):362-86. [pmid: 12785411].
91 Harris AD, Bradham DD, Baumgarten M, et al. The use and interpretation of quasi-experimental studies in infectious diseases. Clin Infect Dis. Jun. 1. 2004;38(11):1586-91. [pmid: 15156447].
92 Perencevich EN, Lautenbach E. Infection prevention and comparative effectiveness research. JAMA. Apr. 13. 2011;305(14):1482-3. [pmid: 21486981].
93 Shardell M, Harris AD, El-Kamary SS, et al. Statistical analysis and application of quasi experiments to antimicrobial resistance intervention studies. Clin Infect Dis. Oct. 1. 2007;45(7):901-7. [pmid: 17806059].