# Methods

Methodological practices followed in this review were derived from the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews”35 (hereafter referred to as the “Methods Guide”) and its subsequent updates.

## Topic Development and Refinement

Key questions were reviewed and refined as needed by the Evidence-based Practice Center (EPC) with input from Key Informants and the Technical Expert Panel (TEP) to assure that the questions were specific and explicit about what information was being reviewed. In addition, for Comparative Effectiveness reviews, the Key Questions were posted for public comment and finalized by the EPC after review of the comments.

Key Informants are the end users of research, including patients and caregivers, practicing clinicians, relevant professional and consumer organizations, purchasers of health care, and others with experience in making health care decisions. Within the EPC program, the Key Informant role is to provide input into identifying the Key Questions for research that will inform health care decisions. The EPC solicited input from Key Informants when developing questions for systematic review or when identifying high priority research gaps and needed new research. Key Informants were not involved in analyzing the evidence or writing the report and have not reviewed the report, except as given the opportunity to do so through the peer or public review mechanism.

Key Informants had to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals were invited to serve as Key Informants and those who presented without potential conflicts were retained. The AHRQ Task Order Officer and the EPC worked to balance, manage, or mitigate any potential conflicts of interest identified.

## Literature Search Strategy

The databases listed below were searched for citations. The full search strings and strategies can be found in Appendix A. The search was limited to literature published from 1990 to the present because this is the evidence most applicable to current practice. The search was limited to the English-language literature because in past projects, our EPC has found the inclusion of non-English language literature did not yield sufficient high quality information to justify the resources required for translation.

- MEDLINE^®^ (January 1, 1990, to March 30, 3012)
- Embase^®^ (January 1, 1990, to March 30, 2012)
- Cochrane Controlled Trials Register (to March 2012)

To identify systematic reviews, we searched MEDLINE^®^, the Cochrane Database of Systematic Reviews, and the Web sites of the National Institute for Clinical Excellence, Guidelines.gov, and the Technology Assessment Programme of the National Health Service. We followed the AHRQ recommendations in its Methods Guide about inclusion of results from previously conducted meta-analyses and systematic reviews.35 Our search strategy used the National Library of Medicine’s Medical Subject Headings (MeSH^®^) keyword nomenclature developed for MEDLINE^®^ and adapted for use in other databases. The searches were limited to humans. We searched the Cochrane Controlled Trials Register using the same search teams utilized for the MEDLINE^®^ and EMBASE^®^ searches.

The TEP and individuals and organizations providing peer review were asked to inform the project team of any studies relevant to the Key Questions that were not included in the draft list of selected studies.

We searched indexed, electronically searchable conference abstracts by subject heading for the following conferences from the past 5 years: Interscience Conference on Antimicrobial Agents and Chemotherapy, Infectious Disease Society of America, Society for Healthcare Epidemiology of America, Association of Professionals in Infection Control and Epidemiology, American College of Physicians, Pediatric Infectious Diseases Society, European Society of Clinical Microbiology and Infectious Diseases, International Society of Infectious Diseases, Australasian Society of Infectious Diseases, International Sepsis Forum, and European Society of Intensive Care Medicine.

We reviewed Scientific Information Packets from the Scientific Resource Center and grey literature from the U.S. Food and Drug Administration Web site and ClinicalTrials.gov. We included those studies that have gone through a process equivalent to journal peer review.

In the course of this project, our EPC transitioned from EndNote^®^ or ProCite^®^ databases to use of Distiller SR^®^. Therefore, search results were initially stored in an EndNote9^®^ database, subsequently transferred to Distiller SR^®^. In an initial screen of titles and abstracts, study selection criteria were applied by a single reviewer who marked each citation as: (1) eligible for review as a full-text article; 92) ineligible for full-text review; or (3) uncertain. Citations marked as uncertain were reviewed by a second reviewer and resolved by consensus opinion; and when necessary, discordant opinions will be resolved by a third reviewer. Throughout the title/abstract screening and study selection processes, reviewer training and quality control procedures were applied to achieve accuracy. Forms to facilitate title and abstract review were pilot tested during reviewer training.

### Inclusion and Exclusion Criteria

We included randomized, controlled trials (RCTs) and nonrandomized, comparative studies (observational, case-control, and cohort studies) of populations, comparisons, interventions, and outcomes that were not adequately studied in controlled trials. We also used observational studies to assess comparative effectiveness in populations not well represented in RCTs. To classify observational study designs, we used the system developed by Briss and colleagues.36 Studies were included that have these design characteristics and meet descriptions included under Population(s), Interventions, Comparators, Outcomes, Timing and Settings. Additionally, studies were excluded that: (1) did not describe any statistical analysis; or (2) report a relevant outcome only as a frequency without a denominator. Table 1 illustrates application of study selection criteria.

Table 1 Study selection criteria

Topic | Question | Exclude if
Language | Is article published in English? | not English
Publication Type | Does article report primary data? | no primary data (narrative reviews, commentaries, editorials, letters, news reports, etc.)
Species | Are the study participants human? | not human
Setting | Was study conducted among patients in ambulatory care or hospital settings? | if not patients in ambulatory health care or hospital settings (nursing homes); also apply if focus is not patients (e.g. health care workers)
Disease | Was MRSA the primary disease focus? | focus of study does not include or is not primarily centered on MRSA
Design | Was the design a comparison of MRSA screening vs. no screening or one screening method with another screening method? | the study is purely a comparison of culture vs. PCR or the study is not a RCT or QEX comparing either:; - screening (by either culture or PCR) vs. no screening or; - universal (all patients admitted to a hospital) vs. targeted screening or; - more limited targeted screening vs. expanded targeted screening
Outcomes | Did the study report a relevant outcome? | no outcome is reported with a denominator or if one of these outcomes is not reported:; - MRSA incidence or prevalence; - morbidity; - mortality; - harms; - MRSA acquisition/transmission, or; - resource utilization
Statistical Analysis | Did the study report a statistical analysis? | no statistical analysis is reported, also sort into categories: 2-group tests vs. regression or time series analysis

MRSA = methicillin-resistant Staphylococcus aureus; PCR = polymerase chain reaction; QEX = quasi-experimental; RCT = randomized controlled trial

### Study Selection

Final study selection criteria were applied to full-text articles to determine inclusion in the systematic review in the same manner as applied to title and abstract screening. Records of the reason for exclusion for each paper retrieved in full-text, but excluded from the review (Appendix B), were kept in the EndNote9^®^ and Distiller SR^®^ databases.

### Search Strategies for Grey Literature

The EPC staff conducted a systematic search of the following grey literature sources to identify unpublished studies or studies published in journals that were not indexed in major bibliographic citation database in accordance with guidance from Effective Health Care Scientific Resource Center. The search strategies can be found in Appendix A.

1. Regulatory Information
  - U.S. Food and Drug Administration (www.FDA.gov)
2. Clinical Trial Registries
  - ClinicalTrials.gov
  - Current Controlled Trials
  - Clinical Study Results
  - World Health Organization Clinical Trials
3. Abstracts and Conference Papers
  - Conference Papers Index
  - Scopus
  - Interscience Conference on Antimicrobial Agents and Chemotherapy
  - The Infectious Disease Society of America
  - The Society for Healthcare Epidemiology of America
  - The Association of Professionals in Infection Control and Epidemiology
  - The American College of Physicians
  - The Pediatric Infectious Diseases Society
  - The European Society of Clinical Microbiology and Infectious Diseases
  - The International Society of Infectious Diseases
  - The Australasian Society of Infectious Diseases
  - The International Sepsis Forum
  - The European Society of Intensive Care Medicine
4. Grants and Federally Funded Research
  - National Institute of Health Research Portfolio Online Reporting Tools (NIH RePORTER) (a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions)
  - Health Services Research Projects in Progress (HSRPROJ) (a database providing access to ongoing grants and contracts in health services research)
  - AHRQ Grants On-Line Database (AHRQ GOLD) (an online searchable database of AHRQ grants, working papers and Department of Health and Human Services recovery act projects)
5. Manufacturer database: Industry stakeholders were invited to submit the following types of information for possible inclusion as evidence:
  - A current product label;
  - Published RCTs and observational studies relevant to the clinical outcomes; and
  - Unpublished RCTs and observational studies relevant to the clinical outcomes.

These sources were searched using sensitive searches similar to the searches in bibliographic databases, except for the following:

- Regulatory information: The FDA website was searched for 510(k) decision summary documents related to devices used for diagnosis of MRSA-Xpert MRSA SA/SSTI^®^, XPert MRSA SA/BC^®^, XPert MRSA^®^, GeneOhm^®^ MRSA assay and BBL ChromAgar MRSA.
- For clinical registries, NIH RePORTER, HSRPROJ, and AHRQ GOLD searches were limited to completed studies only.
- For abstracts and conferences, studies published prior to 2006 were excluded.

## Data Extraction and Data Management

### Data Elements

Using Distiller SR^®^ software, the following data elements from the intervention studies were abstracted, or recorded as “not reported” (see Appendixes C, D, and E). The data elements to be abstracted were defined in consultation with the TEP and included the following:

- Quality Assessment:
  ○ Number of participants and flow of participants through steps of study
  ○ Treatment allocation methods (including concealment)
  ○ Use of blinding
  ○ Prospective vs. retrospective
  ○ Use of independent outcome assessor
- Assessment of Applicability & Clinical Diversity:
  ○ Patient characteristics, including
    ■ Age
    ■ Sex
    ■ Race/ethnicity
    ■ Disease and type
    ■ Disease duration
    ■ Other prognostic characteristics (e.g., comorbidities and other potential confounders and/or effect modifiers)
    ■ Setting
      – Outpatient
      – Inpatient
  ○ Diagnostic and Treatment Characteristics, including
    ■ Type of assay used to screen for MRSA and its turnaround time
    ■ Decision-making for diagnosis and/or treatment
    ■ Antibiotic usage
    ■ Other treatment modalities
    ■ Duration of observation
- Outcome Assessment:
  ○ Identified primary outcome
  ○ Identified secondary outcomes
  ○ Response criteria
  ○ Followup frequency and duration
  ○ Data analysis details:
    ■ Statistical analyses (statistical test/estimation results)
      – Test used
      – Summary measures
      – Sample variability measures
      – Precision of estimate
      – p values
    ■ Regression modeling techniques
    ■ Model type
    ■ Candidate predictors and methods for identifying candidates
    ■ Univariate analysis results
    ■ Selected predictors and methods for selecting predictors
    ■ Testing of assumptions
    ■ Inclusion of interaction terms
    ■ Multivariable model results
    ■ Discrimination or validation methods and results
    ■ Calibration or “goodness-of-fit” results

### Evidence Tables

Templates for evidence tables were created in Microsoft Excel^®^ and Microsoft Word^®^ after data were downloaded from Distiller SR^®^. Forms to facilitate data abstraction were pilot tested during implementation of quality control to achieve accuracy. One reviewer performed primary abstraction of all data elements into the evidence/abstraction tables, and a second reviewer reviewed the articles and evidence tables for accuracy (see Appendix F, Data Abstraction Tables). Disagreements were resolved by discussion, and if necessary, by consultation with a third reviewer. When small differences occurred in quantitative estimates of data from published figures, the values were obtained by averaging the estimates of the two reviewers.

## Quality Assessment of Individual Studies

### Definition of Ratings Based on Criteria

In adherence with the Methods Guide,35 the general approach to grading individual comparative studies was that used by the U.S. Preventive Services Task Force.37 This approach is relevant to both RCTs and nonrandomized comparative interventions studies. Assessment of the quality of included nonrandomized comparative intervention studies by this approach was informed by a selection of items proposed by Deeks et al.,38 as shown in Appendix G. Assessment of individual study quality was greatly informed by whether studies attempted to control for confounding and/or secular trends. Studies that used such analytic techniques are described as “CCS studies,” while those that did not are called “non-CCS” studies. Non-CCS studies used simple two-group statistical analyses. Observational studies that do not attempt to control for confounding and/or secular trends do not provide evidence that supports causal inference and according to U.S. Preventive Services Task Force approach were considered fatally flawed and therefore of poor quality. The quality of the abstracted studies and the body of evidence was assessed by two independent reviewers. Discordant quality assessments were resolved with input from a third reviewer, if necessary.

- The quality of studies was assessed on the basis of the following criteria:
  ○ Initial assembly of comparable groups: adequate randomization, including concealment and whether potential confounders (e.g., other concomitant care) were distributed equally among groups
  ○ Maintenance of comparable groups (includes attrition, crossovers, adherence, contamination)
  ○ Important differential loss to followup or overall high loss to followup
  ○ Measurements: equal, reliable, and valid (includes masking of outcome assessment)
  ○ Clear definition of interventions
  ○ All important outcomes considered
  ○ Analysis: adjustment for potential confounders, intention-to-treat analysis
- The rating of intervention studies encompasses the three quality categories described here.
  ○ Good: Meets all criteria; comparable groups are assembled initially and maintained throughout the study (followup at least 80 percent); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, for RCTs, intention to treat analysis is used.
  ○ Fair: Studies graded as “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: In general, comparable groups are assembled initially but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is done for RCTs.
  ○ Poor: Studies graded as “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study or comparability was not documented; unreliable or invalid measurement instruments are used or not applied at all equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Non-CCS studies would therefore be fatally flawed, while CCS studies may also be rated as poor. For RCTs, intention-to-treat analysis is lacking.

Appropriate analysis is a key aspect of study quality ratings. Among CCS studies, ratings emphasized whether investigators attempted an appropriate analysis which tested for trend, addressed autocorrelation and adjusted for at least one confounder. Studies that reported baseline group characteristics, considered and analyzed at least one healthcare-associated outcome, and conducted appropriate analysis (tested for trend, addressed autocorrelation, and included at least one confounder in the analysis) were rated “good.” Studies that met the criteria for good quality except that they did not report a healthcare-associated outcome were rated “fair.” Studies that failed to report baseline group characteristics and/or to conduct appropriate analysis were rated “poor.” The Results chapter synthesizes the strength of evidence (SOE) for CCS studies that presented at least one healthcare-associated outcome; but CCS studies that did not report at least one healthcare-associated outcome and non-CCS studies are only commented on in the text, and not included in the SOE syntheses.

## Data Synthesis

Because of the heterogeneity of the data, this evidence review did not perform formal data synthesis through meta-analysis. If a meta-analysis could have been performed, subgroup and sensitivity analyses would have been based on assessment of clinical diversity in available studies. Anticipated subgroups included patients at high risk for MRSA, including those with end-stage renal disease and those residing in long-term care facilities. The Methods Guide35 and the paper by Owens and colleagues39 were used to rate the strength of the overall body of evidence.

## Assessment of Applicability

Applicability of findings in this review was assessed within the EPICOT framework (Evidence, Population, Intervention, Comparison, Outcome, Timestamp). Selected studies were assessed for relevance against target populations, interventions of interest, and outcomes of interest.

## Grading the Body of Evidence for Each Key Question

The system used for rating the strength of the overall body of evidence was developed by the AHRQ for its Methods Guide,35,39 based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation Working Group.40 This system explicitly addresses the following domains: risk of bias, consistency, directness, and precision. Additional domains such as strength of association, publication bias, coherence, dose-response relationship, and residual confounding were assessed when appropriate.

Table 2 describes criteria for selecting different levels within each of the four required domains.

Table 2 Strength of evidence rating domains

Domain | Level | Criteria
Risk of bias | General | Degree to which studies have high likelihood of protection against bias; derived from assessment of the risk of bias in individual studies; incorporates both study design and conduct; grading this domain requires assessment of aggregate quality of studies within each major study design and integration into overall risk of bias score; limitations of design for reducing bias in addressing a Key Question should be taken into account. If studies differ substantially in risk of bias, may give greater weight to those studies with low risk of bias.
Risk of bias | Low | At least 1 good quality RCT.
Risk of bias | Medium | At least: 1 fair quality RCT; or 1 good quality observational study and 1 additional study of good or fair quality.
Risk of bias | High | Does not meet minimum requirements for low or medium.
Consistency | General | Degree to which studies are similar in effect sizes; degree to which studies have same direction of effect (even in presence of statistical heterogeneity).
Consistency | Consistent | Effect sizes have same direction.
Consistency | Inconsistent | Effect sizes are in different directions.
Consistency | Unknown | Single study evidence base.
Directness | General | A single direct link between intervention and health outcome; intervention and comparator(s) compared head-to-head within a study.
Directness | Direct | Direct head-to-head comparison of interventions within a study or assesses a health outcome.
Directness | Indirect | Not a direct head-to-head comparison of interventions within a study or assesses an intermediate outcome.
Precision | General | Degree of certainty surrounding an effect estimate.
Precision | Precise | Uncertainty around an effect compatible with only one of these: clinically important superiority, inferiority or noninferiority. In absence of meta-analysis, individual studies consistently report precise and/or statistically significant results.
Precision | Imprecise | Uncertainty around an effect compatible with both clinically important superiority and inferiority. In absence of meta-analysis, individual studies do not consistently report precise and/or statistically significant results.

RCT = randomized controlled trial

The grade of evidence strength is classified into four categories as shown in Table 3. Rules for the starting SOE and factors that would raise or lower the strength are also described in the Table 3.

Table 3 Strength of evidence categories and rules

Strength of Evidence/Rules | Criteria
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence is either unavailable or does not permit estimation of an effect.
Starting level of strength, RCT evidence | High
Starting level of strength, observational evidence | Low
Raise strength | Among observational studies, raise strength by one level if a large effect size is observed, presence of dose-response association or plausible confounding that would decrease the observed effect. A very large effect size could raise strength by two levels.
Reduce strength | Reduce strength by one level is there is serious concern in an area such as: high risk of bias, inconsistent findings; consistency unknown; evidence is indirect; results are imprecise or presence of publication bias. Very serious concern in an area would reduce strength by two levels.

The process of grading a body of evidence can be illustrated with examples. A body of evidence represented by a single RCT rated as good in quality and multiple poor quality observational studies would have a starting strength of high. The risk of bias domain in this instance would be rated as low. If the RCT and observational studies reported results with opposite directions of effect, an inconsistent pattern for the consistency domain, the strength would be reduced by two levels. Assume that studies perform direct head-to-head comparisons of an intervention and comparator and report on an important health outcome, leading to a rating of direct on the directness domain. In the absence of meta-analysis, the pattern of opposite effect directions would render the aggregate results imprecise on the precision domain, reducing strength by at least one level. The path through all domains would take the strength from moderate through three reductions to a final strength of insufficient.

Another purely observational body of evidence that included one good quality study and multiple poor quality studies would have a starting SOE of low. If the body consists of one good quality study and one poor quality study, the risk of bias domain would be rated as high, reducing strength by at least one level. If results are rated consistent, direct, and precise, the starting level of low and the high risk of bias reduction would lead to a final strength of insufficient. However, a large effect could raise the strength to low. In another example, a medium risk of bias would exist if there is a good quality study and at least one other good or fair study. If there were consistent results, direct evidence and precise effect estimates, the strength could be raised above low if there is a large effect, a clear dose-response association or plausible confounding that would reduce the observed effect.

## Peer Review, Public Commentary, and Technical Expert Panel

Peer reviewers were invited to provide written comments on the draft report based on their clinical, content, or methodological expertise. Peer review comments on the preliminary draft of the report were considered by the EPC in preparation of the final draft of the report. Peer reviewers did not participate in the writing or editing of the final report or other products. The synthesis of the scientific literature presented in the final report does not necessarily represent the views of individual reviewers. The dispositions of the peer review comments will be documented and published three months after the publication of the evidence report.

Potential reviewers had to disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Invited peer reviewers could not have any financial conflict of interest greater than $10,000. Peer reviewers who disclosed potential business or professional conflicts of interest were able to submit comments on draft reports through the public comment mechanism.

A TEP was formed to provide consultation on the development of the protocol and evidence tables for the review. Ad hoc clinical questions were also addressed to the TEP.