# Introduction

## Background and Objectives for the Systematic Review

Methicillin-resistant Staphylococcus aureus (MRSA) first emerged as a clinically relevant human pathogen more than 5 decades ago.1 The virulent bacterium was first detected in hospitals and other health care facilities where vulnerable hosts, frequent exposure to the selective pressure of intensive antimicrobial therapy, and the necessity for invasive procedures (which further compromise host defenses) created a favorable environment for dissemination. MRSA emerged as an important cause of health care–associated infections, particularly central line-associated bloodstream infection, ventilator-associated pneumonia, and surgical site infection (SSI). Despite the adoption of a number of measures to prevent spread, the incidence of MRSA infection at most U.S. hospitals steadily increased for many years2 but is now decreasing.3,4 Burton and colleagues found a 49.6 percent decrease in the overall incidence of MRSA central line-associated bloodstream infection in U.S. intensive care units (ICUs) from 1997–2007.^4^ In a study of nine U.S. metropolitan areas, Kallen and colleagues3 found a reduction in the incidence rate of hospital-onset invasive MRSA infections of 9.4 percent per year from 2005–2008 [95% confidence interval (CI): 14.7 to 3.8%; p=0.005]. While the decrease in the incidence of MRSA infection may be due to efforts to screen for MRSA carriage, it may also be due to secular trends (such as efforts to improve patient safety) and to confounders (such as efforts to improve the appropriate use of antibiotics and to decrease healthcare-associated infections in general, including catheter-associated bloodstream infection, ventilator-associated pneumonia and SSI).

Complicating matters, the management of MRSA infections remains a challenge for clinicians. Although not all studies concur, a number of analyses suggest that MRSA infections are associated with increased mortality and cost of care when compared with those due to strains that are susceptible to methicillin. A meta-analysis by Cosgrove and colleagues5 identified a 2-fold increased risk of death associated with methicillin resistance. Engemann and colleagues6 documented a significantly higher risk of poor outcomes and increased cost of managing patients with SSI due to MRSA when compared with patients infected with antibiotic-susceptible strains. Even the availability of newer pharmaceutical agents with specific activity against MRSA, including linezolid and daptomycin, has not lessened the challenge of caring for MRSA patients. The widespread use of these agents has been limited in part because of toxicity, cost, and uncertainty as to optimal indications.7

The management and control of MRSA has been further complicated by dramatic changes in the epidemiology of transmission and infection observed over the past 2 decades. Specifically, S. aureus strains resistant to methicillin, once exclusively linked to hospital care, have increasingly been detected among patients in the community who lack conventional risk factors for MRSA infection (such as prior antimicrobial therapy or invasive procedures).8,9 These so-called community-associated MRSA (CA-MRSA) strains have demonstrated a predilection to affect specific populations. Clusters among schoolchildren and competitive athletes have been extensively described in both the scientific literature and the mass media.7,10 CA-MRSA infection often manifests in characteristic clinical patterns—including aggressive skin and soft tissue infections (typically arising from an initial lesion often mistaken by patients and clinicians for a spider bite) and necrotizing pneumonia.11 Extensive investigation has demonstrated a number of unique genetic and pathogenic features of CA-MRSA isolates that may provide insight into the epidemiology of these bacteria. CA-MRSA strains typically share a distinctive methicillin-resistance cassette that helps to explain the characteristic susceptibility of these strains to non–beta-lactam antimicrobial agents such as clindamycin and trimethoprim/sulfamethoxazole.12 In addition, CA-MRSA isolates commonly overexpress a particular set of virulence factors, including the Panton-Valentine leukocidin.13 While the specific relationship between these features and the unique clinical and epidemiological characteristics of CA-MRSA remain to be elucidated, the importance of these strains continues to grow. CA-MRSA has increasingly been linked to outbreaks of infection in hospitals and health care facilities, and there is some evidence that these strains are now the dominant cause of staphylococcal disease in some settings.14

Strategies for the control of MRSA (whether health care or community-associated) have focused on the prevention of spread from patient to patient (horizontal transmission) as well as on the prevention of healthcare-associated infections more generally (e.g., catheter-associated blood stream infections and SSIs). It is generally acknowledged that environmental contamination and airborne transmission could plausibly play a minor role in transmission.15,16 However, the majority of staphylococcal spread (and of MRSA) likely comes through a chain of transmission linking a colonized or infected patient and a previously unaffected patient by way of the hands or personal items of health-care workers. With this in mind, the most common tools used to prevent the spread of MRSA involve the disruption of these points of contact.

The effectiveness of hand hygiene in preventing the spread of MRSA has been demonstrated in quasi-experimental observational studies in which hand hygiene-promotion campaigns were associated with subsequent reductions in the incidence of MRSA among hospitalized patients. Pittet and colleagues17 demonstrated a significant reduction in MRSA bloodstream infections in one robust investigation. The benefit of hand hygiene appears to be consistent, whether the use of soap and water or alcohol-based hand rubs is promoted.18 The ease of adherence associated with the latter method suggests that this approach may be especially fruitful.

While hand hygiene remains important in the MRSA transmission-control efforts, the continued spread of the pathogen after initial introduction in most facilities has prompted efforts to identify more robust and effective strategies. The use of personal protective equipment—including the donning of gowns and gloves when interacting with patients colonized or infected with MRSA and the assignment of such patients to single rooms or to a room with a group of affected patients—has been widely promoted and adopted. Such isolation precautions now stand as the centerpiece in most authoritative guidelines regarding MRSA control.19 Despite the broad consensus associated with the use of personal protective equipment for MRSA prevention, the specific evidence in support of this practice remains somewhat limited and indirect. Jernigan and colleagues20 noted a significant decrease in the risk of MRSA transmission when isolation precautions were implemented in a pediatric unit. However, the fact that the study was conducted in the midst of a MRSA outbreak in the unit raises questions about the suitability of generalizing these findings to other circumstances, including settings in which MRSA is endemic. Moreover, a number of studies have examined the role of specific elements of isolation precautions (specifically, the use of gowns vs. gloves) with mixed results.21

Given the dissemination of MRSA at most U.S. hospitals despite these measures, it is clear that hand hygiene, barrier precautions and isolation, as presently deployed, have been insufficient to check the spread of MRSA and other antibiotic-resistant pathogens. Much of the blame for this underperformance can likely be attributed to the poor adoption of these measures at most health care facilities. When rigorously assessed, adherence to hand hygiene standards is especially disappointing; many hospitals report a compliance rate of less than 50 percent among health care workers. The situation with personal protective equipment use and adherence to isolation precautions is difficult to assess, as compliance has been less commonly studied and reported. However, a recent report22 found that despite the use of an electronic flag denoting the need for isolation precautions in the records of inpatients at an urban academic medical center, only 58 percent of such patients were placed in a private room and had appropriate signage posted on the door to the room. Other analyses of actual compliance with the donning of gowns and gloves have been similarly disappointing.

A further important limitation of these approaches—and specifically the use of isolation precautions—relates to the potential negative consequences of these measures. A series of studies have associated isolation precautions with worsened outcomes in terms of safety and patient satisfaction.23 In addition, questions have been raised about specific performance measures, such as the frequency with which patients on isolation precautions are visited by treating physicians and the timely recording of vital signs. While the methodology employed in some of these studies has been questioned, no rigorous definitive analysis has been completed to exonerate isolation precautions.24

Based on the failure of conventional control strategies (hand hygiene, barrier precautions and isolation) to adequately control MRSA, more aggressive measures have been promoted in an effort to check the spread of this particularly virulent pathogen. In some European countries, an aggressive containment program colorfully referred to as “search and destroy,” identifies contacts of colonized and infected patients in an effort to intercede to prevent dissemination.25 While such measures have not been widely adopted in most settings, some clinicians, scientists, and increasing numbers of public advocates and legislators have raised the call for more intensive efforts at MRSA control in the U.S. Particular attention has been given to the potential value of active surveillance screening for MRSA. Because routine clinical cultures may identify as few as 18 percent of patients with asymptomatic carriage of antibiotic-resistant organisms such as MRSA, there exists a large reservoir of patients who are silent carriers of these organisms. These individuals may serve as a reservoir for further transmission. With active surveillance, microbiological samples are obtained from at-risk patients even in the absence of signs or symptoms of infection in an effort to identify the underlying population of colonized individuals. In most cases, this involves the collection of a nasal swab, as the nares have been identified as a common sanctuary site for MRSA in colonized individuals. At some centers, additional sites may be sampled, depending on the population under examination (e.g., the umbilicus of newborns; the sites of invasive devices or wounds). By detecting the larger population of colonized individuals, at the very least conventional precautions can be implemented in a broader and a more timely manner so as to interrupt horizontal transmission of MRSA. Detection of colonized patients also permits consideration of more aggressive interventions, including attempts at microbiological eradication or decolonization in order to prevent colonized individuals from becoming infected, as is discussed later.

The specific evidence in support of active surveillance for MRSA has been promising, although a number of questions remain regarding the suitability of this approach in some settings and populations. Some of the evidence for the effectiveness of active surveillance in controlling the spread of antibiotic-resistant organisms came from experience with vancomycin-resistant Enterococcus (VRE). In quasi-experimental studies, rectal screening for this pathogen was associated with decreased transmission at the level of individual units and wards,26 whole hospitals,27 and even across an entire region.28 For MRSA, a number of studies have tested the hypothesis that identification of asymptomatic carriers can result in decreased MRSA transmission. Huang and colleagues29 reported their experience of adding active surveillance screening of patients in the ICU to an already comprehensive control strategy (including hand hygiene promotion) and a bundle of interventions to prevent central line-associated bloodstream infection. Only the addition of active surveillance resulted in a statistically significant decline in the incidence of MRSA bloodstream infections.29 In perhaps the most widely cited report of active surveillance for MRSA, Robicsek and colleagues30 described the impact of a staged implementation of screening, first among patients in an ICU and ultimately involving all patients admitted to a three-hospital health care system in the Chicago suburbs. With this approach, the prevalence and density of MRSA disease fell significantly among all patients. However, this is not to say that the experience with active surveillance has been universally effective. Harbarth and colleagues31 found that active surveillance screening of surgical patients was not associated with a reduction in SSIs in a crossover-design study at a large Swiss center. Thus, questions remain not only about the effectiveness of active surveillance for MRSA carriage, but also about whether screening should be applied to all patient populations (universal screening) or to selected populations, such as patients in the ICU or those undergoing surgical procedures (targeted screening).

A number of methodological issues have been raised about many of the studies of active MRSA surveillance, including both those that support the practice and those that do not. These questions also reflect the methodological uncertainty about deploying the strategy in actual clinical practice. One key issue relates to the microbiological testing method applied. Early on, most surveillance programs relied on conventional culture methods. This approach, while reliable and familiar in the hands of most clinical laboratories, is plagued by the delayed availability of final results, in as much as culturing, subculturing, and formal susceptibility testing can require up to 5 to 6 days in some laboratories. Advances in culture methodology, including the use of chromogenic growth media, can shorten this waiting period, but still do not typically provide clinicians with information regarding the need for isolation precautions until a day or more after the samples are collected. Most recently, the advent of reliable and commercially available polymerase chain reaction (PCR) techniques offer the promise of rapid turnaround time for MRSA detection (often less than several hours). Farr has argued that without standardization and optimization to ensure rapid results from screening, comparisons regarding the relative effectiveness of active surveillance for MRSA are limited.32 Some of the concerns about delayed screening results can be obviated by adopting a policy of early implementation of isolation precautions for all screened patients with the aim to discontinue these measures for those patients who test negative (irrespective of the assay employed). This so-called “guilty until proven innocent” approach, while sound from an epidemiological perspective, has presented logistical challenges at centers where the physical plant limits the availability of rooms and beds for such empirical isolation.

Determining the optimal approach once patients are identified as colonized with MRSA presents an even larger challenge to assessing the effectiveness of active MRSA surveillance. The impact of screening is likely to be exceptionally sensitive to the measures deployed once MRSA carriers are identified. As has been noted, adherence to basic prevention measures, such as hand hygiene and the use of personal protective equipment, is inconsistent in most settings in which compliance has been measured. Nonetheless, these very practices are considered central to the effectiveness of any active surveillance program. Simply stated, knowing which patients are colonized with MRSA should not be expected to affect the frequency of spread if adherence to transmission-control strategies remains inadequate. Surprisingly, even the most robust investigations of the effectiveness of active surveillance have not routinely described the frequency of compliance with hand hygiene and use of personal protective equipment. Similarly, other more intensive measures may dramatically affect the impact of a MRSA-screening program. For example, efforts to decolonize or eradicate MRSA from carrier patients through the use of systemic or topical antimicrobial agents should have an important effect on the likelihood of transmission. This practice has been applied in a number of settings for both MRSA and staphylococcal disease in general.33 The results have been mixed, depending on the population under study, and the risk for emerging antibiotic resistance as the result of such efforts remains a concern. With this in mind, to try to determine the impact of a screening program without detailed information about the deployment of decolonization measures is an important limitation to the available studies and has engendered considerable confusion among clinicians and policymakers.

In light of the promising, but limited, evidence in support of active MRSA surveillance and in consideration of the important methodological questions previously noted, a systematic review of the evidence appears to be both justified and timely. The importance of gaining a better understanding of the evidence is further highlighted by the increasing demand for better control of MRSA and a higher standard for prevention of hospital-acquired infections in general. Policymakers both within and outside of the U.S. health care system have heeded public concern surrounding these issues. The control of MRSA and other antibiotic-resistant bacteria has been highlighted as a likely target for pay-for-performance initiatives on the part of the U.S. Government and a number of private payers. The Joint Commission has highlighted the issue by identifying a National Patient Safety Goal regarding the control and prevention of antibiotic resistance. Perhaps most telling, some state jurisdictions in the U.S. have already mandated screening for MRSA. In some cases, these legislative mandates have been issued even in the face of direct opposition from clinical experts in the field.34 It seems evident that the public and scientific debate regarding the merits and potential negative consequence of widespread MRSA screening will benefit from a systematic review of the available evidence.

## Objective

The objective of this systematic review was to synthesize comparative studies that examined the benefits or harms of screening for MRSA carriage in the inpatient or outpatient settings. The review examined MRSA-screening strategies applied to all hospitalized or ambulatory patients (universal screening), as well as screening strategies applied to selected inpatient or outpatient populations (e.g., patients admitted to the ICU, patients admitted for a surgical procedure, or patients at high-risk of MRSA colonization or infection) and compared them to no screening or to screening of selected patient populations (targeted screening). The review evaluated MRSA-screening strategies that included screening with or without isolation and with or without attempted eradication/decolonization. The patient population included all ambulatory patients (outpatients) and hospitalized patients (inpatients).

## Key Questions

### Key Question 1

Among ambulatory or hospitalized patients, what are the effects of a universal screening strategy for MRSA carriage (screen, isolate, eradicate/decolonize) – when compared to no screening on:

- Intermediate outcomes such as MRSA transmission (as measured by new acquisition events)?
- Health outcomes such as the incidence of MRSA infection, morbidity (including complications of MRSA infection), mortality, adverse events (including allergic and nonallergic toxicity (e.g., hypotension), antimicrobial resistance, reduced quality of care, and medical errors), and hospital resource utilization such as length of stay?

### Key Question 2

Among ambulatory or hospitalized patients, what are the effects of a universal screening strategy for MRSA carriage (screen, isolate, eradicate/decolonize) – when compared to screening of selected patient populations (targeted screening) on:

- Intermediate outcomes such as MRSA transmission (as measured by new acquisition events)?
- Health outcomes such as the incidence of MRSA infection, morbidity (including complications of MRSA infection), mortality, adverse events (including allergic and nonallergic toxicity (e.g., hypotension), antimicrobial resistance, reduced quality of care, and medical errors), and hospital resource utilization such as length of stay?

### Key Question 3A

Among ambulatory or hospitalized patients, what are the effects of screening ICU patients for MRSA carriage (screen, isolate, eradicate/decolonize) – when compared to no screening on:

- Intermediate outcomes such as MRSA transmission (as measured by new acquisition events)?
- Health outcomes such as the incidence of MRSA infection, morbidity (including complications of MRSA infection), mortality, adverse events (including allergic and nonallergic toxicity (e.g., hypotension), antimicrobial resistance, reduced quality of care, and medical errors), and hospital resource utilization such as length of stay?

### Key Question 3B

Among ambulatory or hospitalized patients, what are the effects of screening surgical patients for MRSA carriage (screen, isolate, eradicate/decolonize) – when compared to no screening on:

- Intermediate outcomes such as MRSA transmission (as measured by new acquisition events)?
- Health outcomes such as the incidence of MRSA infection, morbidity (including complications of MRSA infection), mortality, adverse events (including allergic and nonallergic toxicity (e.g., hypotension), antimicrobial resistance, reduced quality of care, and medical errors), and hospital resource utilization such as length of stay?

### Key Question 3C

Among ambulatory or hospitalized patients, what are the effects of screening high-risk patients for MRSA carriage (screen, isolate, eradicate/decolonize) – when compared to no screening on:

- Intermediate outcomes such as MRSA transmission (as measured by new acquisition events)?
- Health outcomes such as the incidence of MRSA infection, morbidity (including complications of MRSA infection), mortality, adverse events (including allergic and nonallergic toxicity (e.g., hypotension), antimicrobial resistance, reduced quality of care, and medical errors), and hospital resource utilization such as length of stay?

### Key Question 4

Among ambulatory or hospitalized patients, what are the effects of an expanded screening strategy for MRSA carriage (e.g., screen, isolate, eradicate/decolonize a broader group of patients, such as patients admitted to the medical ward, the surgical ward or the ICU) – when compared to a limited screening strategy (e.g., screen, isolate, eradicate/decolonize a limited group of patients, such as patients admitted to the ICU) on:

- Intermediate outcomes such as MRSA transmission (as measured by new acquisition events)?
- Health outcomes such as the incidence of MRSA infection, morbidity (including complications of MRSA infection), mortality, adverse events (including allergic and nonallergic toxicity (e.g., hypotension), antimicrobial resistance, reduced quality of care, and medical errors), and hospital resource utilization such as length of stay?

## PICOTS (Population, Intervention, Comparator, Outcome, Timing, and Setting) for the Key Questions

### Patients

All ambulatory patients (outpatients) and all hospitalized patients (inpatients). In addition, the following subpopulations were evaluated: (1) patients admitted to an ICU; (2) patients undergoing surgical procedures; and (3) patients at high-risk of MRSA colonization or infection (e.g., patients transferred from another health care facility, patients receiving hemodialysis).

### Intervention

A MRSA screening strategy applied to all patients in a setting (universal screening) or applied to particular wards, units or patients (targeted screening) that includes:

- 1. MRSA screening using a testing modality (typically PCR) with rapid turnaround (results available on the same day as the testing is performed) or
- 2. MRSA screening using a testing modality with intermediate turnaround (results available next day to 2 days after testing performed) or
- 3. MRSA screening using a testing modality (typically culture) with a longer turnaround time (results available greater than 2 days after testing performed)

And that may include:

- 1. Isolation and/or
- 2. Eradication/decolonization.

### Comparator

No screening or screening of selected patient populations (targeted screening).

### Outcomes

Healthcare-associated MRSA acquisition, health-care associated MRSA infection, morbidity (including complications of MRSA infection), mortality, harms including quality of care for noninfectious conditions, medical errors, adverse effects of screening and treatment including allergic reactions, nonallergic toxicities, and resistance to antimicrobials and hospital resource utilization such as length of stay. Outcome measures should specify whether they are exclusively healthcare-associated or whether they include community-associated outcomes. Healthcare-associated outcomes are most important for MRSA screening in the ambulatory and hospital settings.

### Timing

Intervention through followup.

### Setting

Inpatient (hospital wards and ICUs) and outpatient (ambulatory clinics, urgent care centers and emergency departments).

A comprehensive review evaluating the benefits and harms of screening for MRSA carriage will identify areas of certainty and those that require additional prospective research.

## Analytic Framework

Figure 1 and Figure 2 depict the effects of MRSA screening on intermediate outcomes (including MRSA acquisition) and health outcomes (including infection, morbidity and mortality).

Figure 1 Analytic framework for MRSA screening

KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus

Figure 1 depicts the effects of MRSA screening on intermediate outcomes (including MRSA acquisition) and health outcomes (including MRSA infection, morbidity and mortality).

Figure 2 Detailed analytic framework for MRSA screening

KQ = Key Question; MRSA = methicillin-resistant Staphylococcus aureus; Test + = positive MRSA-screening test result; Test – = negative MRSA-screening test result

Figure 2 depicts the effects of MRSA screening in detail. Once screened, patients may or may not be isolated while awaiting screening results. Once the screening test results are received, patients who screen positive may be isolated; patients who screen negative are not. Eradication/decolonization may be attempted in patients who screen positive. Intermediate outcomes of MRSA screening, including MRSA transmission, are depicted in the figure. Health outcomes, including MRSA infection, morbidity and mortality, are also depicted. The figure illustrates the potential harms of screening, including decreased room availability, decreased attention from health care personnel, antibiotic resistance, allergic reactions, and nonallergic toxicity.