# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report does not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- John Boyce, M.D.
  Clinical Professor of Medicine
  Yale University School of Medicine
  New Haven, CT
- David P. Calfee, M.D., M.S.
  Associate Professor of Public Health and Associate Professor of Medicine
  Weill Cornell Medical College
  New York, NY
- Daniel J. Diekema, M.D., M(ABMM)
  Professor of Medicine and Pathology
  Director, Division of Infectious Diseases
  University of Iowa Hospitals and Clinics
  Iowa City, IA
- W. Charles Huskins, M.D., M.Sc.
  Assistant Professor of Pediatrics
  Mayo Clinic
  Rochester, MN
- Michael Rubin, M.D., Ph.D.
  Associate Professor
  Division of Epidemiology
  Department of Internal Medicine
  University of Utah School of Medicine
  Salt Lake City, UT
- Cassandra D. Salgado, M.D., M.S.
  Associate Professor
  Division of Infectious Disease
  Medical University of South Carolina
  Charleston, SC
- Marin L. Schweizer, Ph.D.
  Assistant Professor
  Department of Internal Medicine
  University of Iowa
  Iowa City, IA
- Sharon B. Wright, M.D., M.P.H.
  Director, Infection Control/Hospital Epidemiology
  Beth Israel Deaconess Medical Center
  Boston, MA