# Technical Expert Panel^*^ * Two Panel members’ names were removed at their request.

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who participated in developing this report follows:

- Craig Conover, M.D., M.P.H.
  State Epidemiologist, Illinois Department of Public Health
  Assistant Professor
  Rush University School of Medicine
  Chicago, IL
- Christopher J. Crnich, M.D., M.S.
  Assistant Professor of Medicine
  Division of Infectious Diseases
  University of Wisconsin School of Medicine and Public Health
  Madison, WI
- Robert S. Daum, M.D., C.M., M.Sc., B.Sc.
  Professor, Committee on Molecular Medicine and Microbiology
  Professor of Pediatrics
  University of Chicago
  Chicago, IL.
- Eli N. Perencevich, M.D., M.S., FIDSA
  Professor of Internal Medicine
  Department of Internal Medicine
  University of Iowa Carver College of Medicine
  Iowa City, IA