# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who participated in developing this report follows:

- Lauren Gallagher, M.P., C.P.H., C.I.C.
  Health Care-Associated Infections Coordinator
  Illinois Department of Public Health
  Chicago, IL
- Susan Gerber, M.D.
  Infectious Diseases
  Department of Pediatrics
  University of Chicago
  Chicago, IL
- Cassandra D. Salgado, M.D., M.S.
  Associate Professor
  Division of Infectious Disease
  Medical University of South Carolina
  Charleston, SC
- Barbara Soule, R.N., M.P.A., C.I.C.
  Practice Leader, Infection Prevention and Control Services
  Joint Commission Resources (JCR) and Joint Commission International (JCI)
  Oakbrook, IL
- Fred Tenover, Ph.D., (D)ABMM, (F)AAM, (F)IDSA
  Associate Director for Laboratory Science
  Division of Healthcare Quality Promotion
  Centers for Disease Control and Prevention
  Bethesda, MD