# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Claudia Bonnell, R.N., M.L.S.; Sharon Flaherty; Lisa Garofalo, B.A.; Lisa Sarsany, M.A.; and Kathleen Ziegler, Pharm.D.