# Discussion

## Key Findings and Strength of Evidence

### Summary of Results

This review found a low strength of evidence to support the effectiveness of universal screening for MRSA carriage compared to no screening in reducing healthcare-associated MRSA infection. However, the available evidence is insufficient to reach a conclusion regarding the effectiveness of screening for MRSA carriage for all of the other comparisons and outcomes of interest evaluated. The bulk of the available literature on the comparative effectiveness of screening for MRSA carriage consists of quasi-experimental studies, largely observational studies with a before/after study design. The sole cluster RCT46 in this literature showed no favorable impact of screening, though concerns about the lengthy turnaround time of the screening modality used and the failure to implement barrier precautions, isolation and/or decolonization while awaiting screening test results limit the applicability of this study’s findings. The use of observational studies to determine causal inference requires protection against bias and confounding through features of design, conduct or analysis. For example, because the incidence of MRSA infection has been decreasing, studies that utilize a before/after study design without adequately controlling for secular trends are unable to distinguish between an effect due to the intervention and an effect due to the persistence of the secular trend itself. Similarly, because other interventions geared toward patient safety, quality improvement or prevention of healthcare-associated infections may also decrease the incidence of MRSA infection, as may unmonitored efforts at decolonization/eradication or improvements to the physical plant that increase the availability of private hospital rooms, studies that utilize a before/after design and do not adequately control for these and other similar confounders cannot establish whether the effect seen is due to the intervention or to the confounding variable. Therefore, studies that performed simple statistical tests without attempts to control for confounding and/or secular trends were excluded from the SOE analysis.

An important limitation of the available evidence regarding MRSA screening relates to heterogeneity in the nature of the interventions performed. By its nature, MRSA screening itself would not be expected to impact the frequency of subsequent transmission or infection. Rather, clinical outcomes are influenced by the application of additional infection control interventions in response to the detection of colonization, including more rigorous hand hygiene, barrier precautions, environmental cleaning, and antimicrobial decolonization. That these interventions are often deployed as part of a “bundle” further limit the conclusions that can be drawn about the attributable benefit of screening compared to any other component of the intervention.

Many of the included studies provided insufficient information about the full scope of interventions deployed in conjunction with screening for MRSA carriage, especially those measures implemented in response to the new detection of MRSA colonization. For example, while decolonization for MRSA-positive patients may not have been recommended as part of the screening intervention, most studies did not address whether or not decolonization was specifically prohibited. As a result, the measured effect of the screening strategy may have been influenced by the application of uncontrolled and unmeasured interventions targeting MRSA colonization.

In addition, included studies often failed to examine the potential impact of other concurrent infection-prevention efforts on the measured impact of screening for MRSA carriage. Campaigns to reduce the frequency of vascular device infections, initiatives to improve hand hygiene, and interventions to promote an institutional culture of safety have been shown to influence the frequency of many healthcare-associated infections, including those caused by MRSA. Therefore, their omission may be important.

Based on the most important and distinctive subgroups of evaluations of MRSA screening strategies, the review is organized to examine the clinical effectiveness of MRSA screening under the following circumstances: (1) universal screening compared to no screening, (2) universal screening compared to screening of selected patient populations, (3a) screening of ICU patients compared to no screening, (3b) screening of surgical patients compared to no screening, (3c) screening of other high-risk patients compared to no screening and (4) screening of a broader population (expanded screening) compared to screening of a limited population (limited screening). This discussion specifically addresses the outcomes of MRSA screening strategies in studies that attempted to control for confounders and/or secular trends (CCS studies). When studies that did not attempt to control for confounders and/or secular trends addressed an outcome, we provided our comments on such studies.

#### MRSA Transmission

By design, the most immediate effect of MRSA screening strategies should be to interrupt the transmission of MRSA between patients, irrespective of the clinical setting under investigation. The impact of MRSA screening on the frequency of transmission can be estimated through examination of the acquisition of MRSA colonization (often considered in conjunction with the incidence of new infection) among patients not previously affected. Based on the CCS studies included in this review, there was insufficient evidence to reach a conclusion on the effect of any screening strategy (universal screening vs. no screening, universal screening vs. screening of selected patient populations, screening of ICU patients vs. no screening, screening of surgical patients vs. no screening, screening of high-risk patients vs. no screening, screening of limited patient populations vs. screening of expanded patient populations) on MRSA transmission.

#### Incidence of MRSA Infection

Reduction in the incidence of MRSA infection is the primary anticipated clinical benefit of intensive strategies for MRSA control, and specifically screening. Based on the findings of this review, there was low SOE in support of universal vs. no screening for MRSA carriage. However, we found insufficient evidence to determine the impact of MRSA screening on the incidence of MRSA infection for all of the other comparisons examined (universal screening vs. screening of selected patient populations, screening of ICU patients vs. no screening, screening of surgical patients vs. no screening, screening of high-risk patients vs. no screening, screening of limited patient populations vs. screening of expanded patient populations).

#### Morbidity and Mortality

Ideally, MRSA screening and other infection prevention strategies will meaningfully impact consequences of infection such as overall patient morbidity and mortality. Unfortunately, comprehensive review of the available literature identified only one study (and none that attempted to control for confounders and/or secular trends) that specifically addressed the issue of whether MRSA screening impacts patient morbidity (including complications of MRSA infection) or mortality compared to no screening or to limited screening. As a result, there is insufficient evidence to reach a conclusion.

#### Potential Harms

In assessing the comparative effectiveness of any intervention, whether diagnostic, therapeutic or screening, it is essential to assess the potential harms of the intervention compared to the harms of not performing the intervention. Unfortunately, none of the studies that attempted to control for confounders and/or secular trends addressed the harms of screening compared to the harms of not screening or the harms of screening compared to the harms of screening selected patient populations. As a result, there is insufficient evidence to reach a conclusion.

#### Hospital Resource Utilization

Hospital resource utilization is an increasingly important element of any intervention that is considered for widespread adoption. MRSA screening programs could offer both the anticipated benefit of reduced consumption of some resources (for example, reduced length of hospital stay). However, the potential benefits must be weighed against the possibility that screening and subsequent infection prevention interventions could also be associated with additional costs. In this review, no study that attempted to control for confounders and/or secular trends was identified that systematically examined the impact of screening compared to no screening or to limited screening on resource utilization. As a result, the evidence is insufficient to support a conclusion regarding the comparative impact of screening on resource utilization.

#### Strength of Evidence

Overall, this review found a low SOE to support the effectiveness of universal screening for MRSA carriage compared to no screening for the outcome of healthcare-associated MRSA infection. However, this review found insufficient evidence available to reach a conclusion regarding the effectiveness of screening for MRSA carriage for all of the other comparisons and outcomes of interest evaluated. Given the observational nature of many of the studies included in this review, a higher quality rating was assigned to those reports that endeavored to control for the risk of bias and confounding through the use of advanced statistical measures. Because the incidence of MRSA infection has been decreasing, studies that utilize a before/after study design without adequately controlling for secular trends are unable to distinguish between an effect due to the intervention and an effect due to the persistence of the secular trend. Similarly, because interventions geared toward patient safety, quality improvement or prevention of healthcare-associated infections (such as catheter-associated bloodstream infections or SSIs) may also decrease the incidence of MRSA infection, as may unmonitored efforts at decolonization/eradication or improvements to the physical plant that increase the availability of private hospital rooms, studies that utilize a before/after design and do not adequately control for these and other confounders are unable to determine whether the effect seen is due to the intervention or to the confounding variable. The use of observational studies to determine causal inference requires protection against bias and confounding through features of design, conduct or analysis. Therefore, studies that performed simple statistical tests without attempts to control for confounding and/or secular trends were excluded from the SOE analysis. Unfortunately, these studies comprised the bulk of the available literature on screening for MRSA carriage. The one RCT46 (a design that minimizes the risk of bias) to examine the impact of MRSA surveillance failed to show a favorable impact of screening, though concerns about the lengthy turnaround time of the screening modality used and the failure to implement barrier precautions, isolation and/or decolonization while awaiting screening test results limit the applicability of this study’s findings.

Publication bias is a consideration in weighing the potential impact of a new strategy or technique in infection prevention and clinical quality improvement. There is considerable experience with screening for MRSA in hospitals as these strategies are routinely and commonly used for hospital based performance improvement. However, the published literature represents data which is generated as part of clinical trials in assessing the effectiveness of such screening strategies. This published data is only a fraction of the total experience and therefore, may be biased in important ways. However, examination of meeting abstracts and other grey literature did not support publication bias.

As was acknowledged by the authors of many of the reports assessed as part of this review, substantial limitations exist that preclude the opportunity to reach important conclusions about the overall effect and utility of MRSA screening. Many of these limitations are detailed specifically later in this discussion. Foremost among these considerations is the ability to adequately control for bias and confounding owing to omissions in design features and statistical analysis of observational studies. In addition, only one non-CCS study assessed the morbidity and mortality associated with MRSA screening compared to no screening or to limited screening. No studies evaluated the potential harms and resource utilization associated with MRSA screening compared to no screening or to limited screening.

## Findings in Relationship to What Is Already Known

### Systematic Reviews

At least two previous systematic reviews have been undertaken in order to assess the impact of MRSA screening in a variety of settings.87,88 A 2008 systematic review87 identified 16 observational studies and four economic analyses. The authors reported that none of the assessed studies was graded as good quality. The authors concluded that there were significant gaps in the evidence that precluded definitive recommendations about the effectiveness of MRSA screening.

Tacconelli et al.88 reviewed nine intervention studies and one cluster randomized crossover trial in 2009. This meta-analysis of studies reporting the same outcome measures revealed a statistically significant reduction in the risk of MRSA bloodstream infections but not SSIs.

While some the conclusions of the present report are not substantially different than those reached in the previous systematic reviews, there are some differences in the interpretation of the findings. In all three reports, the paucity of rigorous, well-controlled studies employing standardized microbiological and infection control techniques serves as a critical limitation. In the present review, a much larger set of published studies is included for assessment. This is largely a function of the large number of studies and reports that have been published since the time that the previous two reports were completed. This is also an indicator of the intense activity in this field over the past several years, itself indicative of the proliferation of MRSA screening in the U.S. and elsewhere. Also distinguishing the present study is the more rigorous grading of the available evidence which may have contributed to the different conclusions reached in the systematic reviews.

### Guidelines and Public Policy

Though the evidence-based reviews have reached similar conclusions, authoritative bodies have expressed diverse opinions and recommendations. The 2006 Guidelines for the Management of Multidrug-Resistant Organisms in Healthcare Settings published by the CDC Healthcare Infection Control Practices Advisory Committee (HICPAC)89 include active surveillance screening as a recommended intensified control strategy for multidrug resistant organisms (MDRO), including MRSA. The document recommends that such interventions should be implemented when the frequency of MDRO infections are not decreasing despite the use of more routine control measures.

The 2003 Society for Healthcare Epidemiology of America Guidelines for Preventing Nosocomial Transmission of Multidrug-Resistant Strains of Staphylococcus aureus and Enterococcus90 take a more affirmative stand regarding the deployment of MRSA screening. The authors recommend that active surveillance cultures and contact precautions be implemented to prevent the spread of epidemiologically significant antibiotic-resistant pathogens. The guidelines further advise that these measures “should be implemented in all types of healthcare facilities throughout the system.”

On the basis of such strong conclusions articulated by authoritative bodies, MRSA screening has been accepted by many key stakeholders as an established standard of care. In a number of U.S. jurisdictions, the practice has been mandated through legislative and regulatory rules, beginning in 2008. A subsequent SHEA position paper,34 stepped back from advocating for mandatory screening, citing concerns about the importance of institutional risk assessment and possible unintended consequences of mandatory and widespread screening.

Based on the conclusions reached in the current review of specific Key Questions regarding MRSA screening, the applicability of these findings and the strength of the available evidence do not appear to readily support or refute the recommendations adopted by the CDC HICPAC89 or in the earlier SHEA Guidelines. That MRSA screening has been adopted as a mandatory practice through legislative action in some jurisdictions is also not easily supported or refuted by the findings of the present review.

## Applicability

Ultimately, the value of published evidence regarding MRSA screening or indeed any clinical intervention is largely determined by the applicability of these data to a wider range of populations in diverse settings. Applicability assessment depends on a body of evidence sufficient to permit conclusions about the comparative outcomes of MRSA screening strategies. This body of evidence does not reach a level of sufficiency; therefore, comments will be limited to relevance to the PICOTS (population, intervention, comparator, outcomes, timing, setting) elements rather than applicability.40 The PICOTS format provides a practical and useful structure to this exercise and is employed in the subsections that follow.40

### Population and Settings

The question of which patient populations may benefit most from MRSA screening remains controversial and is reflected in the diversity of clinical contexts in which screening has been evaluated to date. In a number of studies, the impact of screening when applied to groups of clinically or geographically well-defined populations has been examined. Prominent among these are the ICU and surgery inpatient populations. The application of findings from the ICU and surgery patients to other patient populations is questionable. Specifically, ICU and surgery patients are at especially high risk for healthcare-associated infection as a result of distinctive aspects of their condition and management. For example, patients in both groups frequently undergo compromise of the integument barrier (e.g., insertion of vascular access devices, other invasive procedures) that increases their likelihood of clinically significant infection caused by colonizing strains of bacteria. Therefore, these groups may be especially likely to derive benefit from interventions that reduce the risk of acquisition or colonization with virulent pathogens such as MRSA.

Perhaps in recognition of this potential bias, a number of studies reviewed here examined the impact of MRSA screening in more clinically heterogeneous patient populations, encompassing a broader range of risk for subsequent deep infection. When high-risk patients are identified among this more diverse pool, the same questions arise regarding the applicability to less vulnerable patients.

The potential benefit and harms of MRSA screening have not yet been systematically evaluated in a number of special populations. Specifically, this review did not identify published studies that attempted to control for confounders and/or secular trends that specifically examined the comparative effectiveness of screening for MRSA carriage among children, pregnant women or elderly individuals (except in those cases where advanced age was identified as a specific indicator of high risk). An evaluation of the favorable and unfavorable experience with MRSA screening in such groups is essential.

### Interventions

The first fundamental barrier to widespread applicability of the findings of any MRSA screening program relates to technical variation in the screening methodology itself. Given the limited evidence base, the present review did not allow for a more rigorous and systematic comparison of the relative performance of various laboratory methods or reporting standards. That said, these differences have been widely identified as important potential confounders affecting the evaluation of the performance of an MRSA screening program. One key element relates to the timing with which microbiologic assay results are returned and made available to treating clinicians. Presumably, a delay in reporting these results (such as might be associated with a culture-based lab approach) could limit the potential impact of screening in that the benefit in reduced transmission derived from the implementation of barrier precautions would itself be delayed. Such a delay, or for that matter variability in the performance sensitivity of one laboratory method versus another, could impact the effectiveness of a screening program and the resultant applicability.

Another important limitation to the applicability of the available evidence regarding MRSA screening relates to heterogeneity in the nature of the interventions performed. By its nature, MRSA screening itself (that is to say, the act of detecting MRSA through microbiologic techniques) would not be expected to impact the frequency of subsequent transmission or infection. Rather, it is the application of additional infection control interventions in response to the detection of colonization, including more rigorous hand hygiene and strict barrier precautions, environmental cleaning and even antimicrobial decolonization, that will influence clinical outcomes. That these interventions are often deployed as part of a “bundle” can further limit the conclusions that can be drawn about the attributable benefit of screening versus any of the other interventions.

A number of the studies examined as part of this review offered insufficient information to the reader regarding the full scope of interventions deployed in conjunction with MRSA screening, and specifically those measures implemented in response to the new detection of MRSA colonization. While the application of barrier precautions (the donning of gowns and gloves when caring for MRSA-positive patients) was frequently cited, most reports did not completely control for other practice standards that may have changed in light of new positive screening tests. For example, while decolonization may not have been recommended as part of an MRSA screening intervention, available studies do not, for the most part, address whether or not the use of products such as intranasal mupirocin was specifically prohibited. As a result, the reader cannot be certain that the measured effect was not influenced by the application of such uncontrolled and unmeasured interventions targeting MRSA. In addition, the studies examined as part of this review frequently excluded mention of the assessment of compliance to the specified interventions, leaving readers uncertain as to whether the failure to impact clinical outcomes can be attributed to a lack of effect or poor execution on the part of practitioners.

The heterogeneity in describing interventions was further compounded by a failure in the majority of reviewed reports to explicitly examine the potential impact of other concurrent interventions targeting different outcomes apart from MRSA that could have affected the measured impact of MRSA screening itself. These include but are not limited to campaigns to reduce the frequency of vascular device infections, hand hygiene improvement initiatives and even interventions meant to promote an institutional culture of safety. In that such measures have been shown to potentially influence the frequency of a diversity of healthcare-associated infections (including those caused by MRSA), their omission may be important.

### Comparisons

The majority of studies included in this review are of an observational nature and employ a relatively straightforward before/after design. While this approach is generally appreciated to be of limited rigor, the application of historical controls (pre-intervention) may be especially problematic in the assessment of interventions to prevent the dissemination of infectious pathogens in closed populations (such as hospital inpatients). More specifically, studies conducted in this environment and in this manner are subject to confounding owing to epidemiological trends and phenomena that contribute to typical variations in the incidence of infectious diseases over time. In this context, the smaller the population, the greater the variability that may be encountered. While such changes over time may reflect statistical variation alone, changes in disease incidence may also be due to clusters of infection (which in turn might be attributable to new and more virulent strains of pathogens such as MRSA), deviations and departures from best practice or even the application of other interventions that might influence transmission or infection.

Larger before/after studies, even when conducted across multiple geographic sites and clinical settings, could also be influenced by larger secular trends in the incidence of contagious diseases.41 These broader changes in infectious diseases epidemiology may be attributed to diverse influences including the more widespread dissemination of new prevention practices, changes in antibiotic prescribing, seasonal influences or other unknown factors. That there have been changes in the incidence of some specific MRSA infections over the past decade has been well documented. Unless these macro-trends in epidemiology are identified and accounted for, it is possible that such phenomena could be attributed to the influence of interventions such as MRSA screening.

Where specific populations have been screened (e.g., high risk, surgical patients, etc.) also introduces a challenge to applicability. This is especially the case when decision rules are applied in order to identify individuals at high risk for MRSA carriage and/or infection. While some risk factors for MRSA disease have been well characterized across diverse populations (e.g., prior antibiotic receipt or frequent contact with the health care system), other factors may be more institution- or population-specific, again limiting the applicability of some of these studies.

### Outcomes

The challenge of identifying specific direct health outcomes (such as morbidity and mortality) affected by MRSA screening again limits the applicability of the available evidence and is discussed in greater detail later. In general however, it can be noted that the value of transmission or new acquisition as a surrogate for more meaningful clinical outcomes is limited. Acquisition of new colonization represents just one step in the continuum of a patient progressing through the following states: 1) uncolonized to 2) colonized to 3) infected to 4) complications including death. To the extent that there is variation between individual patients, patient types, clinical settings and institutions in terms of the risk of progressing from colonized to overtly infected and from infected to morbidity and mortality will impact the applicability of the results based on just consideration of acquisition. Similarly, one must anticipate that even in the rare studies in which more meaningful outcomes are reported (including mortality), variation in clinical practices and management between patients, providers and organizations could serve to blunt or exaggerate the benefit attributed to MRSA screening itself.

More detailed analysis of the effect of MRSA screening on specific types of infection (such as vascular access device related bloodstream infections and SSI), whether considered as a primary outcome or examined on a post hoc basis, offers at least the opportunity to more clearly estimate the applicability of study findings. However, this opportunity is contingent on an examination and quantification of the impact of other variables related to both the risk of and interventions to prevent such infections in the study population. Unfortunately, such analysis was not available among the studies included in the present review.

## Implications for Clinical and Policy Decisionmaking

Based on the relatively limited strength of the evidence base and its uncertain applicability, evidence gaps limit the implications that can be drawn for clinical practice and policy decision-making. Further, decision-making is influenced by the complex context regarding the deployment of a resource intensive strategy such as MRSA screening. Factors that contribute to this complexity are outlined in the following sections which consider the circumstances surrounding decision-making at the level of an individual hospital and the wider community.

### Clinical (Hospital-Based) Decisionmaking

Clinical and administrative leaders make decisions about the deployment of hospital-based infection prevention strategies based on a number of factors. First among these is the clinical impact of the particular infection or pathogen that is to be targeted (as determined by the size of the population affected and the severity of associated disease). In this context, infections that occur frequently and that are associated with substantial morbidity and mortality are generally targeted as a high priority for intervention. Ideally, an important next step is to critically examine the performance of those prevention strategies that have already been deployed. In addition to pursuing rigorous surveillance data to accurately measure the impact on outcomes, hospital decision makers strive to determine whether the effectiveness of these strategies is in any way limited, such as by poor compliance with best practices or inadequate resource allocation. The next step is to determine the likely impact of the strategy under consideration. This assessment, which is aligned most closely with the type of systematic examination of the available evidence included in this review, compels hospital leadership to identify best practices that are most applicable to the problem and the local environment. A critical element of this review was to ascertain the potential unintended consequences and harms of the intervention so as to best assess the impact and to try to mitigate risk. Finally, economic considerations must be evaluated. In general, resources applied to infection prevention are limited and must be allocated efficiently so as to minimize risk of infection to the greatest number of patients.

According to accreditation standards adopted at most U.S. hospitals, the process described in the preceding paragraph should be undertaken on a periodic basis by a multidisciplinary group as part of formal infection control risk assessment. This exercise, which may be undertaken in a semi-quantitative fashion employing standardized tools, is intended to ensure that infection prevention resources are allocated in the most rational manner.

Based on examination of the available evidence as summarized in this review, it appears that insufficient information is currently available to support or refute the routine implementation of MRSA screening by local infection prevention experts and hospital leaders as part of organizational infection control risk assessment in all settings. Fundamental limitations (discussed in the following section) regarding the impact of MRSA screening on diverse populations and a variety of outcomes are most critical. Decision-making is further hindered by a near complete absence of systematic evidence regarding the potential harms of MRSA screening. However, even in the absence of these data, hospital leaders may feel compelled to make a determination regarding the appropriateness of MRSA screening based on the other factors described at the beginning of this section. More specifically, if MRSA infection is affecting a large number of patients and the resultant infections are severe and even life threatening, infection prevention experts and hospital leadership may feel the potential benefits of screening outweigh the risks, even in light of the limited available evidence to deploy a screening program. This may especially be the case if other interventions, when maximally deployed and supported, have been unable to check the spread of infection. In essence, this advice mirrors that offered in the CDC HICPAC guidelines previously cited.

### Policy Decisionmaking

The challenges of applying the available evidence base are further compounded when decision making about MRSA screening is considered as a matter of public policy (such as in accreditation standards or legislative mandates). In this context, limitations of the applicability of the available evidence (see previous section) are especially important. One of the key arguments that has been raised against the application of broad policy mandates compelling the implementation of MRSA screening relates to the value of institutional risk assessment in determining the most appropriate control strategies for MRSA and indeed all infectious threats. In this setting, understanding the precise needs and values of the institution and then reviewing the available evidence to determine the extent to which the experience reported in the literature can be applied is essential.

## Limitations of the Comparative Effectiveness Review Process

There were a number of questions and potential limitations that arose during the clinical effectiveness review process. One unexpected challenge related to intense research and policy activity surrounding MRSA screening in the time during which the review was conducted. Ongoing surveillance of the available literature as well as close scrutiny of meeting abstracts and the grey literature was undertaken to mitigate the risk that important new studies would be omitted.

Another important challenge came when determining the scope of the review. In general, the decision was made to be inclusive in considering the available literature, in which observational studies make up the bulk of the literature.

In the same vein, contributors to this review were challenged to negotiate a rational and justifiable framework for grading the SOE of the many observational reports included in the assessment. To this end, the decision was made to recognize the importance of more advanced statistical methods in attempting to control for confounding inherent in this study approach.91–93 As a result, those reports that employed regression analysis or time series analysis were assigned a higher level of quality than other reports. A more detailed discussion of the review of the SOE is provided elsewhere in this report.

## Limitations of the Evidence Base, Research Gaps and Future Research Opportunities

As has been noted, there are numerous limitations to the available evidence base that ultimately compromise the applicability of these findings to clinical and policy decision-making. In this section, these limitations are more clearly articulated and then important gaps in the available evidence are identified as targets for future research. In undertaking the comprehensive needs assessment, the PICOTS structure is once again adapted. Finally, specific concerns related to study design and analytical methods are outlined, again in the hopes of encouraging improved standards in future research.

### Populations and Settings

There is an inherent tension when selecting patient populations and clinical settings for the application of MRSA screening. Larger and more diverse patient groups (such as those that might be captured in a universal screening algorithm) offer the greatest opportunity to detect benefits and harms as measured by meaningful clinical outcomes (including morbidity and mortality). At the same time, the impact of screening on such heterogeneous groups may be biased by uncontrolled confounders or diluted by the inclusion of patients at varying degree of risk for MRSA acquisition or subsequent infection.

Ideally, future studies could target larger more homogeneous patient populations. This approach will permit the detection of even rare outcomes while simultaneously extending the applicability of the findings to similar large populations and patient groups. Moreover, by restricting inclusion so as to control for confounding that arises in heterogeneous patient populations, the opportunity to detect true biological predictors of benefit or harm are maximized. Realistically, this degree of scale will only be achieved through large multicenter trials, as is noted at the end of this section. In the future, widespread use of electronic medical records may provide predictors of benefits or harms.

Another concern regarding the patient populations included in the available evidence base relates to the study of special populations. While the risk of MRSA infection varies in some of these groups, it is essential that the potential positive and negative impact of MRSA screening on unique groups such as children and pregnant women be explored.

### Interventions

As has been noted, there are severe limitations in the available evidence that can be attributed to pronounced inconsistency in defining, applying and measuring the various interventions that are bundled as part of MRSA screening. As a result, future studies that aim to contribute evidence on the benefits of screening for MRSA carriage must take a more controlled approach to the application of specific laboratory measures (e.g., PCR versus culture), test turnaround time, the management of patients while awaiting test results, transmission prevention strategies (e.g., contact precautions), and the use of decolonization therapy and environmental control. In addition, more precise accounting is required in order to best understand and quantify the potential bias introduced by secular and local epidemiologic trends and the influence of concomitant infection prevention strategies and interventions. This last point is especially important as infection prevention strategies (including MRSA screening) are typically deployed in sequence or concurrently. In this manner, it is essential to document the context in which screening was implemented so as to best understand the impact of the intervention. Important considerations could include prior MDRO control programs and an assessment of the culture of safety at the study sites.

In terms of addressing these shortcomings, it is unrealistic to believe that a standardized and uniform approach can be recommended and applied to all future studies of MRSA screening. Lacking such a standard, a maximally transparent approach to reporting such details is absolutely critical. During study design and budgeting, extreme caution should be applied to ensure that early methodological decisions (such as the selection of a testing modality with a lengthy turnaround time) do not undermine the applicability and strength of the findings that might ultimately be generated.

Ideally, additional studies can be undertaken that will effectively compare the impact of screening strategies employing a variety of specific interventions and approaches. In essence, this work will entail examining each element of an intervention bundle in order to accurately determine the attributable benefit or harm for each component of the bundle. It may be the case, for example, that a component such as decolonization for incidentally discovered cases of MRSA may independently produce a significant clinical benefit.

### Comparisons

Clinically meaningful and methodologically sound comparisons serve as the cornerstones that support the SOE and applicability of applied clinical research. This is especially true when reporting the findings of observational studies. If there is one key shortcoming in the available evidence for MRSA screening, it relates to fundamental issues of study design and specifically the overreliance on before/after studies.

As has been noted elsewhere in this discussion, the before/after design allows for the introduction of considerable unmeasured bias into even large observational epidemiologic studies. In this regard, even the large multicenter examinations of the impact of MRSA screening, when executed as a simple before/after design, may be seen as severely flawed.

Increasingly, it is recognized that the optimal design for testing and evaluating the impact of a novel infection prevention strategy is the cluster-RCT. With this approach, an individual unit (such as a single ICU) is randomized to either an intervention or control arm. However, cluster RCTs may also face barriers to feasibility due to the large number of institutions needed to achieve balance after randomization. It is also imperative to improve the quality of quasi-experimental studies through: (1) more rigorous study design; (2) controlling for secular trends and confounders; and (3) reporting on the full range of clinically important outcomes.

### Outcomes

Deficiencies in the evidence base regarding specific outcomes can be addressed in alignment with the outcomes of interest that served as the original basis for much of this review. For any future research comparing MRSA screening strategies, it is critical that these clinically significant outcomes be precisely defined and collected.

In terms of the incidence of MRSA infection, we found that many comparative studies of screening for MRSA carriage reported on healthcare-associated MRSA infection. However, the definition of MRSA infection varied among studies. For future research in this field, it is imperative that case definitions are precise and specific. Ideally these will be adjusted to harmonize with existing case definitions from the CDC and elsewhere.

Precise estimates of the impact of MRSA screening on morbidity and mortality remain lacking in the extant literature that evaluates the comparative effectiveness of screening for MRSA carriage. To allow more meaningful assessment of these crucial health outcomes, future studies will need to enroll sufficient numbers of patients to be adequately powered to detect the effect of screening for MRSA carriage compared to no screening or to screening of selected patient populations on morbidity and mortality. Once again, this purpose will be best served in all likelihood through the establishment of multicenter studies.

So long as more comprehensive studies of morbidity and mortality remain elusive, the use of MRSA acquisition and transmission as a surrogate to measure the impact of screening will persist. That said, the rigor with which this outcome is tested should be enhanced. Specifically, there is the opportunity to apply more standardized approaches to the collection of surveillance specimens to detect new colonization events. Moreover, the confounding that could be introduced by failing to examine the frequency with which various patient populations proceed from colonization to infection can be mitigated through more careful analysis.

If there is a singular deficiency in determining the applicability of the results of MRSA screening studies it is directly linked to the failure to measure the unintended harms that can come with even a well-intentioned screening program compared with the harms of not screening or of screening selected patient populations. Among the numerous potential harms that have been associated with MRSA screening and related interventions are: social isolation and increased risk of safety events associated with contact precautions, inappropriate use of mupirocin, increased risk of inappropriate systemic antibiotic use, delays in patient flow and hospital discharge, and stigma associated with colonization or infection. To attempt to measure the favorable impact of MRSA screening while ignoring the potential risks is to present incomplete and potentially misleading data.

## Conclusions

There is low SOE that universal screening of hospital patients decreases MRSA infection. However, there is insufficient evidence on other outcomes of universal MRSA screening, including morbidity, mortality, harms and resource utilization. There is also insufficient evidence to support or refute the effectiveness of MRSA screening on any outcomes in other settings. The available literature consisted mainly of observational studies with insufficient controls for secular trends and confounding to support causal inference, particularly because other inventions were inconsistently bundled together with MRSA screening. Future research on MRSA screening should use design features and analytic strategies addressing secular trends and confounding. Designs should also permit assessment of effects of specific bundles of screening and infection control interventions and address outcomes including morbidity, mortality, harms and resource utilization.