# Deeks’ Criteria To Assess Quality of Nonrandomized Comparative Studies

The quality of included nonrandomized comparative intervention studies was also assessed based on a selection of items proposed by Deeks et al.,^*^ to inform the approach used by the U.S. Preventive Services Task Force,^†^ as follows:

* Deeks JJ, Dinnes J, D’Amico R, et al. Evaluating non-randomised intervention studies. Health Technol Assess. 2003;7(27):iii-x. 1. 173. [pmid: 14499048].

† Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].

- Was sample definition and selection prospective or retrospective?
- Were inclusion/exclusion criteria clearly described?
- Were participants selected to be representative?
- Was there an attempt to balance groups by design?
- Were baseline prognostic characteristics clearly described and groups shown to be comparable?
- Were interventions clearly specified?
- Were participants in treatment groups recruited in the same time period?
- Was there an attempt by investigators to allocate participants to treatment groups in an attempt to minimize bias?
- Were concurrent/concomitant treatments clearly specified and given equally to treatment groups?
- Were outcome measures clearly valid, reliable and equally applied to treatment groups?
- Were outcome assessors blinded?
- Was the length of follow-up adequate?
- Was attrition below an overall high level (less than 20 percent)?
- Was the difference in attrition between treatment groups below a high level (less than 15 percent)?
- Did the analysis of outcome data incorporate a method for handling confounders such as statistical adjustment?