# Data Abstraction Tables

Appendix Table F1 Characteristics of studies that used statistical methods to attempt to control for confounding or secular trends

Appendix Table F2 Characteristics of studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F3 Infection control practices in studies that used statistical methods to attempt to control for confounding or secular trends

Appendix Table F4 Infection control practices in studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F5 Health care-associated MRSA colonization or infection: studies that used statistical methods to attempt to control for confounding or secular trends

Appendix Table F6 Health care-associated or acquired MRSA infection or colonization: studies that used statistical methods to attempt to control for confounding or secular trends

Appendix Table F7 Health care-associated MRSA infection: studies that used statistical methods to attempt to control for confounding or secular trends

Appendix Table F8 MRSA infection: studies that used statistical methods to attempt to control for confounding or secular trends

Appendix Table F9 Health care-associated MRSA bacteremia or BSI: studies that used statistical methods to attempt to control for confounding or secular trends

Appendix Table F10 Health care-associated or acquired MRSA bacteremia or BSI: studies that used statistical methods to attempt to control for confounding or secular trends

Appendix Table F11 Healthcare associated MRSA surgical site infections: studies that used statistical methods to attempt to control for confounding or secular trends

Appendix Table F12 Health care-associated MRSA colonization or infection: studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F13 Health care-associated or acquired MRSA infection or colonization: studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F14 Healthcare-associated MRSA infection: studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F15 MRSA infection: studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F16 Health care-associated MRSA bacteremia or BSI: studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F17 Health care-associated or acquired MRSA bacteremia or BSI: studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F18 MRSA BSI (not clearly acquired): studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F19 Healthcare associated MRSA surgical site infection: studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F20 MRSA related morbidity: studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F21 MRSA related mortality: studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F22 MRSA resource utilization: studies that did not use statistical methods to attempt to control for confounding or secular trends

Appendix Table F23 USPSTF study quality ratings

## Appendix F Reference Citations

1 Chaberny IF, Schwab F, Ziesing S, et al. Impact of routine surgical ward and intensive care unit admission surveillance cultures on hospital-wide nosocomial methicillin-resistant Staphylococcus aureus infections in a university hospital: an interrupted time-series analysis. J Antimicrob Chemother. Dec. 2008;62(6):1422-9. [pmid: 18765411].
2 Chowers MY, Paitan Y, Gottesman BS, et al. Hospital-wide methicillin-resistant Staphylococcus aureus control program: A 5-year follow-up. Infect Control Hosp Epidemiol. Aug. 2009;30(8):778-81. [pmid: 19580437].
3 Ellingson K, Muder RR, Jain R, et al. Sustained reduction in the clinical incidence of methicillin-resistant Staphylococcus aureus colonization or infection associated with a multifaceted infection control intervention. Infect Control Hosp Epidemiol. Jan. 2011;32(1):1-8. [pmid: 21133794].
4 Gould IM, MacKenzie FM, MacLennan G, et al. Topical antimicrobials in combination with admission screening and barrier precautions to control endemic methicillin-resistant Staphylococcus aureus in an Intensive Care Unit. Int J Antimicrob Agents. May. 2007;29(5):536-43. [pmid: 17337163].
5 Harbarth S, Fankhauser C, Schrenzel J, et al. Universal screening for methicillin-resistant Staphylococcus aureus at hospital admission and nosocomial infection in surgical patients. JAMA. 2008;299(10):1149-57. [pmid: 18334690].
6 Harbarth S, Martin Y, Rohner P, et al. Effect of delayed infection control measures on a hospital outbreak of methicillin-resistant Staphylococcus aureus. J Hosp Infect. Sep. 2000;46(1):43-9. [pmid: 11023722].
7 Holzmann-Pazgal G, Monney C, Davis K, et al. Active surveillance culturing impacts methicillin-resistant Staphylococcus aureus acquisition in a pediatric intensive care unit. Pediatric Critical Care Medicine. 2011;12(4):e171-e5. [pmid: 20838355].
8 Huang SS, Yokoe DS, Hinrichsen VL, et al. Impact of routine intensive care unit surveillance cultures and resultant barrier precautions on hospital-wide methicillin-resistant Staphylococcus aureus bacteremia. Clin Infect Dis. Oct. 15. 2006;43(8):971-8. [pmid: 16983607].
9 Huskins WC, Huckabee CM, O’Grady NP, et al. Intervention to reduce transmission of resistant bacteria in intensive care. N Engl J Med. Apr. 14. 2011;364(15):1407-18. [pmid: 21488763].
10 Jain R, Kralovic SM, Evans ME, et al. Veterans Affairs initiative to prevent methicillin-resistant Staphylococcus aureus infections. N Engl J Med. Apr. 14. 2011;364(15):1419-30. [pmid: 21488764].
11 Leonhardt KK, Yakusheva O, Phelan D, et al. Clinical effectiveness and cost benefit of universal versus targeted methicillin-resistant Staphylococcus aureus screening upon admission in hospitals. Infection Control and Hospital Epidemiology. 2011;32(8):797-803. [pmid: 21768764].
12 Muder RR, Cunningham C, McCray E, et al. Implementation of an industrial systems-engineering approach to reduce the incidence of methicillin-resistant Staphylococcus aureus infection. Infect Control Hosp Epidemiol. Aug. 2008;29(8):702-8. 7 p following 8. [pmid: 18624651].
13 Raineri E, Crema L, De Silvestri A, et al. Meticillin-resistant Staphylococcus aureus control in an intensive care unit: a 10 year analysis. J Hosp Infect. Dec. 2007;67(4):308-15. [pmid: 17945395].
14 Reilly JS, Stewart S, Christie P, et al. Universal screening for meticillin-resistant Staphylococcus aureus in acute care: risk factors and outcome from a multicentre study. J Hosp Infect. Jan. 2012;80(1):31-5. [pmid: 22104473].
15 Robicsek A, Beaumont JL, Paule SM, et al. Universal surveillance for methicillin-resistant Staphylococcus aureus in 3 affiliated hospitals. Ann Intern Med. Mar. 18. 2008;148(6):409-18. [pmid: 18347349].
16 Rodriguez-Bano J, Lopez-Prieto MD, Portillo MM, et al. Epidemiology and clinical features of community-acquired, healthcare-associated and nosocomial bloodstream infections in tertiary-care and community hospitals. Clin Microbiol Infect. Sep. 2010;16(9):1408-13. [pmid: 19845694].
17 Blumberg LH, Klugman KP. Control of methicillin-resistant Staphylococcus aureus bacteraemia in high-risk areas. Eur J Clin Microbiol Infect Dis. Jan. 1994;13(1):82-5. [pmid: 8168568].
18 Bowler WA, Bresnahan J, Bradfish A, et al. An integrated approach to methicillin-resistant Staphylococcus aureus control in a rural, regional-referral healthcare setting. Infect Control Hosp Epidemiol. Mar. 2010;31(3):269-75. [pmid: 20102280].
19 Boyce JM, Havill NL, Kohan C, et al. Do infection control measures work for methicillin-resistant Staphylococcus aureus?. Infect Control Hosp Epidemiol. 2004;25(5):395-401. [pmid: 15188845].
20 Chen AF, Chivukula S, Jacobs LJ, et al. What Is the Prevalence of MRSA Colonization in Elective Spine Cases?. Clin Orthop Relat Res. 2012. Mar. 23. [pmid: 22441994].
21 Clancy M, Graepler A, Wilson M, et al. Active screening in high-risk units is an effective and cost-avoidant method to reduce the rate of methicillin-resistant Staphylococcus aureus infection in the hospital. Infect Control Hosp Epidemiol. 2006;27(10):1009-17. [pmid: 17006806].
22 de la Cal MA, Cerda E, van Saene HK, et al. Effectiveness and safety of enteral vancomycin to control endemicity of methicillin-resistant Staphylococcus aureus in a medical/surgical intensive care unit. J Hosp Infect. Mar. 2004;56(3):175-83. [pmid: 15003664].
23 Enoch DA, Cargill JS, Sismey A, et al. MRSA surveillance in a UK district hospital: measuring clinical isolates with MRSA is more useful than measuring MRSA bacteraemias. J Hosp Infect. Dec. 2011;79(4):287-91. [pmid: 21978609].
24 Eveillard M, Mortier E, Lancien E, et al. Consideration of age at admission for selective screening to identify methicillin-resistant Staphylococcus aureus carriers to control dissemination in a medical ward. Am J Infect Control. 2006;34(3):108-13. [pmid: 16630972].
25 Girou E, Azar J, Wolkenstein P, et al. Comparison of systematic versus selective screening for methicillin-resistant Staphylococcus aureus carriage in a high-risk dermatology ward. Infect Control Hosp Epidemiol. Sep. 2000;21(9):583-7. [pmid: 11001261].
26 Jog S, Cunningham R, Cooper S, et al. Impact of preoperative screening for meticillin-resistant Staphylococcus aureus by real-time polymerase chain reaction in patients undergoing cardiac surgery. J Hosp Infect. Jun. 2008;69(2):124-30. [pmid: 18387695].
27 Kelly JC, O’Briain DE, Walls R, et al. The role of pre-operative assessment and ringfencing of services in the control of methicillin resistant Staphlococcus aureus infection in orthopaedic patients. The surgeon : journal of the Royal Colleges of Surgeons of Edinburgh and Ireland. Apr. 2012;10(2):75-9. [pmid: 22385528].
28 Keshtgar MR, Khalili A, Coen PG, et al. Impact of rapid molecular screening for meticillin-resistant Staphylococcus aureus in surgical wards. Br J Surg. Mar. 2008;95(3):381-6. [pmid: 18041109].
29 Kim DH, Spencer M, Davidson SM, et al. Institutional prescreening for detection and eradication of methicillin-resistant Staphylococcus aureus in patients undergoing elective orthopaedic surgery. J Bone Joint Surg Am. Aug. 4. 2010;92(9):1820-6. [pmid: 20610773].
30 Kurup A, Chlebicka N, Tan KY, et al. Active surveillance testing and decontamination strategies in intensive care units to reduce methicillin-resistant Staphylococcus aureus infections. Am J Infect Control. Jun. 2010;38(5):361-7. [pmid: 20189267].
31 Lipke VL, Hyott AS. Reducing surgical site infections by bundling multiple risk reduction strategies and active surveillance. AORN J. Sep. 2010;92(3):288-96. [pmid: 20816102].
32 Malde DJ, Abidia A, McCollum C, et al. The success of routine MRSA screening in vascular surgery: a nine year review. Int Angiol. Jun. 2006;25(2):204-8. [pmid: 16763540].
33 Nixon M, Jackson B, Varghese P, et al. Methicillin-resistant Staphylococcus aureus on orthopaedic wards: incidence, spread, mortality, cost and control. J Bone Joint Surg Br. Jun. 2006;88(6):812-7. [pmid: 16720779].
34 Pan A, Carnevale G, Catenazzi P, et al. Trends in methicillin-resistant Staphylococcus aureus (MRSA) bloodstream infections: effect of the MRSA “search and isolate” strategy in a hospital in Italy with hyperendemic MRSA. Infect Control Hosp Epidemiol. 2005;26(2):127-33. [pmid: 15756881].
35 Pofahl WE, Goettler CE, Ramsey KM, et al. Active surveillance screening of MRSA and eradication of the carrier state decreases surgical-site infections caused by MRSA. J Am Coll Surg. May. 2009;208(5):981-6. discussion 6–8. [pmid: 19476875].
36 Salaripour M, McKernan P, Devlin R. A multidisciplinary approach to reducing outbreaks and nosocomial MRSA in a university-affiliated hospital. Healthc Q. Oct. 2006;9(Spec No):54-60. [pmid: 17087169].
37 Sankar B, Hopgood P, Bell KM. The role of MRSA screening in joint-replacement surgery. Int Orthop. Jun. 2005;29(3):160-3. [pmid: 15864590].
38 Schelenz S, Tucker D, Georgeu C, et al. Significant reduction of endemic MRSA acquisition and infection in cardiothoracic patients by means of an enhanced targeted infection control programme. J Hosp Infect. Jun. 2005;60(2):104-10. [pmid: 15866007].
39 Simmons S. Effects of selective patient screening for MRSA on overall MRSA hospital-acquired infection rates. Crit Care Nurs Q. Jan–Mar. 2011;34(1):18-24. [pmid: 21160296].
40 Sott AH, Jones R, Davies S, et al. The value of pre-operative screening for MRSA in the reduction of sepsis in total hip replacement associated with MRSA. A prospective audit. HIP Int. 2001;11(2):102-6.
41 Souweine B, Traore O, Aublet-Cuvelier B, et al. Role of infection control measures in limiting morbidity associated with multi-resistant organisms in critically ill patients. J Hosp Infect. Jun. 2000;45(2):107-16. [pmid: 10860687].
42 Supriya M, Shakeel M, Santangeli L, et al. Controlling MRSA in head and neck cancer patients: what works?. Otolaryngol Head Neck Surg. 2009;140(2):224-7. [pmid: 19201293].
43 Thomas S, Cantrill S, Waghorn DJ, et al. The role of screening and antibiotic prophylaxis in the prevention of percutaneous gastrostomy site infection caused by methicillin-resistant Staphylococcus aureus. Aliment Pharmacol Ther. Mar. 1. 2007;25(5):593-7. [pmid: 17305760].
44 Thompson DS, Workman R, Strutt M. Decline in the rates of meticillin-resistant Staphylococcus aureus acquisition and bacteraemia in a general intensive care unit between 1996 and 2008. J Hosp Infect. 2009;71(4):314-9. [pmid: 19217186].
45 Trautmann M, Pollitt A, Loh U, et al. Implementation of an intensified infection control program to reduce MRSA transmissions in a German tertiary care hospital. Am J Infect Control. Dec. 2007;35(10):643-9. [pmid: 18063128].
46 Walsh EE, Greene L, Kirshner R. Sustained reduction in methicillin-resistant Staphylococcus aureus wound infections after cardiothoracic surgery. Arch Intern Med. Jan. 10. 2011;171(1):68-73. [pmid: 20837818].
47 Wernitz MH, Swidsinski S, Weist K, et al. Effectiveness of a hospital-wide selective screening programme for methicillin-resistant Staphylococcus aureus (MRSA) carriers at hospital admission to prevent hospital-acquired MRSA infections. Clin Microbiol Infect. 2005;11(6):457-65. [pmid: 15882195].
48 West TE, Guerry C, Hiott M, et al. Effect of targeted surveillance for control of methicillin-resistant Staphylococcus aureus in a community hospital system. Infect Control Hosp Epidemiol. Mar. 2006;27(3):233-8. [pmid: 16532409].