# Excluded Studies

## Excluded: Foreign Language

1 Bailly P, Mulin B, Minary P, Talon D. Control of methicillin-resistant Staphylococcus aureus infections in a university hospital: Critical analysis of results: Controle des infections Staphylococcus aureus meticillinoresistant dans un CHU: Analyse critique des resultats obtenus. Med Mal Infect. 1999;29(3):178-183. Ref ID 1284.

## Excluded: No Primary Data

1 Kohli HS. Methicillin-resistant Staphylococcus aureus screening in Scotland. Natl Med J India. 2007;20(5):260-1. Ref ID 1. [pmid: 18254526].
2 Pavlov. High colonization pressure might compromise the efficiency of routine methicillin-resistant Staphylococcus aureus screening. Clin Infect Dis. 2007;44(5):766. author reply 766–7. Ref ID 58. [pmid: 17278082].
3 EMR has key role in screening program to reduce MRSA infection. Perform Improv Advis. 2005;9(11):129-30. 121. Ref ID 225. [pmid: 16363105].
4 Duckworth G, Charlett A. Improving surveillance of MRSA bacteraemia. BMJ. 2005;331(7523):976-7. Ref ID 226. [pmid: 16254275].
5 Johnson P, Pearson A, Duckworth G. Surveillance and epidemiology of MRSA bacteraemia in the UK. J Antimicrob Chemother. 2005;56(3):455-62. Ref ID 239. [pmid: 16046464].
6 Verbrugh HA. Value of screening and isolation for control of methicillin-resistant Staphylococcus aureus. Clin Infect Dis. 2005;41(2):268-9. author reply 270–1. Ref ID 245. [pmid: 15983928].
7 Bissett L. Controlling the risk of MRSA infection: screening and isolating patients. Br J Nurs. 2005;14(7):386-90. Ref ID 276. [pmid: 15924014].
8 Meek C. Isolate patients, screen staff to fight MRSA. CMAJ. 2004;171(10):1158. Ref ID 323. [pmid: 15534301].
9 Farr BM. Prevention and control of methicillin-resistant Staphylococcus aureus infections. Curr Opin Infect Dis. 2004;17(4):317-22. Ref ID 346. [pmid: 15241075].
10 Hawley LA, Fridkin SK, Whitney CG. Drug-resistant Streptococcus pneumoniae and methicillin-resistant Staphylococcus aureus surveillance. Emerg Infect Dis. 2003;9(10):1358-9. Ref ID 406. [pmid: 14626229].
11 Muto CA, Jernigan JA, Ostrowsky BE, Richet HM, Jarvis WR, Boyce JM, Farr BM. SHEA guideline for preventing nosocomial transmission of multidrug-resistant strains of Staphylococcus aureus and enterococcus. Infect Control Hosp Epidemiol. 2003;24(5):362-86. Ref ID 446. [pmid: 12785411].
12 Cooper BS, Stone SP, Kibbler CC, Cookson BD, Roberts JA, Medley GF, Duckworth GJ, Lai R, Ebrahim S. Systematic review of isolation policies in the hospital management of methicillin-resistant Staphylococcus aureus: a review of the literature with epidemiological and economic modelling. Health Technol Assess. 2003;7(39):1-194. Ref ID 466. [pmid: 14636487].
13 Arnold MS, Dempsey JM, Fishman M, McAuley PJ, Tibert C, Vallande NC. The best hospital practices for controlling methicillin-resistant Staphylococcus aureus: on the cutting edge. Infect Control Hosp Epidemiol. 2002;23(2):69-76. Ref ID 520. [pmid: 11893151].
14 Farr BM, Jarvis WR. Would active surveillance cultures help control healthcare-related methicillin-resistant Staphylococcus aureus infections?. Infect Control Hosp Epidemiol. 2002;23(2):65-8. Ref ID 521. [pmid: 11893150].
15 Wilcox MH, Swann A. Methicillin-resistant Staphylococcus aureus and healthcare associated infection surveillance. J Hosp Infect. 2002;50(1):80-1. Ref ID 528. [pmid: 11825058].
16 Hospital’s aggressive screening efforts save money in long run. Health Care Cost Reengineering Rep. 1997;2(9):135-40. Ref ID 711. [pmid: 10173922].
17 Thornsberry C. Epidemiology of staphylococcal infections--a USA perspective. J Chemother. Suppl 2. 1994;6:61-5. Ref ID 797. [pmid: 7799056].
18 Thompson RL, Cabezudo I, Wenzel RP. Epidemiology of nosocomial infections caused by methicillin-resistant Staphylococcus aureus. Ann Intern Med. 1982;97(3):309-17. Ref ID 881. [pmid: 7114627].
19 Slekovec C, Talon D, Bertrand X. Which screening is needed in intensive care units: MRSA or Pseudomonas aeruginosa?. J Hosp Infect. 2010;75(4):329-330. Ref ID 896. [pmid: 20381902].
20 Raghunath D. Editorial: National antibiotic resistance surveillance and control. Indian J Med. Microbiol. 2010;28(3):189-190. Ref ID 906. [pmid: 20644302].
21 Salgado C, Schrenzel J, McDaniel G. New CLSI report provides guidance on methicillin-resistant Staphylococcus aureus (MRSA) surveillance. Lab Med. 2010;41(6):375-376. Ref ID 909.
22 Tauman V, Robicsek A, Roberson J, Boyce JM. Health care - Associated infection prevention and control: Pharmacists’ role in meeting national patient safety goal 7. Hosp Pharm. 2009;44(5):401-411. Ref ID 972.
23 Hefferman H. Other surveillance reports. New Zealand Public Health Surveill Rep. 2007;5(2):4-5. Ref ID 1054.
24 McDowell R, McLean M, Johnston A. Other surveillance reports. New Zealand Public Health Surveill Rep. 2004;2(1):4-5. Ref ID 1175.
25 Diekema D. Benefits and drawbacks of universal surveillance of methicillin-resistant Staphylococcus aureus. Ann Intern Med. 2008;149(1):67. author reply 68–9. Ref ID 9014. [pmid: 18591646].
26 Gould FK, Brindle R, Chadwick PR, Fraise AP, Hill S, Nathwani D, Ridgway GL, Spry MJ, Warren RE. Guidelines 2008 for the prophylaxis and treatment of methicillin-resistant Staphylococcus aureus (MRSA) infections in the United Kingdom. J Antimicrob Chemother. 2009;63(5):849-61. Ref ID 9019. [pmid: 19282331].
27 Griffin FA. 5 Million Lives Campaign. Reducing methicillin-resistant Staphylococcus aureus (MRSA) infections. Jt Comm J Qual Patient Saf. 2007;33(12):726-31. Ref ID 9022. [pmid: 18200897].
28 Harris R. Universal screening for methicillin-resistant Staphylococcus aureus by hospitals. JAMA. 2008;300(5):503. author reply 504–5. Ref ID 9027. [pmid: 18677020].
29 Jarvis WR, Muto C. Universal screening for methicillin-resistant Staphylococcus aureus by hospitals. JAMA. 2008;300(5):504. author reply 504–6. Ref ID 9030. [pmid: 18677021].
30 Kypraios T, O’Neill PD, Huang SS, Rifas-Shiman SL, Cooper BS. Assessing the role of undetected colonization and isolation precautions in reducing methicillin-resistant Staphylococcus aureus transmission in intensive care units. BMC Infect Dis. 2010;10:29. Ref ID 9039. [pmid: 20158891].
31 Lee BY, Wiringa AE, Bailey RR, Goyal V, Lewis GJ, Tsui BY, Smith KJ, Muder RR. Screening cardiac surgery patients for MRSA: an economic computer model. Am J Manag Care. 2010;16(7):e163-73. Ref ID 9040. [pmid: 20645662].
32 McGinigle KL, Gourlay ML, Buchanan IB. The use of active surveillance cultures in adult intensive care units to reduce methicillin-resistant Staphylococcus aureus-related morbidity, mortality, and costs: a systematic review. Clin Infect Dis. 2008;46(11):1717-25. Ref ID 9043. [pmid: 18494098].
33 Melzer M, Bain L, Drabu YJ. Rapid screening for MRSA: Preventing infections from cannulas reduces MRSA. BMJ. 2008;336(7653):1085-6. Ref ID 9044. [pmid: 18483019].
34 Morgan DJ, Diekema DJ, Sepkowitz K, Perencevich EN. Adverse outcomes associated with Contact Precautions: a review of the literature. Am J Infect Control. 2009;37(2):85-93. Ref ID 9046. [pmid: 19249637].
35 Nelson RB. Benefits and drawbacks of universal surveillance of methicillin-resistant Staphylococcus aureus. Ann Intern Med. 2008;149(1):67-8. author reply 68–9. Ref ID 9050. [pmid: 18591645].
36 Salgado CD, Vos MC, Farr BM. Universal screening for methicillin-resistant Staphylococcus aureus by hospitals. JAMA. 2008;300(5):503-4. author reply 504–5. Ref ID 9061. [pmid: 18677019].
37 Tacconelli E. Screening and isolation for infection control. J Hosp Infect. 2009;73(4):371-7. Ref ID 9066. [pmid: 19699554].
38 Tacconelli E, De Angelis G, de Waure C, Cataldo MA, La Torre G, Cauda R. Rapid screening tests for meticillin-resistant Staphylococcus aureus at hospital admission: systematic review and meta-analysis. Lancet Infect Dis. 2009;9(9):546-54. Ref ID 9067. [pmid: 19695491].
39 Wagenvoort JH, De Brauwer EI, Gronenschild JM, Toenbreker HJ, Schopen AM. Active surveillance cultures for methicillin-resistant Staphylococcus aureus in an intensive care unit. Clin Infect Dis. 2008;47(9):1237-8. Ref ID 9074. [pmid: 18831703].
40 Wenzel RP, Bearman G, Edmond MB. Screening for MRSA: a flawed hospital infection control intervention. Infect Control Hosp Epidemiol. 2008;29(11):1012-8. Ref ID 9078. [pmid: 18937571].
41 Wilcox MH. Screening for MRSA. BMJ. 2008;336(7650):899-900. Ref ID 9079. [pmid: 18417520].
42 MRSA infections decline, but new bacterial strains threaten. You can take action to protect yourself against drug-resistant bacteria. Duke Med Health News. 2010;16(11):7. Ref ID 12000.
43 MRSA program reaps rewards at VA. Hosp Peer Rev. 2011;36(6):63-6. Ref ID 12001. [pmid: 21678879].
44 What is the best weapon against MRSA? You might be surprised. ED Manag. 2011;23(3):25-7. Ref ID 12002. [pmid: 21449509].
45 Almyroudis NG, Segal BH. Transmission of resistant bacteria in intensive care. N Engl J Med. 2011;365(8):762-3. author reply 764–5. Ref ID 12014. [pmid: 21864175].
46 Bhatia R, Narain JP. The growing challenge of antimicrobial resistance in the South-East Asia Region - are we losing the battle?. Indian Journal of Medical Research. 2010;132(11):482-486. Ref ID 12043. [pmid: 21149995].
47 Butterly, Schmidt U, Wiener-Kronish J. Methicillin-resistant Staphylococcus aureus colonization, its relationship to nosocomial infection, and efficacy of control methods. Anesthesiology. 2010;113(6):1453-9. Ref ID 12070. [pmid: 21068653].
48 Corey GR, Stryjewski ME. New rules for clinical trials of patients with acute bacterial skin and skin-structure infections: do not let the perfect be the enemy of the good. Clin Infect Dis. Suppl 7. 2011;52:S469-76. Ref ID 12102. [pmid: 21546623].
49 Dancer SJ, Carling PC. All that glistens may be neither gold nor clean. J Hosp Infect. 2010;76(2):177-8. Ref ID 12112. [pmid: 20691502].
50 Desikan P. Research snippets from the medical world. Indian Journal of Medical Microbiology. 2011;29(1):80-81. Ref ID 12124.
51 Dolgin E. Sequencing of superbugs seen as key to combating their spread. Nature Medicine. 2010;16(10):1054. Ref ID 12130.
52 Dzubow L. Apples, oranges, and methicillin-resistant Staphylococcus aureus. Dermatol Surg. 2010;36(10):1541-3. Ref ID 12134. [pmid: 20698868].
53 Fares WH, Weber DJ. Transmission of resistant bacteria in intensive care. N Engl J Med. 2011;365(8):763-4. author reply 765. Ref ID 12147. [pmid: 21864172].
54 Farr BM, Jarvis WR. Transmission of resistant bacteria in intensive care. N Engl J Med. 2011;365(8):762. author reply 764–5. Ref ID 12148. [pmid: 21864176].
55 Foster TJ. Staphylococci and staphylococcal infections. Expert Review of Anti-Infective Therapy. 2010;8(12):1337-1338. Ref ID 12158. [pmid: 21133658].
56 Gardy JL, Brunham RC. Editorial: Navigating transmission networks with genomics and phylogenetic trees. Future Virology. 2010;5(3):251-253. Ref ID 12176.
57 Gould D. MRSA: implications for hospitals and nursing homes. Nurs Stand. 2011;25(18):47-56. quiz 58. Ref ID 12195.
58 Gupta K, Strymish JM, Lawler E. Transmission of resistant bacteria in intensive care. N Engl J Med. 2011;365(8):763. author reply 765. Ref ID 12206. [pmid: 21864173].
59 Harbarth S, Hawkey PM, Tenover F, Stefani S, Pantosti A, Struelens MJ. Update on screening and clinical diagnosis of meticillin-resistant Staphylococcus aureus (MRSA). Int J Antimicrob Agents. 2011;37(2):110-7. Ref ID 12215. [pmid: 21163628].
60 Karimi K, Adamson PA. Methicillin-resistant Staphylococcus aureus in the ambulatory setting. Plast Surg Nurs. 2011;31(1):32-5. Ref ID 12264. [pmid: 21368646].
61 Kekre N. Editorial: Microbes strike back: End of golden era of antibiotics. Indian Journal of Urology. 2010;26(3):325. Ref ID 12271. [pmid: 21116347].
62 Kollef MH, Barie PS. Methicillin-resistant Staphylococcus aureus (MRSA) nasal colonization predicts intensive care unit-acquired MRSA infections: True or false?. Surgical Infections. 2010;11(6):497-499. Ref ID 12284. [pmid: 20969467].
63 Lee BY, Wiringa AE, Bailey RR, Goyal V, Tsui B, Lewis GJ, Muder RR, Harrison LH. The economic effect of screening orthopedic surgery patients preoperatively for methicillin-resistant Staphylococcus aureus. Infect Control Hosp Epidemiol. 2010;31(11):1130-8. Ref ID 12301. [pmid: 20923285].
64 Lingaratnam S, Thursky KA, Slavin MA. Fluoroquinolone prophylaxis: A word of caution. Leukemia and Lymphoma. 2011;52(1):5-6. Ref ID 12315. [pmid: 21067448].
65 Liu C. The bundled approach to MRSA surgical site infection prevention: is the whole greater than the sum of its parts?. comment on “Sustained reduction in methicillin-resistant Staphylococcus aureus wound infections after cardiothoracic surgery”. Arch Intern Med. 2011;171(1):73-4. Ref ID 12318. [pmid: 21220664].
66 Luciano S, Van Saene HKF. Hospital-acquired infections due to gram-negative bacteria [5]. New England Journal of Medicine. 2010;363(15):1482. Ref ID 12330.
67 Luteijn JM, Hubben GA, Pechlivanoglou P, Bonten MJ, Postma MJ. Diagnostic accuracy of culture-based and PCR-based detection tests for methicillin-resistant Staphylococcus aureus: a meta-analysis. Clin Microbiol Infect. 2011;17(2):146-54. Ref ID 12331. [pmid: 20219085].
68 May D. It’s time to come clean. Innovation is key in healthcare, but one stubborn problem doesn’t need much. Mod Healthc. 2011;41(5):25. Ref ID 12348.
69 McNicoll L, Marsella M. The growing problem of methicillin-resistant Staphylococcus aureus: will hospitals prevail?. Med Health R I. 2010;93(9):267-70. Ref ID 12354. [pmid: 20957909].
70 Monnet DL, Suetens C, Earnshaw S, Gagliotti C, Griskeviciene J, Heuer OE, Khazeeva E, Kleinkauf N, Liljestedt E, Magiorakos AP, Santos F, Struelens MJ, Weber JT, Weist K. Antimicrobial resistance 2010: Global attention on carbapenemase-producing bacteria. Eurosurveillance. 2010;15(46). #Pages#. Ref ID 12376.
71 Moucha CS, Clyburn T, Evans RP, Prokuski L. Modifiable risk factors for surgical site infection. J Bone Joint Surg Am. 2011;93(4):398-404. Ref ID 12382. [pmid: 21325594].
72 O’Grady NP, Alexander M, Burns LA, Dellinger EP, Garland J, Heard SO, Lipsett PA, Masur H, Mermel LA, Pearson ML, Raad II, Randolph AG, Rupp ME, Saint S. Guidelines for the prevention of intravascular catheter-related infections. American Journal of Infection Control. 2011;39(4 SUPPL):S1-S34. Ref ID 12403. [pmid: 21511081].
73 Peleg Y, Hooper DC. The authors reply. New England Journal of Medicine. 2010;363(15):1483-1484. Ref ID 12430. [pmid: 20931682].
74 Perry. Despite progress, we still need to be vigilant about MRSA. Nurs Times. 2011;107(23):11. Ref ID 12434. [pmid: 21834296].
75 Peterson LR, Karchmer T, Tenover FC. Transmission of resistant bacteria in intensive care. N Engl J Med. 2011;365(8):761-2. author reply 764–5. Ref ID 12436. [pmid: 21864177].
76 Platt R. Time for a culture change?. N Engl J Med. 2011;364(15):1464-5. Ref ID 12441. [pmid: 21488769].
77 Porter LF, Khan RU, Kelly SP. Unintended consequences and MRSA screening policy. J Hosp Infect. 2010;76(3):275. Ref ID 12448. [pmid: 20692068].
78 Raviglione MC, Lange C, Migliori GB. Preventing and managing antimicrobial resistance: Imperative for chest physicians. European Respiratory Journal. 2011;37(5):978-981. Ref ID 12457. [pmid: 21532012].
79 Silvestri L, van Saene HK, Parodi PC. Decolonization strategies to control Staphylococcus aureus infections in breast implant surgery. Plast Reconstr Surg. 2011;128(1):328-9. Ref ID 12514. [pmid: 21701360].
80 Sydnor ERM, Perl TM. Hospital epidemiology and infection control in acute-care settings. Clinical Microbiology Reviews. 2011;24(1):141-173. Ref ID 12536. [pmid: 21233510].
81 Talan DA, Partida CN. Emergency department ultrasound infection control: do unto (and into) others. Ann Emerg Med. 2011;58(1):64-6. Ref ID 12544. [pmid: 21492960].
82 Teplick R. Caveats for comparing catheter-associated bloodstream infection rates. Critical Care Medicine. 2011;39(2):392-394. Ref ID 12554. [pmid: 21248515].
83 Tice D, Rehm SJ. Meeting the challenges of methicillin-resistant Staphylococcus aureus with outpatient parenteral antimicrobial therapy. Clin Infect Dis. Suppl 2. 2010;51:S171-5. Ref ID 12560. [pmid: 20731574].
84 Warye K. VBP will reward HAI reduction. MLO Med Lab Obs. 2011;43(4):58. Ref ID 12598. [pmid: 21520732].
85 Widmer F. Transmission of resistant bacteria in intensive care. N Engl J Med. 2011;365(8):763. author reply 764–5. Ref ID 12606. [pmid: 21864174].
86 Wilson J, Conly J, Wong T, Jayaraman G, Sargeant J, Papadopoulos A, Young V, Quist-Moyer M, Bauer S. Strategies to control community-associated antimicrobial resistance among enteric bacteria and methicillin-resistant Staphylococcus aureus in Canada - Executive summary. Canadian Journal of Infectious Diseases and Medical Microbiology. 2010;21(3):133-134. Ref ID 12609. [pmid: 21886651].
87 Wunderink RG. Ventilator-associated tracheobronchitis: Public-reporting scam or important clinical infection?. Chest. 2011;139(3):485-488. Ref ID 12614. [pmid: 21362648].
88 Zastrow RL. Emerging infections: the contact precautions controversy. Am J Nurs. 2011;111(3):47-53. Ref ID 12620. [pmid: 21346468].
89 Aldeyab MA, Kearney MP, Scott MG, McElnay JC. Practical steps to deal with methicillin-resistant Staphylococcus aureus in hospitals. J Hosp Infect. 2010;75(2):145-6. Ref ID 12628. [pmid: 20399534].
90 Matthews D. Road to denial: patient safety and quality healthcare. MLO Med Lab Obs. 2009;41(6):48. Ref ID 12671. [pmid: 19626946].
91 Pope DM, Morrison GA, Hansen TS. MRSA reduction: myths and facts. Nurs Manage. 2009;40(5):24-8. quiz 28–9. Ref ID 12676. [pmid: 19412078].
92 Chavez TT, Decker CF. Health care-associated. MRSA versus community-associated MRSA. Dis Mon. 2008;54(12):763-8. Ref ID 12692. [pmid: 18996277].
93 Curtis L. Environmental control of methicillin-resistant Staphylococcus aureus and other hospital acquired infections. J Burn Care Res. 2008;29(6):1015. Ref ID 12696. [pmid: 18849837].
94 Taubes G. The bacteria fight back. Science. 2008;321(5887):356-61. Ref ID 12703. [pmid: 18635788].
95 ABC’s of HCA’s MRSA control program. OR Manager. 2008;24(2):8-9. Ref ID 12717.
96 Dramatic results achieved with MRSA initiative. Healthcare Benchmarks Qual Improv. 2007;14(12):136-8. Ref ID 12724. [pmid: 18019788].
97 Cimolai N. MRSA control and the counter-culture. J Hosp Infect. 2007;66(2):189-90. Ref ID 12742. [pmid: 17512632].
98 Dancer SJ, Simmons NA. MRSA behind bars?. J Hosp Infect. 2006;62(3):261-3. Ref ID 12790. [pmid: 16387388].
99 Nolan JL. A flexible approach to methicillin-resistant Staphylococcus aureus (MRSA). Nurs Times. 2001;97(46):57-8. Ref ID 12870. [pmid: 11966057].
100 Barrett S. Control of MRSA: too much or too little?. Hosp Med. 1998;59(12):916-7. Ref ID 12890. [pmid: 10696350].
101 Mylotte JM. Control of methicillin-resistant Staphylococcus aureus: the ambivalence persists. Infect Control Hosp Epidemiol. 1994;15(2):73-7. Ref ID 12929. [pmid: 8201237].
102 Perez MK, Kleman BT, Nield LS. Case 3 Presentation. Pediatr. Rev. 108. +. 111. 2009;30(3):107-113. Ref ID 12983. [pmid: 19255124].
103 Cunha BA. A useful clinical approach to community-acquired methicillin-resistant Staphylococcus aureus (CA-MRSA) infections. J Hosp Infect. 2008;68(3):271-273. Ref ID 13004. [pmid: 18289722].
104 Platt R, Takvorian SU, Septimus E, Hickok J, Moody J, Perlin J, Jernigan JA, Kleinman K, Huang SS. Cluster randomized trials in comparative effectiveness research: randomizing hospitals to test methods for prevention of healthcare-associated infections. Med Care. 2010;48(6 Suppl):S52-7. Ref ID 13133. [pmid: 20473200].
105 Lomas C. Are you ready for MRSA screening?. Nurs Times. 2009;105(4):8-10. Ref ID 13208.

## Excluded: Animal Study

1 Pittet D, Safran E, Harbarth S, Borst F, Copin P, Rohner P, Scherrer JR, Auckenthaler R. Automatic alerts for methicillin-resistant Staphylococcus aureus surveillance and control: role of a hospital information system. Infect Control Hosp Epidemiol. 1996;17(8):496-502. Ref ID 748. [pmid: 8875292].

## Excluded: NRS

1 Lee ES, Song JS, Hwang SJ, Suh HK, Cheong HJ. Possibility of reciprocal infection of methicillin-resistant Staphylococcus aureus between medical personnel and patients undergoing middle ear surgery. ORL J Otorhinolaryngol Relat Spec. 2001;63(2):87-91. Ref ID 577. [pmid: 11244367].
2 Pedler SJ, Baylis PH. Screening medical students for MRSA. J Hosp Infect. 1998;39(2):159-60. Ref ID 695. [pmid: 9651861].
3 Suh HK, Jeon YH, Song JS, Hwang SJ, Cheong HJ. A molecular epidemiologic study of methicillin-resistant Staphylococcus aureus infection in patients undergoing middle ear surgery. Eur Arch Otorhinolaryngol. 1998;255(7):347-51. Ref ID 704. [pmid: 9783130].
4 Chait J. How much do you know about MRSA?. Diabetes Self Manag. 2010;27(6):67-68. Ref ID 12079. [pmid: 21291153].
5 Ma XX, Sun DD, Wang S, Wang ML, Li M, Shang H, Wang EH, Luo EJ. Nasal carriage of methicillin-resistant Staphylococcus aureus among preclinical medical students: epidemiologic and molecular characteristics of methicillin-resistant S. aureus clones. Diagn Microbiol Infect Dis. 2011;70(1):22-30. Ref ID 12332. [pmid: 21513841].

## Excluded: Not Relevant Study Design

1 Amazian K, Fendri C, Missoum MF, Bouzouaia N, Rahal K, Savey A, Saadatian-Elahi M, Fabry J. Multicenter pilot survey of resistant bacteria in the Mediterranean area. Eur J Clin Microbiol Infect Dis. 2006;25(5):340-3. Ref ID 156. [pmid: 16601956].
2 Singh N, Squier C, Wannstedt C, Keyes L, Wagener MM, Cacciarelli TV. Impact of an aggressive infection control strategy on endemic Staphylococcus aureus infection in liver transplant recipients. Infect Control Hosp Epidemiol. 2006;27(2):122-6. Ref ID 194. [pmid: 16465627].
3 Tokars JI, Miller ER, Alter MJ, Arduino MJ. National surveillance of dialysis-associated diseases in the United States, 1997. Semin Dial. 2000;13(2):75-85. Ref ID 628. [pmid: 10795109].
4 Ng SP, Gomez JM, Lim SH, Ho NK. Reduction of nosocomial infection in a neonatal intensive care unit (NICU). Singapore Med J. 1998;39(7):319-23. Ref ID 692. [pmid: 9885694].
5 Maragakis LL, Tucker MG, Miller RG, Carroll KC, Perl TM. Incidence and prevalence of multidrug-resistant acinetobacter using targeted active surveillance cultures. J Am Med Assoc. 2008;299(21):2513-2514. Ref ID 1019.
6 Tramper-Stranders GA, van der Ent CK, Gerritsen SAM, Fleer A, Kimpen JLL, Wolfs TFW. Macrolide-resistant Staphylococcus aureus colonization in cystic fibrosis patients: Is there transmission to household contacts?. J Antimicrob Chemother. 2007;60(3):665-668. Ref ID 1046. [pmid: 17604321].
7 Behera B, Mathur P. High levels of antimicrobial resistance at a tertiary trauma care centre of India. Indian Journal of Medical Research. 2011;133(3):343-345. Ref ID 12036. [pmid: 21441693].
8 Bonilla MF, Avery RK, Rehm SJ, Neuner EA, Isada CM, van Duin D. Extreme alkaline phosphatase elevation associated with tigecycline. Journal of Antimicrobial Chemotherapy. 2011;66(4):952-953. Ref ID 12053. [pmid: 21393193].
9 DeRuiter J, Holston PL. 2010;35:HS2-HS18. Ref ID 12122.
10 Shukla D, Kovoor J, Devi BI. Haustra cerebri. Pediatric Neurosurgery. 2010;46(3):247-248. Ref ID 12512. [pmid: 21051927].
11 Wick JY, Zanni GR. Health buzzwords: Speaking a new language. Consultant Pharmacist. 2011;26(7):498-504. Ref ID 12605. [pmid: 21729851].
12 Harrington G, Watson K, Bailey M, Land G, Borrell S, Houston L, Kehoe R, Bass P, Cockroft E, Marshall C, Mijch A, Spelman D. Reduction in hospitalwide incidence of infection or colonization with methicillin-resistant Staphylococcus aureus with use of antimicrobial hand-hygiene gel and statistical process control charts. Infect Control Hosp Epidemiol. 2007;28(7):837-44. Ref ID 19. [pmid: 17564987].
13 Furuno JP, Harris AD, Wright MO, Hartley DM, McGregor JC, Gaff HD, Hebden JN, Standiford HC, Perencevich EN. Value of performing active surveillance cultures on intensive care unit discharge for detection of methicillin-resistant Staphylococcus aureus. Infect Control Hosp Epidemiol. 2007;28(6):666-70. Ref ID 29. [pmid: 17520538].
14 Shaw BE, Boswell T, Byrne JL, Yates C, Russell NH. Clinical impact of MRSA in a stem cell transplant unit: analysis before, during and after an MRSA outbreak. Bone Marrow Transplant. 2007;39(10):623-9. Ref ID 38. [pmid: 17384657].
15 Warren DK, Guth RM, Coopersmith CM, Merz LR, Zack JE, Fraser VJ. Impact of a methicillin-resistant Staphylococcus aureus active surveillance program on contact precaution utilization in a surgical intensive care unit. Crit Care Med. 2007;35(2):430-4. Ref ID 65. [pmid: 17205021].
16 Robotham JV, Jenkins DR, Medley GF. Screening strategies in surveillance and control of methicillin-resistant Staphylococcus aureus (MRSA). Epidemiol Infect. 2007;135(2):328-42. Ref ID 67. [pmid: 16836799].
17 Huang SS, Rifas-Shiman SL, Warren DK, Fraser VJ, Climo MW, Wong ES, Cosgrove SE, Perl TM, Pottinger JM, Herwaldt LA, Jernigan JA, Tokars JL, Diekema DJ, Hinrichsen VL, Yokoe DS, Platt R. Improving methicillin-resistant Staphylococcus aureus surveillance and reporting in intensive care units. J Infect Dis. 2007;195(3):330-8. Ref ID 69. [pmid: 17205470].
18 Lam ET, Fung KS. Comparative evaluation of culture-based methods for screening of methicillin-resistant Staphylococcus aureus (MRSA) from nasal swabs of hospitalised patients. Pathology. 2006;38(6):577-9. Ref ID 95. [pmid: 17393990].
19 Morange-Saussier V, Giraudeau B, van der Mee N, Lermusiaux P, Quentin R. Nasal carriage of methicillin-resistant staphylococcus aureus in vascular surgery. Ann Vasc Surg. 2006;20(6):767-72. Ref ID 99. [pmid: 17086484].
20 Davidson MM, Evans R, Hay AJ. Same-day detection of meticillin-resistant Staphylococcus aureus from screening swabs by real-time polymerase chain reaction. J Hosp Infect. 2006;63(4):484-5. Ref ID 138. [pmid: 16759746].
21 Eveillard M, Leroy C, Teissiere F, Lancien E, Branger C, de Lassence A, Joly-Guillou ML, Brun P. Impact of selective screening in the emergency department on meticillin-resistant Staphylococcus aureus control programmes. J Hosp Infect. 2006;63(4):380-4. Ref ID 139. [pmid: 16759741].
22 Jensen JU, Jensen ET, Larsen AR, Meyer M, Junker L, Ronne T, Skov R, Jepsen OB, Andersen LP. Control of a methicillin-resistant Staphylococcus aureus (MRSA) outbreak in a day-care institution. J Hosp Infect. 2006;63(1):84-92. Ref ID 159. [pmid: 16542758].
23 Sax H, Posfay-Barbe K, Harbarth S, Francois P, Touveneau S, Pessoa-Silva CL, Schrenzel J, Dharan S, Gervaix A, Pittet D. Control of a cluster of community-associated, methicillin-resistant Staphylococcus aureus in neonatology. J Hosp Infect. 2006;63(1):93-100. Ref ID 160. [pmid: 16542756].
24 Bootsma MC, Diekmann O, Bonten MJ. Controlling methicillin-resistant Staphylococcus aureus: quantifying the effects of interventions and rapid diagnostic testing. Proc Natl Acad Sci U S A. 2006;103(14):5620-5. Ref ID 164. [pmid: 16565219].
25 Ridenour GA, Wong ES, Call MA, Climo MW. Duration of colonization with methicillin-resistant Staphylococcus aureus among patients in the intensive care unit: implications for intervention. Infect Control Hosp Epidemiol. 2006;27(3):271-8. Ref ID 180. [pmid: 16532415].
26 Kaye KS, Engemann JJ, Fulmer EM, Clark CC, Noga EM, Sexton DJ. Favorable impact of an infection control network on nosocomial infection rates in community hospitals. Infect Control Hosp Epidemiol. 2006;27(3):228-32. Ref ID 182. [pmid: 16532408].
27 Fawley WN, Parnell P, Hall J, Wilcox MH. Surveillance for mupirocin resistance following introduction of routine peri-operative prophylaxis with nasal mupirocin. J Hosp Infect. 2006;62(3):327-32. Ref ID 184. [pmid: 16377029].
28 Harbarth S, Masuet-Aumatell C, Schrenzel J, Francois P, Akakpo C, Renzi G, Pugin J, Ricou B, Pittet D. Evaluation of rapid screening and pre-emptive contact isolation for detecting and controlling methicillin-resistant Staphylococcus aureus in critical care: an interventional cohort study. Crit Care. 2006;10(1):R25. Ref ID 189. [pmid: 16469125].
29 Sandri M, Dalarosa MG, Ruschel de Alcantara L, da Silva Elias L, Zavascki AP. Reduction in incidence of nosocomial methicillin-resistant Staphylococcus aureus (MRSA) infection in an intensive care unit: role of treatment with mupirocin ointment and chlorhexidine baths for nasal carriers of MRSA. Infect Control Hosp Epidemiol. 2006;27(2):185-7. Ref ID 190. [pmid: 16465636].
30 Meyer E, Schwab F, Gastmeier P, Jonas D, Rueden H, Daschner FD. Methicillin-resistant Staphylococcus aureus in German intensive care units during 2000–2003 data from Project SARI. (Surveillance of Antimicrobial Use and Antimicrobial Resistance in Intensive Care Units). Infect Control Hosp Epidemiol. 2006;27(2):146-54. Ref ID 192. [pmid: 16465631].
31 Thorburn K, Taylor N, Saladi SM, van Saene HK. Use of surveillance cultures and enteral vancomycin to control methicillin-resistant Staphylococcus aureus in a paediatric intensive care unit. Clin Microbiol Infect. 2006;12(1):35-42. Ref ID 197. [pmid: 16460544].
32 Eveillard M, Lancien E, de Lassence A, Branger C, Barnaud G, Benlolo JA, Joly-Guillou ML. Impact of the reinforcement of a methicillin-resistant Staphylococcus aureus control programme: a 3-year evaluation by several indicators in a French university hospital. Eur J Epidemiol. 2006;21(7):551-8. Ref ID 202. [pmid: 16915525].
33 Boyce JM, Havill NL, Maria B. Frequency and possible infection control implications of gastrointestinal colonization with methicillin-resistant Staphylococcus aureus. J Clin Microbiol. 2005;43(12):5992-5. Ref ID 216. [pmid: 16333087].
34 Finkelstein R, Rabino G, Mashiah T, Bar-El Y, Adler Z, Kertzman V, Cohen O, Milo S. Surgical site infection rates following cardiac surgery: the impact of a 6-year infection control program. Am J Infect Control. 2005;33(8):450-4. Ref ID 227. [pmid: 16216658].
35 Dailey L, Coombs GW, O’Brien FG, Pearman JW, Christiansen K, Grubb WB, Riley TV. Methicillin-resistant Staphylococcus aureus, Western Australia. Emerg Infect Dis. 2005;11(10):1584-90. Ref ID 232. [pmid: 16318700].
36 Lucet JC, Paoletti X, Lolom I, Paugam-Burtz C, Trouillet JL, Timsit JF, Deblangy C, Andremont A, Regnier B. Successful long-term program for controlling methicillin-resistant Staphylococcus aureus in intensive care units. Intensive Care Med. 2005;31(8):1051-7. Ref ID 243. [pmid: 15991010].
37 Panhotra BR, Saxena AK, Al Mulhim AS. Prevalence of methicillin-resistant and methicillin-sensitive Staphylococcus aureus nasal colonization among patients at the time of admission to the hospital. Ann Saudi Med. 2005;25(4):304-8. Ref ID 247. [pmid: 16212123].
38 Kobayashi H. National hospital infection surveillance on methicillin-resistant Staphylococcus aureus. J Hosp Infect. 2005;60(2):172-5. Ref ID 269. [pmid: 15866017].
39 Roberts SA, Morris AJ, McGuiness CA, Birse L, Jowitt DM. Reducing the time interval for screening for methicillin-resistant Staphylococcus aureus. J Hosp Infect. 2005;60(1):86-7. Ref ID 274. [pmid: 15823665].
40 Aragon D, Sole ML, Brown S. Outcomes of an infection prevention project focusing on hand hygiene and isolation practices. AACN Clin Issues. 2005;16(2):121-32. Ref ID 278. [pmid: 15876879].
41 Taiwo SS, Bamidele M, Omonigbehin EA, Akinsinde KA, Smith SI, Onile BA, Olowe AO. Molecular epidemiology of methicillin-resistant Staphylococcus aureus in Ilorin, Nigeria. West Afr J Med. 2005;24(2):100-6. Ref ID 286. [pmid: 16092307].
42 Orsi GB, Raponi M, Franchi C, Rocco M, Mancini C, Venditti M. Surveillance and infection control in an intensive care unit. Infect Control Hosp Epidemiol. 2005;26(3):321-5. Ref ID 290. [pmid: 15796288].
43 Eveillard M, Lancien E, Barnaud G, Hidri N, Gaba S, Benlolo JA, Joly-Guillou ML. Impact of screening for MRSA carriers at hospital admission on risk-adjusted indicators according to the imported MRSA colonization pressure. J Hosp Infect. 2005;59(3):254-8. Ref ID 291. [pmid: 15694984].
44 Nijssen S, Bonten MJ, Weinstein RA. Are active microbiological surveillance and subsequent isolation needed to prevent the spread of methicillin-resistant Staphylococcus aureus?. Clin Infect Dis. 2005;40(3):405-9. Ref ID 298. [pmid: 15668864].
45 Kobayashi Y, Kizaki M, Kawakami Y, Uchida H, Ikeda Y. Assessment of oxacillin salt agar for detection of MRSA identified by presence of the mecA gene. J Hosp Infect. 1993;23(4):279-85. Ref ID 822. [pmid: 8099927].
46 Sarda V, Molloy A, Kadkol S, Janda WM, Hershow R, McGuinn M. Active surveillance for methicillin-resistant staphylococcus aureus in the neonatal intensive care unit. Infect Control Hosp Epidemiol. 2009;30(9):854-860. Ref ID 953. [pmid: 19637960].
47 Aldeyab MA, Kearney MP, Hughes CM, Scott MG, Tunney MM, Gilpin DF, Devine MJ, Watson JD, Gardiner A, Funston C, Savage K, McElnay JC. Can the use of a rapid polymerase chain screening method decrease the incidence of nosocomial meticillin-resistant Staphylococcus aureus?. J Hosp Infect. 2009;71(1):22-8. Ref ID 9001. [pmid: 19036472].
48 Aldeyab MA, Monnet DL, Lopez-Lozano JM, Hughes CM, Scott MG, Kearney MP, Magee FA, McElnay JC. Modelling the impact of antibiotic use and infection control practices on the incidence of hospital-acquired methicillin-resistant Staphylococcus aureus: a time-series analysis. J Antimicrob Chemother. 2008;62(3):593-600. Ref ID 9002. [pmid: 18467307].
49 Conterno LO, Shymanski J, Ramotar K, Toye B, van Walraven C, Coyle D, Roth VR. Real-time polymerase chain reaction detection of methicillin-resistant Staphylococcus aureus: impact on nosocomial transmission and costs. Infect Control Hosp Epidemiol. 2007;28(10):1134-41. Ref ID 9011. [pmid: 17828689].
50 Creamer E, Dolan A, Sherlock O, Thomas T, Walsh J, Moore J, Smyth E, O’Neill E, Shore A, Sullivan D, Rossney AS, Cunney R, Coleman D, Humphreys H. The effect of rapid screening for methicillin-resistant Staphylococcus aureus (MRSA) on the identification and earlier isolation of MRSA-positive patients. Infect Control Hosp Epidemiol. 2010;31(4):374-81. Ref ID 9013. [pmid: 20184438].
51 Flore K, Van den Abeele AM, Verschraegen G. Speed of molecular detection techniques for methicillin-resistant Staphylococcus aureus admission screening in an acute care hospital. J Hosp Infect. 2010;75(2):103-6. Ref ID 9017. [pmid: 20381915].
52 Hardy K, Price C, Szczepura A, Gossain S, Davies R, Stallard N, Shabir S, McMurray C, Bradbury A, Hawkey PM. Reduction in the rate of methicillin-resistant Staphylococcus aureus acquisition in surgical wards by rapid screening for colonization: a prospective, cross-over study. Clin Microbiol Infect. 2010;16(4):333-9. Ref ID 9024. [pmid: 19622077].
53 Hardy KJ, Szczepura A, Davies R, Bradbury A, Stallard N, Gossain S, Walley P, Hawkey PM. A study of the efficacy and cost-effectiveness of MRSA screening and monitoring on surgical wards using a new, rapid molecular test (EMMS). BMC Health Serv Res. 2007;7:160. Ref ID 9025. [pmid: 17915008].
54 Jeyaratnam D, Whitty CJ, Phillips K, Liu D, Orezzi C, Ajoku U, French GL. Impact of rapid screening tests on acquisition of meticillin resistant Staphylococcus aureus: cluster randomised crossover trial. BMJ. 2008;336(7650):927-30. Ref ID 9031. [pmid: 18417521].
55 Uckay, Sax H, Iten A, Camus V, Renzi G, Schrenzel J, Perrier A, Pittet D. Effect of screening for methicillin-resistant Staphylococcus aureus carriage by polymerase chain reaction on the duration of unnecessary preemptive contact isolation. Infect Control Hosp Epidemiol. 2008;29(11):1077-9. Ref ID 9070. [pmid: 18844467].
56 Viviani M, Van Saene HK, Pisa F, Lucangelo U, Silvestri L, Momesso E, Berlot G. The role of admission surveillance cultures in patients requiring prolonged mechanical ventilation in the intensive care unit. Anaesth Intensive Care. 2010;38(2):325-35. Ref ID 9072. [pmid: 20369767].
57 Wassenberg MW, Kluytmans JA, Box AT, Bosboom RW, Buiting AG, van Elzakker EP, Melchers WJ, van Rijen MM, Thijsen SF, Troelstra A, Vandenbroucke-Grauls CM, Visser CE, Voss A, Wolffs PF, Wulf MW, van Zwet AA, de Wit GA, Bonten MJ. Rapid screening of methicillin-resistant Staphylococcus aureus using PCR and chromogenic agar: a prospective study to evaluate costs and effects. Clin Microbiol Infect. 2010. #volume#(), #Pages#. Ref ID 9076.
58 Byrnes MC, Adegboyega T, Riggle A, Chipman J, Beilman G, Reicks P, Boeser K, Irwin E. Nasal swabs collected routinely to screen for colonization by methicillin-resistant Staphylococcus aureus in intensive care units are a sensitive screening test for the organism in clinical cultures. Surg Infect (Larchmt). 2010;11(6):511-5. Ref ID 12071. [pmid: 20969468].
59 Diederen BM. Comparison of the Cepheid Xpert MRSA assay with culture in a low prevalence setting in The Netherlands. J Infect. 2010;61(6):509-10. Ref ID 12127. [pmid: 20933001].
60 Francis ST, Rawal S, Roberts H, Riley P, Planche T, Kennea NL. Detection of meticillin-resistant staphylococcus aureus (MRSA) colonization in newborn infants using real-time polymerase chain reaction (PCR). Acta Paediatr. 2010;99(11):1691-4. Ref ID 12161. [pmid: 20528798].
61 Jones G, Matthews R, Cunningham R, Jenks P. Comparison of automated processing of flocked swabs with manual processing of fiber swabs for detection of nasal carriage of Staphylococcus aureus. Journal of Clinical Microbiology. 2011;49(7):2717-2718. Ref ID 12253. [pmid: 21525218].
62 Lai CC, Wang CY, Liu WL, Hou CC, Huang YT, Hsueh PR. Time to blood culture positivity as a predictor of methicillin resistance in Staphylococcus aureus bacteremia. Journal of Infection. 2011;62(2):190-191. Ref ID 12294. [pmid: 21108966].
63 Melendez JH, Frankel YM, An AT, Williams L, Price LB, Wang NY, Lazarus GS, Zenilman JM. Real-time PCR assays compared to culture-based approaches for identification of aerobic bacteria in chronic wounds. Clin Microbiol Infect. 2010;16(12):1762-9. Ref ID 12356. [pmid: 21077984].
64 Murthy, De Angelis G, Pittet D, Schrenzel J, Uckay I, Harbarth S. Cost-effectiveness of universal MRSA screening on admission to surgery. Clin Microbiol Infect. 2010;16(12):1747-53. Ref ID 12389. [pmid: 20331684].
65 Song X, Cheung S, Klontz K, Short B, Campos J, Singh N. A stepwise approach to control an outbreak and ongoing transmission of methicillin-resistant Staphylococcus aureus in a neonatal intensive care unit. Am J Infect Control. 2010;38(8):607-11. Ref ID 12524. [pmid: 20570396].
66 Gillespie EE, ten Berk de Boer FJ, Stuart RL, Buist MD, Wilson JM. A sustained reduction in the transmission of methicillin resistant Staphylococcus aureus in an intensive care unit. Crit Care Resusc. 2007;9(2):161-5. Ref ID 27. [pmid: 17536985].
67 Gopal Rao G, Michalczyk P, Nayeem N, Walker G, Wigmore L. Prevalence and risk factors for meticillin-resistant Staphylococcus aureus in adult emergency admissions--a case for screening all patients?. J Hosp Infect. 2007;66(1):15-21. Ref ID 45. [pmid: 17376560].
68 Harbarth S, Schrenzel J, Renzi G, Akakpo C, Ricou B. Is throat screening necessary to detect methicillin-resistant Staphylococcus aureus colonization in patients upon admission to an intensive care unit?. J Clin Microbiol. 2007;45(3):1072-3. Ref ID 61. [pmid: 17229852].
69 Cunningham R, Jenks P, Northwood J, Wallis M, Ferguson S, Hunt S. Effect on MRSA transmission of rapid PCR testing of patients admitted to critical care. J Hosp Infect. 2007;65(1):24-8. Ref ID 77. [pmid: 17145100].
70 Heininger, Meyer E, Schwab F, Marschal M, Unertl K, Krueger WA. Effects of long-term routine use of selective digestive decontamination on antimicrobial resistance. Intensive Care Med. 2006;32(10):1569-76. Ref ID 121. [pmid: 16896852].
71 Curran ET, Hamilton K, Monaghan A, McGinlay M, Thakker B. Use of a temporary cohort ward as part of an intervention to reduce the incidence of meticillin-resistant Staphylococcus aureus in a vascular surgery ward. J Hosp Infect. 2006;63(4):374-9. Ref ID 136. [pmid: 16765483].
72 Meurman O, Routamaa M, Peltonen R. Screening for methicillin-resistant Staphylococcus aureus: which anatomical sites to culture?. J Hosp Infect. 2005;61(4):351-3. Ref ID 218. [pmid: 16214261].
73 Wernitz MH, Keck S, Swidsinski S, Schulz S, Veit SK. Cost analysis of a hospital-wide selective screening programme for methicillin-resistant Staphylococcus aureus (MRSA) carriers in the context of diagnosis related groups (DRG) payment. Clin Microbiol Infect. 2005;11(6):466-71. Ref ID 263. [pmid: 15882196].
74 Johnston P, Norrish AR, Brammar T, Walton N, Hegarty TA, Coleman NP. Reducing methicillin-resistant Staphylococcus aureus (MRSA) patient exposure by infection control measures. Ann R Coll Surg Engl. 2005;87(2):123-5. Ref ID 288. [pmid: 15826424].
75 Poutanen SM, Vearncombe M, McGeer AJ, Gardam M, Large G, Simor AE. Nosocomial acquisition of methicillin-resistant Staphylococcus aureus during an outbreak of severe acute respiratory syndrome. Infect Control Hosp Epidemiol. 2005;26(2):134-7. Ref ID 303. [pmid: 15756882].
76 Lucet JC, Grenet K, Armand-Lefevre L, Harnal M, Bouvet E, Regnier B, Andremont A. High prevalence of carriage of methicillin-resistant Staphylococcus aureus at hospital admission in elderly patients: implications for infection control strategies. Infect Control Hosp Epidemiol. 2005;26(2):121-6. Ref ID 305. [pmid: 15756880].
77 Cepeda JA, Whitehouse T, Cooper B, Hails J, Jones K, Kwaku F, Taylor L, Hayman S, Cookson B, Shaw S, Kibbler C, Singer M, Bellingan G, Wilson AP. Isolation of patients in single rooms or cohorts to reduce spread of MRSA in intensive-care units: prospective two-centre study. Lancet. 2005;365(9456):295-304. Ref ID 309. [pmid: 15664224].
78 Chaberny F, Ziesing S, Mattner F, Barwolff S, Brandt C, Eckmanns T, Ruden H, Sohr D, Weist K, Gastmeier P. The burden of MRSA in four German university hospitals. Int J Hyg Environ Health. 2005;208(6):447-53. Ref ID 312. [pmid: 16325553].
79 Yap FH, Gomersall CD, Fung KS, Ho PL, Ho OM, Lam PK, Lam DT, Lyon DJ, Joynt GM. Increase in methicillin-resistant Staphylococcus aureus acquisition rate and change in pathogen pattern associated with an outbreak of severe acute respiratory syndrome. Clin Infect Dis. 2004;39(4):511-6. Ref ID 344. [pmid: 15356814].
80 Vietri NJ, Dooley DP, Davis CEJ, Longfield JN, Meier PA, Whelen AC. The effect of moving to a new hospital facility on the prevalence of methicillin-resistant Staphylococcus aureus. Am J Infect Control. 2004;32(5):262-7. Ref ID 345. [pmid: 15292889].
81 Lee SC, Chen KS, Tsai CJ, Lee CC, Chang HY, See LC, Kao YC, Chen SC, Wang CH. An outbreak of methicillin-resistant Staphylococcus aureus infections related to central venous catheters for hemodialysis. Infect Control Hosp Epidemiol. 2004;25(8):678-84. Ref ID 348. [pmid: 15357161].
82 Kampf G, Kramer A. Eradication of methicillin-resistant Staphylococcus aureus with an antiseptic soap and nasal mupirocin among colonized patients--an open uncontrolled clinical trial. Ann Clin Microbiol Antimicrob. 2004;3:9. Ref ID 360. [pmid: 15175106].
83 Eckmanns T, Geffers C, Weist K, Ruden H. One hour versus 24 h sampling intervals for the screening of patients with methicillin-resistant Staphylococcus aureus (MRSA). J Hosp Infect. 2004;57(1):93-4. Ref ID 374. [pmid: 15142723].
84 Tai CC, Nirvani AA, Holmes A, Hughes SP. Methicillin-resistant Staphylococcus aureus in orthopaedic surgery. Int Orthop. 2004;28(1):32-5. Ref ID 383. [pmid: 12961035].
85 El-Zimaity D, Dawson SJ, Barrett S, Moseley E. Preoperative screening of elective orthopaedic patients for MRSA. J Hosp Infect. 2004;56(2):164-5. Ref ID 384. [pmid: 15019230].
86 Montesinos, Salido E, Delgado T, Lecuona M, Sierra A. Epidemiology of methicillin-resistant Staphylococcus aureus at a university hospital in the Canary Islands. Infect Control Hosp Epidemiol. 2003;24(9):667-72. Ref ID 418. [pmid: 14510249].
87 Fishbain JT, Lee JC, Nguyen HD, Mikita JA, Mikita CP, Uyehara CF, Hospenthal DR. Nosocomial transmission of methicillin-resistant Staphylococcus aureus: a blinded study to establish baseline acquisition rates. Infect Control Hosp Epidemiol. 2003;24(6):415-21. Ref ID 441. [pmid: 12828317].
88 Que TL, Ho PL, Yip KT, Ng HL, Leung FY, Lai KK, Yuen KY. Three-year study of targeted screening for methicillin-resistant Staphylococcus aureus at hospital admission. Eur J Clin Microbiol Infect Dis. 2003;22(4):268-70. Ref ID 451. [pmid: 12709843].
89 Lucet JC, Chevret S, Durand-Zaleski I, Chastang C, Regnier B. Prevalence and risk factors for carriage of methicillin-resistant Staphylococcus aureus at admission to the intensive care unit: results of a multicenter study. Arch Intern Med. 2003;163(2):181-8. Ref ID 462. [pmid: 12546608].
90 Cooper C, Ochota MA. Surveillance of hospital-acquired methicillin-resistant Staphylococcus aureus in South Australia. Commun Dis Intell. Suppl. 2003;27:S92-6. Ref ID 465.
91 Vriens M, Blok H, Fluit A, Troelstra A, Van Der Werken C, Verhoef J. Costs associated with a strict policy to eradicate methicillin-resistant Staphylococcus aureus in a Dutch University Medical Center: a 10-year survey. Eur J Clin Microbiol Infect Dis. 2002;21(11):782-6. Ref ID 486. [pmid: 12461587].
92 Gastmeier P, Sohr D, Geffers C, Nassauer A, Dettenkofer M, Ruden H. Occurrence of methicillin-resistant Staphylococcus aureus infections in German intensive care units. Infection. 2002;30(4):198-202. Ref ID 506. [pmid: 12236560].
93 Merlino J, Watson J, Funnell G, Gottlieb T, Bradbury R, Harbour C. New screening medium for detection and identification of methicillin/oxacillin-resistant Staphylococcus aureus for nosocomial surveillance. Eur J Clin Microbiol Infect Dis. 2002;21(5):414-6. Ref ID 517. [pmid: 12072932].
94 Jung SI, Kiem S, Lee NY, Kim YS, Oh WS, Cho HL, Peck KR, Song JH. One-point population analysis and effect of osmolarity on detection of hetero-vancomycin-resistant Staphylococcus aureus. J Clin Microbiol. 2002;40(4):1493-5. Ref ID 518. [pmid: 11923379].
95 Eveillard M, Ernst C, Cuviller S, Lescure FX, Malpaux M, Defouilloy I, Gresanleux M, Duboisset M, Lienard J, Eb F. Prevalence of methicillin-resistant Staphylococcus aureus carriage at the time of admission in two acute geriatric wards. J Hosp Infect. 2002;50(2):122-6. Ref ID 522. [pmid: 11846539].
96 Padoveze MC, Tresoldi AT, von Nowakonski A, Aoki FH, Branchini ML. Nasal MRSA colonization of AIDS Patients cared for in a Brazilian university hospital. Infect Control Hosp Epidemiol. 2001;22(12):783-5. Ref ID 532. [pmid: 11876459].
97 Tarzi S, Kennedy P, Stone S, Evans M. Methicillin-resistant Staphylococcus aureus: psychological impact of hospitalization and isolation in an older adult population. J Hosp Infect. 2001;49(4):250-4. Ref ID 533. [pmid: 11740872].
98 Lepelletier D, Richet H. Surveillance and control of methicillin-resistant Staphylococcus aureus infections in French hospitals. Infect Control Hosp Epidemiol. 2001;22(11):677-82. Ref ID 536. [pmid: 11842986].
99 Annigeri R, Conly J, Vas S, Dedier H, Prakashan KP, Bargman JM, Jassal V, Oreopoulos D. Emergence of mupirocin-resistant Staphylococcus aureus in chronic peritoneal dialysis patients using mupirocin prophylaxis to prevent exit-site infection. Perit Dial Int. 2001;21(6):554-9. Ref ID 542. [pmid: 11783763].
100 Simor E, Goodfellow J, Louie L, Louie M. Evaluation of new medium, oxacillin resistance screening agar base, for the detection of methicillin-resistant Staphylococcus aureus from clinical specimens. J Clin Microbiol. 2001;39(9):3422. Ref ID 549. [pmid: 11558472].
101 Oliveira GA, Dell’Aquila AM, Masiero RL, Levy CE, Gomes MS, Cui L, Hiramatsu K, Mamizuka EM. Isolation in Brazil of nosocomial Staphylococcus aureus with reduced susceptibility to vancomycin. Infect Control Hosp Epidemiol. 2001;22(7):443-8. Ref ID 557. [pmid: 11583214].
102 Dupeyron C, Campillo SB, Mangeney N, Richardet JP, Leluan G. Carriage of Staphylococcus aureus and of gram-negative bacilli resistant to third-generation cephalosporins in cirrhotic patients: a prospective assessment of hospital-acquired infections. Infect Control Hosp Epidemiol. 2001;22(7):427-32. Ref ID 558. [pmid: 11583211].
103 Shiomori T, Miyamoto H, Makishima K. Significance of airborne transmission of methicillin-resistant Staphylococcus aureus in an otolaryngology-head and neck surgery unit. Arch Otolaryngol Head Neck Surg. 2001;127(6):644-8. Ref ID 562. [pmid: 11405862].
104 Scanvic, Denic L, Gaillon S, Giry P, Andremont A, Lucet JC. Duration of colonization by methicillin-resistant Staphylococcus aureus after hospital discharge and risk factors for prolonged carriage. Clin Infect Dis. 2001;32(10):1393-8. Ref ID 564. [pmid: 11317238].
105 Petros J, O’Connell M, Roberts C, Wade P, van Saene HK. Systemic antibiotics fail to clear multidrug-resistant Klebsiella from a pediatric ICU. Chest. 2001;119(3):862-6. Ref ID 572. [pmid: 11243969].
106 Gardam M, Brunton J, Willey B, McGeer A, Low D, Conly J. A blinded comparison of three laboratory protocols for the identification of patients colonized with methicillin-resistant Staphylococcus aureus. Infect Control Hosp Epidemiol. 2001;22(3):152-6. Ref ID 573. [pmid: 11310693].
107 Kim T, Oh PI, Simor AE. The economic impact of methicillin-resistant Staphylococcus aureus in Canadian hospitals. Infect Control Hosp Epidemiol. 2001;22(2):99-104. Ref ID 579. [pmid: 11232886].
108 Roghmann MC, Siddiqui A, Plaisance K, Standiford H. MRSA colonization and the risk of MRSA bacteraemia in hospitalized patients with chronic ulcers. J Hosp Infect. 2001;47(2):98-103. Ref ID 581. [pmid: 11170772].
109 Grover M, Dimmer S, Rodger J. Oxoid aura system as a semi-automated, standard antimicrobial susceptibility test method. Br J Biomed Sci. 2001;58(3):146-53. Ref ID 584. [pmid: 11575736].
110 Prasad KN, Kumar R, Tiwari DP, Mishra KK, Ayyagari A. Comparison of various conventional methods with a polymerase chain reaction assay for detecting methicillin-resistant & susceptible Staphylococcus aureus strains. Indian J Med Res. 2000;112:198-202. Ref ID 590. [pmid: 11247196].
111 Fitzpatrick F, Murphy OM, Brady A, Prout S, Fenelon LE. A purpose built MRSA cohort unit. J Hosp Infect. 2000;46(4):271-9. Ref ID 592. [pmid: 11170758].
112 Rochon-Edouard S, Pestel-Caron M, Lemeland JF, Caron F. In vitro synergistic effects of double and triple combinations of beta-lactams, vancomycin, and netilmicin against methicillin-resistant Staphylococcus aureus strains. Antimicrob Agents Chemother. 2000;44(11):3055-60. Ref ID 594. [pmid: 11036022].
113 Scudeller L, Leoncini O, Boni S, Navarra A, Rezzani A, Verdirosi S, Maserati R. MRSA carriage: the relationship between community and healthcare setting. A study in an Italian hospital. J Hosp Infect. 2000;46(3):222-9. Ref ID 597. [pmid: 11073732].
114 MacKinnon MM, Allen KD. Long-term MRSA carriage in hospital patients. J Hosp Infect. 2000;46(3):216-21. Ref ID 598. [pmid: 11073731].
115 Loureiro MM, de Moraes BA, Quadra MR, Pinheiro GS, Suffys PN, Asensi MD. Molecular epidemiology of methicillin resistant Staphylococcus aureus isolated from newborns in a hospital in Rio de Janeiro, Brazil. Mem Inst Oswaldo Cruz. 2000;95(6):777-82. Ref ID 599. [pmid: 11080760].
116 Mylotte JM, Kahler L, Graham R, Young L, Goodnough S. Prospective surveillance for antibiotic-resistant organisms in patients with spinal cord injury admitted to an acute rehabilitation unit. Am J Infect Control. 2000;28(4):291-7. Ref ID 603. [pmid: 10926706].
117 Cetinkaya Y, Kocagoz S, Hayran M, Uzun O, Akova M, Gursu G, Unal S. Analysis of a mini-outbreak of methicillin-resistant Staphylococcus aureus in a surgical ward by using arbitrarily primed-polymerase chain reaction. J Chemother. 2000;12(2):138-44. Ref ID 619. [pmid: 10789553].
118 Goettsch W, Bronzwaer SL, de Neeling AJ, Wale MC, Aubry-Damon H, Olsson-Liljequist B, Sprenger MJ, Degener JE. Standardization and quality assurance for antimicrobial resistance surveillance of Streptococcus pneumoniae and Staphylococcus aureus within the European Antimicrobial Resistance Surveillance System (EARSS). Clin Microbiol Infect. 2000;6(2):59-63. Ref ID 629. [pmid: 11168073].
119 Chang SC, Hsieh SM, Chen ML, Sheng WH, Chen YC. Oral fusidic acid fails to eradicate methicillin-resistant Staphylococcus aureus colonization and results in emergence of fusidic acid-resistant strains. Diagn Microbiol Infect Dis. 2000;36(2):131-6. Ref ID 630. [pmid: 10705056].
120 Nicola F, Bantar C, Canigia LF, Relloso S, Bianchini H, Smayevsky J. Comparison of several methods to determine methicillin-resistance in Staphylococcus aureus with focus on borderline strains. Diagn Microbiol Infect Dis. 2000;36(2):91-3. Ref ID 631. [pmid: 10705049].
121 Oh J, von Baum H, Klaus G, Schaefer F. Nasal carriage of Staphylococcus aureus in families of children on peritoneal dialysis. European Pediatric Peritoneal Dialysis Study Group (EPPS). Adv Perit Dial. 2000;16:324-7. Ref ID 633. [pmid: 11045321].
122 Gales C, Jones RN, Pfaller MA, Gordon KA, Sader HS. Two-year assessment of the pathogen frequency and antimicrobial resistance patterns among organisms isolated from skin and soft tissue infections in Latin American hospitals: results from the SENTRY antimicrobial surveillance program, 1997–98. SENTRY Study Group. Int J Infect Dis. 2000;4(2):75-84. Ref ID 635. [pmid: 10737843].
123 Dancer SJ, Crawford A. Keeping MRSA out of a district general hospital. J Hosp Infect. Suppl. 1999;43:S19-27. Ref ID 644. [pmid: 10658755].
124 Fierobe L, Decre D, Muller C, Lucet JC, Marmuse JP, Mantz J, Desmonts JM. Methicillin-resistant Staphylococcus aureus as a causative agent of postoperative intra-abdominal infection: relation to nasal colonization. Clin Infect Dis. 1999;29(5):1231-8. Ref ID 649. [pmid: 10524968].
125 Marriott DJ, Karagiannis T, Harkness JL, Kearney P. Further evaluation of the MRSA-Screen kit for rapid detection of methicillin resistance. J Clin Microbiol. 1999;37(11):3783-4. Ref ID 650. [pmid: 10610377].
126 Wong SS, Ho PL, Woo PC, Yuen KY. Bacteremia caused by staphylococci with inducible vancomycin heteroresistance. Clin Infect Dis. 1999;29(4):760-7. Ref ID 654. [pmid: 10589883].
127 Ender PT, Durning SJ, Woelk WK, Brockett RM, Astorga A, Reddy R, Meier PA. Pseudo-outbreak of methicillin-resistant Staphylococcus aureus. Mayo Clin Proc. 1999;74(9):885-9. Ref ID 658. [pmid: 10488789].
128 Morgan M, Salmon R, Keppie N, Evans-Williams D, Hosein I, Looker DN. All Wales surveillance of methicillin-resistant Staphylococcus aureus (MRSA): the first year’s results. J Hosp Infect. 1999;41(3):173-9. Ref ID 672. [pmid: 10204119].
129 Villari P, Iacuzio L, Torre I, Scarcella A. Molecular epidemiology as an effective tool in the surveillance of infections in the neonatal intensive care unit. J Infect. 1998;37(3):274-81. Ref ID 683. [pmid: 9892532].
130 Girou E, Pujade G, Legrand P, Cizeau F, Brun-Buisson C. Selective screening of carriers for control of methicillin-resistant Staphylococcus aureus (MRSA) in high-risk hospital areas with a high level of endemic MRSA. Clin Infect Dis. 1998;27(3):543-50. Ref ID 685. [pmid: 9770155].
131 Vannuffel P, Laterre PF, Bouyer M, Gigi J, Vandercam B, Reynaert M, Gala JL. Rapid and specific molecular identification of methicillin-resistant Staphylococcus aureus in endotracheal aspirates from mechanically ventilated patients. J Clin Microbiol. 1998;36(8):2366-8. Ref ID 688. [pmid: 9666026].
132 Kibbler C, Quick A, O’Neill AM. The effect of increased bed numbers on MRSA transmission in acute medical wards. J Hosp Infect. 1998;39(3):213-9. Ref ID 690. [pmid: 9699141].
133 Torrens JK. Is it time to stop searching for MRSA? Selective screening for MRSA should be considered. BMJ. 1997;315(7099):57. Ref ID 715. [pmid: 9233340].
134 Philp R, McCann R, Rowland P. Is it time to stop searching for MRSA? Follow up screening within the community needs clarification. BMJ. 1997;315(7099):57. Ref ID 716. [pmid: 9233339].
135 Kampf G, Weist K, Swidsinski S, Kegel M, Ruden H. Comparison of screening methods to identify methicillin-resistant Staphylococcus aureus. Eur J Clin Microbiol Infect Dis. 1997;16(4):301-7. Ref ID 718. [pmid: 9177964].
136 Simor, Ofner-Agostini M, Paton S. The Canadian Nosocomial Infection Surveillance Program: results of the first 18 months of surveillance for methicillin-resistant Staphylococcus aureus in Canadian hospitals. Can Commun Dis Rep. 1997;23(6):41-5. Ref ID 721. [pmid: 9094792].
137 Hartstein I, LeMonte AM, Iwamoto PK. DNA typing and control of methicillin-resistant Staphylococcus aureus at two affiliated hospitals. Infect Control Hosp Epidemiol. 1997;18(1):42-8. Ref ID 733. [pmid: 9013246].
138 Crowcroft N, Maguire H, Fleming M, Peacock J, Thomas J. Methicillin-resistant Staphylococcus aureus: investigation of a hospital outbreak using a case-control study. J Hosp Infect. 1996;34(4):301-9. Ref ID 741. [pmid: 8971619].
139 Blanc S, Petignat C, Moreillon P, Wenger A, Bille J, Francioli P. Quantitative antibiogram as a typing method for the prospective epidemiological surveillance and control of MRSA: comparison with molecular typing. Infect Control Hosp Epidemiol. 1996;17(10):654-9. Ref ID 743. [pmid: 8899439].
140 Mayall, Martin R, Keenan AM, Irving L, Leeson P, Lamb K. Blanket use of intranasal mupirocin for outbreak control and long-term prophylaxis of endemic methicillin-resistant Staphylococcus aureus in an open ward. J Hosp Infect. 1996;32(4):257-66. Ref ID 756. [pmid: 8744510].
141 Jernigan JA, Titus MG, Groschel DH, Getchell-White S, Farr BM. Effectiveness of contact isolation during a hospital outbreak of methicillin-resistant Staphylococcus aureus. Am J Epidemiol. 1996;143(5):496-504. Ref ID 759. [pmid: 8610665].
142 Quinio, Albanese J, Bues-Charbit M, Viviand X, Martin C. Selective decontamination of the digestive tract in multiple trauma patients. A prospective double-blind, randomized, placebo-controlled study. Chest. 1996;109(3):765-72. Ref ID 760. [pmid: 8617089].
143 Hartstein I, Denny MA, Morthland VH, LeMonte AM, Pfaller MA. Control of methicillin-resistant Staphylococcus aureus in a hospital and an intensive care unit. Infect Control Hosp Epidemiol. 1995;16(7):405-11. Ref ID 770. [pmid: 7673646].
144 Lugeon, Blanc DS, Wenger A, Francioli P. Molecular epidemiology of methicillin-resistant Staphylococcus aureus at a low-incidence hospital over a 4-year period. Infect Control Hosp Epidemiol. 1995;16(5):260-7. Ref ID 776. [pmid: 7657973].
145 Baiocchi P, Capone A, Di Rosa R, Penni A, Santini C, Venditti M. Surveillance study on Staphylococcus aureus in Rome: preliminary data on the frequency of methicillin resistance among nosocomial and community isolates. Ann Ig. 1995;7(2):77-81. Ref ID 779. [pmid: 8814666].
146 Saunders GL, Hammond JM, Potgieter PD, Plumb HA, Forder AA. Microbiological surveillance during selective decontamination of the digestive tract (SDD). J Antimicrob Chemother. 1994;34(4):529-44. Ref ID 790. [pmid: 7868405].
147 Thevanesam V, Wijeyawardana WL, Ekanayake EW. Methicillin resistant Staphylococcus aureus: the scale of the problem in a Shri Lankan hospital. J Hosp Infect. 1994;26(2):123-7. Ref ID 802. [pmid: 7911145].
148 Voss, Milatovic D, Wallrauch-Schwarz C, Rosdahl VT, Braveny I. Methicillin-resistant Staphylococcus aureus in Europe. Eur J Clin Microbiol Infect Dis. 1994;13(1):50-5. Ref ID 808. [pmid: 8168564].
149 Lingnau W, Allerberger F. Control of an outbreak of methicillin-resistant Staphylococcus aureus (MRSA) by hygienic measures in a general intensive care unit. Infection. Suppl 2. 1994;22:S135-9. Ref ID 810. [pmid: 7927832].
150 Brakstad OG, Maeland JA, Tveten Y. Multiplex polymerase chain reaction for detection of genes for Staphylococcus aureus thermonuclease and methicillin resistance and correlation with oxacillin resistance. APMIS. 1993;101(9):681-8. Ref ID 814. [pmid: 8240787].
151 Stamm M, Long MN, Belcher B. Higher overall nosocomial infection rate because of increased attack rate of methicillin-resistant Staphylococcus aureus. Am J Infect Control. 1993;21(2):70-4. Ref ID 820. [pmid: 8498697].
152 Venezia RA, Harris V, Miller C, Peck H, San Antonio M. Investigation of an outbreak of methicillin-resistant Staphylococcus aureus in patients with skin disease using DNA restriction patterns. Infect Control Hosp Epidemiol. 1992;13(8):472-6. Ref ID 834. [pmid: 1325496].
153 Cohen SH, Morita MM, Bradford M. A seven-year experience with methicillin-resistant Staphylococcus aureus. Am J Med. 1991;91(3B):233S-237S. Ref ID 842. [pmid: 1928170].
154 Hicks NR, Moore EP, Williams EW. Carriage and community treatment of methicillin-resistant Staphylococcus aureus: what happens to colonized patients after discharge?. J Hosp Infect. 1991;19(1):17-24. Ref ID 843. [pmid: 1684593].
155 Piper J, Astorga A, Hadfield T. Commercially available technique for rapid laboratory detection of methicillin resistance among Staphylococcus aureus. Diagn Microbiol Infect Dis. 1988;11(3):177-80. Ref ID 862. [pmid: 3246145].
156 Ribner BS, Landry MN, Gholson GL. Strict versus modified isolation for prevention of nosocomial transmission of methicillin-resistant Staphylococcus aureus. Infect Control. 1986;7(6):317-20. Ref ID 874. [pmid: 3635495].
157 Peterson, Marquez P, Terashita D, Burwell L, Mascola L. Hospital methicillin-resistant Staphylococcus aureus active surveillance practices in Los Angeles County: Implications of legislation-based infection control, 2008. Am J Infect Control. 2010;38(8):653-656. Ref ID 884. [pmid: 20471715].
158 Kaier K, Meyer E, Dettenkofer M, Frank U. Epidemiology meets econometrics: Using time-series analysis to observe the impact of bed occupancy rates on the spread of multidrug-resistant bacteria. J Hosp Infect. 2010;76(2):108-113. Ref ID 889. [pmid: 20599296].
159 Nakamura MM, McAdam AJ, Sandora TJ, Moreira KR, Lee GM. Higher prevalence of pharyngeal than nasal Staphylococcus aureus carriage in pediatric intensive care units. J Clin Microbiol. 2010;48(8):2957-2959. Ref ID 901. [pmid: 20573867].
160 Nseir S, Grailles G, Soury-Lavergne A, Minacori F, Alves I, Durocher A. Accuracy of American Thoracic Society/Infectious Diseases Society of America criteria in predicting infection or colonization with multidrug-resistant bacteria at intensive-care unit admission. Clin Microbiol Infect. 2010;16(7):902-908. Ref ID 904. [pmid: 19694760].
161 Chen C-B, Chang H-C, Huang Y-C. Nasal meticillin-resistant Staphylococcus aureus carriage among intensive care unit hospitalised adult patients in a Taiwanese medical centre: one time-point prevalence, molecular characteristics and risk factors for carriage. J Hosp Infect. 2010;74(3):238-244. Ref ID 927. [pmid: 20153554].
162 Kirby, Graham R, Williams NJ, Wootton M, Broughton CM, Alanazi M, Anson J, Neal TJ, Parry CM. Staphylococcus aureus with reduced glycopeptide susceptibility in Liverpool, UK. J Antimicrob Chemother. 2010;65(4):721-724. Ref ID 930. [pmid: 20124288].
163 Yetkin G, Kuzucu C, Durmaz B, Durmaz R, Cizmeci Z, Iseri L. Molecular typing of methicillin-resistant Staphylococcus aureus isolated from bloodstream infections in a university hospital. Turk J Med Sci. 2009;39(6):959-968. Ref ID 942.
164 Kleinschmidt S, Lidstone C, Henderson B, Faoagali J. Comparison of the BD(trademark) GeneOhm MRSA assay, broth enrichment culture and chromID(trademark) MRSA for detection of methicillin-resistant Staphylococcus aureus from inter-hospital intensive care transfer patients. Healthc Infect. 2009;14(3):89-93. Ref ID 944.
165 Hacek M, Paule SM, Thomson RB Jr, Robicsek A, Peterson LR. Implementation of a universal admission surveillance and decolonization program for methicillin-resistant Staphylococcus aureus (MRSA) reduces the number of MRSA and total number of S. aureus isolates reported by the clinical laboratory. J Clin Microbiol. 2009;47(11):3749-3752. Ref ID 947. [pmid: 19794056].
166 Kock R, Brakensiek L, Mellmann A, Kipp F, Henderikx M, Harmsen D, Daniels-Haardt I, von Eiff C, Becker K, Hendrix MGR, Friedrich AW. Cross-border comparison of the admission prevalence and clonal structure of meticillin-resistant Staphylococcus aureus. J Hosp Infect. 2009;71(4):320-326. Ref ID 975. [pmid: 19201056].
167 Robicsek, Beaumont JL, Peterson LR. Duration of colonization with methicillin-resistant staphylococcus aureus. Clin Infect Dis. 2009;48(7):910-913. Ref ID 979. [pmid: 19231982].
168 Evison J, Muhlemann K. Screening for carriage of methicillin-resistant Staphylococcus aureus shortly after exposure may lead to false-negative results. Infect Control Hosp Epidemiol. 2008;29(8):774-776. Ref ID 1013. [pmid: 18590454].
169 Perez LRR, Dias C, D’Azevedo PA. Agar dilution and agar screen with cefoxitin and oxacillin: What is known and what is unknown in detection of meticillin-resistant Staphylococcus aureus. J Med Microbiol. 2008;57(8):954-956. Ref ID 1015. [pmid: 18628494].
170 Walker S, Peto TEA, O’Connor L, Crook DW, Wyllie D. Are there better methods of monitoring MRSA control than bacteraemia surveillance? An observational database study. PLoS ONE. 2008;3(6). #Pages#. Ref ID 1018.
171 Small H, Casey AL, Elliott TSJ, Rollason J, Hilton AC, Ball S. The oral cavity - An overlooked site for MRSA screening and subsequent decolonisation therapy?. J Infect. 2007;55(4):378-379. Ref ID 1045. [pmid: 17604838].
172 Mertz, Frei R, Jaussi B, Tietz A, Stebler C, Fluckiger U, Widmer AF. Throat swabs are necessary to reliably detect carriers of Staphylococcus aureus. Clin Infect Dis. 2007;45(4):475-477. Ref ID 1047. [pmid: 17638197].
173 Baddour MM, Abuelkheir MM, Fatani AJ, Bohol MF, Al-Ahdal MN. Molecular epidemiology of methicillin-resistant Staphylococcus aureus (MRSA) isolates from major hospitals in Riyadh, Saudi Arabia. Can J Microbiol. 2007;53(8):931-936. Ref ID 1049. [pmid: 17898849].
174 Suetens, Morales I, Savey A, Palomar M, Hiesmayr M, Lepape A, Gastmeier P, Schmit JC, Valinteliene R, Fabry J. European surveillance of ICU-acquired infections (HELICS-ICU): methods and main results. J Hosp Infect. 2007;65(SUPPL 2):171-173. Ref ID 1052. [pmid: 17540265].
175 Anwar R, Botchu R, Viegas M, Animashawun Y, Shashidhara S, Slater GJR. Preoperative methicillin-resistant Staphylococcus aureus (MRSA) screening: An effective method to control MRSA infections on elective orthopaedics wards. Surg Pract. 2006;10(4):135-137. Ref ID 1067.
176 Maskell NA, Batt S, Hedley EL, Davies CWH, Gillespie SH, Davies RJO. The bacteriology of pleural infection by genetic and standard methods and its mortality significance. Am J Respir Crit Care Med. 2006;174(7):817-823. Ref ID 1073. [pmid: 16840746].
177 Wilson PR, Hayman S, Cepeda JA, Singer M, Bellingan G. Screening for MRSA and GISA in the intensive care unit. J Hosp Infect. 2006;64(1):85-86. Ref ID 1079. [pmid: 16820246].
178 Salgado D, Farr BM. What proportion of hospital patients colonized with methicillin-resistant Staphylococcus aureus are identified by clinical microbiological cultures?. Infect Control Hosp Epidemiol. 2006;27(2):116-121. Ref ID 1105. [pmid: 16465626].
179 Lepelletier, Perron S, Huguenin H, Picard M, Bemer P, Caillon J, Juvin M-E, Drugeon HB. Which Strategies Follow from the Surveillance of Multidrug-Resistant Bacteria to Strengthen the Control of Their Spread? A French Experience. Infect Control Hosp Epidemiol. 2004;25(2):162-164. Ref ID 1190. [pmid: 14994943].
180 Sasaki R, Fujino T, Saruta K, Kawasaki J, Shigeto N, Kirikae T. Molecular epidemiological surveillance of methicillin-resistant Staphylococcus aureus in a hiroshima community hospital in 2002. Jpn J Infect Dis. 2002;55(3):93-95. Ref ID 1248. [pmid: 12195052].
181 Akins PT, Belko J, Banerjee A, Guppy K, Herbert D, Slipchenko T, DeLemos C, Hawk M. Perioperative management of neurosurgical patients with methicillin-resistant Staphylococcus aureus. J Neurosurg. 2010;112(2):354-61. Ref ID 9000. [pmid: 19522572].
182 Awad SS, Palacio CH, Subramanian A, Byers PA, Abraham P, Lewis DA, Young EJ. Implementation of a methicillin-resistant Staphylococcus aureus (MRSA) prevention bundle results in decreased MRSA surgical site infections. Am J Surg. 2009;198(5):607-10. Ref ID 9004. [pmid: 19887186].
183 Chaberny F, Bindseil A, Sohr D, Gastmeier P. A point-prevalence study for MRSA in a German university hospital to identify patients at risk and to evaluate an established admission screening procedure. Infection. 2008;36(6):526-32. Ref ID 9007. [pmid: 18726552].
184 Diller R, Sonntag AK, Mellmann A, Grevener K, Senninger N, Kipp F, Friedrich AW. Evidence for cost reduction based on pre-admission MRSA screening in general surgery. Int J Hyg Environ Health. 2008;211(1–2):205-12. Ref ID 9015. [pmid: 17692566].
185 Edmond MB, Ober JF, Bearman G. Active surveillance cultures are not required to control MRSA infections in the critical care setting. Am J Infect Control. 2008;36(6):461-3. Ref ID 9016. [pmid: 18675155].
186 Goodman R, Platt R, Bass R, Onderdonk AB, Yokoe DS, Huang SS. Impact of an environmental cleaning intervention on the presence of methicillin-resistant Staphylococcus aureus and vancomycin-resistant enterococci on surfaces in intensive care unit rooms. Infect Control Hosp Epidemiol. 2008;29(7):593-9. Ref ID 9018. [pmid: 18624666].
187 Gregory ML, Eichenwald EC, Puopolo KM. Seven-year experience with a surveillance program to reduce methicillin-resistant Staphylococcus aureus colonization in a neonatal intensive care unit. Pediatrics. 2009;123(5):e790-6. Ref ID 9021. [pmid: 19403471].
188 Harris D, Furuno JP, Roghmann MC, Johnson JK, Conway LJ, Venezia RA, Standiford HC, Schweizer ML, Hebden JN, Moore AC, Perencevich EN. Targeted surveillance of methicillin-resistant Staphylococcus aureus and its potential use to guide empiric antibiotic therapy. Antimicrob Agents Chemother. 2010;54(8):3143-8. Ref ID 9026. [pmid: 20479207].
189 Khan, Lampitoc M, Salaripour M, McKernan P, Devlin R, Muller MP. Rapid control of a methicillin resistant Staphylococcus aureus (MRSA) outbreak in a medical surgical intensive care unit (ICU). Can J Infect Control. 2009;24(1):12-6. Ref ID 9035. [pmid: 19517879].
190 Mertz D, Frei R, Periat N, Scheidegger C, Battegay M, Seiler W, Widmer AF. Eradication of an epidemic methicillin-resistant Staphylococcus aureus (MRSA) from a geriatric university hospital: evidence from a 10-year follow-up. Eur J Clin Microbiol Infect Dis. 2010;29(8):987-93. Ref ID 9045. [pmid: 20521159].
191 Nulens, Broex E, Ament A, Deurenberg RH, Smeets E, Scheres J, van Tiel FH, Gordts B, Stobberingh EE. Cost of the meticillin-resistant Staphylococcus aureus search and destroy policy in a Dutch university hospital. J Hosp Infect. 2008;68(4):301-7. Ref ID 9051. [pmid: 18353496].
192 Reilly JS, Stewart S, Christie P, Allardice G, Smith A, Masterton R, Gould IM, Williams C. Universal screening for meticillin-resistant Staphylococcus aureus: interim results from the NHS Scotland pathfinder project. J Hosp Infect. 2010;74(1):35-41. Ref ID 9055. [pmid: 19959256].
193 Rymzhanova R, Thouverez M, Talon D, Bertrand X. Usefulness of weekly methicillin-resistant Staphylococcus aureus screening. Infect Control Hosp Epidemiol. 2009;30(11):1113-5. Ref ID 9059. [pmid: 19780674].
194 Sakamoto, Yamada H, Suzuki C, Sugiura H, Tokuda Y. Increased use of alcohol-based hand sanitizers and successful eradication of methicillin-resistant Staphylococcus aureus from a neonatal intensive care unit: A multivariate time series analysis. Am J Infect Control. 2010. #volume#(), #Pages#. Ref ID 9060.
195 Simoens S, Ophals E, Schuermans A. Search and destroy policy for methicillin-resistant Staphylococcus aureus: cost-benefit analysis. J Adv Nurs. 2009;65(9):1853-9. Ref ID 9063. [pmid: 19694848].
196 Vikram R, Dumigan DG, Kohan C, Havill NL, Tauman A, Boyce JM. Discontinuation of contact precautions for patients no longer colonized with methicillin-resistant Staphylococcus aureus. Infect Control Hosp Epidemiol. 2010;31(5):541-3. Ref ID 9071. [pmid: 20337527].
197 Weber DJ, Sickbert-Bennett EE, Brown V, Rutala WA. Comparison of hospitalwide surveillance and targeted intensive care unit surveillance of healthcare-associated infections. Infect Control Hosp Epidemiol. 2007;28(12):1361-6. Ref ID 9077. [pmid: 17994516].
198 Adam J, Allen VG, Currie A, McGeer AJ, Simor AE, Richardson SE, Louie L, Willey B, Rutledge T, Lee J, Goldman RD, Somers A, Ellis P, Sarabia A, Rizos J, Borgundvaag B, Katz KC. Community-associated methicillin-resistant Staphylococcus aureus: Prevalence in skin and soft tissue infections at emergency departments in the greater toronto area and associated risk factors. Canadian Journal of Emergency Medicine. 2009;11(5):439-446. Ref ID 12003. [pmid: 19788788].
199 Alexander L, Morgan DJ, Kesh S, Weisenberg SA, Zaleskas JM, Kaltsas A, Chevalier JM, Silberzweig J, Barron Y, Mediavilla JR, Kreiswirth BN, Rhee KY. Prevalence, persistence, and microbiology of Staphylococcus aureus nasal carriage among hemodialysis outpatients at a major New York Hospital. Diagn Microbiol Infect Dis. 2011;70(1):37-44. Ref ID 12013. [pmid: 21334154].
200 Ananda-Rajah MR, McBryde ES, Buising KL, Redl L, Macisaac C, Cade JF, Marshall C. The role of general quality improvement measures in decreasing the burden of endemic MRSA in a medical-surgical intensive care unit. Intensive Care Med. 2010;36(11):1890-8. Ref ID 12019. [pmid: 20689907].
201 Barry, McNicholas S, Smyth E, Humphreys H, Fitzpatrick F. Audit of the management of Staphylococcus aureus bloodstream infection: Gaps to be plugged. Journal of Hospital Infection. 2010;76(3):272-273. Ref ID 12033. [pmid: 20435374].
202 Bolesh DT. RE: Methicillin-resistant Staphylococcus aureus infections in U.S. service members deployed to Iraq. published in [Mil Med 2009; 174(4):408–11]. Mil Med. 2010;175(9):x-xi. Ref ID 12051. [pmid: 20882916].
203 Briggs J, Milstone AM. Changes over time in caregivers’ knowledge, attitudes, and behaviors regarding methicillin-resistant Staphylococcus aureus. J Pediatr. 2011;158(6):1039. Ref ID 12063. [pmid: 21353247].
204 Chaberny F, Wriggers A, Behnke M, Gastmeier P. Antibiotics: MRSA prevention measures in German hospitals: results of a survey among hospitals, performed as part of the MRSA-KISS module. Dtsch Arztebl Int. 2010;107(37):631-7. Ref ID 12078. [pmid: 20959890].
205 Choi SH, Cho SY, Park JH, Chung JW. Impact of infectious-disease specialist consultations on outcomes of Staphylococcus aureus bacteremia in a hospital with a low volume of patients with S. aureus bacteremia. Journal of Infection. 2011;62(2):181-185. Ref ID 12091. [pmid: 21163299].
206 Conrad, Kaier K, Frank U, Dettenkofer M. Are short training sessions on hand hygiene effective in preventing hospital-acquired MRSA? A time-series analysis. Am J Infect Control. 2010;38(7):559-61. Ref ID 12099. [pmid: 20227792].
207 Garcia-Rodriguez F, Alvarez-Diaz H, Lorenzo-Garcia MV, Mendez-Lage S, Marino-Callejo A, Sesma-Sanchez P. Non-hospital-associated methicillin-resistant Staphylococcus aureus and MRSA chronic carrier patients in infection control. Am J Infect Control. 2011;39(3):250-3. Ref ID 12174. [pmid: 21367491].
208 Garvin L, Konigsberg BS. Infection following total knee arthroplasty: Prevention and management. Journal of Bone and Joint Surgery - Series A. 2011;93(12):1167-1175. Ref ID 12177.
209 Ghazal SS, Hakawi AM, Demeter CV, Joseph MV, Mukahal MA. Intervention to reduce the incidence of healthcare-associated methicillin-resistant Staphylococcus aureus infection in a Tertiary Care Hospital in Saudi Arabia. Infect Control Hosp Epidemiol. 2011;32(4):411-3. Ref ID 12182. [pmid: 21460502].
210 Kaplan SL. Acute hematogenous osteomyelitis in Children: Differences in clinical manifestations and management. Pediatric Infectious Disease Journal. 2010;29(12):1128-1129. Ref ID 12263. [pmid: 21099652].
211 Kashuk JL, Moore EE, Price CS, Zaw-Mon C, Nino T, Haenel J, Biffl WL, Burlew CC, Johnson JL. Patterns of early and late ventilator-associated pneumonia due to methicillin-resistant Staphylococcus aureus in a trauma population. J Trauma. 2010;69(3):519-22. Ref ID 12266. [pmid: 20173657].
212 Kassakian SZ, Mermel LA, Jefferson JA, Parenteau SL, Machan JT. Impact of chlorhexidine bathing on hospital-acquired infections among general medical patients. Infect Control Hosp Epidemiol. 2011;32(3):238-43. Ref ID 12267. [pmid: 21460508].
213 Kaye KS, Marchaim D, Chen TY, Chopra T, Anderson DJ, Choi Y, Sloane R, Schmader KE. Predictors of nosocomial bloodstream infections in older adults. J Am Geriatr Soc. 2011;59(4):622-7. Ref ID 12270. [pmid: 21366545].
214 Lietard, Lejeune B, Metzger MH, Thiolet JM, Coignard B. National point prevalence survey of healthcare-associated infections: Results for people aged 65 and older, FRANCE, 2006. Journal of the American Geriatrics Society. 2011;59(4):763-765. Ref ID 12311. [pmid: 21492109].
215 Lin SH, Lai CC, Tan CK, Liao WH, Hsueh PR. Comparative efficacy of vancomycin and teicoplanin in the treatment of hospitalised elderly patients with persistent meticillin-resistant Staphylococcus aureus (MRSA) bacteraemia. Int J Antimicrob Agents. 2011;37(2):179-81. Ref ID 12313. [pmid: 21163634].
216 McNicholas S, Andrews C, Boland K, Shields M, Doherty GA, Murray FE, Smyth EG, Humphreys H, Fitzpatrick F. Delayed acute hospital discharge and healthcare-associated infection: The forgotten risk factor. Journal of Hospital Infection. 2011;78(2):157-158. Ref ID 12353. [pmid: 21497945].
217 Ratnayake, Olver WJ. Rapid PCR detection of methicillin-resistant Staphylococcus aureus and methicillin-sensitive S. aureus samples from charcoal-containing blood culture bottles. J Clin Microbiol. 2011;49(6):2382. Ref ID 12456. [pmid: 21450968].
218 Saderi, Owlia P, Sahebnasagh R. Determination of prevalence of resistance to methicillin in Staphylococcus aureus clinical isolates in Tehran, Iran, by PCR method. International Journal of Infectious Diseases. 2011;15:S46. Ref ID 12481.
219 Salangsang JA, Harrison LH, Brooks MM, Shutt KA, Saul MI, Muto CA. Patient-associated risk factors for acquisition of methicillin-resistant Staphylococcus aureus in a tertiary care hospital. Infect Control Hosp Epidemiol. 2010;31(11):1139-47. Ref ID 12485. [pmid: 20923281].
220 Soriano, Mensa J. Is transesophageal echocardiography dispensable in hospital-acquired staphylococcus aureus bacteremia?. Clinical Infectious Diseases. 2011;53(1):10-12. Ref ID 12525. [pmid: 21653296].
221 Thompson. Hospital infection control and the reduction in intensive care unit-acquired MRSA between 1996 and 2009. J Hosp Infect. 2010;76(3):271-2. Ref ID 12555. [pmid: 20547430].
222 Vandana KE, Varghese G, Krishna S, Mukhopadhyay C, Kamath A, Ajith V. Screening at admission for carrier prevalence of multidrug-resistant organisms in resource-constrained settings: a hospital-based observational study. J Hosp Infect. 2010;76(2):180-1. Ref ID 12579. [pmid: 20542353].
223 Viale P, Gesu G, Privitera G, Allaria B, Petrosillo N, Zamparini E, Scudeller L. Multicenter, prospective surveillance study of Staphylococcus aureus nasal colonization in 28 Italian intensive care units: the ISABEL Study. Infect Control Hosp Epidemiol. 2011;32(2):193-7. Ref ID 12587. [pmid: 21460479].
224 Burton C, Edwards JR, Horan TC, Jernigan JA, Fridkin SK. Methicillin-resistant Staphylococcus aureus central line-associated bloodstream infections in US intensive care units, 1997–2007. JAMA. 2009;301(7):727-36. Ref ID 13207. [pmid: 19224749].
225 Nicastri, Leone S, Petrosillo N, Ballardini M, Pisanelli C, Magrini P, Cerquetani F, Ippolito G, Comandini E, Narciso P, Meledandri M. Decrease of methicillin resistant Staphylococcus aureus prevalence after introduction of a surgical antibiotic prophylaxis protocol in an Italian hospital. New Microbiol. 2008;31(4):519-25. Ref ID 13225. [pmid: 19123308].

## Excluded: No Relevant Outcome

1 Mahamat, MacKenzie FM, Brooker K, Monnet DL, Daures JP, Gould IM. Impact of infection control interventions and antibiotic use on hospital MRSA: a multivariate interrupted time-series analysis. Int J Antimicrob Agents. 2007;30(2):169-76. Ref ID 6. [pmid: 17560085].
2 Kotilainen P, Routamaa M, Peltonen R, Oksi J, Rintala E, Meurman O, Lehtonen OP, Eerola E, Salmenlinna S, Vuopio-Varkila J, Rossi T. Elimination of epidemic methicillin-resistant Staphylococcus aureus from a university hospital and district institutions, Finland. Emerg Infect Dis. 2003;9(2):169-75. Ref ID 461. [pmid: 12603986].
3 Kotilainen P, Routamaa M, Peltonen R, Evesti P, Eerola E, Salmenlinna S, Vuopio-Varkila J, Rossi T. Eradication of methicillin-resistant Staphylococcus aureus from a health center ward and associated nursing home. Arch Intern Med. 2001;161(6):859-63. Ref ID 571. [pmid: 11268229].
4 Spencer, Gulczynski D. Cut down on SSIs. Nurs Manage. 2010;41(10):26-31. quiz 32. Ref ID 12526. [pmid: 20847707].

## Excluded: No Statistical Analysis Reported

1 van Trijp MJ, Melles DC, Hendriks WD, Parlevliet GA, Gommans M, Ott A. Successful control of widespread methicillin-resistant Staphylococcus aureus colonization and infection in a large teaching hospital in the Netherlands. Infect Control Hosp Epidemiol. 2007;28(8):970-5. Ref ID 5. [pmid: 17620246].
2 Pastila S, Sammalkorpi KT, Vuopio-Varkila J, Kontiainen S, Ristola MA. Control of methicillin-resistant Staphylococcus aureus outbreak involving several hospitals. J Hosp Infect. 2004;58(3):180-6. Ref ID 329. [pmid: 15501331].
3 Myatt R, Langley S. Changes in infection control practice to reduce MRSA infection. Br J Nurs. 2003;12(11):675-81. Ref ID 436. [pmid: 12829967].
4 Coello R, Jimenez J, Garcia M, Arroyo P, Minguez D, Fernandez C, Cruzet F, Gaspar C. Prospective study of infection, colonization and carriage of methicillin-resistant Staphylococcus aureus in an outbreak affecting 990 patients. Eur J Clin Microbiol Infect Dis. 1994;13(1):74-81. Ref ID 806. [pmid: 8168567].
5 Walsh TJ, Vlahov D, Hansen SL, Sonnenberg E, Khabbaz R, Gadacz T, Standiford HC. Prospective microbiologic surveillance in control of nosocomial methicillin-resistant Staphylococcus aureus. Infect Control. 1987;8(1):7-14. Ref ID 871. [pmid: 3102395].
6 Tavares DA, Sa-Leao R, Miragaia M, de Lencastre H. Large screening of CA-MRSA among Staphylococcus aureus colonizing healthy young children living in two areas (urban and rural) of Portugal. BMC Infect. Dis. 2009;10. #Pages#. Ref ID 918.
7 Higgins, Lynch M, Gethin G. Can ‘search and destroy’ reduce nosocomial methicillin-resistant Staphylococcus aureus in an Irish hospital?. J Hosp Infect. 2010;75(2):120-3. Ref ID 9028. [pmid: 20236729].
8 Kochar S, Sheard T, Sharma R, Hui A, Tolentino E, Allen G, Landman D, Bratu S, Augenbraun M, Quale J. Success of an infection control program to reduce the spread of carbapenem-resistant Klebsiella pneumoniae. Infect Control Hosp Epidemiol. 2009;30(5):447-52. Ref ID 9037. [pmid: 19301985].
9 Lepelletier D, Corvec S, Caillon J, Reynaud A, Roze JC, Gras-Leguen C. Eradication of methicillin-resistant Staphylococcus aureus in a neonatal intensive care unit: which measures for which success?. Am J Infect Control. 2009;37(3):195-200. Ref ID 9041. [pmid: 19181423].
10 Martinez-Capolino C, Reyes K, Johnson L, Sullivan J, Samuel L, Digiovine B, Eichenhorn M, Horst HM, Varelas P, Mickey MA, Washburn R, Zervos M. Impact of active surveillance on meticillin-resistant Staphylococcus aureus transmission and hospital resource utilisation. J Hosp Infect. 2010;74(3):232-7. Ref ID 9042. [pmid: 20153553].
11 Murillo JL, Cohen M, Kreiswirth B. Results of nasal screening for methicillin-resistant Staphylococcus aureus during a neonatal intensive care unit outbreak. Am J Perinatol. 2010;27(1):79-81. Ref ID 9048. [pmid: 19544247].
12 Peterson LR, Hacek DM, Robicsek A. 5 Million Lives Campaign. Case study: an MRSA intervention at Evanston Northwestern Healthcare. Jt Comm J Qual Patient Saf. 2007;33(12):732-8. Ref ID 9052. [pmid: 18200898].
13 Richer SL, Wenig BL. The efficacy of preoperative screening and the treatment of methicillin-resistant Staphylococcus aureus in an otolaryngology surgical practice. Otolaryngol Head Neck Surg. 2009;140(1):29-32. Ref ID 9056. [pmid: 19130957].
14 Cordova KB, Grenier N, Chang KH, Dufresne R Jr. Preoperative methicillin-resistant Staphylococcus aureus screening in Mohs surgery appears to decrease postoperative infections. Dermatol Surg. 2010;36(10):1537-40. Ref ID 12101. [pmid: 20698869].
15 Pofahl WE, Ramsey KM, Nobles DL, Cochran MK, Goettler C. Importance of methicillin-resistant Staphylococcus aureus eradication in carriers to prevent postoperative methicillin-resistant Staphylococcus aureus surgical site infection. Am Surg. 2011;77(1):27-31. Ref ID 12443. [pmid: 21396301].

## Excluded: Does Not Meet Criteria During Quality Control: Review

1 Merrer J, Santoli F, Appere de Vecchi C, Tran B, DeJonghe B, Outin H. Colonization pressure and risk of acquisition of methicillin-resistant Staphylococcus aureus in a medical intensive care unit. Infect Control Hosp Epidemiol. 2000;21(11):718-23. Ref ID 596. [pmid: 11089656].
2 Chaix C, Durand-Zaleski I, Alberti C, Brun-Buisson C. Control of endemic methicillin-resistant Staphylococcus aureus: a cost-benefit analysis in an intensive care unit. JAMA. 1999;282(18):1745-51. Ref ID 648. [pmid: 10568647].
3 Pujol M, Pena C, Pallares R, Ayats J, Ariza J, Gudiol F. Risk factors for nosocomial bacteremia due to methicillin-resistant Staphylococcus aureus. Eur J Clin Microbiol Infect Dis. 1994;13(1):96-102. Ref ID 804. [pmid: 8168571].
4 Rao, Jacobs S, Joyce L. Cost-effective eradication of an outbreak of methicillin-resistant Staphylococcus aureus in a community teaching hospital. Infect Control Hosp Epidemiol. 1988;9(6):255-60. Ref ID 864. [pmid: 3136202].
5 Sheridan RL, Weber J, Benjamin J, Pasternack MS, Tompkins RG. Control of methicillin-resistant Staphylococcus aureus in a pediatric burn unit. AM J INFECT CONTROL. 1994;22(6):340-345. Ref ID 1297. [pmid: 7695112].
6 Graf K, Sohr D, Haverich A, Kuhn C, Gastmeier P, Chaberny IF. Decrease of deep sternal surgical site infection rates after cardiac surgery by a comprehensive infection control program. Interact Cardiovasc Thorac Surg. 2009;9(2):282-6. Ref ID 9020. [pmid: 19416962].
7 Jarlier V, Trystram D, Brun-Buisson C, Fournier S, Carbonne A, Marty L, Andremont A, Arlet G, Buu-Hoi A, Carlet J, Decre D, Gottot S, Gutmann L, Joly-Guillou ML, Legrand P, Nicolas-Chanoine MH, Soussy CJ, Wolf M, Lucet JC, Aggoune M, Brucker G, Regnier B. Curbing methicillin-resistant Staphylococcus aureus in 38 French hospitals through a 15-year institutional control program. Arch Intern Med. 2010;170(6):552-9. Ref ID 9029. [pmid: 20308642].
8 Seybold U, Halvosa JS, White N, Voris V, Ray SM, Blumberg HM. Emergence of and risk factors for methicillin-resistant Staphylococcus aureus of community origin in intensive care nurseries. Pediatrics. 2008;122(5):1039-46. Ref ID 9062. [pmid: 18977985].
9 Vos MC, Behrendt MD, Melles DC, Mollema FP, de Groot W, Parlevliet G, Ott A, Horst-Kreft D, van Belkum A, Verbrugh HA. 5 years of experience implementing a methicillin-resistant Staphylococcus aureus search and destroy policy at the largest university medical center in the Netherlands. Infect Control Hosp Epidemiol. 2009;30(10):977-84. Ref ID 9073. [pmid: 19712031].
10 Wang JT, Lauderdale TL, Lee WS, Huang JH, Wang TH, Chang SC. Impact of active surveillance and contact isolation on transmission of methicillin-resistant Staphylococcus aureus in intensive care units in an area with high prevalence. J Formos Med Assoc. 2010;109(4):258-68. Ref ID 9075. [pmid: 20434035].
11 Chuang YC, Chen YC, Chang SC, Sun CC, Chang YY, Chen ML, Hsu LY, Wang JT. Secular trends of healthcare-associated infections at a teaching hospital in Taiwan, 1981–2007. J Hosp Infect. 2010;76(2):143-9. Ref ID 12093. [pmid: 20663585].
12 Kusachi S, Nagao J, Saida Y, Watanabe M, Nakamura Y, Asai K, Okamoto Y, Arima Y, Watanabe R, Uramatsu M, Saito T, Kiribayashi T, Sato J. Twenty years of countermeasures against postoperative methicillin-resistant Staphylococcus aureus infections. Surg Today. 2011;41(5):630-6. Ref ID 12291. [pmid: 21533933].
13 Sarikonda KV, Micek ST, Doherty JA, Reichley RM, Warren D, Kollef MH. Methicillin-resistant Staphylococcus aureus nasal colonization is a poor predictor of intensive care unit-acquired methicillin-resistant Staphylococcus aureus infections requiring antibiotic treatment. Crit Care Med. 2010;38(10):1991-5. Ref ID 12492. [pmid: 20683260].