# Search Strategies

The following electronic databases were searched for citations.

- MEDLINE® (January 1, 1990, to September 1, 2011)
- EMBASE® (January 1, 1990, to September 1, 2011)
- Cochrane Controlled Trials Register (to September 1, 2011)

The MEDLINE® search resulted in 4746 unique citations. The EMBASE® search resulted in 3199 citations. The Cochrane search resulted in no new citations.

## PubMed Search

8/24/10 – yield 4746

Search updated 9/1/11 for 8/24/10 to 9/1/11

“Methicillin-Resistant Staphylococcus aureus”[Mesh]

OR (“Methicillin Resistance”[Mesh] AND “Staphylococcus aureus”[Mesh])

OR “methicillin-resistant staphylococcus aureus” OR MRSA

AND

“prevention and control “[Subheading] OR “Mass Screening”[Mesh] OR screening OR screened OR screen OR surveillance OR diagnosis

AND

randomized controlled trial [pt] OR controlled clinical trial [pt] OR randomized controlled trials [mh] OR random allocation [mh] OR double-blind method [mh] OR single-blind method [mh] OR clinical trial [pt] OR clinical trials [mh] OR “clinical trial” OR ((singl* OR doubl* OR trebl* OR tripl* ) AND (mask* OR blind* )) OR placebos [mh] OR placebo* OR random* OR research design [mh:noexp] OR follow-up studies [mh] OR prospective studies [mh] OR prospectiv* OR volunteer*) OR “Comparative Study “[Publication Type] OR “Evaluation Studies “[Publication Type] OR control OR controlled OR controls

## EMBASE Search

10/18/10 – yield 3199

Search updated 9/1/11 for 10/18/10 to 9/1/11

‘methicillin-resistant staphylococcus aureus’/exp OR (‘methicillin resistance’/exp AND ‘staphylococcus aureus’/exp) OR MRSA AND [humans]/lim

AND

‘prevention and control’/exp OR ‘mass screening’/exp OR ‘screening’/exp OR screened OR screen OR surveillance OR ‘diagnosis’/exp AND [humans]/lim

AND

‘randomized controlled trial’/exp OR ‘randomised controlled trial’/exp OR ‘controlled clinical trial’/exp OR ‘clinical trial’/exp OR (singl* OR doubl* OR trebl* OR tripl* AND (mask* OR blind*)) OR placebo* OR random* OR ‘follow-up study’/exp OR ‘prospective study’/exp OR prospectiv* OR volunteer* OR ‘comparative study’/exp OR ‘evaluation study’ OR ‘control’/exp OR controlled OR controls AND [humans]/lim

## Cochrane Search

10/18/10

Search updated 9/1/11 – search last 12 months – no unique records found

“methicillin-resistant staphylococcus aureus” OR (“Methicillin Resistant” AND “Staphylococcus aureus”)

AND

Screening OR Diagnosis OR surveillance

## Search Strategy for Gray Literature

### Regulatory Information

#### FDA

Source: http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfpmn/pmn.cfm

Date searched: 6/21/2011

Search strategy: 510(k) summary documents for the following were searched on FDA@devices

Xpert MRSA SA/SSTI

XPert MRSA SA/BC)

XPert MRSA

GeneOhm MRSA assay

BBL ChromAgar MRSA

Records: 49

### Clinical Trial Registries

#### NIH Database

Source: http://clinicaltrials.gov/

Date searched: 6/17/2011

Search strategy: Keyword + [ALL-FIELDS] AND “COMPLETED” [OVERALL-STATUS]

Key words: “MRSA Screen” “MRSA Screening” “MRSA surveillance” “MRSA active surveillance” “MRSA intervention” “MRSA prevention”

Records: 63

#### BioMed Central

Source: http://www.controlled-trials.com/mrct/

Date searched: 6/13/2011

Search strategy: “MRSA” for completed trials

Records:13

#### PhRMA

Source: http://www.clinicalstudyresults.org/home/

Date searched: 6/20/2011

Search strategy: Search String = “MRSA” for completed trials

Records: 2

#### WHO International Clinical Trials Registry Platform Search Portal

Source: http://apps.who.int/trialsearch/

Date searched: 6/20/2011

Search strategy: Search String = “MRSA” in the Title for ALL recruitment status trials

Records: 90

### Conference Papers and Abstracts

#### Cambridge Scientific Abstracts

Source: http://www.csa.com/factsheets/cpi-set-c.php

Date searched: 6/28/2011

Search strategy: search string “MRSA”

Records: 73

#### Scopus

Source: http://www.scopus.com/home.url

Date searched: 6/29/2011

Search strategy: search string “MRSA”

Records: 211

#### Specific Conferences and Association Meetings

Source:

1. ICAAC (Interscience Conference on Antimicrobial Agents and Chemotherapy)
2. The Infectious Disease Society of America
3. The Society for Healthcare Epidemiology of America
4. The Association of Professionals in Infection Control and Epidemiology
5. The American College of Physicians
6. The Pediatric Infectious Diseases Society
7. The European Society of Clinical Microbiology and Infectious Diseases
8. The International Society of Infectious Diseases
9. The Australasian Society of Infectious Diseases
10. The International Sepsis Forum
11. The European Society of Intensive Care Medicine

Date searched: 6/21/2011

Search strategy: KW: “MRSA”

Records: 829

### Government Documents

#### RePORTER

Source: http://projectreporter.nih.gov/reporter.cfm

Date searched: 6/20/2011

Search strategy: key word “MRSA” OR “methicillin-resistant”

Records: 9

#### HSRPROJ

Source: http://wwwcf.nlm.nih.gov/hsr_project/home_proj.cfm

Date searched: 6/15/2011

Search strategy: key word “MRSA” OR “methicillin-resistant”

Records: 6

#### AHRQ GOLD

Source: http://gold.ahrq.gov/projectsearch/

Date searched: 6/15/2011

Search strategy: key word “MRSA” OR “methicillin-resistant”

Records: 0

### Manufacturer Database

Source: CEPHEID

Date posted: 8/3/11

Date searched: 6/29/2011

Search strategy: Not applicable

Records: 95