# Abbreviations

Abd: abdominal
ACP: American College of Physicians
AHRQ: Agency for Healthcare Research and Policy
ANOVA: analysis of variance
ANCOVA: analysis of covariance
APIC: Association of Professionals in Infection Control and Epidemiology
BA: before/after
BICP: background infection control practices
BP: barrier precautions
BPCC: barrier precautions compliance checks
BSI: bloodstream infections
C: control
CADTH: Canadian Agency for Drugs and Technologies in Health
CA-MRSA: community-acquired MRSA
CCS: studies attempted to control for confounding/secular trends
CDC: Centers for Disease Control and Prevention
CG: control group
CHKGL: checklist/guidelines
CI: confidence interval
Coh: cohorting
EPC: Evidence-based Practice Center
EPICOT: Evidence, Population, Intervention, Comparison, Outcome, Timestamp
ESCMID: European Society of Clinical Microbiology and Infectious Diseases
ESICM: European Society of Intensive Care Medicine
FDA: U.S. Food and Drug Administration
GRADE: Grading of Recommendations Assessment, Development and Evaluation
HICPAC: Healthcare Infection Control Practices Advisory Committee
HCA: health care-associated
HCW: health care worker
HH: hand hygiene
HW: handwashing
ICAAC: Interscience Conference on Antimicrobial Agents and Chemotherapy
ICP: infection control practices
ICPW: infection control practices while waiting for MRSA test results
ICU: intensive care unit
INAM: intranasal antimicrobial
Int: intervention
IRR: incidence rate ratio
ISDA: Infectious Disease Society of America
ISF: International Sepsis Forum
ISID: International Society of Infectious Diseases
Iso: isolation
ITS: interrupted time series
IV: intravenous
IVAB: intravenous antibiotics
KI: Key Informants
KQ: Key Question
MDRO: multi-drug resistant organism
MeSH^®^: Medical Subject Headings^®^
MICU: medical intensive care unit
MRSA: methicillin-resistant Staphylococcus aureus
MSSA: methicillin-sensitive Staphylococcus aureus
NA: not applicable
N/n: no; number
NG: nasogastric
NHS: National Health Service
NHSN: National Healthcare Safety Network
non-CCS: studies did not attempt to control for confounding/secular trends
NR: not reported
NSS: not statistically significant
PCR: polymerase chain reaction
PEG: percutaneous endoscopic gastrostomy
PICU: pediatric intensive care unit
PICOTS: patient(s), intervention(s), comparator(s), outcome(s), timing, setting(s)
PIDS: Pediatric Infectious Diseases Society
PO: oral/by mouth
POAB: oral antibiotics
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
QEX: quasi-experimental
RCT: randomized, controlled trial
RR: relative risk
SHEA: Society for Healthcare Epidemiology of America
SICU: surgical intensive care unit
SIR: standardized infection ratio
SOE: strength of evidence
SS: statistically significant
SSI: surgical site infection
TAMW: topical antimicrobial washes
TEP: Technical Expert Panel
Test +: positive MRSA screening test result
Test −: negative MRSA screening test result
TOO: Task Order Officer
U.S.: United States
U: unclear/unknown
UK: United Kingdom
Unspec: unspecified
USPSTF: U.S. Preventive Services Task Force
VRE: vancomycin-resistant Enterococcus
WHO: World Health Organization
X-over: crossover
Y: yes