# Results

## Introduction

This chapter first presents the results of our literature searches. We then discuss the findings of our analyses for each Key Question (KQ) in turn; we address the following as relevant to the KQs, in this order:

- Surgical procedures, specifically:
  ○ tympanostomy tubes (TT), comparisons of different types or insertion approaches
  ○ TT versus myringotomy or nonsurgical interventions (delayed treatment or watchful waiting);
  ○ TT plus adenoidectomy versus myringotomy plus adenoidectomy or adenoidectomy alone;
  ○ myringotomy versus myringotomy, comparison of different approaches, various combinations of myringotomy plus adenoidectomy;
  ○ adenoidectomy versus nonsurgical interventions or TT; and
  ○ pharmacological interventions, specifically, oral or topical nasal steroids
- Nonpharmacological interventions, specifically, autoinflation
- Other treatment strategies, specifically delayed treatment or watchful waiting are presented in comparison with other treatment approaches above.

We did not find any randomized controlled trial (RCT) evidence concerning complementary or alternative medicine (CAM) treatments or procedures; therefore, this intervention will not be discussed further.

We describe all included studies for each treatment comparison at the beginning of the results for KQ 1. Because virtually all studies are included in KQ 1, we did not repeat the description of studies for other KQs. Exceptions are of the specifically identified studies in these tables included in the review solely for evidence of harms (KQ 3).43–45 We then present key points along with grades for strength of evidence for major comparisons and outcomes, followed by text and tables providing a more detailed synthesis of the included studies. When no studies reported on categories of outcomes, we note this finding in key points and do not repeat it in detailed synthesis.

We present all of the relevant results from meta-analyses that were conducted in the recent Cochrane reviews as part of our evidence. Because of the heterogeneity of populations, interventions, or outcomes in the newly included studies and because all of the included earlier reviews were recently completed, we did not find any additional bodies of information that lent themselves to quantitative synthesis. As a result, all results new to this systematic review are based on qualitative “narrative” synthesis.

In summary tables that describe included studies, we specify not only study type (e.g., RCT, nonrandomized trial, or observational study) but also whether the arms of the study were determined by ear or by participant. Evidence tables for included studies are provided in Appendix C and include the risk-of-bias assessments for each of the included studies and systematic reviews.

We included in these analyses only studies that we had rated as low or medium risk of bias, except for KQ 3 (harms) where two studies (in three articles) with high risk of bias were included.43–45 Studies rated high risk of bias are listed in Appendix E together with the principal reason(s) for that rating.

We did not include in our analysis 24 articles concerning benefits of treatment that we evaluated as high risk of bias because we believed that they would not provide reliable estimates in our qualitative synthesis and could detract from the findings in the more methodologically rigorous studies. Three RCTs46–48 were determined to have a high risk of bias because participants received co-interventions that were either not accounted for in the analysis or because they received interventions included in comparison arms. Seven nonrandomized controlled trials43,44,49–53 were determined to have a high risk of bias for similar reasons as the RCTs and/or because baseline characteristics of participants were not adequately reported to determine that the study arms were comparable. Similarly, 14 cohort studies26,45,54–65 inadequately reported baseline characteristics to evaluate selection bias and did not control for potential confounding; and one case control study66 inadequately reported patient characteristics and inclusion/exclusion criteria so that we were unable to determine if outcome differences were due to the procedures that patients received or patient characteristics.

Detailed strength of evidence tables are presented in Appendix F. The final strength of evidence grades for the most critical findings are presented in this chapter. A description of procedures for measuring hearing, language, and quality-of-life measures is found in Table 5.

Table 5 Description of procedures/measures of hearing, language and quality of life related to OME

Method of Measurement and Example Indices | Description | Range/Meaning of Possible Scores | Improvement Indication
Hearing Measures: Pure-tone audiometry (PTA) | PTA is a behavioral test used to measure hearing sensitivity. Pure-tone thresholds (PTTs) or hearing levels (HLs) indicate the softest sound audible to an individual at least 50% of the time. Results are often averaged over different frequency levels. A modified form is sweep audiometry. | Normal hearing is age dependent: 15 dB for young children, 20 dB for children through early adolescence; and 25 dB for older adolescents and adults. The least intense audible sound is 0 dB. A sound 10 times more powerful is 10 dB, a sound 100 times more powerful than 0 dB is 20 dB, and a sound 1,000 greater is 30 dB. A 10 dB increase from 35 to 45 is much larger than a threshold increase from 15 dB to 25 dB. | Reduction in PTA HLs
Hearing Measures: Air-Bone Gap (ABG) | A method of diagnosing conductive hearing loss. It is the difference in audiometric hearing thresholds using bone conduction and air conduction. | The degree of conductive hearing loss is represented by difference in audiometric hearing thresholds using bone conduction in which sound transmission bypasses the middle ear and air conduction. Greater ABGs indicate greater hearing loss. | Reductions in ABGs
Hearing Measures: Sweep audiometry | A modified form of pure tone audiometry. | Same interpretation as PTA. | Same as PTA
Hearing Measures: Speech Recognition Threshold (SRT) | The speech recognition threshold is the softest level at which speech is understood. | Scores are given in dBs and have the same meaning as pure tone hearing levels. | Reduction in SRTs
Speech and Language: Receptive language | Receptive language measures how one understands language. | Usually provided as a standard score that has been normed on a representative sample. | Increases in standard scores
Speech and Language: Expressive language | Expressive language measures how one produces language. | Usually provided as a standard score that has been normed on a representative sample. | Increases in standard scores
Quality of Life: Otitis Media 6 (OM-6) | Parent-reported scale measuring effects of OME on quality of life. | 1–7, higher scores associated with poorer quality of life. | Decreases

dB = decibels; OME = otitis media with effusion

## Results of Literature Searches

Figure 3 presents our literature search results. Initial literature searches completed on February 28, 2012, and updated on August 13, 2012, for the current report identified 4,967 unduplicated citations. Appendix A provides a list of all search terms used and the results of each literature search.

Figure 3 Disposition of articles on otitis media with effusion

^a^ We accepted the risk of bias assessment conducted by the review authors for the studies included in one of the 5 earlier systematic reviews (56 articles). We conducted our own risk of bias assessment for 17 new articles not included in one of those reviews.

^b^ One of the 5 included systematic reviews was updated during our peer review period. We reviewed both the original report and the update.

Figure 3 is a PRISMA tree that describes the steps and yield from each stage of this review. We identified 6,163 abstracts of which we excluded 4,207 during title and abstract review. We reviewed the full text for 764 studies and excluded studies for the following reasons: publication or study type (268), population (193), intervention (98), comparison (87), and same data included in recent systematic reviews (17). We assessed the risk of bias of 96 articles and 6 systematic reviews. One of the systematic reviews published an update during the period of our review and so both the original and the newer publication were evaluated for risk of bias. We excluded 24 articles from the analysis that were considered high risk of bias for benefits. One of these articles was included for harms. We included 59 studies (73 publications) and 5 systematic reviews in this report. Of the 73 included articles, 56 were included in one of the systematic reviews included as evidence and 17 were newly identified by our review team.

After applying our eligibility and exclusion criteria to titles and abstracts of all identified citations, 764 citations for full-text review remained. We reapplied our inclusion criteria and excluded 663 of these articles from further review before risk-of-bias assessment. Appendix B provides a list of excluded studies and reasons for exclusion at the full-text stage.

Of the 102 publications included after full-text review (96 articles and five systematic reviews [one systematic review was updated and so was included as 2 reports]), we dropped 24 articles from further analysis of benefits because of their high risk of bias but included 1 of these articles in our assessment of harms. Thus, we included a total of 73 articles (reporting on 59 studies) and data from 5 systematic reviews in qualitative synthesis; including 17 newly identified articles (reporting on 17 studies) and 56 articles identified in the earlier reviews (reporting on 42 studies). Evidence tables for these articles and systematic reviews are provided in Appendix C and risk-of-bias assessments for the newly identified articles can be found in Appendix D. Risk-of-bias assessments are also provided for the 24 high risk-of-bias studies in Appendix E.

Of the 59 studies included in this review, 49 were RCTs (33 by person, 12 by ear, 4 by person and ear), six were nonrandomized control trials (one by person and five by ear), and four were cohort studies. Of the 17 articles not included in one of the five systematic reviews, we assessed 15 as medium risk of bias, one as low risk of bias and one as high risk of bias. Of the five included systematic reviews, four were limited to RCTs. We assessed four systematic reviews as low risk of bias and one as medium risk of bias (Appendix E, Table E-3 presents details of these assessment).

A study by Paradise et al. was cited as evidence in two of the systematic reviews21,22 and is included as evidence within our review.67–74 This seminal study concerning TT for otitis media with effusion (OME) merits specific mention here because it was very influential. Investigators enrolled infants from birth to 2 months of age from a variety of clinical settings around Pittsburgh, Pennsylvania. The randomized subjects, who were from lower socioeconomic status backgrounds than the general population68 and mainly were African American or White, were recruited from both urban and rural areas.70 The study excluded children with other comorbid risk factors such as prematurity, being small for gestational age, serious illness, major congenital anomaly, or maternal limitations that may preclude their children from participating in the study. The study enrolled more than 6,000 subjects who were followed to determine if they met the criteria for OME. Once children were enrolled in the study, the investigators followed the sample to evaluate middle ear effusion (MEE) at least monthly using validated pneumatic otoscopy. Children were eligible for randomization if they had: bilateral OME for >90 days, unilateral OME for >135 days, or a more prolonged intermittent presence of OME up until age 3 years; and hearing thresholds less than 40dB (decibels).

Of those followed, 588 became eligible for randomization, and 429 were randomized and included in the study. The investigators randomized participants to either immediate or delayed TT insertion., By the time they received TT, the immediate treatment group had already had 3 months of OME and the delayed group had 9 months of OME (3 months prior to being randomized, followed by 6 months of delay) for bilateral effusion and 12 total months for unilateral OME (3 months prior to being randomized, followed by 9 months of delay). Children in the delayed group could get TT placement more quickly if parents preferred or if other clinical indications existed. Average age at randomization was 15 months. The analysis and interpretation of results were complicated by some of the early treatment group and a large number of the delayed group not receiving treatment. By 3 years of age, 83 percent of the early treatment group and 39 percent of the delayed treatment group had received TT.68 The study followed children until they were between 11 and 13 years of age with little attrition. Outcomes included clinical findings such as effusion and hearing and also functional outcomes such as developmental status and school performance.

## KQ 1 Comparative Effectiveness of Interventions: Clinical Outcomes or Health Care Utilization

### Surgical Interventions: Tympanostomy Tube Comparisons

#### Description of Studies

The included evidence about comparisons of different types of TT consisted of 14 studies, (eight studies from a recent systematic review by Hellstrom et al.21 and six additional studies). These are indicated in Table 6. All studies compared groups by “ears,” so that the participant acted as his or her own comparison, although one study also randomized by person. In some studies, the choice of ear that received a particular treatment was randomized and these are considered RCTs; in others, the choice of ear was based on “left” versus “right” ear or other criteria and these studies are considered nonrandomized trials if they meet other trial criteria.

Table 6 Characteristics of studies: Tympanostomy tube comparisons

Study, Study Type, Country | Arm N Randomized | Diagnosis Criteria | Wait Period Between Diagnosis and Study | Inclusion/Exclusion Criteria | Length of Followup | Age (Range) | Risk of Bias
Wielinga et al.,1990^83^ RCT by ear Ireland | G1: Goode Silicon tube (N=15) G2: Teflon Armstrong tube (N=15) | Otoscopy, PTA, tympanometry | ≤ 6 months | Include: OME, 6 months unsuccessful treatment with standard decongestive meds; mucoid secretion | Mean: 6.8 years | Male mean: 7 years Female mean: 6 years | Medium
Abdullah et al., 1994^84^ NRCT by ear England | G1: Trimmed high-grade silicone Shah permavent tube (N=25) G2: Polyethylene Shah tube (N=25) | NR | NR | Include: Age 3–10 years, de novo MEE Exclude: History of significant AOM | 29 months | Mean: 6 years (3–10 years) | Medium
Licameli et al., 2008^85^ RCT by ear United States | G1: Phophorylcholine-coated fluoroplastic Armstrong tube (N=70) G2: Uncoated fluoroplastic Armstrong tube (N=70) | NR | 3–4 months | Include: OME with 3–4 months medical management Exclude: Prior TT | 24 months | Mean: 19 months (8–51 months) | Medium
Iwaki et al., 1998^86^ Observational by ear Japan | G1: Teflon Shepard tube (N=75) G2: Silicone Goode-T tube (N=39) G3: Silicone Paparella II tube (N=106) | Audiometry, tympanometry and clinical history | 6 months | Include: 25 dB air-bone gap conductive HL, failed politerization and unsuccessful conservative management, retracted and glue-colored TM Exclude: children with craniofacial problems | 24 months | Mean: G1: 6.2 G2: 6.2 G3: 5.8 (3–12 years) | Medium
Ovesen et al., 2000^87^ RCT by person and by ear Demark | G1: TT^a^ + N-acetylcysteine instilled (N=37) G2: TT^a^ + placebo vehicle (N=38) | Otiomicroscopic examinations including tympanometry | 3 months | Include: OME, pressure <200mmHg Exclude: Recent antibiotics or AOM at time of surgery | 39 months | Mean: 38 months (1–7 years) | Medium
Slack et al., 1987^45,b^ Retrospective cohort by ear | G1: Shepard TT (N=214) G2: Shah TT (N=70) G3: Paparella TT (N=275) | NR | NR | Include: Children < 16 years old; TT inserted for OME in 1983 | Until extrusion or end of study period | Children < 16 years old | High
Hellstrom et al., 2011^21^ Systematic Review Hampal et al., 1991,^75^ Heaton et al.,1991,^76^ Hern and Jonathan, 1999,^77^ Youngs and Gartland, 1988,^78^ Pearson et al., 1996,^79^ Kinsella et al., 1994,^80,b^ Salam and Cable, 1993,^81,b^ and Hampton and Adams, 1996^82,b^ | Arms differ across 9 studies (arms appear in Table 7 and Table 31) (N=828 participants) | Varies by study | Minimum of 3 months | Include: RCTs (individual or ear), NRCTs, and cohort studies published between 1966 and 2007 of effectiveness of TT on hearing, language development, QOL and of complications | Various | Children or adolescents, one study included an unknown mix of adults and children79 | Medium

AOM = acute otitis media; dB = decibels; G = group; HL= hearing loss; MEE = middle ear effusion; mmHg = millimeters of mercury; mos = months; N = number; NR = not reported; NRCT = nonrandomized controlled trial; OME = otitis media with effusion; PTA = pure-tone audiometry; QOL = quality of life; RCT = randomized controlled trial; TM = tympanic membrane; TT = tympanostomy tubes; tx = treatment

a Tympanostomy tube type not specified.

b Study included for harms (KQ 3) only.

Of the TT comparison studies included in the Hellstrom systematic review, five studies provide evidence for KQ 1.^75–79^ Three additional TT comparison studies in the Hellstrom review were limited to harms and are discussed in relation to KQ 3.^80–82^ We identified six additional studies; five of these provide evidence for KQ 1.^83–87^ One other TT comparison study provides evidence for harms only.45

Of the 10 studies that provided evidence for KQ 1, seven are RCTs; four of these were included in the Hellstrom review75–78 and we identified three additional studies.83,85,87 Hellstrom included one nonrandomized controlled trial,79 and we identified a second.84 One observational study was a retrospective medical record review.86

TT comparisons included tube design (shape or size), materials, and routes or techniques for insertion. TT are often categorized by length of time they can be expected to stay in place—broadly speaking, short- or long-term. Short term tubes have an average extrusion time of 8 months to 16 months while long-term tubes have average extrusion rates from 18 months to 3 years or until they are removed by a surgeon.24,88,89 Virtually all evidence is limited to children and only one study identified that a portion of the sample included children less than 1 year of age.85

#### Key Points

We found that variation in length of retention corresponded to whether TT were designed to be short versus long-term. Evidence for other comparisons was sparse: tube size and material, approach to insertion, and topical prophylaxis therapies.

OME recurrence was inconsistently associated with length of retention (insufficient strength of evidence). No studies compared OME recurrence based on other design features (strength of evidence insufficient because of no evidence).

Hearing outcomes did not differ between short- and long-term TT in two studies (strength of evidence insufficient because of sparse and imprecise data).

No studies compared vestibular outcomes, or health care service use as a function of type of TT or routes or techniques in their insertion (strength of evidence insufficient because there are no studies).

#### Detailed Synthesis

Types of TT were compared in relation to clinical outcomes including tube retention time, OME recurrence, and hearing (Table 7). Included studies compare outcomes based on TT design TT material, and TT placement position and technique.

Table 7 Clinical outcomes: Tympanostomy tube comparisons

Study | Arm (N Randomized) | Study Duration Until Outcome Measurement (N Analyzed if Reported) | Tube Retention (% Retained Unless Otherwise Noted) | OME Recurrence | Measured Hearing
Wielinga and Smyth, 1990^83^ | G1: Goode Silicon tube (N=15) G2: Teflon Armstrong tube (N=15) | NA | Mean months (range): G1: 52.5 (5–88) G2:17.5 (1–56) p=NR | NR | Mean hearing loss: G1: 14dB G2: 11dB p=NR
Wielinga and Smyth, 1990^83^ | G1: Goode Silicon tube (N=15) G2: Teflon Armstrong tube (N=15) | Year 1 | G1: 93 G2: 67 p=NS | NR | NR
Wielinga and Smyth, 1990^83^ | G1: Goode Silicon tube (N=15) G2: Teflon Armstrong tube (N=15) | Year 2 | G1: 80 G2: 13 p<0.05 | NR | NR
Wielinga and Smyth, 1990^83^ | G1: Goode Silicon tube (N=15) G2: Teflon Armstrong tube (N=15) | Year 3 | G1: 73 G2: 7 p<0.05 | NR | NR
Wielinga and Smyth, 1990^83^ | G1: Goode Silicon tube (N=15) G2: Teflon Armstrong tube (N=15) | Year 4 | G1: 53 G2: 7 p<0.05 | NR | NR
Wielinga and Smyth, 1990^83^ | G1: Goode Silicon tube (N=15) G2: Teflon Armstrong tube (N=15) | Year 5 | G1: 33 G2: 0 p=NS | NR | NR
Wielinga and Smyth, 1990^83^ | G1: Goode Silicon tube (N=15) G2: Teflon Armstrong tube (N=15) | Years 6 and 7 | G1: 27 G2: 0 p=NS | NR | NR
Abdullah et al., 1994^84^ | G1: Trimmed high grade silicone Shah permavent tube (N=25) G2: Polyethylene Shah tube (N=25) | Month 12 (N=25) | G1: 100 G2: 56 p=NR | NR | NR
Abdullah et al., 1994^84^ | G1: Trimmed high grade silicone Shah permavent tube (N=25) G2: Polyethylene Shah tube (N=25) | Month 29 (N=17) | G1: 71^a^ G2: 18^a^ p=NR | G1: 6%^a^ G2: 53% p=NR | NR
Licameli et al., 2008^85^ | G1: Phophorylcholine-coated fluoroplastic Armstrong tube (N=70) G2: Uncoated fluoroplastic Armstrong tube (N=70) | Year 2 | G1: 21 G2: 28 p=0.84 | NR | NR
Iwaki et al., 1998^86^ | G1: Teflon Shepard tube (N=75) G2: Silicone Goode-T tube (N=39) G3: Silicone Paparella II tube (N=106) | Seen at 1–3 month intervals postsurgery and at 1–3 month post-tube removal or extrusion | Mean months: G1: 5.9 G2: 10.7 G3: 15.1 p=NR | NR | NR
Iwaki et al., 1998^86^ | G1: Teflon Shepard tube (N=75) G2: Silicone Goode-T tube (N=39) G3: Silicone Paparella II tube (N=106) | 24 months | G1: 9.3 G2: 20.5 G3: 50 p=NR | G1: 40% G2: 28.2% G3: 17.0% p<0.01 | NR
Ovesen et al., 2000^87^ | G1: TT^b^ + N-acetylcysteine instilled (N=37) G2: TT^b^ + placebo vehicle (N=38) | Mean months (range): 16.5^a^ (11 to 39) | Mean months: G1: 9 G2: 7 p>0.14 | Total # episodes G1:15 G2: 25 p=NR Persistent OME: G1: 13.5% G2: 37% p<0.025 Recurrence at single examination postextrusion: G1: 16% G2: 13% p=NR | NR
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Hampal et al., 1991^75^ G1: Shah tube (N=116 ears) G2: Mini-Shah (N=116 ears) | Year 1 (N=91) | G1: 70% G2: 6% p<0.001 | G1: 7% G2: 18% p<0.05 | Mean threshold at 1 year: (N=64) G1:17.5 dB G2:18.4 dB p=0.34 Mean threshold at 2 years: (N=69) G1: 17.2 dB G2: 17.1 dB p=NS
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Heaton, et al., 1991^76^ G1: Shepard tube G2:Sheehy tube (Total=292 ears) | 21–36 months (N=124) | G1: 8% G2: 24%^a^ p<0.001 | G1:38 (29%) G2:28 (21%)^a^ p = NS | NR
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Heaton, et al., 1991^76^ (second study analysis combines TT types) G1: Anteroinferior placement of TT in TM (N=191 ears) G2: Posteroinferior placement of TT in TM (N=71 ears) | 1–12 months post-TT extrusion | G1 remaining in situ longer than G2 whichever TT was used p=0.002 Shepard: G1: 9% vs. G2: 6% Sheehy: G1: 29% vs. G2: 8% | NR | NR
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Hern and Jonathan, 1999^77^ G1: Shah TT placed in anterosuperior quadrant (N=54 ears) G2: Shah TT placed anteroinferior quadrant (N=54 ears) | 3–26 months until extrusion | Mean months: G1: 12.7 months G2: 13.7 months Diff: 1 (95% CI, −2.96 to 0.96) | NR | NR
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Youngs and Gartland, 1988^78^ Companion: McRae, et al.,1989^90^ G1: Shah Teflon tube + aspiration before placement (N=55 ears) G2: Shah Teflon tube (no aspiration) (N=55 ears) | 1 month (N=53) | G1: 98% G2: 98% | | Audiometric improvement at the 5% level: (N=51) G1 vs. G2: no difference
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Youngs and Gartland, 1988^78^ Companion: McRae, et al.,1989^90^ G1: Shah Teflon tube + aspiration before placement (N=55 ears) G2: Shah Teflon tube (no aspiration) (N=55 ears) | 3 months | G1: 46 (90%) G2: 47 (92%) p=1.0 | NR | Audiometric improvement at the 5% level: (N=51) G1 vs. G2: no difference
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Youngs and Gartland, 1988^78^ Companion: McRae, et al.,1989^90^ G1: Shah Teflon tube + aspiration before placement (N=55 ears) G2: Shah Teflon tube (no aspiration) (N=55 ears) | 6 months | G1: 39 (76%) G2: 41 (80%) p=0.71 | NR | NR
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Youngs and Gartland, 1988^78^ Companion: McRae, et al.,1989^90^ G1: Shah Teflon tube + aspiration before placement (N=55 ears) G2: Shah Teflon tube (no aspiration) (N=55 ears) | 12 months | G1: 24 (47%) G2: 21 (41%) p=0.71 | NR | NR
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Youngs and Gartland, 1988^78^ Companion: McRae, et al.,1989^90^ G1: Shah Teflon tube + aspiration before placement (N=55 ears) G2: Shah Teflon tube (no aspiration) (N=55 ears) | 18 months | G1: 4 (7.8%) G2: 3 (5.8%) p=1.0 | NR | NR
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Youngs and Gartland, 1988^78^ Companion: McRae, et al.,1989^90^ G1: Shah Teflon tube + aspiration before placement (N=55 ears) G2: Shah Teflon tube (no aspiration) (N=55 ears) | 3 months | G1: 143 (96%) G2: 143 (96%) p=NS^a^ | Bilateral effusion^a^ G1: 5 (5.4%) G2 10 (10.9%) | Hearing gain (N=165) G1: 13.6 dB G2: 12.9 dB p=NS
Hellstrom et al., 2011^21^ Systematic Review | 1 NRCT (by person) Pearson et al., 1996^79^ G1: Teflon Shah TT + steroid/abx otic drops postoperatively G2: Teflon Shah TT (N=165) | 3 months | G1: 143 (96%) G2: 143 (96%) p=NS^a^ | Bilateral effusion^a^ G1: 5 (5.4%) G2 10 (10.9%) | Hearing gain (N=165) G1: 13.6 dB G2: 12.9 dB p=NS

abx= antibiotic; CI = confidence interval; dB = decibel; Diff = difference; G = group; N = number; NA = not applicable; NR = not reported; NRCT = nonrandomized controlled trial; NS = not significant; OME = otitis media with effusion; RCT = randomized controlled trial; TM = tympanic membrane; TT = tympanostomy tube; vs. = versus

a Calculated by investigator.

b Tympanostomy tube type not specified.

##### Tube Retention and OME Recurrence

We identified five studies that compared outcomes based on TT design. Three of these studies compared long-term with short-term TT types. Wielinga et al. compared silicon Goode-T tubes (considered long-term TT) and Teflon Armstrong TT (considered short-term TT) and demonstrated that the average retention of the Goode-T tubes was longer, an average of 52 months (range: 5–88 months) while the Teflon Armstrong TT were retained an average of 17 months (range: 1–56 months). Another RCT compared Sheehy TT (considered long term) and Shepard TT (considered short term).76 The Sheehy TT were retained significantly longer than the Shepard TT; at up to 36 months, 24 percent of ears retained the Sheehy TT, as did 8 percent of ears with the Shepard. An observational study also compared TT types considered long term (Goode-T tubes and Paparella II tubes) and short term (Shepard Teflon tubes).86 The Paparella II TT was retained for 15 months, the Goode-T tubes were retained for almost 11 months, and the Shepard TT were retained for six months. Statistical differences were not reported in this study.

An RCT of 116 participants compared two types of Shah TT, the standard Shah and the mini-Shah; the standard Shah TT had significantly longer retention; at 1 year, 70 percent of those with the Shah retained their TT and 6 percent of those with the mini-Shah.75 A second comparison of Shah TT demonstrated that at 29-month followup, silicone permavent tubes had a 71 percent retention rate as contrasted with an 18 percent rate for the polyethylene Shah tubes.84

Four studies examined TT retention based on TT placement technique or position. One small study (N=54) compared anteroinferior versus anterosuperior placement location of Shah (short acting) TT and found that it did not affect length of time that the TT stayed in place (mean months: 12.7 vs. 13.7).77 In contrast, in a second larger study of Shepard and Sheehy TT (N=292 ears) anteroinferior placement was retained longer than anterosuperior placement.76

N-acetylcysteine infused at the time of insertion was not found to change retention time.87 A second study reported that infusion of steroid and antibiotic combined otic drops infused at the time of surgery did not change retention rate at 3 months.79

One study compared extrusion rates based on material of the TT, Armstrong TT (considered short term), with and without phosphorylcholine-coated fluoroplastic. Rates did not differ appreciably at 2-year followup (21% vs. 28%, respectively, p=0.84).85

OME recurrence was inconsistently associated with length of retention. Two studies reported a higher rate of OME recurrence in the TT that had a shorter retention: mini-Shah TT (18%) versus Shah (7%),75 and Shepard (40%) versus Goode-T (28%) versus Paperella (17%).86 One study76 that reported a difference in retention rates, did not find a reduction in OME recurrence associated with longer lasting TT. Another study83 with differences in retention rates did not examine OME recurrence. Results were measured at different end points and generally, the samples were small.

##### Measured Hearing

Two studies compared hearing outcomes based on TT design. Hampal et al.75 found no differences between Shah and mini-Shah TT in hearing thresholds at 1 and 2 years after placement.75 Similarly, Wielenga and Smith compared short-term (Armstrong) and long-term (Goode-T) TT, and found no differences in mean hearing loss.83

Two studies examined hearing outcomes by technique of tube insertion. Youngs and Gartland (1988) failed to find a difference in hearing outcomes based on aspiration before TT placement.78 Similarly, infusion of steroid and antibiotic drops at the time of TT placement did not change hearing outcomes at up to 30 months after placement.79

### Surgical Interventions: Tympanostomy Tubes Versus Watchful Waiting or Myringotomy

#### Description of Studies

The evidence consisted of 12 studies, all of which were RCTs (Table 8). Two recent systematic reviews, one of which was a Cochrane review by Browning et al.22 included 10 studies and the second was by Hellstrom et al.,21 which included six of the studies in the Browning review (three additional reports of later followup of studies included in Browning review). We identified two additional studies through our search.91,92 We also found later published results of the Medical Research Council (MRC) Trial of Alternative Regimens in Glue Ear Treatment (TARGET) study. The study’s preliminary findings were included in the Browning review.19 We also present outcomes in this section that were reported in later follow-up papers of Paradise and colleagues but were not discussed in either the Browning or the Hellstrom reviews.

Table 8 Characteristics of studies: Tympanostomy tubes versus watchful waiting or myringotomy

Study, Study Type Country | Arm (N Randomized) | Diagnosis Criteria | Wait Period Between Diagnosis and Study | Inclusion/Exclusion Criteria | Length of Study Followup | Age | Risk of Bias
Browning et al., 2010^22^ Systematic Review Maw et al.,1999,^93^ MRC TARGET, 2001 and 2012,^19^ Rovers et al., 2000,^94^ Gates et al., 1987,^95^ Mandel et al., 1992,^96^ Paradise et al., 2001,^68^ Black et al., 1990,^97^ Dempster et al.,1993,^98^ Maw and Herod, 1986,^99^ and Rach et al., 1991^100^ | Arms differ across comparisons: 10 trials (1,728 participants) | Combination of otoscopy (including pneumatic and microscopic), tympanometry and audiometry | NR | Include: RCTs of short-term TT; randomization could be by child or by ear Exclude: Observational studies or NRCTs; studies including adenoidectomy (unless the adenoidectomy arms could be excluded) | Child: 6–9 and 12 months Ear: 4–6, 7–12 months | 1 to12 years | Low
Koopman et al., 2004^91^ RCT by ear Amsterdam | G1: Donaldson or Goode TT + cold knife myringotomy (N=208) G2: Laser myringotomy (N=208) | Binocular otoscopy tympanometry and audiometry | 3 months | Include: Bilateral OME; <11 years; 3 months of hearing problem per parent report Exclude: Unilateral OME; uncooperative; clinically admitted patients; asymmetric perceptive HL; previously operated ears with other than myringotomy or TT | 6 months | <11 years | Medium
Mandel et al., 1989^92^ RCT, clustered first by HL United States | Without significant HL G1: Myringotomy (N=27) G2: Myringotomy + Armstrong TT (N=30) G3: No surgery (N=29) With significant HL G4: Myringotomy (N=12) G5: Myringotomy + Armstrong TT (N=11) | Tympanometry and middle ear muscle reflex testing | 2 months and medical treatment | Include: MEE ≥2 months duration persisting after a 14 day course of antimicrobial and pseudoephedrine Exclude: craniofacial malformations; systemic illnesses; history of ear surgery | 3 years | 7 months to 12 years | Medium

G = group; HL= hearing loss; MEE = middle ear effusion; MRC = Medical Research Counsel; N = number; NR = not reported; NRCTs = nonrandomized controlled trials; OME = otitis media with effusion; RCT = randomized controlled trial; TARGET = Trial of Alternative Regimens in Glue Ear Treatment; TT = tympanostomy tubes; yrs = years

Watchful waiting, also known as active monitoring, is defined as a period of time in which no surgery is performed; the patient’s condition is monitored at specified periods; if the OME or sequelae worsen, treatment could be initiated. Delayed treatment with TT was the strategy used in the RCT of Paradise et al., 2001^68^ and was defined as providing TT after a delay of 6 months for bilateral OME and 9 months for unilateral OME if the effusion persisted.

The Browning et al. review summarized 10 RCTs of TT in treating children with OME; seven of which were in comparison with watchful waiting or delayed treatment68,93,94,98–101 and two were in comparison with myringotomy in the control ear;95,97 Mandel96 examined both myringotomy and watchful waiting (separately) in relation to TT. While Hellstrom21 reviewed six RCTs comparing TT with watchful waiting or myringotomy that were all included in the Browning et al. review, data on hearing outcomes from Gates et al., 1989^102^ were only reported in the Hellstrom review.21

We identified two additional studies that compared TT placement with either myringotomy and/or watchful waiting.91,92 Mandel92 compared 3-year outcomes in children who received TT, myringotomy or no surgery as well as outcomes in a small group of children with conductive hearing loss who received either TT or myringotomy. Koopman et al. examined children who received TT and laser myringotomy in randomized ears, following the children through 6 months post-treatment.91

All of these 12 RCTs were of children, most of whom were younger than 12 years of age but older than 1 year (except for the Paradise et al., 2001 study where participants could have been as young as 3 months). None of the studies included children with any medical conditions such as cleft palate or Down syndrome.

#### Key Points

- Meta-analyses found that TT placement was associated with less time with MEE compared with watchful waiting or delayed treatment, at 1 year (32% less time) (strength of evidence high), less time with MEE compared with myringotomy at 1 year (42% less time) (strength of evidence moderate), and less time with MEE compared with watchful waiting or myringotomy at 2 years (13% less time) (strength of evidence moderate) (Table 9). Evidence was only available based on one small study comparing TT with either myringotomy or watchful waiting at 3 years post-treatment (insufficient strength of evidence).
- In relation to improved hearing, comparing TT placement with watchful waiting, a meta-analysis of three studies combined with qualitative synthesis of one additional study showed improved hearing with TT in comparison with watchful waiting at up to 9 months post-treatment. Strength of evidence is high.
- No significant differences in hearing between TT and watchful waiting were detected in two meta-analyses at longer followup of 12 and 18 months post-treatment; Strength of evidence is moderate.
- Based on a meta-analysis of three studies with ears randomized, TT placement improved hearing up to 6 months followup in relation to a comparison group of watchful waiting or myringotomy (Strength of evidence is high).
- No significant differences in hearing between TT placement and watchful waiting or myringotomy were detected at longer followup of 7 to 12 months after treatment, based on a meta-analysis of three studies by ear (Strength of evidence is low).
- One small RCT comparing TT and myringotomy examined differences in hearing at 24 months post-treatment (Strength of evidence is insufficient).
- Only one small RCT examined acute otitis media (AOM) outcomes. Strength of evidence is insufficient.
- We found no evidence concerning vestibular or health care use outcomes. Strength of evidence is insufficient.

Table 9 Strength of evidence for KQ 1: Clinical outcomes and health care utilization

Treatment Comparison | OME Signs and Symptoms | Objective Hearing | AOM | Balance | Health Care Utilization
TT vs. watchful waiting | High 1 MA (3, 574) 32% less time with TT at 1 year Insufficient 1, 119 No difference at 3 years | High 1 MA (3, 523); 1, 248 Better hearing with TT at 3–6 months of 8.8 dB and 6–9 months of 4.2 dB Low 1 MA (2, 328), 1 MA (2, 283) 1, 248 No difference in hearing, by child, at 12, 18, and average of 12, 18, and 24 months Insufficient 1, 281 No difference at 5 years of age Insufficient One study by ear (N=72) at 24 months | Insufficient 1 study | Insufficient (No studies) | Insufficient (No studies)
TT vs. myringotomy | Moderate 2, 294 Up to 42% less time with MEE through 1 year Insufficient 1 study at 2 and 3 years | | NR | NR | NR
TT vs. WW or myringotomy | Moderate 1 MA (3, 426) 13% less time with TT at 2 years | High 1 MA (3, 230 ears) Better hearing with TT at 4–6 months of 10 dB Low 1 MA (3, 232 ears) No difference at 7–12 months Insufficient 1 study at 24 months | NR | NR | NR

MEE = middle ear effusion; myr = myringotomy; OME = otitis media with effusion; TT = tympanostomy tubes; WW = watchful waiting

#### Detailed Synthesis

##### Duration of Middle Ear Effusion

Two meta-analyses conducted by Browning et al., 2010^22^ and two additional single studies (Koopman et al., 2004^91^ and Mandel et al., 1989^92^) found superior results concerning MEE with TT compared with myringotomy, watchful waiting, and/or delayed tubes measured at different endpoints, with either ears or participants randomized (Table 10).

Table 10 Clinical outcomes: Tympanostomy tubes versus watchful waiting or myringotomy

Study | Arm (N) | Study Duration Until Outcome Measurement | Middle Ear Effusion/Time With Effusion/AOM | OME Recurrence/Ventilation | Measured Hearing
Browning et al., 2010^22^ | MA:3 studies Maw et al.,1999^93^ MRC TARGET, 2001^103^ Rovers et al., 2000^94^ (N=523) | 6–9 months | NR | NR | Bilateral TT vs. WW: Mean Diff: − 4.20 (95% CI, −6.00 to −2.39) (favors tube)
Browning et al., 2010^22^ | MA: 3 studies Mandel et al., 1992^96^ Paradise et al., 2001^68^ Rovers, 2000^94^ (N=574) | 12 months | Bilateral TT vs. delayed treatment or WW: Mean diff: −0.32 (95% CI, −0.48 to −0.17) (favors tube) | NR | NR
Browning et al., 2010^22^ | MA: 2 studies MRC TARGET, 2001^103^ Rovers et al., 2000^94^ (N=328) | 12 months | NR | NR | Bilateral TT vs. WW: Mean Diff − 0.41 (95% CI, −2.37, 1.54)
Browning et al., 2010^22^ | MA: 2 studies Maw et al.,1999^93^ MRC TARGET, 2001^103^ (N=283) | 18 months | NR | NR | Bilateral TT vs. WW Mean Diff: −0.02 (95% CI, −3.22, 3.18)
Browning et al., 2010^22^ | MA: 3 studies Gates et al., 1987^95^ Mandel et al., 1992^96^ Paradise et al., 2001^68^ (N=426) | 2 years | Billateral TT vs. myringotomy, delayed treatment or WW: Mean diff: −0.13 (95% CI, −0.17, −0.08) (favors TT) | NR | NR
Browning et al., 2010^22^ | 1 study MRC TARGET, 2012^19^ TT (N=126) WW (N=122) | 3–6 months average | NR | NR | Bilateral TT vs. WW Mean diff=− 8.8 dB (95% CI, −7.1 to −10.5) (favors tube)
Browning et al., 2010^22^ | 1 study MRC TARGET, 2012^19^ TT (N=126) WW (N=122) | 12, 18, 24 months average | NR | NR | Bilateral TT vs. WW Mean diff= −0.7 dB (statistics not reported)
Browning et al., 2010^22^ | 1 study MRC TARGET, 2012^19^ TT (N=126) WW (N=122) | 3 months to 2 years average | NR | NR | Bilateral TT vs. WW Mean diff = 2.9 dB (statistics not reported)
Browning et al., 2010^22^ | 1 study Johnston, et al., 2004^104^ G1: Early TT (N=147) G2: Late TT (N=134) | 5–6 years of age | | | Early TT vs. Late TT Left Ear: G1 = 6.2 G2 = 5.5 Mean Diff=−0.7, p=0.13 Right Ear G1: 6.2 G2: 6.0 Mean Diff = −.0.2 p=0.80
Browning et al., 2010^22^ | MA: 3 studies Black et al., 1990,^97^ Dempster et al.,1993,^98^ and Maw and Herod, 1986^99^ (N=230 ears) | 4 to 6 months | NR | NR | Unilateral TT vs. WW (2 studies) or myringotomy (1 study): Mean Diff: −10.08 (95% CI, −19.12, to −1.05) (favors tube)
Browning et al., 2010^22^ | MA: 3 studies Black et al., 1990^97^ Dempster et al.,1993^98^ Maw and Herod, 1986^99^ (N=234 ears) | 7 to 12 months | NR | NR | Unilateral TT vs. WW (2 studies) or myringotomy (1 study): Mean Diff: −5.18 (95% CI, −10.43, 0.07)
Browning et al., 2010^22^ | 1 study (by ears) Black et al, 1990^97^ Unilateral TT: (N=74) Myringotomy: (N=37) No surgery: (N=37) | 24 months | NR | NR | Unilateral TT vs. myringotomy: Mean Diff: −3.4 (95% CI, −1.1 to 8.0) Unilateral TT vs. no surgery: Mean Diff: −0.5 (95% CI, −3.7 to 4.6)
Koopman et al., 2004^91^ | G1: Donaldson or Goode TT + cold knife myringotomy (N=208) G2: Laser myringotomy (N=208) | 1 month | Absence of effusion G1: 87.4% G2: 46.6% | NR | NR
Koopman et al., 2004^91^ | G1: Donaldson or Goode TT + cold knife myringotomy (N=208) G2: Laser myringotomy (N=208) | 2 months | G1: 81.9% G2: 35.5% | NR | NR
Koopman et al., 2004^91^ | G1: Donaldson or Goode TT + cold knife myringotomy (N=208) G2: Laser myringotomy (N=208) | 3 months | G1: 81.5% G2: 38.6% | NR | NR
Koopman et al., 2004^91^ | G1: Donaldson or Goode TT + cold knife myringotomy (N=208) G2: Laser myringotomy (N=208) | 4 months | G1: 75.5% G2: 41.6% | NR | NR
Koopman et al., 2004^91^ | G1: Donaldson or Goode TT + cold knife myringotomy (N=208) G2: Laser myringotomy (N=208) | 5 months | G1: 68.5% G2: 39.1% | NR | NR
Koopman et al., 2004^91^ | G1: Donaldson or Goode TT + cold knife myringotomy (N=208) G2: Laser myringotomy (N=208) | 6 months | G1: 70.7% G2: 39.1% all p<0.001^a^ | NR | NR
Mandel et al., 1989^92^ | Without significant HL G1: Myringotomy G2 :Myringotomy + Armstrong TT G3: WW With significant conductive HL G4: Myringotomy G5: Myringotomy + Armstrong TT | 2 months | NR | NR | SRT in dB Right ear G1: 18.5 G2: 16.2 G3: 6.2 G4: 22.0 G5: 5.5
Mandel et al., 1989^92^ | Without significant HL G1: Myringotomy G2 :Myringotomy + Armstrong TT G3: WW With significant conductive HL G4: Myringotomy G5: Myringotomy + Armstrong TT | 1 year | % Time with OME G1: 56.6% G2:16.4% G3: 56.3% G4: 56.7% G5: 9.8% G1 or G3 vs. G2: p<0.001 G4 vs. G5: p<0.001 | NR
Mandel et al., 1989^92^ | Without significant HL G1: Myringotomy G2 :Myringotomy + Armstrong TT G3: WW With significant conductive HL G4: Myringotomy G5: Myringotomy + Armstrong TT | 2 years | G1: 35.2% G2: 20.4% G3: 28.2% G4: 39.9% G5: 28.3% p=NS | NR | NR
Mandel et al., 1989^92^ | (N=93) | 3 years | G1: 25.5% G2: 25.0% G3: 19.2% G4: 14.4% G5: 30.3% p=NS AOM Episodes/person-year G1: 0.58 G2: 0. 18 G3: 0.38 G4: 0.31 G5: 0.41 G2 reported to have fewer episodes than G1 or G3 | NR | NR

AOM = acute otitis media; CI = confidence interval; dB= decibels; Diff = difference; G = group; HL = hearing loss; MA = meta-analysis; MRC = Medical Research Council; N = number; NR = not reported; NS = not significant; OME = otitis media with effusion; SRT = speech related threshold; TARGET = Trial of Alternative Regimens in Glue Ear Treatment; TT = tympanostomy tube; WW = watchful waiting; vs.= versus

a p values calculated by investigators.

One meta-analysis of three studies conducted by Browning et al., 2010^22^ found that bilateral TT reduced time with effusion compared with watchful waiting/delayed TT placement. The reduction was 32 percent at 1 year post-treatment (95% CI, 17% to 48%). A study by Mandel et al., 1989^92^ similarly found that TT were superior to watchful waiting at 1 year post-treatment (40 percentage point difference).

Two studies found that TT were superior to myringotomy alone. Koopman et al., 2004^91^ reported superiority through 6 months post-treatment (42 percentage point difference), and Mandel reported superiority through 1 year post-treatment (40 percentage point difference).92 These studies were not included with the meta-analysis because their comparisons or time frame were different than those in the meta-analysis of the Browning et al., 2010 systematic review.

A second meta-analysis reported in Browning et al.22 examined time with MEE at 2 years post-treatment in children with TT compared with children who had myringotomy, delayed TT, or no surgery; findings showed a difference of 13 percent favoring the TT group (95% CI, 8% to 17%). Mandel et al., 1989,^92^ who examined TT in comparison to myringotomy and watchful waiting separately, reported a difference between TT and both myringotomy and watchful waiting at 1 year but no statistically significant difference in time with OME at either 2 or 3 years post-treatment. The percentage of time with effusion declined over time in the watchful waiting and myringotomy groups but increased in the TT group so that by 3 years, the time was similar across the three groups.

##### Measured Hearing

Five meta-analyses presented in the Browning et al. review (2010)22 and data from four individual studies19,92,97,104 reported hearing outcomes. These analyses compared TT with watchful waiting, delayed TT, and/or myringotomy.

One meta-analysis of 3 studies reported in Browning showed a significant improvement in hearing in the TT arm compared with watchful waiting at 6–9 months of −4.2 dB (95% CI, −6.00 to −2.39). However, results of two meta-analyses at 12 and 18 months did not find that TT were superior to watchful waiting (12 months: −0.41 dB [95% CI, −2.37 to 1.54]; 18 months: −0.02 dB [95% CI, −3.22 to 3.18]). Results reported in the MRC TARGET study (2012)19 also provide evidence of an early advantage for TT in comparison with watchful waiting (3- and 6-month average followup: 8.8 dB [95% CI, 7.1 to 10.5]) that did not persist at later followup of up to 24 months (statistics not reported). Johnston et al.,104 reporting data from the Paradise and colleagues RCT, did not find differences in hearing between children who received early TT and those who received late TT when they were between 5 to 6 years of age (TT insertion ranged from 3 months of age to 3 years of age) (left ear: −0.7 dB, p=0.13; right ear: −0.2 dB, p=0.80).

Two meta-analyses included three studies randomized by ear that compared TT with either watchful waiting or with myringotomy (combined) at 4 to 6 months and at 7 to 12 months. Only the MA at 4 to 6 months found an advantage for TT (−10.18 dB [95% CI, −19.12 to −1.05]). At 7 to 12 months the advantage disappeared (−5.18 dB [95% CI, −10.43 to 0.07]). In addition, another study randomized by ear (Black et al., 1990^97^) failed to find differences between TT and either myringotomy (3.4 dB [95% CI, −1.1 to 8.0]) or watchful waiting (0.5 dB [95% CI, −3.7 to 4.6)] at 24 month followup.

##### Recurrent AOM

After 3 years of observation, even though rates in all groups were low, children who had received TT had fewer episodes per person year of AOM after placement (0.18) compared with children with myringotomy alone (0.58) and those who had not had surgery (0.38).92

### Surgical Interventions: Tympanostomy Tubes Plus Adenoidectomy Versus Myringotomy Plus Adenoidectomy or Adenoidectomy Alone

#### Description of Studies

The evidence comparing the effectiveness of TT with myringotomy or no surgery when added to adenoidectomy was contained in 11 studies (Table 11). Hellstrom et al.21 included four studies in which the participants in both arms received adenoidectomy and one arm also received TT.105,102,106,107 Another report (Tos and Stangerup [1989]108) that was a followup to the Bonding and Tos (1985) study105 reported in Hellstrom was also included.

We identified an additional seven studies109–115 The studies were all of children. Although one study included children as young as 1 year of age, most studies included children who were at least 3 years of age.

Four of the 11 studies (12 reports) compared outcomes by ears in which one ear received TT and the other ear received no surgery, among children who all had adenoidectomies.106,109–111 Three studies (four articles) compared outcomes by ears with TT with ears with myringotomy, among children who all had adenoidectomies.105,107,108,114 Of these, Maw and Bawden107 included participants who had received either adenotonsillectomy or adenoidectomy; in this study, children were randomized to adenoidectomy/adenotonsillectomy or not prior to randomizing ears to a unilateral TT or no TT. Four studies randomized children (in contrast to ears) to TT or myringotomy; all participants also had adenoidectomies.102,111,112,115 No studies included children with comorbid conditions. Length of study followup generally ranged from 2 days to 12 months. However, one study followed patients for 10 years.107

Table 11 Characteristics of studies: Tympanostomy tubes and adenoidectomy versus watchful waiting or myringotomy and adenoidectomy or adenoidectomy alone

Study, Study Type, Country | Arm (N) | Diagnosis Criteria | Wait Period Between Diagnosis and Study | Inclusion/Exclusion Criteria | Length of Study Followup | Age (range) | Risk of Bias
Brown et al., 1978^109^ RCT by ear Wales | G1: Shepard TT + adenoidectomy (N=55) G2: Adenoidectomy (N=55) | Medical history, Otoscopy, Audiometry | Not specified | Not specified | 48 hrs, 3, 6, 9, 12 months, 5 years | 4–10 years | Medium
Austin, 1994^110^ NRCT by ear United States | G1: TT^a^ + adenoidectomy (N=31) G2: Adenoidectomy (N=31) | Audiometry | Not specified | Include: OME; Indication for adenotonsillectomy; resistant to ENT or pediatric management | 3 months | NR | Medium
Lildholdt, 1979^111^ NRCT by ear Denmark | G1:Donaldson TT+ adenoidectomy (N=91) G2: Adenoidectomy (N=91) | Tympanometry and audiometry | Not specified | Include: Bilateral OME; minimal between ear difference in pressure and hearing Exclude: Previous ear surgery | Until extrusion, 8 months | Mean: 4 years (1–10 years) | Medium
D’Eredita and Shah, 2006^112^ RCT by person Italy | G1: Shah mini TT + adenoidectomy (N=15) G2: CDLM + adenoidectomy (N=15) | Tympanometry | 3 months | Include: OME for 3 months Exclude: History of prior surgery, craniofacial syndrome, MR or cognitive disorder | 12 months | Mean: 4 years (2–6 years) | Medium
Popova et al., 2010^113^ RCT by person Bulgaria | G1: Donaldson TT + adenoidectomy (N=42) G2: Myringotomy + adenoidectomy (N=36) | Pneumatic otoscopy and tympanometry | 3 months | Include: OME for 3 months; conductive HL >20 dB Excluded: Previous ear or throat surgery; craniofacial syndromes; destructive middle ear disease; conductive HL attributed to destructive middle ear changes; sensorineural HL | 12 months | Mean: G1: 60 months G2: 61 months | Medium
Shishegar and Hobhoghi, 2007^114^ RCT by ear Iran | G1: Shepard TT + adenoidectomy (n=30) G2: Myringotomy + adenoidectomy (N=30) | Otoscopy, tympanometry, audiometry | Not specified | Include: OME unresponsive to medical therapy Exclude: Prior ear surgery or adenoidectomy; cleft palate; perforated TM | 6 months | 4–8 years | Medium
Vlastos et al., 2011^115^ RCT by person Greece | G1: Shepard TT + adenoidectomy (N=25) G2: Adenoidectomy + myringotomy (N=27) | Otoscopy, tympanometry, pure tone audiometry | Not specified | Include: Bilateral OME; scheduled for adenoidectomy due to sleep apnea; >3 yrs age Excluded: chronic OME; previous ear surgery; language delays; behavioral problems; anatomic changes | 12 months | Mean: G1: 4.6 years (3–7 years) G2: 4.4 years (3–7 years) | Medium
Hellstrom et al., 2011^21^ Systematic Review Gates et al., 1989^102^ Lildholdt, 1983^106^ Bonding, 1985^105^ Maw, 1994^107^ | Arms differ across comparisons (Arms appear in tables 13 and 33,) 4 studies (N=1,054 participants) | Varies by study | Minimum of 3 months | Include: RCTs (individual or ear), NRCTs, and cohort studies published between 1966 and 2007 of TT effectiveness on hearing, QOL, language development, and complications | Various | Children or adolescents | Medium

CDLM = Contact diode laser myringotomy dB = decibel; ENT = ear, nose, and throat; G = group; HL = hearing loss; hrs = hours; MR = mental retardation; N = number; NR = not reported; NRCT = nonrandomized controlled trial; OME = otitis media with effusion; QOL = quality of life; RCT = randomized controlled trial; TM = tympanic membrane; TT = tympanostomy tubes; yrs = years

a Tympanostomy tube type not specified.

#### Key Points

- Two studies found that TT confer no additional benefit for limiting OME recurrence to that obtained by adenoidectomy alone (strength of evidence insufficient) (Table 12).
- The evidence that TT and adenoidectomy reduce OME recurrence in comparison with myringotomy and adenoidectomy is mixed. One RCT found no difference in recurrence rate with the addition of TT, but two studies found that OME recurred later with TT plus adenoidectomy compared with myringotomy plus adenoidectomy. Strength of evidence is insufficient for mixed findings.
- Findings from four studies are mixed concerning whether TT and adenoidectomy improve hearing in comparison to adenoidectomy alone beyond 3 weeks post-treatment. Strength of evidence is insufficient for mixed results.
- Five of six studies did not find that TT plus adenoidectomy was superior to myringotomy plus adenoidectomy for hearing outcomes. Strength of evidence is low for no difference.
- Only one small RCT examined AOM, and no difference was found between TT and adenoidectomy and myringotomy and adenoidectomy. Strength of evidence is insufficient.
- Evidence was insufficient for vestibular outcomes and health care service use because we found no studies.

Table 12 Strength of evidence for KQ 1: Clinical outcomes and health care utilization

Treatment Comparison | OME Recurrence/Ventilation | AOM | Measured Hearing
TT+ adenoidectomy vs. Adenoidectomy alone | Insufficient No difference, two small studies | Insufficient (No studies) | Insufficient Mixed results
TT+ adenoidectomy vs. Myringotomy + adenoidectomy | Insufficient Mixed results | Insufficient Single study No difference | Low No difference (6 mos, 12 mos and >3 years)

mos = months; TT = tympanostomy tubes; yrs = years

#### Detailed Synthesis

##### Recurrence of Middle Ear Effusion

Six studies102,106,107,109,112,113 examined MEE or ventilation as an outcome (Table 13). The two studies106,109 that compared TT added to adenoidectomy in comparison with no ear surgery found no significant difference in OME recurrence at follow-up points from 48 hours to 5 years. Later data were shown in figures only.

Table 13 Clinical outcomes: Tympanostomy tubes plus adenoidectomy versus watchful waiting or myringotomy plus adenoidectomy or adenoidectomy alone

Study | Arm (N randomized) | Study Duration Until Outcome Measurement | OME Recurrence/Ventilation | AOM | Measured Hearing
Brown et al., 1978^109^ | G1: Shepard TT + adenoidectomy (N=55) G2: Adenoidectomy (N=55) | 48 hours | G1: 2% G2: 4% p=NS | NR | PTA G1: 8.9 dB G2: 24.7 dB (significant but no p-value reported)
Brown et al., 1978^109^ | G1: Shepard TT + adenoidectomy (N=55) G2: Adenoidectomy (N=55) | 3 months | NR | NR | G1: 11.4 dB G2: 16.6 dB (significant but no p-value reported)
Brown et al., 1978^109^ | G1: Shepard TT + adenoidectomy (N=55) G2: Adenoidectomy (N=55) | 5 years | NR | NR | G1: 17 dB G2: 14 dB p=NR
Austin, 1994^110^ | G1: TT^a^ + adenoidectomy (N=31) G2: Adenoidectomy (N=31) | 1–3 months | NR | NR | Air-bone gap G1: 13.2 G2: 14.4 p>0.1 Mean improvement in Air-bone gap G1:16 dB G2: 12.2 dB p>0.1 Mean difference: 1.9 dB in hearing between ears p=NS
Lildholdt, 1979^111^ | G1:Donaldson TT+ adenoidectomy (N=91) G2: Adenoidectomy (N=91 | 3–18 months | NR | NR | Mean HL at 3 months G1: 5.5 dB G2: 6.1 dB at 6 months G1: 8.8 dB G2: 7.6 dB at 9 months G1: 4.9 dB G2: 7.3 dB at 12 months G1: 8.2 dB G2: 5.0 dB at 15 months G1: 4.7 dB G2: 4.1 dB at 18 months G1: 8.8 dB G2: 2.4 dB All p’s=NS
D’Eredita and Shah, 2006^112^ | G1: Shah mini + adenoidectomy (N=15) G2: CDLM + adenoidectomy (N=15) | NA | Middle ear ventilation maintained G1: 6.3 months G2: 3.5 months p<0.001 | NR | NR
D’Eredita and Shah, 2006^112^ | G1: Shah mini + adenoidectomy (N=15) G2: CDLM + adenoidectomy (N=15) | 3 months | Number ears ventilated (%) G1: 30 (100) G2: 11 (36.6) p=NR | NR | NR
Popova et al., 2010^113^ | G1: Donaldson TT + adenoidectomy (N=42) G2: Myringotomy + adenoidectomy (N=36) | 1 month | NR | NR | PTA G1: 13.9 dB G2: 14.1 dB p=0.83
Popova et al., 2010^113^ | G1: Donaldson TT + adenoidectomy (N=42) G2: Myringotomy + adenoidectomy (N=36) | 6 months | NR | NR | G1: 7.6 dB G2: 8.0 dB p=0.68
Popova et al., 2010^113^ | G1: Donaldson TT + adenoidectomy (N=42) G2: Myringotomy + adenoidectomy (N=36) | 12 months | OME recurrence G1: 10% G2:14% p=0.547 | # episodes ≥ 1 G1: 28% G2: 25% p=NR | G1: 5.5 dB G2: 6.3 dB p=0.24
Shishegar and Hobhoghi, 2007^114^ | G1: Shepard TT + adenoidectomy (N=30) G2: Myringotomy + adenoidectomy (N=30) | 1 month | NR | NR | Air-bone gap improvement G1: 17.47 dB G2: 16.04 dB p=NS Mean SRT hearing threshold G1: 18.3 dB G2: 17 dB p=NS
Shishegar and Hobhoghi, 2007^114^ | G1: Shepard TT + adenoidectomy (N=30) G2: Myringotomy + adenoidectomy (N=30) | 6 months | NR | NR | Air-bone gap improvement G1:17.62 dB G2: 16.25 dB p=NS Means SRT Hearing threshold G1: 19.3 dB G2: 17.16 dB p=NS
Vlastos et al., 2011^115^ | G1: Shepard TT + adenoidectomy (N=25) G2: Myringotomy + adenoidectomy (N=27) | 6 months | NR | NR | Change in hearing G1: −7.41 dB G2: −4.06 dB Mean HL change, dB 3.35 (95% CI, −6.64 to 10.35)
Vlastos et al., 2011^115^ | G1: Shepard TT + adenoidectomy (N=25) G2: Myringotomy + adenoidectomy (N=27) | 12 months | NR | NR | Change in hearing: G1: −8.06 dB G2: −7.40 dB Mean HL change, dB: 0.66(95% CI, −6.82 to 8.15)
Hellstrom et al., 2011^21^ Systematic Review | 1 NRCT (by ears) 2 articles Bonding, 1985^105^ Companion Study: Tos and Strangerup, 1989^108^ G1: Adenoidectomy + Donaldson TT (N=146) G2: Myringotomy + adenoidectomy (N=146) | While grommet functioning (N=224 children) | NR | NR | % with hearing threshold > 20 dB G1:4 G2: 31 p<0.01
Hellstrom et al., 2011^21^ Systematic Review | 1 NRCT (by ears) 2 articles Bonding, 1985^105^ Companion Study: Tos and Strangerup, 1989^108^ G1: Adenoidectomy + Donaldson TT (N=146) G2: Myringotomy + adenoidectomy (N=146) | 2–3 years | NR | NR | Mean hearing threshold, PTA G1: 15.0 dB G2: 14.7 dB p=NR Mean gain after treatment : G1: 14.5 dB G2: 13.1 dB p=NR
Hellstrom et al., 2011^21^ Systematic Review | 1 NRCT (by ears) 2 articles Bonding, 1985^105^ Companion Study: Tos and Strangerup, 1989^108^ G1: Adenoidectomy + Donaldson TT (N=146) G2: Myringotomy + adenoidectomy (N=146) | 6–7 years | NR | NR | Mean hearing threshold, PTA G1: 11.7 dB G2: 11.1 dB p=NR Mean gain after treatment G1: 3.3 dB G2: 3.6 dB
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT Gates et al., 1989^102^ G1: Adenoidectomy + TT^a^ (N=125) G2: Adenoidectomy + myringotomy (N=130) | 2 years | Days until recurrence G1: 240 ±22 G2: 92 ±33 p<0.0001 Time with effusion G1: 0.258 ±0.212 G2: 0.302 ±0.250 p=0.2364 | NR | Proportion of time with hearing threshold >20 dB (better ear) G1: 0.065 G2: 0.078 p=0.5042
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Lildholdt, 1983^106^ G1: Donaldson TT + adenoidectomy (N=150 ears) G2:Adenoidectomy (N=150 ears) | 3 weeks | NR | NR | Hearing loss: PTA Data shown in figures only p<0.001 favoring TT ear
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by ear) Lildholdt, 1983^106^ G1: Donaldson TT + adenoidectomy (N=150 ears) G2:Adenoidectomy (N=150 ears) | 5 years | Flat tympanogram G1: NR G2: NR p=NS | NR | Hearing loss: PTA Data shown in figures only p=NS
Hellstrom et al., 2011^21^ Systematic Review | 1 RCT (by person and ear) Maw, 1994^107^ G1:Shepard TT + Adenoidectomy/adenotonsillectomy (N=139) G2: Adenoidectomy/adenotonsillectomy alone (N=139) | 6/12 months–10 years | % without MEE at 6/12 mos G1: 88.4 G2: 50.9 at 1 years G1: 78.1 G2: 60.1 at 2 years G1: 78.3 G2: 66.7 at 3 years G1: 89.8 G2: 79.8 at 4 years G1: 89.4 G2: 87.7 at 5 years G1: 91.9 G2: 82 at 7 years G1: 92.7 G2: 92.9 at 10 years G1: 95.4 G2: 90.9 all p’s=NR | | Mean hearing loss, dB at 6/12 mos G1: 17.6 G2: 21.3 G1: 19.1 G2: 20.9 G1: 18.1 G2: 20.0 G1: 17.3 G2: 17.0 G1: 17.5 G2: 16.6 G1: 16.4 G2: 17.0 G1: 14.7 G2: 14.6 all p’s=NR

AOM = acute otitis media; CDLM = contact diode laser for myringotomy; dB = decibel; G = group; HL = hearing level; MEE = middle ear effusion; mos = months; N = number; NA = not applicable; NR = not reported; NRCT = nonrandomized controlled trial; NS = not significant; OME = otitis media with effusion; PTA = pure tone average; RCT = Randomized controlled trial; SRT = speech reception threshold; TT = tympanostomy tubes

a Tympanostomy tube type not specified.

Results were mixed comparing TT with myringotomy, when added to adenoidectomy. One small study113 (N=78) comparing TT with myringotomy found similar and nonsignificant OME recurrence at 12 months post-surgery. Over a 2-year period, Gates et al. (1989)102 found recurrence an average of 148 days later in children with TT and adenoidectomy compared with children with myringotomy and adenoidectomy (p< 0.0001) but the percentage of time with effusion was similar between the two groups. In another small study (N=30), D’Eredita and Shah112 found that ears with TT remained ventilated, on average, 2.8 months longer than those that received myringotomy (p<0.001), when all children received adenoidectomy.

##### Measured Hearing

Hearing outcomes were examined by all studies but D’Eredita and Shah.112 Two110,111 of the four studies comparing TT plus adenoidectomy with adenoidectomy alone did not find that TT added any benefit to hearing that was not obtained by adenoidectomy alone at a number of follow-up points, from 1 to 18 months. Two other studies found that TT conferred a benefit when added to adenoidectomy at 48 hours and 3 months postsurgery109 and at 3 weeks postsurgery.106 Neither of the latter two studies found a benefit at 5-year followup.

In the three studies (four reports)105,107,108,114 that compared TT to myringotomy by ears, only the Bonding and Tos (1985)105 study found that TT conferred an advantage, but only during the period in which the grommets were intact (4% of ears with hearing threshold greater than 20 dB vs. 31%). None of the three studies102,113,115 that examined children (in contrast to ears) randomized to either TT or myringotomy along with adenoidectomy found a benefit for TT; followup in these studies occurred between 1 month and 2 years and outcomes were typically similar in both arms.

##### Acute Otitis Media

Only one small RCT examined whether TT plus adenoidectomy were superior to myringotomy plus adenoidectomy for developing AOM. Popova et al. (2010)113 reported that at 12-month followup approximately one-quarter of each group developed one or more cases of AOM following treatment.

### Surgical Interventions: Myringotomy Comparisons

#### Description of Studies

The included evidence consisted of one RCT by Ragab116 (Table 14). This study was designed to compare two different procedures for myringotomy; namely, radio frequency myringotomy with mitomycin C, a topical chemotherapeutic agent, in comparison to radio frequency myringotomy alone. In this trial, a subset of individuals received an adenoidectomy (73% and 67% respectively by arm). Followup was short term.

Table 14 Characteristics of studies: Myringotomy comparisons

Study, Study Type, Country | Arm (N) | Diagnosis Criteria | Wait Period Between Diagnosis and Study | Inclusion/Exclusion Criteria | Length of Study Follow-up | Age in Years | Risk of Bias
Ragab, 2005^116^ RCT Egypt | G1: Radiofrequency myringotomy + Mitomycin C (N=30) 73% had adenoidectomy G2: Radiofrequency myringotomy (no Mitomycin C) (N=30) 67% had adenoidectomy | History, pneumatic otoscopy and tympanometry | NR | Include: Patients undergoing surgery for OME | 3 months | Mean G1: 4.8 G2: 5.2 | Medium

G = group; N = number; NR = not reported; OME = otitis media with effusion; RCT = randomized control trial

#### Key Points

One small RCT comparing approaches to myringotomy found a significant difference in resolution of OME favoring myringotomy with mitomycin C but no significant differences in hearing improvement. Based on one small study, the strength of evidence is insufficient.

#### Detailed Synthesis

##### OME Signs and Symptoms Outcomes

Ragab116 examined resolution of middle ear effusion and reported a significant difference favoring radio frequency myringotomy with mitomycin C at 3 months (p<0.01) (Table 15). This study did not present data on either OME recurrence or AOM.

Table 15 Clinical outcomes: Myringotomy comparisons

Study | Arm (N) | Study Duration Until Outcome Measurement | Middle Ear Effusion/Time With Effusion | Patency | Measured Hearing
Ragab, 2005^116^ | G1: Radiofrequency myringotomy + mitomycin C (N=30) G2: Radiofrequency myringotomy (no mitomycin C) (N=30) | 3 months | Resolution of OME G1: 59% G2: 28% p<0.01 | G1: 5.3 weeks G2: 3.5 weeks p<0.01 | Air-bone gap Improvement: G1: 12 dB G2: 10 dB p=NS

dB = decibel; G = group; N = number; NS = not significant; OME = otitis media with effusion

##### Hearing Outcomes

Both myringotomy with and without mitomycin C groups demonstrated a significant air-bone gap improvement 3 months postsurgery compared with presurgery but no significant difference in improvement was observed in air-bone gap improvement rates between the two groups.116

### Surgical Interventions: Myringotomy With Adenoidectomy Comparisons

#### Description of Studies

One retrospective cohort study compared two different procedures for myringotomy—namely, laser myringotomy with cold knife myringotomy (Table 16).117 In both arms, all participants received an adenoidectomy. Patients included children older than 4 years of age who had refractory OME or children of any age who needed a second TT insertion.

Table 16 Characteristics of studies: Myringotomy with adenoidectomy

Study, Study Type, Country | Arm (N) | Inclusion/Exclusion Criteria | Length of Followup | Age in Years (Range) | Risk of Bias
Szeremeta et al., 2000^117^ Retrospective cohort USA | G1: Laser myringotomy + adenoidectomy (N=29) G2: Cold knife myringotomy + adenoidectomy (N=35) | Include: Children >4 yrs with refractory OME or children any age with a need for a second tube; spring operations | Mean time in months (range) G1: 16.6 (6–27) G2: 20.2 (12–48) | Mean: G1: 6.5 (2.74 to 12.52) G2: 7.4 (3.86 to 5.34) | Medium

G = group; N = number; OME = otitis media with effusion; USA = United States of America; yrs = years

#### Key Points

A particular approach to myringotomy (laser vs. cold knife) among patients who had also all received adenoidectomy displayed mixed findings in relation to clinical outcomes in an evidence base consisting of one study. The study did not find that laser myringotomy was superior to cold knife myringotomy in the percentage of patients with OME but did find it superior in relation to the intermediate outcome of patency of ears (open hole based on myringotomy), postoperatively. Based on one small study, the evidence is graded as insufficient.

This one study evidence base did not report any other clinical or health care utilization outcomes such as AOM, balance, or use of health care services.

#### Detailed Synthesis

Outcomes focused on the percentage of ears with MEE and patency of ears at the first postsurgery visit (Table 17). Laser myringotomy with adenoidectomy did not differ from cold knife myringotomy with adenoidectomy in the percentage of ears presenting with MEE at followup. However, the authors reported a significant difference in the percentage of ears that were patent at the first postoperative visit, favoring laser myringotomy with adenoidectomy (p<0.01).

Table 17 Clinical outcomes: Myringotomy with adenoidectomy comparisons

Study | Arm (N) | Study Duration Until Outcome Measurement | Middle Ear Effusion/Time With Effusion | OME Recurrence or Ventilation
Szeremeta et al., 2000^117^ | G1: Laser myringotomy + adenoidectomy (N=29) G2: Cold knife myringotomy + adenoidectomy (N=35) | Within 50 days | MEE G1: 10.3% G2: 17.1% p>0.1 | Patency G1: 20.5% G2: 0% p<0.01

G = group; MEE = middle ear effusion; N = number; OME = otitis media with effusion

### Surgical Interventions: Adenoidectomy Versus Other Interventions

#### Description of Studies

The evidence comparing the effectiveness of adenoidectomy to other interventions was included in a recent Cochrane review by van den Aardweg et al.29 and a newly published TARGET study conducted by the MRC Multicentre Otitis Media Study Group (2012)19 (Table 18). Included studies were all RCTs of children (1 to 15 years of age) with persistent or recurrent OME lasting at least 3 months, who were followed for 6 months or more. We included seven of the studies summarized in the Cochrane review that were limited to OME patients (N=1,103).95,97–99,118–120 Treatment comparisons included: adenoidectomy with and without myringotomy versus nonsurgical treatment, myringotomy or watchful waiting only; adenoidectomy with unilateral TT versus a unilateral TT only; and adenoidectomy with bilateral TT versus bilateral TT only.

Table 18 Characteristics of studies: Adenoidectomy versus other interventions

Study, Study Type, Country | Arm (N) | Diagnosis Criteria | Wait Period Between Diagnosis and Study | Inclusion/ Exclusion Criteria | Length of Study Followup | Age Range | Risk of Bias
van den Aardweg et al., 2010^29^ Systematic review 7 RCTs included in analysis: Dempster et al., 1993,^98^ Black et al., 1990,^97^ Maw and Herod, 1986,^99^ and Fiellau-Nikolajsen et al., 1980,^118^ RCT: Gates et al, 1987,^95^ Roydhouse et al., 1980,^120^ and Casselbrant et al., 2009^119^ | Arms differ across comparisons: 7 RCTs (1,103 participants) (Arms appear in tables 20 and 34) | Various criteria including clinical judgment, otoscopy, tympanometry, pure tone thresholds | Various | Include: RCTs of adenoidectomy for OME compared with nonsurgical tx or TT alone; children ≤18 yrs of age Exclude: Quasi randomized trials (e.g., allocation by DOB or record number) | At least 6 months | 2–14 yrs | Low
MRC TARGET, 2012^19^ RCT UK | G1: Ad + myr + bilateral Shepard TT G2: Myr + bilateral Shepard TT G3: WW (N=376) | On 2 visits, 3 mos. apart: a bilateral B+B or B+C2 tympanogram combination and better ear HL ≥20 dB HL averaged across 0.5, 1,2, and 4 kHz and air-bone gap >10 dB | 3 months | Include: A bilateral B+B or B+C2 tympanogram combination and better ear HL ≥20 dB HL averaged across 0.5, 1,2, and 4 kHz and air-bone gap >10 dB, on 2 visits, 3 months apart HL >40 dB HL could choose to not be randomized | 3, 6, 12, 18, and 24 months | 3.25 to 6.75 years at first visit | Medium

Ad = adenoidectomy; dB = decibels; DOB = date of birth; HL = hearing level; kHz = kilohertz; mos = months; MRC = Medical Research Council; myr = myringotomy; N = number; RCT = randomized controlled trial; TARGET = Trial of Alternative Regimens in Glue Ear Treatment; TT = tympanostomy tubes; tx = treatment; UK = United Kingdom; ww = watchful waiting; yrs = years

#### Key Points

- Adenoidectomy was superior to no treatment in resolving OME at both 6 months and 12 months followup, based on evidence from meta-analyses of studies by ear (Table 19).29 At 6 months, the risk difference was 0.27 (95% CI, 0.13 to 0.42), measured through otoscopy and 0.22 (95% CI, 0.12 to 0.32) measured through tympanometry. At 12 months the risk difference was 0.29 (95% CI, 0.19 to 0.39). High strength of evidence.
- Resolution of OME and hearing were superior with adenoidectomy and myringotomy at 24 months in one large study (N=237) compared with myringotomy alone. Low strength of evidence.
- Results of studies using varied effusion outcome measures (time with effusion and percentage of patients with effusion) that examined whether the addition of adenoidectomy to TT was superior to TT alone after 1 to 3 years were mixed. Strength of evidence is insufficient for mixed results.
- Measured hearing levels were mixed in the adenoidectomy group compared with no treatment. Insufficient strength of evidence.
- Measured hearing was superior with adenoidectomy and TT compared with watchful waiting at all follow-up visits between 3 to 6 months and 2 years in one study (N=250). Low strength of evidence.
- Measured hearing outcomes at 6-month followup were similar in three studies measuring differences between adenoidectomy and TT groups and TT only groups. However, by 1 year followup, results were mixed in the adenoidectomy and TT group compared with the TT-only group in two studies. Strength of evidence is insufficient for mixed results.
- Evidence was insufficient to determine the comparative effectiveness of adenoidectomy versus no treatment or TT in relation to vestibular function and health services-related outcomes.

Table 19 Strength of evidence for KQ 1: Clinical outcomes and health care utilization

Treatment Comparison | OME Signs and Symptoms | Objective Hearing | AOM | Balance | Health Care Utilization
Adenoidectomy vs. no treatment | High OME resolution favors adenoidectomy vs. no treatment 2 MA at 6 mos (2,153) (3, 297), 1 MA at 12 mos (3, 298) | Insufficient Mixed results (2, 221) | Insufficient No studies | Insufficient No studies | Insufficient No studies
Adenoidectomy plus myringotomy vs. myringotomy | Low Mean time with effusion favors adenoidectomy+ myringotomy over myringotomy alone at 24 mos (1, 237) | Low Hearing favors adenoidectomy+ myringotomy over myringotomy alone at 24 mos (1, 237) | Insufficient No studies | Insufficient No studies | Insufficient No studies
Adenoidectomy plus TT vs. TT | Insufficient Mixed results (3, 538) | Insufficient Mixed results (4, 683) | Insufficient One study | Insufficient No studies | Insufficient No studies
Adenoidectomy plus TT vs. WW | Insufficient No studies | Low Hearing favors adenoidectomy+TT over WW at 3 to 24 mos (1, 250) | Insufficient No studies | Insufficient No studies | Insufficient No studies

AOM = acute otitis media; OME = otitis media with effusion; mos = months; MA = meta-analysis; TT = tympanostomy tubes; vs. = versus; WW = watchful waiting

#### Detailed Synthesis

##### OME Signs and Symptoms Outcomes

OME resolution was superior in the adenoidectomy group compared with no treatment in three meta-analyses conducted by van den Aardweg et al. that compared unoperated ears in patients with unilateral TT, both at 6 months based on otoscopy (risk difference=0.27, based on 2 studies) and tympanometry (risk difference=0.22, based on three studies) and at 12 months based on tympanometry (risk difference=0.29, based on three studies) (Table 20).29 In a single study, Gates et al. also found that the mean time with effusion over a 24-month period was significantly lower in the adenoidectomy and myringotomy group compared with the myringotomy-only group (SMD=−0.76) and that the mean time to recurrence of effusion was almost twice as long in the adenoidectomy and myringotomy group compared with the myringotomy-only group, 92 and 54 days, respectively.95

Table 20 Clinical outcomes: Adenoidectomy versus other interventions

Study | Arm (N) | Study Duration Until Outcome Measurement | MEE/Time With Effusion | OME Resolution | AOM | Measured Hearing
van den Aardweg et al., 2010^29^ | RCT (by person and ear): Dempster et al., 1993^98^ G1: Adenoidectomy G2: Control (N=72) | 6 months | NR | Included in MA | NR | Mean hearing level (dB) (95% CI) G1: 18.0 G2: 21.1 SMD: −0.25 (−0.71 to 0.22)
van den Aardweg et al., 2010^29^ | RCT (by person and ear): Dempster et al., 1993^98^ G1: Adenoidectomy G2: Control (N=72) | 12 months | NR | Otoscopy G1: 54% G2: 37% Risk diff: 17% (95% CI, −6% to 40%) | NR | G1; 15.6 G2: 18.4 SMD: −0.29 (−0.76 to 0.17)
van den Aardweg et al., 2010^29^ | RCT: Black et al., 1990 (by person and ear)97 G1: Adenoidectomy G2: Control (N=149) | 6 months | NR | NR | NR | Diff in change in mean dB: 4.3 (1.4 to 9.9)
van den Aardweg et al., 2010^29^ | RCT: Black et al., 1990 (by person and ear)97 G1: Adenoidectomy G2: Control (N=149) | 12 months | NR | NR | NR | Diff in chance in mean dB: 4.3 (−3.1 to 11.6)
van den Aardweg et al., 2010^29^ | MA: 2 RCTs (by ears): Dempster et al., 1993^98^ Maw and Herod, 1986^99^ G1: Adenoidectomy G2: No treatment (N =153) | 6 months | NR | Otoscopy G1: 49% G2: 21% Risk diff: 0.27 (95% CI, 0.13 to 0.42) | NR | NR
van den Aardweg et al., 2010^29^ | MA: 3 RCTs (by ears): Dempster et al., 1993^98^ Black et al., 1990^97^ Maw and Herod, 1986^99^ G1: Adenoidectomy G2: No treatment (N =297) | 6 months | NR | Tympanometry G1: 39% G2: 17% Risk diff: 0.22 (95% CI, 0.12 to 0.32) | NR | NR
van den Aardweg et al., 2010^29^ | MA: 3 RCTs (by ears): Dempster et al., 1993^98^ Maw and Herod, 1986^99^ Black et al., 1990^97^ G1: Adenoidectomy G2: No treatment (N=298) | 12 months | NR | Tympanometry G1: 47% G2: 20% Risk diff: 0.29 (95% CI, 0.19 to 0.39) | NR | NR
van den Aardweg et al., 2010^29^ | RCT: Fiellau-Nikolajsen et al., 1980^118^ G1: Adenoidectomy + Myringotomy G2: Myringotomy (N=42) | 6 months | NR | Normal ears (Type A tympanogram) G1: 68% G2: 52% Risk diff: 15% (95% CI, −5% to 46%) | NR | NR
van den Aardweg et al., 2010^29^ | RCT: Gates et al, 1987^95^; Gates et al., 1989^102^ G1: Adenoidectomy + myringotomy G2: Myringotomy G3: Adenoidectomy + Shepard TT G4: Shepard TT (N=491) Gates (cont.) | 24 months (ITT) | Median days to first recurrence of effusion G1: 92 (±33) G2: 54 (±2) (p<0.0007) G3: 240 (±22) G4: 222 (±11) (p=0.2314) Mean time with effusion G1: 0.302 G2: 0.491 SMD: −0.76 (95% CI, −1.02 to −0.49) | NR | NR | Mean time HL ≥20 dB better ear G1: 0.078 G2: 0.186 SMD: −0.66 (95% CI, −0.93 to −0.40) Mean time HL ≥20 dB worse ear G1: 0.220 G2: 0.375 SMD: −0.65 (95% CI, −0.91 to −0.39) Mean time HL ≥20 dB better ear G3: 0.065 G4: 0.101 SMD: −0.23 (95% CI, −0.48 to 0.02)
van den Aardweg et al., 2010^29^ | RCT: Gates et al, 1987^95^; Gates et al., 1989^102^ G1: Adenoidectomy + myringotomy G2: Myringotomy G3: Adenoidectomy + Shepard TT G4: Shepard TT (N=491) Gates (cont.) | 24 months (ITT) | G3: 0.258 G4: 0.349 SMD: −0.40 (95% CI, −0.65 to −0.15) | NR | NR | Mean time HL ≥20 dB worse ear G3: 0.224 G4: 0.304 SMD: −0.35 (95% CI, −0.60 to −0.11)
van den Aardweg et al., 2010^29^ | RCT: Maw and Herod, 1986^99^ G1: Adenoidectomy + unilateral Shepard TT G2: Unilateral Shepard TT (N=103) | 6 months | NR | Presented in MA | NR | Mean hearing level (dB) (SD) G1: 16.4 (8.03) G2: 17.5 (9.79) (p=NS)
van den Aardweg et al., 2010^29^ | RCT: Maw and Herod, 1986^99^ G1: Adenoidectomy + unilateral Shepard TT G2: Unilateral Shepard TT (N=103) | 12 months | NR | Presented in MA | NR | Mean hearing level (dB) (SD) G1: 16.4 (8.03) G2: 17.5 (8.61) (p=NS)
van den Aardweg et al., 2010^29^ | RCT: Black et al., 1990^97^ G1: Adenoidectomy+ myringotomy + unilateral Shepard TT G2: Myringotomy + unilateral Shepard TT (N=72) | 6 months | NR | NR | NR | Diff in change in mean dB: 2.1 (95% CI, −2.6 to 6.8)
van den Aardweg et al., 2010^29^ | RCT: Black et al., 1990^97^ G1: Adenoidectomy+ myringotomy + unilateral Shepard TT G2: Myringotomy + unilateral Shepard TT (N=72) | 12 months | NR | NR | NR | Diff in change in mean dB: 2.4 (95% CI, −2.7 to 7.6)
van den Aardweg et al., 2010^29^ | RCT: Roydhouse, 1980^120^ G1: Adenoidectomy + bilateral TT G2: Bilateral TT (N = 95) | 12 months | % with effusion G1: 18% G2: 23% Risk diff: −5% (95% CI, −8% to 17%) | NR | NR | NR
van den Aardweg et al., 2010^29^ | RCT: Roydhouse, 1980^120^ G1: Adenoidectomy + bilateral TT G2: Bilateral TT (N = 95) | 24 months | G1: 15% G2: 18% Risk diff: −3% (95% CI, −10% to 15%) | | NR | NR
van den Aardweg et al., 2010^29^ | RCT: Casselbrant et al., 2009^119^ G1: Adenoidectomy + myringotomy + bilateral Teflon Armstrong TT G2: Myringotomy + bilateral Teflon Armstrong TT (N=62) | 18 months (ITT) | Mean time with effusion G1: 18% G2: 12% Diff G1 vs. G2: 6% (95% CI, −12 to 24) | NR | >1 episode G1: 27% G2: 23% Diff G1 vs. G2: (p=0.58) | NR
van den Aardweg et al., 2010^29^ | Casselbrant et al., 2009^119^ | 36 months (ITT) | Mean time with effusion G1: 21% G2: 19% Diff G1 vs. G2: 2% (95% CI, −19 to 23) | NR | # episodes G1: 7 G2: 6 Risk diff: 5% (95% CI, −22 to 32) >1 episode G1: 58% G2: 55% Diff G1 vs. G2: (p=0.77) # episodes G1: 17 G2: 21 Risk diff: −18% (95% CI, −37 to 1) | NR
MRC TARGET, 2012^19^ | G1: Adenoidectomy + myringotomy + bilateral Shepard TT G2: Myringotomy + bilateral Shepard TT G3: WW (N=376) | 3- and 6-month visit (ITT) (N at 3 mos=332) | NR | NR | NR | Mean hearing levels: G1: 14.6 (95% CI, 13.6 to 15.7) G2: 15.9 (95% CI, 14.8 to 17.0) G3: 24.7 (95% CI, 23.3 to 26.1) Diff TES G1 vs. G3: 1.50 (p<0.05) G1 vs. G2: 0.23 (p=NS)
MRC TARGET, 2012^19^ | G1: Adenoidectomy + myringotomy + bilateral Shepard TT G2: Myringotomy + bilateral Shepard TT G3: WW (N=376) | 12-, 18-, and 24-mo visit (ITT) (N at 12 mos=323) | NR | NR | NR | G1: 15.9 (95% CI, 14.9 to 17.0) G2: 20.1 (95% CI, 19.0 to 21.2) G3: 19.4 (95% CI, 18.3 to 20.5) Diff TES G1 vs. G3: 0.55 (p<0.05) G1 vs. G2: 0.69 (p<0.05)
MRC TARGET, 2012^19^ | G1: Adenoidectomy + myringotomy + bilateral Shepard TT G2: Myringotomy + bilateral Shepard TT G3: WW (N=376) | 2-year combined average (ITT) (N at 24 mos=321) | NR | NR | NR | G1: 15.5 (95% CI, 14.5 to 16.4) G2: 18.5 (95% CI, 17.6 to 19.5) G3: 21.4 (95% CI, 20.4 to 22.4) Diff TES G1 vs. G3: 1.11 (p<0.05) G1 vs. G2: 0.61 (p<0.05)

Ad = adenoidectomy; AOM = acute otitis media; bil = bilateral; CI = confidence interval; dB = decibel; diff = difference; G = group; HL = hearing level; ITT = intent to treat; MA = meta-analysis; mos = months; MEE = middle ear effusion; MRC = Medical Research Council; myr = myringotomy; N = number; NR = not reported; NS = not significant; OME = otitis media with effusion; RCT = randomized controlled trial; SD = standard deviation; SMD = standard mean difference; TARGET = Trial of Alternative Regimens in Glue Ear Treatment; TES = treatment effect size; TT = tympanostomy tubes; vs. = versus; ww = watchful waiting

OME-related outcomes were better in adenoidectomy and TT groups compared with TT alone, in two of three studies. Roydhouse et al. found that, among patients with adenoidectomies and TT, 18 percent had MEE at the end of year 1 and 15 percent at the end of year 2.^120^ In contrast, among patients who had only TT, effusion was present in 23 percent at the end of year 1 and 18 percent at the end of year 2, but risk differences were not significant at either time point. In a second study, Gates et al. found that the mean time with effusion over a 2-year period was 26 percent of visits among patients with adenoidectomies and TT and 35 percent of visits among patients with only TT (SMD: −0.40 [95% CI, −0.65 to −0.15]).95 In a third small study by Casselbrant et al., mean time with effusion was higher in the adenoidectomy plus TT arm at 18 and 36 months, but differences were small and not statistically significant.119

##### Hearing Outcomes

Hearing measures differed across two RCTs that measured outcomes by ears but the directon of the results was consistent. Comparing adenoidectomy alone with no treatment at 6-month followup, one study found significantly larger improvement in hearing outcomes in the adenoidectomy group (4.3dB).97 A second study found better mean hearing levels in the adenoidectomy group (SMD = −0.25) but the results were not statistically significant.98 Studies continued to find different results in the two groups at 12-month followup but in both studies the differences were not statistically significant.

The larger TARGET study found significantly better hearing in the adenoidectomy, myringotomy, and TT arm compared with the watchful waiting arm at 3- to 6-month followup, 12- to 24-month followup, and overall for the 24-month combined average (mean hearing levels of 15.5 dB compared with 21.4 dB).19

Three studies compared hearing outcomes for patients who received adenoidectomy and TT with those that received TT alone. At 6-month followup, outcomes were similar in the two groups and not significantly different.19,97,99 At 12 months, Black et al.97 and Maw and Herod99 studies, comparing one ear in each patient, continued to find differences between groups to be small and not statistically significant. In contrast, the TARGET study, randomized by child, found significantly better hearing outcomes in the adenoidectomy group.19 The mean hearing level at 12 to 24 months was 15.9 dB in adenoidectomy and TT patients and 20.1 dB in TT-only patients.

##### Other Outcomes

Episodes of AOM were measured in one study included in the systematic review and they were similar at 18 or 36 months.119 No studies measured vestibular function.

### Pharmaceutical Interventions: Oral or Topical Nasal Steroids

#### Description of Studies

The included evidence consisted of one recent Cochrane review31 which was updated32 during the period of this review. The update includes one more recent trial, conducted by Williamson et al.20,121 (Table 21). The Cochrane review summarized evidence from nine RCTs of oral steroids and three RCTs of topical intranasal steroids, excluding studies limited to ears (rather than children). The Williamson et al. study with topical intranasal steroids was conducted by the UK Health Technology Assessment Programme, and published as a report20 and peer-reviewed manuscript.121 All studies were in comparison with placebo controls and some of the oral steroid studies included antibiotics in both arms. All studies included participants 14 years of age and younger. The studies in the Cochrane review did not exclude children with comorbidities, except for the Williamson et al. study which excluded children with Down syndrome, cleft palate, and other comorbidities (Table 21). The studies in the Cochrane review included 1 week and 1- to 6-month followup; except for the Williamson RCT which also included 9-month followup. Both the original review and the update were assessed as low risk of bias.

Table 21 Characteristics of studies: Oral or topical nasal steroids

Study, Study Type, Country | Arm (N) | Diagnosis Criteria | Wait Period Between Diagnosis and Study | Inclusion/Exclusion Criteria | Length of Followup | Age Range | Risk of Bias
Thomas et al., 2006^31^ Systematic review International 11 RCTs included in analysis: Giebink et al., 1990,^122^ Macknin et al., 1985^123^ Niederman et al., 1984,^124^ Mandel et al., 2002,^125^ Podoshin et al., 1990,^126^ Tracy et al., 1998,^127^ Hemlin et al., 1997,^128^ Williamson et al., 2010,^121^ Schwartz et al., 1980,^129^ Lambert, 1986,^130^ Berman et al., 1990,^131^ and Shapiro et al., 1982^132^ | Arms differ across comparisons:11 trials (728 participants) | OME determined by:; A. Air-bone gap of 10 dB or more + 2 or more of: otomicroscopy, pneumatic otoscopy, tympanometry (type B or C2); B. 2 or more of: otomicroscopy, pneumatic otoscopy, tympanometry (type B or C2); C. 1 of otoscopy alone or tympanometry (type B or C2); D. Poorly or not defined; Significant hearing loss defined by:; A. Pure-tone audiometry hearing loss of >20 dB at 2 or more times within 3 months (e.g., mean of 500, 1,000, and 2,000 Hz hearing loss bilaterally); B. Defined, but less strict than A; C. Uncertain or not defined | NR | Include: RCTs of oral and topical intranasal steroids, including studies using non-intervention controls with adequate blinding of outcome assessor. Exclude: Observational studies, studies reporting outcomes only with ears as unit of analysis; studies (or data from arms of studies) comparing steroid + additional treatment vs. treatment with placebo + placebo because effect of steroid could not be isolated. However, studies with antibiotic co-intervention were included, if identical in both arms. | 1–2, and 6 months | 0–14 yrs | Low
Simpson et al.,2011^32^ Systematic review update of Thomas et al., 2006^31^ 11 RCTs included in Thomas et al., 2006^31^ plus Williamson et al., 2009^20^ | Arms differs across comparisons:12 trials (945 participants) | Same criterion as Thomas et al.,2006^31^ | NR | Same criterion as Thomas et al., 2006^31^ except additional study Williamson et al. 2009^20^ Excluded: cleft palate, Down syndrome, primary ciliary dyskinesia | 1–3 wks, 1–3 months, 6 months, 9 months | 0–12 yrs | Low

dB = decibel; Hz = Hertz; mos = months; NR = not reported; OME = otitis media with effusion; RCT = randomized control trial; vs. = versus; wks= weeks; yrs = years

#### Key Points

- Meta-analyses comparing oral steroids and controls (N=106) did not show differences in MEE at 1- or 2-month followup (low strength of evidence) (Table 22).
- Meta-analyses comparing oral steroids and controls (N=243) (with oral antibiotic adjunctive therapy) did not show differences in MEE at 1- or 2-month followup (medium strength of evidence).
- We found insufficient evidence comparing oral steroids with controls (with or without oral antibiotic adjunctive therapy) at 3 months or longer for any hearing outcomes.
- Patients receiving topical intranasal steroids did not differ from controls in cure rates or hearing loss at 3-month or longer followup, based on results from one low risk-of-bias study (low strength of evidence).
- No studies reported on AOM or other clinical or health care use outcomes (insufficient evidence).

Table 22 Strength of evidence: Clinical outcomes and health care utilization

Comparison | OME Signs And Symptoms | Measured Hearing
Oral steroids vs. control (1–2 months) | Low Persisting OME: no difference MA, 3, 106 | Insufficient Hearing gain: no diff 1, 49
Oral steroids + antibiotic vs. control + antibiotic (1–2 months) | Moderate Persisting OME: no difference MA, 2, 243 | Insufficient No studies
Topical intranasal steroid vs. control (1, 3, and 9 or more months) | Low Cure rate: no diff 1, 217 | Low Hearing loss: no diff 1, 217
Topical intranasal steroid + antibiotic vs. control + antibiotic (3 or more months) | Insufficient Persisting OME (6 months): no diff 1, 59 | Insufficient No studies
Oral steroids vs. control (3 months) | Insufficient No studies | Insufficient Hearing gain: no difference 1, 49
Oral steroids + antibiotic vs. control + antibiotic (6 or more months) | Insufficient Persisting: No diff 1, 15 | Insufficient No study

diff = difference; MA = meta-analysis; OME = otitis media with effusion; RCT = randomized control trial; vs. = versus; wks = weeks; yrs = years

#### Detailed Synthesis

##### OME Signs and Symptoms Outcomes

The Cochrane reviews31,32 presented results on outcomes related to MEE through two measures: persisting OME and cure rates as measured by a flat tympanogram (Table 23). The reviews found oral steroids plus antibiotics to be superior to placebo plus antibiotics at less than one month, based on a meta-analysis of five studies, Risk Ratio (RR): 1.99 (95% CI, 1.14 to 3.49) (N=409). In contrast, one study that did not include antibiotics found no difference at 3 weeks, RR: 0.64 (95% CI, 0.31 to 1.31).132 We found no differences in any treatment comparisons at any end points of longer duration. At 1- to 2-month followup, the systematic review found no difference between oral steroids versus controls in relation to persisting OME, RR=1.54 (95% CI, 0.76 to 3.14) based on a meta-analysis of three studies (N=106) or similarly for oral steroids versus controls, when both arms also received antibiotic treatment, RR=1.44 (95% CI, 0.97 to 2.13), based on a meta-analysis of three studies (N=231).32 The Williamson et al. study also found no significant difference in cure rates in topical steroids versus controls at 1 month, controlling for season, age, atrophy, and clinical severity, RR=0.97 (95% CI, 0.74 to 1.26) (N=194).

Table 23 Clinical outcomes: Oral or topical nasal steroids

Study | Arm (N) | Study Duration Until Outcome Measurement | Middle Ear Effusion/Time With Effusion | Measured Hearing
Thomas et al., 2006^31^ Systematic review Simpson, et al., 2011^32^ Update systematic review | MA of 5 RCTs: Oral steroid plus antibiotic vs. control plus antibiotic (N=409) Berman et al., 1990,^131^ Hemlin et al., 1997,^128^ Lambert et al., 1986,^130^ Mandel et al., 2002,^125^ Schwartz et al., 1980^129^ | 7–28 days | OME resolution RR: 1.99 (95% CI 1.14 to 3.49) | NR
Thomas et al., 2006^31^ Systematic review Simpson, et al., 2011^32^ Update systematic review | MA of 3 RCTs: Oral steroid vs. control Giebink et al., 1990,^122^ Macknin et al., 1985,^123^ Niederman et al., 1984^124^ (N=106) | 1–2 months 4–6 weeks | Persisting OME Peto OR: 0.55 (95% CI, 0.21 to 1.48) OME resolution a RR:1.54 (95% CI 0.76 to 3.14) | NR
Thomas et al., 2006^31^ Systematic review (continued) | 1 RCT: Macknin et al., 1985^123^ Oral steroid vs. control (N=49) | 1–2 months | NR | Hearing gain by at least 10 dB in either ear OR: 1.47 (95% CI, 0.39 to 5.57) (baseline: NR) Hearing not improved by at least 10 dB in either ear RR: 1.09 (95% CI, 0.80 to 1.49 )^a^
Thomas et al., 2006^31^ Systematic review (continued) | MA: 2 RCTs: Mandel et al., 2002^125^ Podoshin et al., 1990^126^ Oral steroids + antibiotic vs. control + antibiotic (N=243) (N=231)^a^ | 1–2 months | Persisting OME Peto OR: 0.75 (95% CI, 0.45 to 1.27) OME resolution^a^ RR: 1.44 (95% CI, 0.97 to 2.13) | NR
Thomas et al., 2006^31^ Systematic review (continued) | 1 RCT^a^ Podoshin et al., 1990^126^ Oral steroid + antibiotic vs. control + antibiotic (N=99) | 2 months | NR | Hearing loss through assessment of air-bone gap (at least some conductive loss)^a^ G1: 60% G2: 60% RR:1.01 (95% CI, 0.73 to 1.40)
Thomas et al., 2006^31^ Systematic review (continued) | 1 RCT^a^ Shapiro et al., 1982^132^ Intranasal steroid vs. control | 3 weeks | OME resolution: RR: 0.64 (95% CI, 0.31 to 1.31) | NR
Thomas et al., 2006^31^ Systematic review (continued) | 1 RCT: Tracy et al., 1998^127^ Intranasal steroid + antibiotic vs. placebo + antibiotic or antibiotic alone (N=59) | 3 months | Persisting OME OR: 0.72 (95% CI, 0.21 to 2.44) OME resolution^a^ RR: 1.26 (95% CI, 0.54 to 2.96) | NR
Thomas et al., 2006^31^ Systematic review (continued) | 1 RCT: Hemlin et al., 1997^128^ Oral steroid + antibiotic vs. control + antibiotic (N=15) | 6 months | Persisting OME OR: 0.15 (95% CI, 0.00 to 7.80) | NR
Thomas et al., 2006^31^ Systematic review (continued) | 1 RCT: Williamson et al., 2010^121^ Williamson et al., 2009^20^ Intranasal steroid vs. control (N=141) | 1–6 months | NR | Audiometry failing on ≥ 2 out of 5 frequencies in both ears^a^ RR: 1.17 (95% CI, 0.87 to 1.58)
Thomas et al., 2006^31^ Systematic review (continued) | Williamson et al., 2010^121^ Williamson et al., 2009^20^ Intranasal steroid vs. control G1: 96 G2: 98 | 1 month | Cure rate^b^ Diff in OR (adj): 0.934 (0.498 to 1.751) Diff in RR (adj): 0.97 (0.74 to 1.26) | NR
Thomas et al., 2006^31^ Systematic review (continued) | Williamson et al., 2010^121^ Williamson et al., 2009^20^ Intranasal steroid vs. control G1: 86 G2: 86 | 3 months | Diff in OR (adj): 1.451 (0.742 to 2.838) Diff in relative risk(adj): 1.23 (0.84 to 1.80) OME resolution^a^ RR 1.11 (95% CI, 0.85 to 1.46) | Pass/fail criteria on sweep audiometry (fail at 2 or more frequencies at 25 dB in the better ear): G1: 52/83 (63%) G2: 47/81 (58%) Hearing loss from tympanograms, median days (IQR) G1: 19.43 (14.64–1.21) G2: 21.15 (14.86–0.94) WMD: 0.0 (95% CI, 4.51 to 4.51^a^ Baseline hearing G1: 30.97 (23.8–32.65) G2: 30.94(24.03–32.21)
| Williamson et al., 2010^121^ Williamson et al., 2009^20^ Intranasal steroid vs. control G1: 72 G2: 72 | 9 months | Diff in OR (adj): 0.822 (0.387 to 1.746) Diff in relative risk (adj): 0.90 (0.58 to 1.41) OME resolution^a^ RR: 0.85 (95% CI, 0.65 to 1.11) | Pass/fail criteria on sweep audiometry (fail at 2 or more frequencies at 25 dB in the better ear): G1: 44/74 (59%) G2: 34/67 (51%) Audiometery failing on ≥ 2 out of 5 frequencies in both ears)^a^ RR: 1.17 (0.87 to 1.58) Hearing loss from tympanograms, median (IQR) G1:19.56(14.88–0.84) G2: 17.89 (14.11–3.55)

adj = adjusted; CI = confidence interval; dB = decibel; diff = difference; G = group; IQR = interquartile range; MA = meta-analysis; N = number; NR = not reported; OME = otitis media with effusion; OR = odds ratio; RCT = randomized controlled trial; RR = risk Ratio; vs. = versus; WMD = weighted mean difference

a Denotes information from update review, Simpson, et al., 2011.^32^

b Determined by A or C1 tympanogram in at least 1 ear; adjusted results (OR and RR) controlling for season, age, atrophy, and clinical severity score.

At 3-month followup, in two studies, MEE, as measured by OME resolution, was superior with intranasal steroids but results were not statistically significant. Tracy et al. included antibiotics in both arms in one small RCT, RR= 1.26 (95% CI, 0.54 to 2.96) (N=59).127 We also found small nonsignificant differences in cure rates based on evidence from the larger Williamson et al. study, RR=1.11 (95% CI, 0.85 to 1.46) (N=172).32 At 6-month followup, persisting OME did not differ significantly between patients receiving oral steroid treatment plus antibiotic and controls plus antibiotic, based on evidence from one trial (N=15).128 At 9-month followup, OME resolution did not differ between topical steroids and control, based on the Williamson et al. study, RR=0.85 (95% CI, 0.65 to 1.11) (N=144).32,121

##### Hearing Outcomes

Hearing did not differ between topical steroid and control groups, as measured at 3 and 9 months through audiometry and tympanometry based on one low risk-of-bias study (Table 23).20 We did not find evidence related to hearing outcomes based on oral steroid treatment at 3 months or later.31

##### Other Outcomes

We found no evidence on other clinical outcomes, including OME episodes of AOM or vestibular function.

### Nonpharmaceutical Interventions: Autoinflation

#### Description of Studies

The evidence consisted of one recent Cochrane review by Perera et al.30 (Table 24) summarizing evidence from six RCTs of any form of autoinflation, a technique designed to increase oropharyngeal pressure via a nasal balloon or other process. Two different types of autoinflation devices were reviewed. One required the patient to actively inflate a balloon type device, whereas the other was a passive device in which the air was delivered into the nose while the patient swallowed. The review included five studies with children 3–12 years of age (Arick and Silman, 2005;133 Blanshard et al., 1993;134 Brooker et al., 1992;135 Fraser et al.,1977;^136^ Stangerup and Tos, 1992^137^) and one study of adults, 16–75 years of age Lesinskas, 2003.^138^ All studies were in comparison to no autoinflation. Other treatments (e.g., analgesics, antibiotics) were permitted as long as they were provided equally to both arms. The Cochrane review included one study with an end point of 4 weeks post-treatment,133 one study at the end of treatment and 50 days post-treatment138 and one study at the end of treatment and approximately 2 weeks, 6 weeks, and 10 weeks post-treatment.137 The other three trials recorded outcomes only at the end of treatment, the length of which differed.134–136

Table 24 Characteristics of studies: Autoinflation

Study, Study Type, Country | Arm (N) | Diagnosis Criteria | Wait Period Between Diagnosis and Study | Inclusion/Exclusion Criteria | Length of Study Followup | Age Range | Risk of Bias
Perera et al., 2009^30^ Systematic review International 6 RCT’s Arick & Silman, 2005,^133^ Blanshard et al., 1993^134^ Brooker et al., 1992;^135^ Fraser et al.,1977,^136^ Lesinskas 2003, and Stangerup and Tos, 1992^137^ | Autoinflation vs. control:6 trials (602 participants) | Tympanometry (type B or C2), either alone or in combination with simple or pneumatic otoscopy or audiometry | Various | Include: RCTs; any form of autoinflation; other treatments had to be given to both arms | 3 trials: at end of treatment 1 trial: 4 wks post-treatment 1 trial: 2 mos 1 trial: 3 mos | 3–16 yrs (5 studies) 16–75 yrs (1 study) | Medium

mos = months; RCT = randomized controlled trial; wks = weeks; yrs = years; vs.= versus

#### Key Points

- Based on two meta-analyses of two studies,134,137 included in the Perera et. al systematic review,30 autoinflation improved middle ear status as measured by tympanometry in the short term (e.g., a month or less from treatment initiation) (low strength of evidence). Autoinflation did not show improvement in tympanometry at more than 1 month from treatment (insufficient strength of evidence) (Table 25).
- Groups receiving autoinflation did not differ significantly from controls in measured hearing (pure tone audiometry [PTA]) at either the end of treatment or 4 weeks after treatment (insufficient strength of evidence).
- No included studies reported on AOM, balance, or use of health care services (insufficient strength of evidence).

Table 25 Strength of evidence for KQ 1: Autoinflation

Comparison (G1 vs. G2) | OME Signs and Symptoms | Objective Hearing
Autoinflation vs. Control | Low Two MA (2; 185) Improvement in tympanogram with autoinflation at ≤ 1 mo Insufficient One MA (2: 185) no difference in improvement in tympanogram at > 1 mo | Insufficient One MA (2: 125) No difference in HL improvement using PTA Insufficient One MA (2:179) No difference in average HL using PTA (4 wks post-tx and end of tx)

mo = month; MA = meta-analysis; HL = hearing level; PTA = pure tone audiometry; tx = treatment

#### Detailed Synthesis

##### OME Signs and Symptoms Outcomes

The systematic review30 presented results on improvement in middle ear status as measured with tympanometry (Table 26). Several of the trials reported improvement in tympanometric classification at different time points; in some studies, the outcomes were measured during the period of time that treatment was administered. The results were presented for different classifications at different time points. No study in the review reported on OME recurrence.

Table 26 Clinical outcomes: Autoinflation

Study | Arm (N) | Study Duration Until Outcome Measurement | Middle Ear Effusion | Measured Hearing
Perera et al., 2009^30^ | MA: 3 studies Blanshard et al., 1993^134^ Brooker et al., 1992;^135^ Stangerup and Tos, 1992^137^ (N=225) MA: 2 studies Blanshard et al., 1993;^134^ and Stangerup and Tos, 1992^137^ (N=185) MA: 2 studies Blanshard et al., 1993^134^ and Stangerup and Tos, 1992^137^ (N=185) | ≤1 month | Tympanometry improvement B or C2 to C1 or A: RR: 1.65 (95% CI, 0.49 to 5.56) B to C1 or A RR: 2.71 (95% CI, 1.43 to 5.12) C2 to C1 or A RR: 3.84 (95% CI, 1.94 to 7.59) | NR
Perera et al., 2009^30^ | MA: 2 studies Blanshard et al., 1993^134^ and Stangerup and Tos, 1992^137^ (N=185) | >1 month | B or C2 to C1 or A: RR 1.89 (95% CI, 0.77 to 4.67) | NR
Perera et al., 2009^30^ | MA: 2 studies Blanshard et al., 1993^134^ and Stangerup and Tos, 1992^137^ (N=125) | End of treatment (3 weeks in 1 study and 3 months in the other study) | NR | Improvement in HL ≥10 dB measured by PTA RR 0.80 (95% CI, 0.22 to 2.88)
Perera et al., 2009^30^ | MA 2 studies Arick and Silman, 2005^133^ and Fraser et al.,1977^136^ (N=179) | End of treatment in 1 study (6 weeks) and 4 weeks after treatment in the other study | NR | Average HL measured by PTA Weighted Mean Diff 7.02 (95% CI, −6.92 to 20.96)

CI= confidence interval; dB = decibel; Diff = difference; HL = hearing level; MA = meta-analysis; NR = not reported; N = number; PTA = pure tone average; RR = relative risk

In one meta-analysis of three studies,134,135,137 the systematic review reported that, at 1 month or less, the autoinflation group did not have significant improvement from a B classification (a flat tracing usually indicative of the presence of middle ear fluid) at baseline, or C2 (highly negative curve, which is usually indicative of an abnormality) to a C1 classification (a moderately negative curve indicative as normal) or a tympanometric classification of A (considered to be normal).

Using data from two of the three trials included in the meta-analysis,134,137 the systematic review authors reported two additional meta-analysis subanalyses in which baseline tympanogram classifications were more narrowly combined. They found that autoinflation significantly improved middle ear status relative to no treatment in children with a baseline B classification (presence of middle ear fluid) and in children with a baseline C2 classification (negative pressure, indicative of abnormality) at followup of 1 month or less. However, in the meta-analysis of trials that examined ears at more than 1 month from treatment initiation, Perera et al. found no difference between autoinflation patients and controls in rates of improvement in tympanometry (i.e., from B or C2 classifications indicating presence of fluid or an abnormal to C1 or A classifications, indicating as normal middle ear status).30

##### Hearing Outcomes

Two meta-analyses examined hearing outcomes. In one, change in hearing level was measured by PTA of greater than 10 dB; in the second, the average hearing level was the outcome.30 The first meta-analysis failed to find a difference between the autoinflation and control groups in change in hearing level either at the end of treatment or at 3 months post-treatment [RR= 0.80 (95% CI, 0.22 to 2.88)]. In the second meta-analysis, hearing levels at the end of 6 weeks of treatment or at 4 weeks post-treatment did not differ in the autoinflation and control groups (weighted mean difference = 7.02 [95% CI, −6.92 to 20.96]).

##### Other Outcomes

Other relevant outcomes, such as episodes of AOM, OME recurrence, or vestibular function were not discussed as a function of treatment.

## KQ 2 Comparative Effectiveness of Interventions: Functional and Quality-of-Life Outcomes

### Surgical Interventions: Tympanostomy Tube Comparisons

No studies reported on functional or quality-of-life outcomes.

### Surgical Interventions: Tympanostomy Tubes Versus Watchful Waiting or Myringotomy

#### Key Points

- With one exception, children receiving TT did not display better language comprehension or expression than children who received active monitoring (Table 27). The one finding of superior performance with TT relied on teacher assessment at 4½ years of age. Failure to find differences between those receiving TT and those receiving watchful waiting were observed in a meta-analysis with data collected at 6 to 9 months followup as well as during preschool and the later elementary school years. Strength of evidence is moderate for no effect.
- Two RCTs did not find any differences between TT and watchful waiting on measures of cognitive development at 9 months followup and throughout the elementary school years (low strength of evidence).
- Children with early TT did not exceed children who received delayed treatment on any measure of academic achievement in 2 studies (low strength of evidence).
- In the only study to examine phonological or auditory processing, children with early TT did not differ from children with late TT (insufficient strength of evidence).
- One of two studies found that children with TT displayed better behavior than children receiving watchful waiting at less than 1 year followup (insufficient strength of evidence for mixed findings). Three studies found no differences in behavioral competence between TT and watchful waiting at time points from 1 year to 11 years of age (low strength of evidence for no difference).
- Only one investigation examined quality of life; researchers did not find differences between TT and watchful waiting (insufficient strength of evidence).

Table 27 Strength of evidence for KQ 2: Tympanostomy tubes versus watchful waiting or myringotomy

Treatment Comparison | Speech/Language | Cognitive Development | Academic Achievement | Behavior | Quality of Life
TT vs. watchful waiting 6 to 9 months | Moderate No difference MA: 3, 394; Study: 1, 160 | Low No difference Study: 1,160 | Insufficient No studies | Insufficient Mixed results Studies: 2, 358 | Insufficient No difference Study: 1, 176
TT vs. watchful waiting 1 year or more | Low No difference Study: 1, 393 | Low No difference Studies 2: 553 | Low No difference Studies 2, 499 | Low No difference Studies: 3, 716 | Insufficient No difference Study: 1 Study: 1, 176
TT vs. Myringotomy | Insufficient No studies | Insufficient No studies | Insufficient No studies | Insufficient No studies | Insufficient No studies

MA = meta-analysis; TT = tympanostomy tubes; vs. = versus

#### Detailed Synthesis

The evidence for functional and quality-of-life outcomes of TT as compared with either myringotomy or watchful waiting is found in two systematic reviews,21,22 and more extensively in individual reports for three of the included studies68,93,140 (seven reports) (Table 28). Outcomes include language and cognitive skills, behavior, phonological processing, and academic performance.

Table 28 Functional and health-related quality-of-life outcomes: Tympanostomy tubes versus watchful waiting or myringotomy

Study | Arm (N) | Study Duration Until Outcome Measurement | Speech/Language Cognitive Development | Academic Achievement | Phonological Processing/Auditory Processing | Behavior | Quality of Life
Browning et al., 2010^22^ | MA:3 RCTs (N=394) Maw et al., 1999^93^ Rach et al., 1991^100^ Rovers et al., 2000^94^ | 6–9 months | Language Comprehension, Bilateral TT vs. WW: Mean Difference 0.09 (95% CI, −0.21, 0.39) | NR | NR | NR | NR
Browning et al., 2010^22^ | MA: 3 RCT (N=393) Maw et al., 1999^93^ Rach et al., 1991^100^ Rovers et al., 2000^94^ | 6–9 months | Language Expression TT vs. WW: Mean Difference 0.03 (95% CI, −0.42, 0.49) | NR | NR | NR | NR
Browning et al., 2010^22^ | 1 RCT by child Maw et al., 1999^93^ (N=160) Companions: Wilks et al., 2000^142^ Hall et al., 2009^141^ | 9 months | Griffiths Mental Development Mean Cognitive Index TT vs. WW 106.5 vs. 104.2 (95% CI, −2·58 to 7·04) (p=ns) | NR | NR | Richman Behavioral Scale, % with Problems (N=152) TT vs. WW 30% vs. 47% (95% CI, −33% to –2%) p=0.031 (favors tx) | NR
Browning et al., 2010^22^ | 1 RCT by child Maw et al., 1999^93^ (N=160) Companions: Wilks et al., 2000^142^ Hall et al., 2009^141^ | 18 months (N=152) Mean age 4.5 years | NR | NR | NR | 24% vs. 20% (95% CI, −10% to 19%) p=0.66 | NR
Browning et al., 2010^22^ | 1 RCT by child Maw et al., 1999^93^ (N=160) Companions: Wilks et al., 2000^142^ Hall et al., 2009^141^ | 7 years of age (N=108) | NR | NR | NR | SDQ, Teacher Report^a^ Total Score OR: 2.05 (95% CI, 0.62 to 6.70) p=0.237 | NR
Browning et al., 2010^22^ | 1 RCT by child Maw et al., 1999^93^ (N=160) Companions: Wilks et al., 2000^142^ Hall et al., 2009^141^ | 8 years of age (N=108) | Language Comprehension^a^ Total Score TT vs. WW OR: 1.58 (95% CI, 0.59 to 4.25) p=0.366 Oral Expression^a^ Total Score TT vs. WW OR: 2.10 (95% CI, 0.78 to 5.65 p=0.143 WISC-III^a^ Total Score TT vs. WW OR: 2.39 (95% CI, 0.85 to 6.76) p=0.100 | Reading TT vs. WW OR: 1.57 (95% CI, 0.72 to 3.43) Writing OR: 0.597 (95% CI, 2.05 to 0.92) Mathematics OR: 0.618 (95% CI, 1.71 to 0.77) | NR | NR | NR
Browning et al., 2010^22^ | 1 RCT (by child) Paradise et al., 2001^68^ (N=393) | 3 years of age | PPVT-R Early Tubes vs. Late Tubes 92 vs. 92 (95% CI, −2.8 to 2.8) McCarthy Mental Development Mean General Cognitive Index Early Tubes vs. Late Tubes 99 vs. 101 (95% CI, −4.1 to 1.1) | NR | NR | CBCL (Parent) Mean Total Problem Score Early Tubes vs. Late Tubes 50 vs. 49 (95% CI, −0.6 to 3.4) | NR
Browning et al., 2010^22^ | Paradise et al., 2005^69^ (N=395) | 6 years of age | PPVT-R Early Tubes vs. Late Tubes 94 vs. 94 (95% CI, −3.6 to 3.2) WISC-R Early Tubes vs. Late Tubes 98 v. 98 (95% CI, −3.0 to 2.5) | NR | SCAN Test Early Tubes vs. Late Tubes 95 vs. 94 (95% CI, −4.6 to 1.5) | CBCL (Parent) Early Tubes vs. Late Tubes 49 vs. 48 95% CI, −1.5 to 2.7) | NR
Browning et al., 2010^22^ | Paradise et al., 2007^67^ (N=391) | 9–11 years of age | NR | WJRMT Word Identification Early Tubes vs. Late Tubes 98 vs. 99 (95% CI, −3.2 to 1.3) WJRMT Passage Comprehension Early Tubes vs. Late Tubes 98 vs. 99 (95% CI, −3.2 to 1.2) W-J III Spelling Early Tubes vs. Late Tubes 96 vs. 97 (95% CI, −3.9 to 2.0) WJ III Writing Early Tubes vs. Late Tubes 104 vs. 105 (95% CI, −4.1 to 1.7) | CTPP Elision Subtest Early Tubes vs. Late Tubes 8.6 vs. 8.7 (95% CI, −0.9 to 0.7) Children’s HNT (noise tested from the front Early Tubes vs. Late Tubes −0.4 vs. −0.6 (95% CI, −0.06 vs. 0.58) | CBCL (Parent) Early Tubes vs. Late Tubes 51 vs. 49 (95% CI, 0.2 to 4.8) | NR
Browning et al., 2010^22^ | 1 RCT (by child) Rovers et al., 2001^140^ (N=176) | 6 months | NR | NR | NR | The Erickson child Mean scores TT vs. WW Affection 4.4 vs. 4.6 Avoidance 6.3 vs. 6.5 Compliance 5.1 vs. 5.2 Negativism 6.6 vs. 6.7 Reliance 6.5 vs. 6.7 MANOVA Hotelling Trace p=0.19 | The TAIQOL Mean scores TT vs. WW Vitality 3.3 vs. 3.3 Appetite 5.0 vs. 4.7 Communication G1: 6.7 vs. 5.8 Motoric 4.4 vs. 4.4 Social 3.5 vs. 3.5 Anxiety 4.3 vs. 4.1 Aggression 11.9 vs. 11.1 Eating 3.3 vs. 3.5 Sleeping 6.8 vs. 6.6 MANOVA Hotelling Trace p=0.22
Browning et al., 2010^22^ | 1 RCT (by child) Rovers et al., 2001^140^ (N=176) | 12 months (N=165) | NR | NR | NR | Affection 4.5 vs. 4.9 Avoidance 6.5 vs. 6.9 Compliance 5.2 vs. 5.6 Negativism 6.6 vs. 6.9 Reliance 6.6 vs. 6.8 MANOVA Hotelling Trace p=0.38 | Vitality 3.1 vs.3.2 Appetite 5.3 vs.4.9 Communication 5.9 vs.5.6 Motoric 4.2 vs.4.2 Social 3.5 vs. 3.5 Anxiety 4.6 vs. 4.3 Aggression 11.8 vs.11.5 Eating 3.3 vs. 3.4 Sleeping 6.4 vs. 6.4 MANOVA Hotelling Trace p=0.94

CBCL = Child Behavior Checklist; CI = confidence interval; CTPP = Comprehensive Test of Phonological Processing; HNT = Hearing in Noise Test; MA = meta-analysis; MANOVA = Multivariate analysis of variance; N = number; NR = not reported; ns = not sufficient; OR = odds ratio; PPVT-R = Peabody Picture Vocabulary Test, Revised; RCT = randomized controlled trial; SDQ = Strengths and Difficulties Questionnaire; TAIQOL = TNO-AZL Infant Quality of Life; TT = tympanostomy tubes; tx = treatment; vs. = versus; W-J III = Woodcock-Johnson III Tests of Achievement; WISC-III = Wechsler Intelligence Scale for Children, Third edition; WISC-R = Wechsler Intelligence Scale for Children, Revised; WJRMT = Woodcock-Johnson Reading Mastery Test –Revised; WW = watchful waiting

a Analyses adjusted for age, gender, maternal education, housing and mother’s parity.

##### Speech/Language and Cognitive Outcomes

Browning et al.22 performed meta-analysis of three studies93,94,100 measuring differences in language comprehension and language expression at 6–9 months post-treatment between TT and watchful waiting groups and found no significant difference (mean difference=0.09 [95% CI, −0.21 to 0.39] and mean difference=0.03 [95% CI, −0.41 to 0.49], for language comprehension and expression respectively). Individual studies provided similar evidence that TT were not associated with better language outcomes. In several reports, Paradise and colleagues68,69 failed to find a difference in children’s receptive language skills between those who had received early TT and those who had received late TT at either 3 years of age (mean difference = 0, 95% CI, −2.8 to 2.8) or 6 years of age (mean difference = 0; 95% CI,−3.6 to 3.2). Hall and colleagues141 who followed the sample in Maw et al.93 found significant differences in teacher assessment of language at 4½ years of age favoring TT (adjusted OR, 3.45; 95% CI: 1.42 to 8.39), but the benefit disappeared at 8 years of age, based on a standardized test (language comprehension: adjusted OR, 1.58; 95% CI, 0.59 to 4.25; oral expression: adjusted OR, 2.1; 95% CI, 0.78 to 5.65), controlling for age, gender, maternal education, housing, and mother’s parity.

Two individual studies, one by Paradise and colleagues and one by Maw and colleagues (in four articles), reported on cognitive development.68,69,93,141 No differences were observed between TT and watchful waiting/late TT at any time point from 9 months post-surgery (mean difference, 1.3; 95% CI, −2.58 to 7.04)93; 3 years of age (mean difference, 2.0; 95% CI, −4.1 to 1.1)68; 6 years of age (mean difference, 0; 95% CI, −3.0 to 2.5)69; to 8 years of age (OR, 2.39; 95% CI, 0.85 to 6.76).141

##### Academic Achievement

Two studies examined whether children with TT had better academic achievement scores than children who received delayed treatment.67,141 Followup was at age 8 in the Hall et al. (2009) study and at ages 9 to 11 in the Paradise et al. (2007) study. Neither study reported differences in reading (overall reading; adjusted OR, 1.57; 95% CI, 0.72 to 3.43^141^; passage comprehension: mean difference, 1.0; 95% CI, 3.2 to 1.2,^67^ spelling: mean difference, 1.0; 95% CI, −3.9 to 2.0^67^; mathematics: adjusted OR, 2.05; 95% CI, 0.92 to 4.58,^141^ or writing: adjusted OR, 1.71; 95% CI, 0.77 to 3.81;^141^ mean difference, 1.0; 95% CI, −4.0 to 1.7^67^).

##### Phonological and Auditory Processing

Only the Paradise and colleagues study67,69 examined phonological and auditory processing. The investigators failed to find a difference between children’s performance on measures of phonological and auditory processing at either 6 years of age (mean difference = 1.0 [95% CI, −4.6 to 1.5]) or 9 to 11 years of age (Elision subtest: mean difference = 0.0 [95% CI, −0.9 to 0.7]; Children’s Hearing in Noise Test: mean difference = 0.2 [95% CI, −0.06 to 0.58]).

##### Behavioral Competence

Three studies (seven reports)67–69,140–143 examined behavioral competence comparing TT with watchful waiting. Aside from the Wilks et al. study142 in which children with TT displayed fewer behavior problems (30%) than those in the watchful waiting condition (47%) (95% CI, −33% to −2%) p=0.031, no other differences between TT and watchful waiting or delayed TT were detected.

##### Quality of Life

Rovers et al.140 was the only investigator to include a measure of quality of life. Using the TNO-AZL Infant Quality of Life (TAIQOL) (a health-related quality-of-life measure for 1- to 4-year-olds), they did not find a difference in any of the subscales measured at either 6 months (MANOVA, Hotelling’s trace p=0.19) or 12 months post-treatment (MANOVA, Hotelling’s trace p=0.22).

### Surgical Interventions: Tympanostomy Tubes Plus Adenoidectomy Versus Myringotomy Plus Adenoidectomy or Adenoidectomy Alone

#### Key Findings

- One small study examined differences in quality-of-life between children receiving adenoidectomy and TT and those receiving adenoidectomy and myringotomy. Strength of evidence was insufficient.
- Strength of evidence was insufficient for all speech/language, cognitive and behavioral outcomes because these outcomes were not examined in any study.

#### Detailed Synthesis

Only one small study (N=52) evaluated differences in quality-of-life outcomes between children receiving TT and adenoidectomy and those receiving myringotomy and adenoidectomy115 (Table 29). Although only TT group improved from baseline, the difference between the two groups was not significant.115

Table 29 Functional and health-related quality-of-life outcomes: Tympanostomy tubes plus adenoidectomy versus myringotomy plus adenoidectomy or adenoidectomy alone

Study | Arm (N) | Study Duration Until Outcome Measurement | Speech/Language Cognitive Development | Quality of Life
Vlastos et al., 2011^115^ | G1: Shepard TT + adenoidectomy (N=25) G2: Myringotomy + adenoidectomy (N=27) | 6 months | NR | OM-6 Score Score G1: 1.88 G2: 2.04 Mean Difference: −.0.16 (95% CI, −0.43 to 0.10) Change from Baseline G1: −0.38 G2: −0.00 Mean change: −0.38 (95% CI, −0.65 to −0.10)
Vlastos et al., 2011^115^ | | 12 months | NR | Score G1: 1.84 G2: 2.04 Mean Difference: −0.20 (95% CI, −.0.57 to 0.17) Change from Baseline G1: −0.32 G2: 0.01 Mean change: −0.23 (95% CI, −0.76 to 0.11)

CI = confidence interval; G = group; N = number; NR = not reported; OM-6 = Otitis Media-6; TT = tympanostomy tubes

### Surgical Interventions: Myringotomy Comparisons

#### Key Findings

We found no evidence examining functional outcomes or health-related quality of life.

### Surgical Interventions: Myringotomy Plus Adenoidectomy Comparisons

#### Key Findings

We found no evidence examining functional outcomes or health-related quality of life.

### Surgical Interventions: Adenoidectomy Versus Other Interventions

#### Key Findings

We found no evidence examining functional outcomes or health-related quality of life.

### Pharmaceutical Interventions: Oral or Topical Nasal Steroids

#### Key Points

- Patients receiving topical intranasal steroids versus controls did not differ on the quality-of-life outcome of reported hearing at 3 months (insufficient evidence, one small study).
- Patients receiving topical intranasal steroids versus controls, both receiving antibiotics, did not differ at 3 months on a quality-of-life symptom score (low strength of evidence, one study).
- No study reported on quality-of-life outcomes for oral steroids versus controls (with or without antibiotics) or oral steroids plus antibiotics versus controls (insufficient evidence).
- No study reported on speech or language outcomes, cognitive development, or behavioral outcomes (insufficient evidence).

#### Detailed Synthesis

Topical nasal steroids did not differ from controls in relation to symptom scores in one small study that included antibiotics in both arms (N=39)31 (Table 30). The larger Williamson et al. study comparing nasal steroids to control without the addition of antibiotics did not find significant differences between groups in parent-reported hearing difficulties or days with hearing loss; rates and confidence intervals were similar in both arms.20

Table 30 Functional and health-related quality-of-life outcomes: Oral or topical nasal steroids

Study | Arm (N) | Study Duration Until Outcome Measurement | Quality of Life
Thomas et al., 2010^31^ | 1 RCT: Tracy et al., 1998^127^ Topical intranasal steroid + antibiotic vs. control + antibiotic or antibiotic alone (N=39) | 3 months | Symptom score Weighted mean diff: −4.50 (95% CI, −10.28 to 1.28)
Williamson et al., 2010^121,b^ Williamson et al., 2009^20^ | Baseline: (N=196) G1: Topical intranasal steroid (N=86) G2:Control (N=86) | Baseline: G1: 6.06 (2.83–8.57) G2: 5.88 (2.33–7.60) 3 months | Parent-reported hearing difficulties, median (IQR) G1: 5.54 (0.90–8.43) G2: 3.92 (0.90–7.60) (p=NS)^a^
Williamson et al., 2010^121,b^ Williamson et al., 2009^20^ | G1: 72 G2: 72 | 9 months | G1: 2.33 (0.21 to 7.60) G2: 2.33 (0.42–6.60) (p=NS)^a^
Williamson et al., 2010^121,b^ Williamson et al., 2009^20^ | G1: 86 G2: 86 | 3 months | Days with hearing loss, median (IQR) G1: 4 (0 to 24.5) G2: 4 (0 to 18.5) p=0.45

CI = confidence interval; IQR = interquartile range; mos = months; N = number; NS = not significant; vs. = versus

a Calculated by authors.

b Study included in Simpson et al. systematic revidew update, 2011.^31^

### Nonpharmaceutical Interventions: Autoinflation

#### Key Findings

We found no evidence examining functional outcomes or health-related quality of life.

## KQ 3 Harms or Tolerability

### Surgical Interventions: Tympanostomy Tube Comparisons

#### Key Points

- Otorrhea rates differed by TT type; placement of longer-term TT are related to a higher probability of otorrhea (low strength of evidence).
- For other side effects, such as perforation, tympanosclerosis, atrophy, cholesteatoma, or granulation, evidence was either not available at all (no studies) or too sparse in too few studies with similar intervention comparisons to determine a direction of effect (insufficient evidence).

#### Detailed Synthesis

We identified 13 studies that compared side effects by type of TT or insertion technique (Table 31). The systematic review by Hellstrom et al.21 included seven studies; 5 RCTs (2 of which were reported in 2 articles)75,76,78,81,82,90,144 and 2 nonrandomized controlled trials.79,80 We identified 6 additional studies: 3 RCTs,83,85,87 1 nonrandomized controlled trial,84 and 2 cohort studies.45,86

Table 31 Treatment harms or tolerability: Tympanostomy tube comparison studies

Study | Arm (N) | Study Duration Until Outcome Measurement | Repeat Tubes | Otorrhea/ Occlusion/Granulation | Perforation/Atelectasis/Retraction | Cholesteatoma/Tympanosclerosis
Wielinga et al., 1990^83^ RCT by ear | G1: Goode Silicon tube (N=15) G2: Teflon Armstrong tube (N=15) | Over 7 year period | G1: 20% G2: 47% | Otorrhea G1: 20% G2: 13% Occlusion G1: 20% G2: 40% Granulation G1: 1 ear (6%) G2: 1 ear (6%) | Perforation G1: 6% G2: 6% | Cholesteatoma G1: 0% G2: 0%
Abdullah et al., 1994^84^ NRCT by ear | G1: Trimmed high grade silicone Shah permavent tube (N=25) G2: Polyethylene Shah tube (N=25) | 24–29 months | G1: 0 G2: 5.8% | Otorrhea G1: (0%) G2: 2 ears: (8%) | Perforation G1: 0% G2: 4% | Tympanosclerosis G1: 7 ears G2: 11 ears None in both ears: 2 children
Licameli et al., 2008^85^ RCT by ear | G1: Phosphorylcholine-coated fluoroplastic Armstrong tube (N=70) G2: Uncoated fluoroplastic Armstrong tube (N=70) | 24 months | NR | Otorrhea G1: 8.7% G2: 7.5% p=0.74 Occlusion G1: 10.3% G2: 13.4 p=0.53 Granulation G1: 4.4% G2: 6.0% p=0.66 | Perforation G1: 4.0% G2: 0% p=0.24 | NR
Iwaki et al., 1998^86^ Retrospective cohort by ear | G1: Teflon Shepard tube (N=75 ears) G2: Silicone Goode-T tube (N=39 ears) G3: Silicone Paparella II tube (N=106 ears) | 12 to 24 months | NR | Otorrhea G1: 9 ears (12%)^a^ G2: 14 ears (36%)^a^ G3: 40 ears (38%)^a^ G2 or G3 vs. G1 diff p<0.01 Granulation G1: 0 ears G2: 0 ears G3: 8 ears (7.5%) G1 vs. G3: p<0.05 | Perforation G1: 0% G2: 7.7% G3: 10.4% G1 vs. G2: p<0.05 G1 vs. G3: p<0.01 Atelectasis G1: 0% G2: 1 ear (2.6%) G3:2 ears (1.9%) p=NR Retraction G1: 12% G2: 10.2% G3: 6.6% p=NR | Cholesteatoma G1: 1.3% G2: 0% G3: 0% p=NS
Slack, Gardner, and Chatfield, 1987^45^ Retrospective cohort by ear | G1: Shepard tube (N=214) G2: Shah tube (N=70) G3: Paparella tube (N=275) | 12 to 24 mos | NR | Otorrhea G1: 5.7% G2: 5.6% G3: 40% G1 vs. G3: p<0.001 G2 vs. G3: p<0.001 | NR | NR
Ovesen et al., 2000^87^ RCT by person and by ear | G1: TT^a^ + N-acetylcysteine instilled in one ear (N=37 ears) G2: TT^a^ + placebo vehicle in one ear (N=38 ears) G3 (contralateral ear): TT^a^ (N=75) | 29 mos | G1: 5 ears (14%) G2: 14 ears (37%) G3: 24 ears (32%) 3-way diff: p<0.025 | Otorrhea G1: 24% G2: 13% G3: 16% p>0.15 | NR | NR
Hellstrom et al., 2011^21^ | NRCT Pearson et al., 1996^79^ (N=165) G1: Teflon Shah TT + steroid/abx otic drops postoperatively G2: Teflon Shah TT | 3 mos | NR | Otorrhea G1:0 G2:2 | NR | NR
Hellstrom et al., 2011^21^ | NRCT (by ear) Kinsella et al., 1994^80^ G1: Shepard TT, no-touch technique (N=60) G2: Shepard TT, touch technique (N=60) | 7–10 days post-operation | NR | Otorrhea G1: 1.67% G2: 1.67% | NR | NR
Hellstrom et al., 2011^21^ | RCT (by ear) Hampal et al., 1991^75^ G1: Shah TT (N=105 ears) G2: Mini-shah TT (N=105 ears) Companion: Dingle et al., 1993^144^ | 1 year | G1:0 G2: 0 | NR | NR | Tympanosclerosis G1: 40% G2: 23% p<0.01
Hellstrom et al., 2011^21^ | RCT (by ear) Hampal et al., 1991^75^ G1: Shah TT (N=105 ears) G2: Mini-shah TT (N=105 ears) Companion: Dingle et al., 1993^144^ | 2 years (N=92) | 14/92 children underwent surgery for recurrent OME; NR by group. | NR | NR | Tympanosclerosis (grades 1–4) G1: 19 of 39 ears G2: 38 of 39 ears
Hellstrom et al., 2011^21^ | RCT by ear Heaton et al., 1991^76^ G1: Shepard TT (N=131) G2: Sheehy TT (N=129) | 15–36 months | NR | | Perforation G1: 2% G2: 1% p=NS | Cholesteatoma G1: 27% G2: 30% p=NS Tympanosclerosis G1: 28%^a^ G2: 31%^a^ p=NS
Hellstrom et al., 2011^21^ | G1: Anterior placement of Shepard TT in TM (N=96 ears) G2: Posterior placement of Shepard TT in TM (N=35 ears) G3: Anterior placement of Sheehy TT in TM (N=95 ears) G4: Posterior placement of Sheehy TT in TM (N=34 ears) | 15–36 months | NR | Otorrhea G1: 5 ears G2: 2 ears G3: 9 ears G4: 3 ears | NR | Tympanosclerosis G1: 31 ears G2: 6 ears G3: 31 ears G4: 9 ears
Hellstrom et al., 2011^21^ | RCT, by ear Salam and Cable, 1993^81^ G1:Sheehy collar (N=162) G2: Sheehy collar plus betnesol-N drops (N=162) | 2 weeks | NR | Otorrhea G1: 8.6% G2: 1.9% p<0.01 Occlusion G1: 4.3% G2: 1.9% p>0.005 | NR | NR
Hellstrom et al., 2011^21^ | RCT, by ear Hampton and Adams, 1996^82^ G1: Armstrong TT placed anteriorly (N=109) G2: Armstrong TT placed posteriorly (N=109) | 3–29 months | NR | NR | Perforation G1: 1.8% G2: 3.7% p>0.05 | NR
Hellstrom et al., 2011^21^ | RCT, by ear Hampton and Adams, 1996^82^ G1: Armstrong TT placed anteriorly (N=109) G2: Armstrong TT placed posteriorly (N=109) | 1 month | NR | Occlusion G1: 3 G2: 4 p=0.85 | NR | NR
Hellstrom et al., 2011^21^ | 1 RCT (by ear) 2 articles Youngs and Gartland,1988^78^ Companion: McRae, et al.,1989^90^ G1: Shah Teflon plus aspiration (N=53) G2: Shah Teflon no aspiration (N=53) | 3 months | NR | Occlusion G1: 7 G2: 4 p=0.72 | NR | NR
Hellstrom et al., 2011^21^ | 1 RCT (by ear) 2 articles Youngs and Gartland,1988^78^ Companion: McRae, et al.,1989^90^ G1: Shah Teflon plus aspiration (N=53) G2: Shah Teflon no aspiration (N=53) | 24 months (N=76 ears) | NR | NR | NR | Tympanosclerosis G1: 66%^a^ G2: 47%^a^ p<0.05

diff = difference; G = group; mos = months; N = number; NR = not reported; NRCT = nonrandomized controlled trial; NS = not sufficient; RCT = randomized controlled trial; TM = tympanic membrane; TT = tympanostomy tubes; vs. = versus

a Calculated by reviewer.

##### Otorrhea

Otorrhea was the most frequently studied harm in the included studies. Similar to our benefits analysis for KQ 1, we examined harms in relation to TT design (short or long term retention), placement technique, and material.

Otorrhea rates were found to vary by type of TT inserted. Based on one RCT and two observational studies, longer-term TT had higher otorrhea rates; Goode-T made with silicon (longer term) versus Armstrong made with Teflon,83 Paparella (longer term) versus Shepard and Shah tubes at 12, 24, and 30 months after placement45 and Paparella versus Shepard TT at 24 months.86 However, the studies did not report otorrhea rates per day that the TT were in place; thus, it is unclear if the design of long-term TT increased otorrhea or if this result was solely because the TT were in place for a longer time.

Otorrhea rates were lower in subjects who got N-acetylcysteine at the time of insertion.87 Ottorhea rates were also lower at 2 weeks post-TT insertion after infusion of benesol-N.81 The technique of touching by the surgeon versus not touching during TT insertion did not change otorrhea rates.80 Two studies of topical antibiotics at the time of TT insertion found decreased rates of otorrhea (data not provided).79,81

Abdullah (1990) and Licamelli (2008) studied otorrhea differences based on TT material, and found no significant difference based on silicon versus polyethylene84 or phosphorylcholine coating of Armstrong tubes.85 Heaton et al found no differences based on anterior versus posterior placement.76

##### Repeat Tube Placement

In one small trial (N=30), patients who received Teflon Armstrong tubes (shorter term) were more likely to undergo repeat TT placement than those receiving the silicone Goode-T tube (47% vs. 20%, respectively).83 Patients who received N-acetylcysteine at the time of TT insertion, compared with placebo or the contralateral ear were also less likely to have repeat TT placement.87

##### Other Harms

Other side effects and potential harms found in studies included risk of cholesteatoma, occlusion, rate of tympanosclerosis, and presence of granulation tissue. Groups did not differ significantly in cholesteatoma formation by tube type.76,83,86 Results were mixed in three studies examining occlusion rates.78,83,85

In relation to tympanosclerosis, standard Shah TT had higher tympanosclerosis rates than mini-Shah TT, but the standard Shah also had higher retention rates.144 Abdullah et al. found a possible increased rate of tympanosclerosis for polyethylene Shah TT compared with silicone permavent Shah TT (65% vs. 41%, no p value reported).84 Aspiration prior to TT placement increased the tympanosclerosis rate in one study over 24 months (p<0.05).90 Finally, Iwaki et al. demonstrated higher rates of granulation tissue at 24 months for silicone Paparella TT compared with either Goode-T silicone or Teflon Shepard TT (7.5%, 0%, 0% respectively, p<0.05).86

### Surgical Interventions: Tympanostomy Tubes Versus Watchful Waiting or Myringotomy

#### Key Points

- Otorrhea and tympanosclerosis were found to occur more frequently in ears with TT (strength of evidence moderate).
- Evidence was insufficient for all other side effects or harms.

#### Detailed Synthesis

We identified nine studies that compared side effects by treatment (Table 32). Seven studies19,96,98,102,104,140,145 were discussed in at least one of the two systematic reviews. We included two additional studies91,92 (Table 32).

Table 32 Harms or tolerability: Tympanostomy tubes versus watchful waiting or myringotomy

Study | Arm (N) | Study Duration Until Outcome Measurement | Repeat Tubes/Treatment Failure | Otorrhea/AOM/Otalgia | Atrophy | Tympanosclerosis/Myringosclerosis | Perforation | Cholesteatoma | Granulation
Browning et al., 2010^22^ | 1 RCT by ear Dempster et al., 1993^98^ (N=78 ears) | 1 year | NR | NR | NR | TT vs. none 11 ears vs. 1 ear | NR | NR | NR
Browning et al., 2010^22^ | 1 RCT by child MRC Target, 2012^19^ (N=248) | 24 months | NR | NR | NR | TT vs. WW 20% vs. 0% | Any perforation: 8 of 635 ears with TT. Lasting perforations: 6 of 635 | NR | NR
Browning et al., 2010^22^ | 1 RCT Rovers, 2000^140^ (N=187) | 6 months | NR | Otorrhea TT vs. WW 49% (95% CI, 39% to 60%) vs. 10% (95% CI, 4% to 16%) | NR | NR | NR | NR | NR
Browning et al., 2010^22^ | 1 RCT Gates, 1989^102^ (N=236) G1: Myr G2: TT | NR | G1:31.8% G2 20.2% p=0.004^a^ | AOM TT vs. non-tubed 27% vs. 11% | NR | NR | G1: 3% G2: 2.2% | G1: 3% G2: 2.2% | NR
Browning et al., 2010^22^ | 1 RCT Gates, 1989^102^ (N=236) G1: Myr G2: TT | NR | G1:31.8% G2 20.2% p=0.004^a^ | Otorrhea G1: 22% G2: 29% | NR | NR | G1: 0 G2: 0 | G1: 0 G2: 0 | NR
Hellstrom et al., 2011^21^ | 1 RCT by ear Maw and Bawden145 (N=400 ears) G1: TT G2: no TT | 12 mos | NR | NR | G1: 5.6% G2: 0.5% Atelectasis G1: 3.7% G2: 4.2% Attic retraction: G1: 0.9% G2: 2.9% | G1: 14% G2: 7.5% p=NR | NR | NR | NR
Hellstrom et al., 2011^21^ | 1 RCT Johnston, 2004^104^ G1: Early TT (N=147) G2: Late TT (N=134) | F/U at 5/6 years of age | NR | NR | TT worse in G1 RR: 17.4 | TT worse in G1 RR diff: 24.5 | NR | NR | NR
Hellstrom et al., 2011^21^ | 1 RCT Mandel96 (N=111) | 3 years | NR | 1 year TT: 0.58 Myr: 0.17 No surg: 0.28 p=0.01 3 years TT: 0.36 Myr: 0.29 No surg: 0.29 | | NR | TT: 12 ears | Myr arm: 2 children | NR
Koopman et al., 2004^91^ | G1: TT + cold knife Myr (N=208) G2: Laser Myr (N=208) | NR | NR | Otorrhea G1 more often than G2 p=0.0020 Otalgia without inflammation G1: 1 G2: 0 | NR | NR | NR | NR | NR
Mandel et al., 1989^92^ | Without “significant” hearing loss G1: Myr G2: Myr + TT G3: No surgery With “significant” hearing loss G4: Myr G5: Myr + TT | NR | Tx failure: G1: 0.53 G2: 0 G3: 0.59 G4: 0.75 G5: 0 p=NS | Otorrhea episodes/person yr G1: 0.15 G2: 0.41 G3: 0.23 G4: 0.34 G5: 0.61 In non-TT groups this is tx failures received TT | NR | NR | NR | G3: 1 ear | NR

AOM = acute otitis media; CI = confidence interval; Myr = myringotomy; NR = not reported; NS = not significant RR = relative risk; TT = tympanostomy tubes; tx = treatment; RR= risk ratio; vs. = versus; WW = watchful waiting; yr = year

a Calculated by reviewer.

##### Otorrhea/AOM/Otalgia

Otorrhea occurs with a perforated tympanic membrane or an in-place TT, so that outcome is unlikely to occur with watchful waiting.91,92,140 Higher rates of otorrhea were found in TT arms at 6 months.140 Mandel et al. found a higher rate of otorrhea at 1 year in the TT arm, compared with the myringotomy and no surgery arms but similar rates by 3 years in one study.96 They found higher rates in the TT group at 3 years in an earlier study.92

##### Tympanosclerosis

Tympanosclerosis rates were higher in the TT groups in three studies in subsequent examinations after the tubes had been extruded.19,98,145

##### Atrophy

Three studies evaluated atrophy subsequent to TT versus myringotomy or watchful waiting and results were mixed. TT were associated with higher rates of atrophy in two studies104,145 and no different in a third study.96

##### Other Harms

Three studies evaluated perforation following TT insertion in comparison with myringotomy or no treatment. In all studies, TT were associated with low rates of perforation.19,92,102 Similarly, Gates et al. found a low and comparable rate of cholesteatoma in the TT and myringotomy arms.102

### Surgical Interventions: Tympanostomy Tubes Plus Adenoidectomy Versus Myringotomy Plus Adenoidectomy or Adenoidectomy Alone

#### Key Points

- The risk of tympanosclerosis was higher in patients receiving TT than in patients receiving myringotomy or no surgery in addition to adenoidectomy (strength of evidence was moderate).
- The evidence for otorrhea was insufficient because of inadequate data to perform statistical difference tests.
- Evidence for repeat tubes and perforation was insufficient because of conflicting results or inadequate data to perform statistical difference tests.

#### Detailed Synthesis

The evidence for harms related to TT in comparison with myringotomy or no surgery when added to adenoidectomy is based on six studies we identified 109,111–115 plus three102,105,106 that were in the Hellstrom review.21 All but two109,111 compared TT with myringotomy. Harms included repeat TT, otorrhea, perforation, and tympanosclerosis (Table 33).

Table 33 Harms or tolerability: Tympanostomy tubes plus adenoidectomy versus myringotomy plus adenoidectomy or adenoidectomy alone

Study | Arm (N) | Study Duration Until Outcome Measurement | Repeat Tubes/Treatment Failure | Otorrhea | Perforation | Tympanosclerosis
Brown et al., 1978^109^ | G1: TT + AD (N=55) G2: AD (N=55) | 5 yrs. | NR | NR | NR | G1: N=23 G2: N=0 p<0.05
Lildholdt, 1979^111^ | G1: TT+ AD (N=91 ears) G2: AD (N=91 ears) | 18 mos | G1: 14% (reinsertion) G2: 0.6% (later insertion) | NR | NR | NR
D’Eredita and Shah, 2006^112^ | G1: CDLM + AD (N=15 ears) G2: TT + AD (N=15 ears) | 30 days | NR | Otorrhea G1: 0% G2: 26.7% p=NR | NR | NR
D’Eredita and Shah, 2006^112^ | G1: CDLM + AD (N=15 ears) G2: TT + AD (N=15 ears)
D’Eredita and Shah, 2006^112^ | G1: CDLM + AD (N=15 ears) G2: TT + AD (N=15 ears) | 2 months | NR | G1: 2 reports | NR | NR
D’Eredita and Shah, 2006^112^ | G1: CDLM + AD (N=15 ears) G2: TT + AD (N=15 ears)
D’Eredita and Shah, 2006^112^ | G1: CDLM + AD (N=15 ears) G2: TT + AD (N=15 ears) | 3 months | NR | G2: 4 reports | NR | NR
D’Eredita and Shah, 2006^112^ | G1: CDLM + AD (N=15 ears) G2: TT + AD (N=15 ears)
D’Eredita and Shah, 2006^112^ | G1: CDLM + AD (N=15 ears) G2: TT + AD (N=15 ears) | 1 year | NR | | G1: 0 G2: 6.7% p=NR
Popova et al., 2010^113^ | G1: Donaldson TT + adenoidectomy (N=42) G2: Myr + adenoidectomy (N=36) | NR | NR | G1: 40% G2: 0 Diff=.40 (95% CI, 0.252 to 0.548)^a^ | NR | NR
Shishegar and Hobhoghi, 2007^114^ | G1: Shepard TT + adenoidectomy (N=30 ears) G2: Myr + AD (N=30 ears) | >6 months | NR | G1: 27% G2: 7% | NR | NR
Vlastos et al., 2011^115^ | G1: Shepard TT + adenoidectomy (N=25) G2: Myr + adenoidectomy (N=27) | 12 mos | G1: 0 G2: 20% (TT in nonTT group) | G1: 0 G2: 0 | G1: 0 G2: 0 | NR
Hellstrom, 2011 | NRCT by ear, Bonding & Tos 1985^105^ Companions | 3 yrs. | NR | NR | G1: 3.1% G2: 2.1% | G!: 48% G2:19% p<0.001
Hellstrom, 2011 | Tos and Stangerup, 1989^108^ | 6–7 yrs | NR | NR | NR | G1: 59% G2: 13% p<0.05
Hellstrom, 2011 | Caye-Thomasen, et al., 2008^43^ | 25 yrs G1: (N=146) G2 (N=146) | | | | G1:50% G2: 20% p<0.001
Hellstrom, 2011 | G1: Adenoidectomy + Donaldson TT G2: Adenoidectomy + Myr (N=224, 193 analyzed)
Hellstrom, 2011
Hellstrom, 2011 | NRCT by ear Lildholt, 1983^106^ G1: Donaldson TT +adenoidectomy (N=150) G2: Adenoidectomy (N=150) | 5 yrs | | G1: 2–10% G2: 0% | | G1: 47% G2: 8.7%
Hellstrom, 2011
Hellstrom, 2011 | RCT by person Gates, 1989^102^ G1: AD+Myr (N=130) G2: AD+TT (N=125) | 2 years | G1: 13.1% G2: 13.6% p=.932

AD = adenoidectomy; CDLM = Contact diode laser myringotomy; G = group; Myr = myringotomy; mos = months; NRCT = nonrandomized controlled trial; RCT = randomized controlled trial; TT = tympanostomy tubes

a Calculated by investigators.

##### Tympanosclerosis

Three studies contributed to the evidence for tympanosclerosis for TT in comparison to myringotomy or no surgery (Table 33).105,108,109,111 Later followups43,108 of the Bonding and Tos cohort105 also contributed to the evidence. One study (three reports)43,105,108 examined TT plus adenoidectomy in comparison with myringotomy plus adenoidectomy. Results indicate that ears with TT had a significantly higher rate of tympanosclerosis than did ears with myringotomy from 3 years postsurgery to 25 years postsurgery, with differences as great as 46 percent (p<.001) at 6 to 7 years post-treatment. Brown109 and Lildholdt106 compared tympanosclerosis in tubed ears and ears without surgery. Both found a higher rate of about 40% in tubed ears at 5-year followup, although only Brown provided a significance test (p<.05).

##### Otorrhea

Five studies,57,106,113–115 three of which were assigned by ears, examined otorrhea. In the four studies in which ears received myringotomy,57,113–115 rates of otorrhea in the tubed ears were between 0% and 40%, with no to low rates in the ears with myringotomy. However, statistical differences were only calculated for the Popova et al., 2010^113^ sample where TT was associated with a higher rate of otorrhea (Diff = .40, [95% CI, 0.252 to 0.548]). In the one study in which comparison ears received no surgery,106 the rate of otorrhea was 10 percent in tubed ears compared with no episodes in the ears with no surgery.

##### Perforation

Three studies57,105,115 examined perforation in tubed ears compared with ears with myringotomy. At 1 year post-treatment, D’Eredita and Shah, 2006^112^ found one case in the ear with TT as compared with none in the ear with myringotomy only. Similarly, Vlastos and colleagues, 2011^115^ found no cases in either ears with TT or ears with myringotomy. Lildholdt, 1983^106^ found rates of 3.1 percent in tubed ears as compared with 2.1 percent in ears with myringotomy at 3 years post-treatment.

##### Repeat Tubes or Treatment Failure

Three studies102,111,115 evaluated the need for repeat TT or treatment failure. Vlastos et al. demonstrated that 20 percent of children who initially had adenoidectomy without TT eventually had a TT placed. However, neither Lildholt et al. nor Gates et al. found statistically significant differences in reoperation rates in ears that received no intervention or myringotomy, respectively, compared with TT when adenoidectomy was performed.

### Surgical Interventions: Myringotomy Comparisons

#### Key Points

- We found no evidence examining harms or tolerability.

### Surgical Interventions: Myringotomy Plus Adenoidectomy Comparisons

#### Key Points

- We found no evidence examining harms or tolerability.

### Surgical Interventions: Adenoidectomy Versus Other Interventions

#### Key Points

- In two studies, one child experienced postoperative hemorrhage following adenoidectomy.19,95,102 Strength of evidence is low.
- Based on evidence from one study; 0.8 percent of operated ears had lasting perforations and 20 percent had tympanosclerosis.19 Strength of evidence is insufficient.

#### Detailed Synthesis

Harms from adenoidectomy surgery were rare in the included evidence. Two studies reported that one patient hemorrhaged as a result of the surgery (Table 34).19,95,102

Table 34 Treatment harms: Adenoidectomy versus other interventions

Study | Arm (N) | Study Duration Until Outcome Measurement | Repeat Tubes/Treatment Failure | Otorrhea, Perforation | Tympanosclerosis/Other Harms
RCT: Paradise et al., 1990^74,a^ | G1: Adenoidectomy G2: No treatment (N=99) | | Of 125 who received adenoidectomy, none developed anesthetic complications Mean # of TT/subject (range) procedure Year 1 G1: 0.13 (0–1) G2: 0.29 (0–1) Year 2 G1: 0.13 (0–2) G2: 0.26 (0–2) Year 3 G1: 0.08 (0–1) G2: 0.13 (0–1) | Otorrhea, Mean #/subject (range) Year 1 G1: 0.13 (0–1) G2: 0.13 (0–2) Year 2 G1: 0.09 (0–1) G2: 0.14 (0–1) Year 3 G1: 0.05 (0–1) G2: 0.07 (0–1)
RCT: Casselbrant et al., 2009^119^ | G1: Adenoidectomy+ myr + bilateral TT G2: Myr + bilateral TT (18 mos: N=44) (36 mos: N=39) | | | Otorrhea,1 or more episodes: 0–18 mos: G1: 41% G2:36% Diff G1 vs. G2: p = 0.59 0–36 mos: G1: 47% G2:45% Diff G1 vs. G2: p = 0.59
RCT: Gates et al., 1987^95^ Companion Gates et al., 1989^102^ | G1: Myr (N=107) G2: Bilateral Shepard TT (N=129) G3: Adenoidectomy + Myr (N=130) G4: Adenoidectomy + Bilateral Shepard TT (N=125) | | Surgical retreatments: G1: 46% G2: 24% G3: 12% G4: 11% p = 0.001 | Otorrhea, 1 or more episodes: G1: 22% G2: 29% G3: 19% G4: 24% p = 0.009 | 1 patient bled after adenoidectomy surgery, no other adenoidectomy complications, no deaths
MRC TARGET, 2012^19^ | G1: Adenoidectomy + Myr + Bilateral Shepard TT G2: Myr + bilateral Shepard TT G3: WW (N = 376) | | | Perforation 5 of 635 ears may have lasting perforations, based on observed followup. | Tympanosclerosis 20% in operated ears vs. 0% in unoperated Other, hemorrhage 1 adenoidectomy post-operative hemorrhage (0.6%)

G = group; Myr = myringotomy; mos = months; NRCT = nonrandomized controlled trial; RCT = randomized controlled trial; TARGET = Trial of Alternative Regimens in Glue Ear Treatment; TT = tympanostomy tubes; vs. = versus; WW = watchful waiting

### Pharmaceutical Interventions: Oral or Topical Nasal Steroids

#### Key Points

- Groups did not differ significantly in mild adverse events such as nasal stinging (low strength of evidence).
- Evidence concerning serious harms was sparse (insufficient strength of evidence).

#### Detailed Synthesis

The earlier systematic review focusing on steroid treatment for OME found no serious or lasting harms reported in five studies of oral steroids and two studies of topical steroids (Table 35).31 The review update found no difference in mild to moderate adverse events in a meta-analysis of two RCTs comparing oral steroids plus antibiotics versus control plus antibiotics, at 2 weeks to 6 months, RR=1.34 (95% CI, 0.84 to 2.14) (N=255).32 The Williamson et al. study found no significant difference at 3 months between the topical steroid group and control in relation to stinging nose, nose bleed, dry throat, or cough.20,121

Table 35 Treatment harms or tolerability: Oral or topical nasal steroids

Study | Arm (N) | Study Duration Until Outcome Measurement | Serious Or Lasting Harm Outcomes | Mild Adverse Outcomes
Thomas et al., 2010^31^ Systematic review International | NR | Variable | No serious or lasting harms reported in 5 studies of oral steroids or 2 studies of topical intranasal steroids. | Some studies mentioned mild adverse outcomes: vomiting, diarrhea, dermatitis, transient nasal stinging, and epistaxis.
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^ | MA: 2 RCTs Oral steroids plus antibiotic vs. control plus antibiotic Hemlin et al., 1997^128^ Mandel et al., 2002^125^ (N=255) | 2 weeks to 6 months | | Mild to moderate adverse events RR: 1.34 (95% CI, 0.84 to 2.14)
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^ | 1 RCT: Giebink et al, 1990^122^ Oral steroid vs. control (N=76) | | | “No significant hematologic complications.” 1 prednisone patient was neutropenic 2 weeks after randomization, not leukopenic, remained well.14/18 prednisone-treated patients had depressed cortisol values; of these, 7 had normal values between 2 and 4 days of stopping treatment, 1 normal values at day 14, and 6 normal values at days 17–36 post-treatment.
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^ | 1 RCT: Niederman et al., 1984^124^ Oral steroid vs. control (N=22) | 5 weeks | No significant adverse effects were seen in any study participant.
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^ | 1 RCT: Hemlin et al., 1997^128^ G1: Oral steroid plus antibiotic G2: Control plus antibiotic (N=140) | | | Dermatitis G1: 1.7% G2: 0.0% Diarrhea G1: 6.7% G2: 3.3% Loose stools G1: 3.3% G2: 3.3% Vomiting G1: 1.7% G2: 4.9% Stomach pain G1: 3.3% G2: 3.3% Gastroenteritis G1: 0/0% G2: 1.7%
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^ | Mandel et al., 2002^125^ G1: Oral steroid plus antibiotic G2: Control plus antibiotic (N=144) | | | Hyperactivity G1: N=10 G2: N=6 Increased appetite G1: N=8 G2: N=4 Vomiting G1: N=3 G2: N=2 Diarrhea G1: N=4 G2: N=1 Irritability G1: N=1 G2: N=2 Abdominal discomfort G1: N=1 G2: N=2 Hives G1: N=0 G2: N=1 Other rash G1: N=4 G2: N=2
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^ | 1 RCT^a^ Shapiro et al., 1982^132^ Intranasal steroid vs. Control | | | No sig declining trend for cortisol levels of steroid versus placebo patients (p=0.55) and overall differences in cortisol levels from initiation to conclusion were not statistically sig for inter- or intra- group variation.
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^ | 1 RCT^a^ Williamson et al., 2010^121^ Williamson et al., 2009^20^ | 3 months
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^ | G1: 9/85 (11%) G2: 9/85 (11%) | | | Stinging nose: RR: 1.00 (95% CI, 0.42 to 2.40
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^ | G1: 10/86 (12%) G2: 6/84 (7%) | | | Nose bleed: RR: 1.63 (95% CI, 0.62 to 4.28)
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^ | G1: 10/85 (12%) G2: 7/83 (8%) | | | Dry throat: RR:1.40 (95% CI, 0.56 to 3.49)
Simpson et al., 2011^32^ Systematic review Update of Thomas et al.,2010^31^ | G1: 19/86 (22%) G2: 11/83 (13%) | | | Cough: RR: 1.67 (95% CI, 0.85 to 3.29) Any adverse event: RR: 1.26 (95% CI, 0.80 to 1.99)

CI= confidence interval; G = group; MA = meta-analysis; N = number; NR = not reported; RCT = randomized control trial; RR = relative risk; sig = significant; vs. = versus

a Denotes information from update review, Simpson, et al. 2011.^32^

### Nonpharmaceutical: Autoinflation

#### Key Points

- No quantitative information on rates of serious or mild harms was provided (insufficient strength of evidence).

#### Detailed Synthesis

The systematic review stated that no serious or lasting harms were reported in the six studies of autoinflation, but no data were provided (Table 36).30 It reported that, in one trial, a patient stopped treatment because of pain.30

Table 36 Treatment harms or tolerability: Autoinflation

Study | Arm (N) | Study Duration Until Outcome Measurement | Serious or Lasting Harms | Mild Adverse Outcomes
Perera et al., 2009^30^ | NR | Variable | None of the studies included in the review demonstrated a significant difference in the incidence of side effects between the control or intervention groups. | One trial in the systematic review reported that “that one patient stopped the treatment due to the pain caused by the procedure.”

N = number; NR = not reported

## KQ 4 Comparative Effectiveness of Interventions for Subgroups of Patients

One of the explicit goals of this review was to examine treatment options for subgroups of patients including individuals defined by age groups; adults were of particular interest. Our search found very few studies of any subgroups that met our inclusion criteria. We found one study of adults examining autoinflation and one study of children with sleep apnea who received TT or myringotomy. Other subpopulations of interest included those groups at greater risk for OME such as individuals of American Indian, Alaskan, and Asian backgrounds, individuals with cleft palate, Down syndrome, and other craniofacial anomalies. We had no success in finding studies specific to these groups that met our inclusion criteria. Although we did find OME treatment studies for individuals with cleft palate, the studies did not provide data on pretreatment diagnosis of OME using validated procedures.

### Surgical Interventions: Tympanostomy Tube Comparisons

#### Key Points

No studies reported on patient subgroups. Strength of evidence is insufficient.

### Surgical Interventions: Tympanostomy Tubes Versus Watchful Waiting or Myringotomy

#### Key Points

No studies reported on patient subgroups. Strength of evidence is insufficient.

### Surgical Interventions: Tympanostomy Tubes Plus Adenoidectomy Versus Myringotomy Plus Adenoidectomy or Adenoidectomy Alone

#### Key Points

A single study evaluated subgroups of patients (strength of evidence is insufficient).

#### Detailed Synthesis

One study of children with sleep apnea and OME115 did not find important differences in hearing thresholds after placement of TT or myringotomy (see Tables 13 and 29). Among this group of children who had adenoidectomies for sleep apnea and also had OME, quality of life did not change at 12 months between TT or myringotomy groups. At 6 months, results were mixed with some measures improving more quickly in the TT group, while on other measures TT and myringotomy were the same.115 Twenty percent of the children who initially received a myringotomy eventually also received TT.115 We were unable to compare this rate with other identified studies.

### Surgical Interventions: Myringotomy Comparisons

#### Key Points

- The one study examining differences in myringotomy procedures did not examine the comparative effectiveness of the two approaches within subgroups of patients. Evidence is insufficient.

### Surgical Interventions: Myringotomy With Adenoidectomy Comparisons

#### Key Points

No studies of these interventions reported on patient subgroups. Evidence is insufficient.

### Surgical Interventions: Adenoidectomy Versus Other Interventions

#### Key Points

No studies of these interventions reported on patient subgroups. Evidence is insufficient.

### Pharmaceutical Interventions: Oral or Topical Nasal Steroids

#### Key Points

No studies of these interventions reported on patient subgroups. Evidence is insufficient.

### Nonpharmaceutical Interventions: Autoinflation

#### Key Points

- A subgroup of adults who received autoinflation had better middle ear effusion outcomes than controls at end of treatment and 50 days after treatment (Low strength of evidence, one study).

#### Detailed Synthesis

One study in the Cochrane review on autoinflation,30 Lesinskas, 2003,^138^ included adults (Table 37).138 The treatment intervention was a BD Politzer device used twice a day for 10 days, with or without antibiotics. The control group received equal care except for the intervention. Followup and adherence were 100 percent. The outcome measure was a composite measure of recovery from OME based on pneumo-otoscopy, tympanometry, and audiometry. Individuals in the autoinflation group were significantly more likely to experience a complete recovery than those in the control group at both the end of treatment (p<0.001) and at 50 days after treatment (p<0.001). Similarly, the ears of the participants receiving autoinflation had better recovery rates than control ears at both time points (p<0.001).

Table 37 Comparative effectiveness for adults: Autoinflation

Study | Arm (N) | Study Duration Until Outcome Measurement | Composite Measure of Recovery
Perera et al., 2009^30^ | 1 RCT Lesinskas, 2003^138^ Autoinflation vs. control (n=198) | End of treatment (10 weeks) | Individuals: 50.6% vs. 3.8% Ears: 49.2% vs. 3.9% (p<0.001) (favors autoinflation)
Perera et al., 2009^30^ | 1 RCT Lesinskas, 2003^138^ Autoinflation vs. control (n=198) | 50 days after treatment | Individuals: 55.2% vs. 11% Ears: 57.8% vs. 11.8% (p<0.001) (favors autoinflation)

OME = otitis media with effusion; vs. = versus

## KQ 5 Comparative Effectiveness by Health Care Factors

### Key Points

No included studies for any intervention comparisons examined effectiveness by any health care factors.