# References

1 Stool SE, Berg AO, Berman S, et al. Otitis Media With Effusion in Young Children. Agency for Health Care Policy and Research. AHCPR Publication No. 94-0622. Clinical Practice Guideline, No. 12. Rockville, MD. 1994.
2 Shekelle P, Takata G, Chan LS, et al. Diagnosis, History, and Late Effects of Otitis Media With Effusion. Agency for Healthcare Research and Quality. AHRQ Publication No. 03-E023. Evidence Report/Technology Assessment No. 55. (Prepared by Southern California Evidence-based Practice Center under Contract No 290-97-0001, Task Order No. 4). Rockville, MD. 2003.
3 Williamson IG, Dunleavey J, Bain J, et al. The natural history of otitis media with effusion--a three-year study of the incidence and prevalence of abnormal tympanograms in four South West Hampshire infant and first schools. J Laryngol Otol. Nov. 1994;108(11):930-4. [pmid: 7829943].
4 Cantekin EI, Bluestone CD. Membrane ventilating tube for the middle ear. Ann Otol Rhinol Laryngol. Mar–Apr. 1976;85(2 Suppl 25 Pt 2):270-6. [pmid: 1267358].
5 Klein K, Nardelli A, Stafinski T. A systematic review of the safety and effectiveness of fully implantable middle ear hearing devices: the carina and esteem systems. Otol Neurotol. Aug. 2012;33(6):916-21. [pmid: 22772013].
6 Daly KA. Definition and epidemiology of otitis media. Roberts JE, Wallace IF, Henderson FW, editors. Otitis media in young children: Medical, Developmental, and Educational Considerations. Baltimore. Paul Brooks. 1997:3-41.
7 Rosenfeld RM. Natural history of untreated otitis media. Rosenfeld RM, Bluestone CD, editors. Evidence-based otitis media. Hamilton, Ontario. BC Decker. 1999:157-77.
8 Paradise JL, Rockette HE, Colborn DK, et al. Otitis media in 2253 Pittsburgh area infants: prevalence and risk factors during the first two years of life. Pediatrics. Mar. 1997;99(3):318-33. [pmid: 9041282].
9 Tos M. Epidemiology and natural history of secretory otitis. Am J Otol. Oct. 1984;5(6):459-62. [pmid: 6542752].
10 National Collaborating Centre for Women’s and Children’s Health. Surgical Management of Otitis Media With Effusion in Children. NICE Clinical Guideline 60. London. National Institute for Health and Clinical Excellence. 2008.
11 Maw AR. Otitis media with effusion (glue ear). Kerr AG, Groves J, Evans NG, editors. Scott-Browan’s Otolaryngology. 5th ed. London. Butterworths. 1987:159-76.
12 Finkelstein Y, Ophir D, Talmi YP, et al. Adult-onset otitis media with effusion. Arch Otolaryngol Head Neck Surg. May. 1994;120(5):517-27. [pmid: 8172703].
13 Gravel JS, Wallace IF. Effects of otitis media with effusion on hearing in the first 3 years of life. J Speech Lang Hear Res. Jun. 2000;43(3):631-44. [pmid: 10877434].
14 Sano S, Kamide Y, Schachern PA, et al. Micropathologic changes of pars tensa in children with otitis media with effusion. Arch Otolaryngol Head Neck Surg. Aug. 1994;120(8):815-19. [pmid: 8049041].
15 Rosenfeld RM, Culpepper L, Doyle KJ, et al. Clinical practice guideline: Otitis media with effusion. Otolaryngol Head Neck Surg. May. 2004;130(5 Suppl):S95-118. [pmid: 15138413].
16 Takata GS, Chan LS, Morphew T, et al. Evidence assessment of the accuracy of methods of diagnosing middle ear effusion in children with otitis media with effusion. Pediatrics. 2003;112(6):1379-87. [pmid: 14654613].
17 Madell JR. Impact of Otitis Media on Auditory Function. Rosenfeld RM, Bluestone CD, editors. Evidence-Based Otitis Media. Canada. B.C. Decker Inc. 1999:337-51.
18 Deutsch ES, Cook SP, Shaha S, et al. Duration of patency of laser-assisted tympanic membrane fenestration. Arch Otolaryngol Head Neck Surg. Aug. 2003;129(8):825-8. [pmid: 12925339].
19 MRC Multicentre Otitis Media Study Group. Adjuvant adenoidectomy in persistent bilateral otitis media with effusion: hearing and revision surgery outcomes through 2 years in the TARGET randomised trial. Clin Otolaryngol. Apr. 2012;37(2):107-16. [pmid: 22443163].
20 Williamson I, Benge S, Barton S, et al. A double-blind randomised placebo-controlled trial of topical intranasal corticosteroids in 4- to 11-year-old children with persistent bilateral otitis media with effusion in primary care. Health Technol Assess. Aug. 2009;13(37):1-144. [pmid: 19671372].
21 Hellstrom S, Groth A, Jorgensen F, et al. Ventilation tube treatment: a systematic review of the literature. Otolaryngol Head Neck Surg. Sep. 2011;145(3):383-95. [pmid: 21632976].
22 Browning GG, Rovers MM, Williamson I, et al. Grommets (ventilation tubes) for hearing loss associated with otitis media with effusion in children. Cochrane Database Syst Rev. 2010;(10):CD001801. [pmid: 20927726].
23 Gibb AG, Mackenzie IJ. The extrusion rate of grommets. Otolaryngol Head Neck Surg. Dec. 1985;93(6):695-9. [pmid: 3937089].
24 Isaacson G, Rosenfeld RM. Care of the child with tympanostomy tubes: a visual guide for the pediatrician. Pediatrics. Jun. 1994;93(6 Pt 1):924-9. [pmid: 8190578].
25 Which antibiotic for acute otitis media?. Drug Ther Bull. Jul. 5. 1974;12(14):53-4. [pmid: 4142433].
26 Hassmann E, Skotnicka B, Baczek M, et al. Laser myringotomy in otitis media with effusion: long-term follow-up. Eur Arch Otorhinolaryngol. Jul. 2004;261(6):316-20. [pmid: 14551787].
27 Lin SH, Lai CC, Shiao AS. CO2 laser myringotomy in children with otitis media with effusion. J Laryngol Otol. 2006;120(3):188-92. [pmid: 16359145].
28 Sedlmaier B, Jivanjee A, Gutzler R, et al. Ventilation time of the middle ear in otitis media with effusion (OME) after CO2 laser myringotomy. Laryngoscope. Apr. 2002;112(4):661-8. [pmid: 12150520].
29 van den Aardweg MT, Schilder AG, Herkert E, et al. Adenoidectomy for otitis media in children. Cochrane Database Syst Rev. 2010;(1):CD007810. [pmid: 20091650].
30 Perera R, Haynes J, Glasziou P, et al. Autoinflation for hearing loss associated with otitis media with effusion. Cochrane Database Syst Rev. 2006;(4):CD006285. [pmid: 17054290].
31 Thomas CL, Simpson S, Butler CC, et al. Oral or topical nasal steroids for hearing loss associated with otitis media with effusion in children. Cochrane Database Syst Rev. 2006;(3):CD001935. [pmid: 16855980].
32 Simpson Sharon A, Lewis R, van der Voort J, et al. Oral or topical nasal steroids for hearing loss associated with otitis media with effusion in children. Cochrane Database of Systematic Reviews. John Wiley & Sons, Ltd. 2011.
33 Rosenfeld RM, Bluestone CD, editors. Evidence-Based Otitis Media. Ontario. BC Decker Inc. 1999.
34 Griffin GH, Flynn C, Bailey RE, et al. Antihistamines and/or decongestants for otitis media with effusion (OME) in children. Cochrane Database Syst Rev. 2006;(4):CD003423. [pmid: 17054169].
35 Wahl RA, Aldous MB, Worden KA, et al. Echinacea purpurea and osteopathic manipulative treatment in children with recurrent otitis media: a randomized controlled trial. BMC Complement Altern Med. 2008;8:56. [pmid: 18831749].
36 van Zon A, van der Heijden GJ, van Dongen TM, et al. Antibiotics for otitis media with effusion in children. Cochrane Database Syst Rev. 2012;9:CD009163. [pmid: 22972136].
37 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
38 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. J Clin Epidemiol. Oct. 2009;62(10):1006-12. [pmid: 19631508].
39 Lerman SJ, Kucera JC, Brunken JM. Nasopharyngeal carriage of antibiotic-resistant Haemophilus influenzae in healthy children. Pediatrics. Sep. 1979;64(3):287-91. [pmid: 314623].
40 Higgins JP, Altman DG, Gotzsche PC, et al. The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ. 2011;343:d5928. [pmid: 22008217].
41 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
42 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
43 Caye-Thomasen P, Stangerup SE, Jorgensen G, et al. Myringotomy versus ventilation tubes in secretory otitis media: eardrum pathology, hearing, and eustachian tube function 25 years after treatment. Otol Neurotol. Aug. 2008;29(5):649-57. [pmid: 18520632].
44 Tos M, Bonding P, Poulsen G. Tympanosclerosis of the drum in secretory otitis after insertion of grommets. A prospective, comparative study. J Laryngol Otol. Jun. 1983;97(6):489-96. [pmid: 6683295].
45 Slack RW, Gardner JM, Chatfield C. Otorrhoea in children with middle ear ventilation tubes: a comparison of different types of tubes. Clin Otolaryngol Allied Sci. Oct. 1987;12(5):357-60. [pmid: 3427799].
46 Black N, Crowther J, Freeland A. The effectiveness of adenoidectomy in the treatment of glue ear: a randomized controlled trial. Clin Otolaryngol Allied Sci. Jun. 1986;11(3):149-55. [pmid: 3524910].
47 Ruckley RW, Blair RL. Thermal myringotomy (an alternative to grommet insertion in childhood secretory otitis media?). J Laryngol Otol. Feb. 1988;102(2):125-8. [pmid: 3346587].
48 Yagi HI. The surgical treatment of secretory otitis media in children. J Laryngol Otol. Mar. 1977;91(3):267-70. [pmid: 321716].
49 Honjo I, Fujita A, Kurata K, et al. Significance of adenoidectomy in the treatment of secretory otitis media. Adv Otorhinolaryngol. 1992;47:246-50. [pmid: 1456142].
50 Tatar EC, Unal FO, Tatar I, et al. Investigation of surface changes in different types of ventilation tubes using scanning electron microscopy and correlation of findings with clinical follow-up. Int J Pediatr Otorhinolaryngol. Mar. 2006;70(3):411-7. [pmid: 16125252].
51 Karlan MS, Skobel B, Grizzard M, et al. Myringotomy tube materials: bacterial adhesion and infection. Otolaryngol Head Neck Surg. Nov–Dec. 1980;88(6):783-94. [pmid: 7208047].
52 Ullah Z, Ullah M, Ullah S. Surgical management of Otitis Media with Effusion; A prospective study of 120 patients. J Postgrad Med Inst. 2001;15(2):165-70.
53 Moller P, Dingsor G, Breck P, et al. Transtympanic ventilator tubes in the treatment of seromucous otitis. Indications and results. Rev Laryngol Otol Rhinol (Bord). 1992;113(5):389-95. [pmid: 1344560].
54 Gates GA, Avery CA, Prihoda TJ. Effect of adenoidectomy upon children with chronic otitis media with effusion. Laryngoscope. Jan. 1988;98(1):58-63. [pmid: 3336263].
55 Gibson PG, Stuart JE, Wlodarczyk J, et al. Nasal inflammation and chronic ear disease in Australian Aboriginal children. J Paediatr Child Health. Apr. 1996;32(2):143-7. [pmid: 8860389].
56 Bozkurt MK, Calguner M. The efficacy of CO2 laser myringotomy in serous otitis media. Kulak Burun Bogaz Ihtis Derg. 2004;12(3–4):55-9. [pmid: 16010101].
57 D’Eredita R. Contact diode laser myringotomy and mitomycin C in children. Otolaryngol Head Neck Surg. Jun. 2004;130(6):742-6. [pmid: 15195061].
58 Hornigold R, Morley A, Glore RJ, et al. The long-term effect of unilateral t-tube insertion in patients undergoing cleft palate repair: 20-year follow-up of a randomised controlled trial. Clin Otolaryngol. Jun. 2008;33(3):265-8. [pmid: 18559037].
59 Katz S, Schmelzer B, Van Rompaey D. Surgical management of chronic otitis media with effusion. Acta Otorhinolaryngol Belg. 1995;49(1):69-73. [pmid: 7725924].
60 Marshak G, Neriah ZB. Adenoidectomy versus tympanostomy in chronic secretory otitis media. Ann Otol Rhinol Laryngol Suppl. May–Jun. 1980;89(3 Pt 2):316-8. [pmid: 6778336].
61 Matt BH, Miller RP, Meyers RM, et al. Incidence of perforation with Goode T-tube. Int J Pediatr Otorhinolaryngol. Feb. 1991;21(1):1-6. [pmid: 2037413].
62 Robinson PM. Secretory otitis media in the adult. Clin Otolaryngol Allied Sci. Aug. 1987;12(4):297-302. [pmid: 3665139].
63 Siegel GJ, Chandra RK. Laser office ventilation of ears with insertion of tubes. Otolaryngol Head Neck Surg. Jul. 2002;127(1):60-6. [pmid: 12161732].
64 Strachan D, Hope G, Hussain M. Long-term follow-up of children inserted with T-tubes as a primary procedure for otitis media with effusion. Clin Otolaryngol Allied Sci. Dec. 1996;21(6):537-41. [pmid: 9118577].
65 Yaman H, Guclu E, Yilmaz S, et al. Myringosclerosis after tympanostomy tube insertion: relation with tube retention time and gender. Auris Nasus Larynx. Dec. 2010;37(6):676-9. [pmid: 20392579].
66 Zanetti D, Piccioni M, Nassif N, et al. Diode laser myringotomy for chronic otitis media with effusion in adults. Otol Neurotol. Jan. 2005;26(1):12-8. [pmid: 15699714].
67 Paradise JL, Feldman HM, Campbell TF, et al. Tympanostomy tubes and developmental outcomes at 9 to 11 years of age. N Engl J Med. Jan. 18. 2007;356(3):248-61. [pmid: 17229952].
68 Paradise JL, Feldman HM, Campbell TF, et al. Effect of early or delayed insertion of tympanostomy tubes for persistent otitis media on developmental outcomes at the age of three years. N Engl J Med. Apr. 19. 2001;344(16):1179-87. [pmid: 11309632].
69 Paradise JL, Campbell TF, Dollaghan CA, et al. Developmental outcomes after early or delayed insertion of tympanostomy tubes. N Engl J Med. Aug. 11. 2005;353(6):576-86. [pmid: 16093466].
70 Paradise JL, Dollaghan CA, Campbell TF, et al. Otitis media and tympanostomy tube insertion during the first three years of life: developmental outcomes at the age of four years. Pediatrics. Aug. 2003;112(2):265-77. [pmid: 12897272].
71 Paradise JL, Feldman HM, Campbell TF, et al. Early versus delayed insertion of tympanostomy tubes for persistent otitis media: developmental outcomes at the age of three years in relation to prerandomization illness patterns and hearing levels. Pediatr Infect Dis J. Apr. 2003;22(4):309-14. [pmid: 12690269].
72 Paradise JL, Bluestone CD, Colborn DK, et al. Adenoidectomy and adenotonsillectomy for recurrent acute otitis media: parallel randomized clinical trials in children not previously treated with tympanostomy tubes. JAMA. Sep. 8. 1999;282(10):945-53. [pmid: 10485679].
73 Paradise JL, Dollaghan CA, Campbell TF, et al. Language, speech sound production, and cognition in three-year-old children in relation to otitis media in their first three years of life. Pediatrics. May. 2000;105(5):1119-30. [pmid: 10790473].
74 Paradise JL, Bluestone CD, Rogers KD, et al. Efficacy of adenoidectomy for recurrent otitis media in children previously treated with tympanostomy-tube placement. Results of parallel randomized and nonrandomized trials. JAMA. Apr. 18. 1990;263(15):2066-73. [pmid: 2181158].
75 Hampal S, Flood LM, Kumar BU. The mini-grommet and tympanosclerosis. J Laryngol Otol. Mar. 1991;105(3):161-4. [pmid: 2019798].
76 Heaton JM, Bingham BJ, Osborne J. A comparison of performance of Shepard and Sheehy collar button ventilation tubes. J Laryngol Otol. Nov. 1991;105(11):896-8. [pmid: 1761941].
77 Hern JD, Jonathan DA. Insertion of ventilation tubes: does the site matter?. Clin Otolaryngol Allied Sci. Sep. 1999;24(5):424-5. [pmid: 10542923].
78 Youngs RP, Gatland DJ. Is aspiration of middle ear effusions prior to ventilation tube insertion really necessary?. J Otolaryngol. Aug. 1988;17(5):204-6. [pmid: 3063832].
79 Pearson CR, Thomas MR, Cox HJ, et al. A cost-benefit analysis of the post-operative use of antibiotic ear drops following grommet insertion. J Laryngol Otol. Jun. 1996;110(6):527-30. [pmid: 8763369].
80 Kinsella JB, Fenton J, Donnelly MJ, et al. Tympanostomy tubes and early post-operative otorrhea. Int J Pediatr Otorhinolaryngol. Aug. 1994;30(2):111-4. [pmid: 8063496].
81 Salam MA, Cable HR. The use of antibiotic/steroid ear drops to reduce post-operative otorrhoea and blockage of ventilation tubes. A prospective study. J Laryngol Otol. Mar. 1993;107(3):188-9. [pmid: 8509691].
82 Hampton SM, Adams DA. Perforation rates after ventilation tube insertion: does the positioning of the tube matter?. Clin Otolaryngol Allied Sci. Dec. 1996;21(6):548-9. [pmid: 9118580].
83 Wielinga EW, Smyth GD. Comparison of the Goode T-tube with the Armstrong tube in children with chronic otitis media with effusion. J Laryngol Otol. Aug. 1990;104(8):608-10. [pmid: 2230552].
84 Abdullah VA, Pringle MB, Shah NS. Use of the trimmed Shah permavent tube in the management of glue ear. J Laryngol Otol. Apr. 1994;108(4):303-6. [pmid: 8182314].
85 Licameli G, Johnston P, Luz J, et al. Phosphorylcholine-coated antibiotic tympanostomy tubes: are post-tube placement complications reduced?. Int J Pediatr Otorhinolaryngol. Sep. 2008;72(9):1323-8. [pmid: 18635268].
86 Iwaki E, Saito T, Tsuda G, et al. Timing for removal of tympanic ventilation tube in children. Auris Nasus Larynx. Dec. 1998;25(4):361-8. [pmid: 9853658].
87 Ovesen T, Felding JU, Tommerup B, et al. Effect of N-acetylcysteine on the incidence of recurrence of otitis media with effusion and re-insertion of ventilation tubes. Acta Otolaryngol Suppl. 2000;543:79-81. [pmid: 10908985].
88 Lindstrom DR, Reuben B, Jacobson K, et al. Long-term results of Armstrong beveled grommet tympanostomy tubes in children. Laryngoscope. Mar. 2004;114(3):490-4. [pmid: 15091223].
89 Van Heerbeek N, De Saar GM, Mulder JJ. Long-term ventilation tubes: results of 726 insertions. Clin Otolaryngol Allied Sci. Oct. 2002;27(5):378-83. [pmid: 12383301].
90 McRae D, Gatland DJ, Youngs R, et al. Aspiration of middle ear effusions prior to grommet insertion an etiological factor in tympanosclerosis. J Otolaryngol. Aug. 1989;18(5):229-31. [pmid: 2769837].
91 Koopman JP, Reuchlin AG, Kummer EE, et al. Laser myringotomy versus ventilation tubes in children with otitis media with effusion: a randomized trial. Laryngoscope. May. 2004;114(5):844-9. [pmid: 15126741].
92 Mandel EM, Rockette HE, Bluestone CD, et al. Myringotomy with and without tympanostomy tubes for chronic otitis media with effusion. Arch Otolaryngol Head Neck Surg. Oct. 1989;115(10):1217-24. [pmid: 2789777].
93 Maw R, Wilks J, Harvey I, et al. Early surgery compared with watchful waiting for glue ear and effect on language development in preschool children: a randomised trial. Lancet. Mar. 20. 1999;353(9157):960-3. [pmid: 10459904].
94 Rovers MM, Straatman H, Ingels K, et al. The effect of ventilation tubes on language development in infants with otitis media with effusion: A randomized trial. Pediatrics. Sep. 2000;106(3):E42. [pmid: 10969126].
95 Gates GA, Avery CA, Prihoda TJ, et al. Effectiveness of adenoidectomy and tympanostomy tubes in the treatment of chronic otitis media with effusion. N Engl J Med. Dec. 3. 1987;317(23):1444-51. [pmid: 3683478].
96 Mandel EM, Rockette HE, Bluestone CD, et al. Efficacy of myringotomy with and without tympanostomy tubes for chronic otitis media with effusion. Pediatr Infect Dis J. Apr. 1992;11(4):270-7. [pmid: 1565550].
97 Black NA, Sanderson CF, Freeland AP, et al. A randomised controlled trial of surgery for glue ear. BMJ. Jun. 16. 1990;300(6739):1551-6. [pmid: 2196954].
98 Dempster JH, Browning GG, Gatehouse SG. A randomized study of the surgical management of children with persistent otitis media with effusion associated with a hearing impairment. J Laryngol Otol. Apr. 1993;107(4):284-9. [pmid: 8320510].
99 Maw AR, Herod F. Otoscopic, impedance, and audiometric findings in glue ear treated by adenoidectomy and tonsillectomy. A prospective randomised study. Lancet. Jun. 21. 1986;1(8495):1399-402. [pmid: 2872514].
100 Rach GH, Zielhuis GA, van Baarle PW, et al. The effect of treatment with ventilating tubes on language development in preschool children with otitis media with effusion. Clin Otolaryngol Allied Sci. Apr. 1991;16(2):128-32. [pmid: 2070526].
101 Group MM-cOMS. Risk factors for persistence of bilateral otitis media with effusion. Clin Otolaryngol Allied Sci. Apr. 2001;26(2):147-56. [pmid: 11309057].
102 Gates GA, Avery CA, Cooper JC Jr, et al. Chronic secretory otitis media: effects of surgical management. Ann Otol Rhinol Laryngol Suppl. Jan. 1989;138:2-32. [pmid: 2492178].
103 MRC Group M-cOMS. Risk factors for persistence of bilateral otitis media with effusion. Clin Otolaryngol Allied Sci. Apr. 2001;26(2):147-56. [pmid: 11309057].
104 Johnston LC, Feldman HM, Paradise JL, et al. Tympanic membrane abnormalities and hearing levels at the ages of 5 and 6 years in relation to persistent otitis media and tympanostomy tube insertion in the first 3 years of life: a prospective study incorporating a randomized clinical trial. Pediatrics. Jul. 2004;114(1):e58-67. [pmid: 15231974].
105 Bonding P, Tos M. Grommets versus paracentesis in secretory otitis media. A prospective, controlled study. Am J Otol. Nov. 1985;6(6):455-60. [pmid: 4073252].
106 Lildholdt T. Ventilation tubes in secretory otitis media. A randomized, controlled study of the course, the complications, and the sequelae of ventilation tubes. Acta Otolaryngol Suppl. 1983;398:1-28. [pmid: 6316711].
107 Maw AR, Bawden R. The long term outcome of secretory otitis media in children and the effects of surgical treatment: a ten year study. Acta Otorhinolaryngol Belg. 1994;48(4):317-24. [pmid: 7810300].
108 Tos M, Stangerup SE. Hearing loss in tympanosclerosis caused by grommets. Arch Otolaryngol Head Neck Surg. Aug. 1989;115(8):931-5. [pmid: 2751852].
109 Brown MJ, Richards SH, Ambegaokar AG. Grommets and glue ear: a five-year follow up of a controlled trial. J R Soc Med. May. 1978;71(5):353-6. [pmid: 650647].
110 Austin DF. Adenotonsillectomy in the treatment of secretory otitis media. Ear Nose Throat J. Jun. 1994;73(6):367-9. 73. 4. [pmid: 8076535].
111 Lildholdt T. Unilateral grommet insertion and adenoidectomy in bilateral secretory otitis media: preliminary report of the results in 91 children. Clin Otolaryngol Allied Sci. Apr. 1979;4(2):87-93. [pmid: 455774].
112 D’Eredità R, Shah UK. Contact diode laser myringotomy for medium-duration middle ear ventilation in children. Int J Pediatr Otorhinolaryngol. 2006;(6):1077-80. [pmid: 16406076].
113 Popova D, Varbanova S, Popov TM. Comparison between myringotomy and tympanostomy tubes in combination with adenoidectomy in 3–7-year-old children with otitis media with effusion. Int J Pediatr Otorhinolaryngol. Jul. 2010;74(7):777-80. [pmid: 20399511].
114 Shishegar M, Hoghoghi H. Comparison of adenoidectomy and myringotomy with and without tube placement in the short term hearing status of children with otitis media with effusion: a preliminary report. Iran J Med Sci. 2007;(3):169-72.
115 Vlastos IM, Houlakis M, Kandiloros D, et al. Adenoidectomy plus tympanostomy tube insertion versus adenoidectomy plus myringotomy in children with obstructive sleep apnoea syndrome. J Laryngol Otol. Mar. 2011;125(3):274-8. [pmid: 21205368].
116 Ragab SM. The effect of radiofrequency and mitomycin C on the closure rate of human tympanostomy. Otol Neurotol. May. 2005;26(3):355-60. [pmid: 15891633].
117 Szeremeta W, Parameswaran MS, Isaacson G. Adenoidectomy with laser or incisional myringotomy for otitis media with effusion. Laryngoscope. Mar. 2000;110(3 Pt 1):342-5. [pmid: 10718416].
118 Fiellau-Nikolajsen M, Falbe-Hansen J, Knudstrup P. Adenoidectomy for middle ear disorders: a randomized controlled trial. Clin Otolaryngol Allied Sci. Oct. 1980;5(5):323-7. [pmid: 7002375].
119 Casselbrant ML, Mandel EM, Rockette HE, et al. Adenoidectomy for otitis media with effusion in 2–3-year-old children. Int J Pediatr Otorhinolaryngol. Dec. 2009;73(12):1718-24. [pmid: 19819563].
120 Roydhouse N. Adenoidectomy for otitis media with mucoid effusion. Ann Otol Rhinol Laryngol Suppl. May–Jun. 1980;89(3 Pt 2):312-5. [pmid: 6778335].
121 Williamson I, Benge S, Barton S, et al. Topical intranasal corticosteroids in 4–11 year old children with persistent bilateral otitis media with effusion in primary care: double blind randomised placebo controlled trial. BMJ. 2009;339:b4984. [pmid: 20015903].
122 Giebink GS, Batalden PB, Le CT, et al. A controlled trial comparing three treatments for chronic otitis media with effusion. Pediatr Infect Dis J. Jan. 1990;9(1):33-40. [pmid: 2405348].
123 Macknin ML, Jones PK. Oral dexamethasone for treatment of persistent middle ear effusion. Pediatrics. Feb. 1985;75(2):329-35. [pmid: 4038553].
124 Niederman LG, Walter-Bucholtz V, Jabalay T. A comparative trial of steroids versus placebos for treatment of chronic otitis media with effusion. Recent advances in otitis media with effusion. Philadelphia. BC Decker Inc. 1984:273-5.
125 Mandel EM, Casselbrant ML, Rockette HE, et al. Systemic steroid for chronic otitis media with effusion in children. Pediatrics. Dec. 2002;110(6):1071-80. [pmid: 12456902].
126 Podoshin L, Fradis M, Ben-David Y, et al. The efficacy of oral steroids in the treatment of persistent otitis media with effusion. Arch Otolaryngol Head Neck Surg. Dec. 1990;116(12):1404-6. [pmid: 2248740].
127 Tracy JM, Demain JG, Hoffman KM, et al. Intranasal beclomethasone as an adjunct to treatment of chronic middle ear effusion. Ann Allergy Asthma Immunol. Feb. 1998;80(2):198-206. [pmid: 9494455].
128 Hemlin C, Carenfelt C, Papatziamos G. Single dose of betamethasone in combined medical treatment of secretory otitis media. Ann Otol Rhinol Laryngol. May. 1997;106(5):359-63. [pmid: 9153098].
129 Schwartz RH, Puglese J, Schwartz DM. Use of a short course of prednisone for treating middle ear effusion. A double-blind crossover study. Ann Otol Rhinol Laryngol Suppl. May–Jun. 1980;89(3 Pt 2):296-300. [pmid: 6778331].
130 Lambert PR. Oral steroid therapy for chronic middle ear perfusion: a double-blind crossover study. Otolaryngol Head Neck Surg. Sep. 1986;95(2):193-9. [pmid: 3108758].
131 Berman S, Grose K, Nuss R, et al. Management of chronic middle ear effusion with prednisone combined with trimethoprim-sulfamethoxazole. Pediatr Infect Dis J. Aug. 1990;9(8):533-8. [pmid: 2235167].
132 Shapiro GG, Bierman CW, Furukawa CT, et al. Treatment of persistent eustachian tube dysfunction in children with aerosolized nasal dexamethasone phosphate versus placebo. Ann Allergy. 1982:81-5. [pmid: 7103152].
133 Arick DS, Silman S. Nonsurgical home treatment of middle ear effusion and associated hearing loss in children. Part I: clinical trial. Ear Nose Throat J. Sep. 2005;84(9):567-8. 70. 4. 76 passim. [pmid: 16261757].
134 Blanshard JD, Maw AR, Bawden R. Conservative treatment of otitis media with effusion by autoinflation of the middle ear. Clin Otolaryngol Allied Sci. Jun. 1993;18(3):188-92. [pmid: 8365006].
135 Brooker DS, McNeice A. Autoinflation in the treatment of glue ear in children. Clin Otolaryngol Allied Sci. Aug. 1992;17(4):289-90. [pmid: 1526044].
136 Fraser JG, Mehta M, Fraser PA. The medical treatment of secretory otitis media. A clinical trial of three commonly used regimes. J Laryngol Otol. 1977;(9):757-65. [pmid: 335005].
137 Stangerup SE, Sederberg-Olsen J, Balle V. Autoinflation as a treatment of secretory otitis media. A randomized controlled study. Arch Otolaryngol Head Neck Surg. Feb. 1992;118(2):149-52. [pmid: 1540344].
138 Lesinskas E. Factors affecting the results of nonsurgical treatment of secretory otitis media in adults. Auris Nasus Larynx. Feb. 2003;30(1):7-14. [pmid: 12589843].
139 Stangerup S, Tos M. Autoinflation in the treatment of Eustachian tube dysfunction, secretory otitis media and its sequelae. Recent advances in otitis media. Amsterdam/New York. Kugler Publications. 1994:759-63.
140 Rovers MM, Krabbe PF, Straatman H, et al. Randomised controlled trial of the effect of ventilation tubes (grommets) on quality of life at age 1–2 years. Arch Dis Child. Jan. 2001;84(1):45-9. [pmid: 11124783].
141 Hall AJ, Maw AR, Steer CD. Developmental outcomes in early compared with delayed surgery for glue ear up to age 7 years: a randomised controlled trial. Clin Otolaryngol. Feb. 2009;34(1):12-20. [pmid: 19260880].
142 Wilks J, Maw R, Peters TJ, et al. Randomised controlled trial of early surgery versus watchful waiting for glue ear: the effect on behavioural problems in pre-school children. Clin Otolaryngol Allied Sci. Jun. 2000;25(3):209-14. [pmid: 10944051].
143 Maw R, Wilks J, Harvey I, et al. Randomised controlled trial of early surgery versus watchful waiting for glue ear: the effect of langauge development in pre-school children. J Laryngol. 1999;23(Suppl):40. [pmid: 10944051].
144 Dingle AF, Flood LM, Kumar BU, et al. The mini-grommet and tympanosclerosis: results at two years. J Laryngol Otol. Feb. 1993;107(2):108-10. [pmid: 8496640].
145 Maw AR, Bawden R. Tympanic membrane atrophy, scarring, atelectasis and attic retraction in persistent, untreated otitis media with effusion and following ventilation tube insertion. Int J Pediatr Otorhinolaryngol. Nov. 1994;30(3):189-204. [pmid: 7836032].
146 American Academy of Family P, American Academy of O-H. Neck S, et al. Otitis media with effusion. Pediatrics. May. 2004;113(5):1412-29. [pmid: 15121966].
147 Simpson Sharon A, Thomas Chantal L, van der Linden M, et al. Identification of children in the first four years of life for early treatment for otitis media with effusion. Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
148 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. [pmid: 21463926].
149 Kuhl PK, Coffey-Corina S, Padden DM, et al. Early speech perception and later language development: Implications for the “Critical Period". Lang Learn Dev. 2005;1(3–4):237-64.
150 Grant HR, Quiney RE, Mercer DM, et al. Cleft palate and glue ear. Arch Dis Child. Feb. 1988;63(2):176-9. [pmid: 3348665].
151 Paradise JL, Bluestone CD, Felder H. The universality of otitis media in 50 infants with cleft palate. Pediatrics. Jul. 1969;44(1):35-42. [pmid: 5795401].
152 Ponduri S, Bradley R, Ellis PE, et al. The management of otitis media with early routine insertion of grommets in children with cleft palate -- a systematic review. Cleft Palate Craniofac J. Jan. 2009;46(1):30-8. [pmid: 19115800].
153 Paradise JL, Bluestone CD. Early treatment of the universal otitis media of infants with cleft palate. Pediatrics. Jan. 1974;53(1):48-54. [pmid: 4809194].
154 Moller P. Selective use of ventilating tubes in the treatment of secretory otitis media and retractions of the ear drum. Acta Otolaryngol (Stockh). 1982;93(s386):158-60.
155 Zheng Q, Xu H, He Y. Effects of tympanotomy and pressure equilibrium tube insertion during palatoplasty on prognoses of otitis media with effusion. Hua Xi Kou Qiang Yi Xue Za Zhi. Feb. 2003;21(1):28-30. [pmid: 12674616].
156 ClinicalTrials.gov [Internet]. Identifier: NCT01251432 Risk Factors and Potential Causes of Eustachian Tube Dysfunction in Adults. Bethesda (MD). National Library of Medicine (US). 2010. http://clinicaltrials.gov/ct2/show/NCT01251432. Accessed 2012 May 22.
157 Hall JW 3rd, Grose JH, Pillsbury HC. Long-term effects of chronic otitis media on binaural hearing in children. Arch Otolaryngol Head Neck Surg. Aug. 1995;121(8):847-52. [pmid: 7619408].
158 Schilder AG, Snik AF, Straatman H, et al. The effect of otitis media with effusion at preschool age on some aspects of auditory perception at school age. Ear Hear. Jun. 1994;15(3):224-31. [pmid: 8076720].
159 Hall JW 3rd, Grose JH, Dev MB, et al. The effect of otitis media with effusion on complex masking tasks in children. Arch Otolaryngol Head Neck Surg. Aug. 1998;124(8):892-6. [pmid: 9708715].
160 ClinicalTrials.gov [Internet]. Identifier: NCT00809601 Randomized Controlled Study of Transmyringeal Tubes. Bethesda (MD). National Library of Medicine (US). 2008. http://clinicaltrials.gov/ct2/show/NCT00809601. Accessed 2012 May 22.
161 ClinicalTrials.gov [Internet]. Identifier: NCT00546117, A Clinical Trial of Proton Pump Inhibitors to Treat Children With Chronic Otitis Media With Effusion. Bethesda (MD). National Library of Medicine (US). 2007. http://clinicaltrials.gov/ct2/show/NCT00546117. Accessed 2012 May 22.
162 McCoul ED, Goldstein NA, Koliskor B, et al. A prospective study of the effect of gastroesophageal reflux disease treatment on children with otitis media. Arch Otolaryngol Head Neck Surg. Jan. 2011;137(1):35-41. [pmid: 21242544].
163 van der Pol RJ, Smits MJ, van Wijk MP, et al. Efficacy of proton-pump inhibitors in children with gastroesophageal reflux disease: a systematic review. Pediatrics. May. 2011;127(5):925-35. [pmid: 21464183].
164 ClinicalTrials.gov. Identifier: NCT00393900 Middle Ear Pressure Disregulation After Tympanostomy Tube Insertion. Bethesda (MD). National Library of Medicine (US). 2006. http://clinicaltrials.gov/ct2/show/NCT00393900. Accessed 2012 May 22.
165 Jansen AG, Hak E, Veenhoven RH, et al. Pneumococcal conjugate vaccines for preventing otitis media. Cochrane Database Syst Rev. 2009;(2):CD001480. [pmid: 19370566].