# Methods

The Evidence-based Practice Center (EPC) conducted this review using the research methods described in the Agency for Healthcare Research and Quality (AHRQ) “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”37 Further, we used the PRISMA (Preferred Reporting Items for Systematic Reviews and Meta-Analyses) Statement as a guide to ensure transparent reporting.38

## Topic Refinement and Protocol Review

The EPC developed this topic and Key Questions (KQs) through a public process. The topic was nominated through an online public forum and subsequently developed and refined by a team at the RTI-UNC EPC with input from Key Informants in the field. AHRQ posted KQs for public comment (11/17/2011). We incorporated public comments and guidance from a Technical Expert Panel (TEP) into the final research protocol, which was also posted on the AHRQ Web site (3/20/2012).

## Literature Search Strategy

### Search Strategy

During topic refinement, the EPC identified five recently published systematic reviews with results on comparisons of interest for otitis media with effusion (OME) that were conducted either by the Cochrane Collaboration or commissioned by a national governmental agency. The Cochrane Collaboration conducted four of these;22,29–31 the Swedish Council on Technology Assessment in Health Care commissioned the fifth.21 These reviews covered the following OME-related treatment topics: autoinflation, oral and topical steroids, tympanostomy tubes (TT), and adenoidectomy. One additional Cochrane review, updating the earlier oral and topical steroids report, was identified during the update search.32

To avoid repeating or duplicating the work of these other systematic review teams, we limited our search, review, and analysis for each of our KQs to evidence that these systematic reviews included plus evidence from other reports that these recent reviews would not have considered. These additional elements of our review include observational studies, nonrandomized trials, trials published since the last search dates in those reviews, studies focusing on populations excluded from the reviews, such as adults with OME or children with Down syndrome or cleft palate, who may be differently affected by OME and outcomes excluded from the reviews.

We conducted focused searches of MEDLINE® (via PubMed), Embase, CINAHL (nursing and allied health database) and the Cochrane Library. An experienced research librarian used a predefined list of search terms and medical subject headings (MeSH). The librarian completed the first search on 1/8/2012 and conducted an update search on 8/13/2012, during peer review. We limited searches to studies published in English, given limited resources. The complete search strategies, including specific limitations used for each database, are presented in Appendix A.39

We searched unpublished and grey literature relevant to the review topic. Methods for identifying grey literature included a review of trial registries, specifically ClinicalTrials.gov, Health Services Research Projects in Progress (www.nlm.nih.gov/hsrproj/), and the European Union Clinical Trials Register (https://www.clinicaltrialsregister.eu/). Further, AHRQ requested Scientific Information Packets (SIPs) from the developers and distributors of the interventions identified in the literature review. SIPs allow an opportunity for the intervention developers and distributors to provide the EPC with both published and unpublished data that they believe should be considered for the review. We included unpublished studies that met all inclusion criteria and contained enough information on their research methods to permit us to make a standard risk-of-bias assessment of individual studies.

Lastly, we searched reference lists of review articles that were pertinent but did not meet inclusion criteria for studies that we should consider for inclusion in this review.

### Inclusion and Exclusion Criteria

Table 2 outlines the population, intervention, comparators, outcomes, timing, and settings (PICOTS) that define the major inclusion criteria for studies in this review. In the following sections we provide additional detail related to each of these domains as needed.

Table 2 Inclusion and exclusion criteria for studies of otitis media with effusion

Domain | Description
Population | All individuals with OME. Subpopulations include infants; adults; individuals from different racial/ethnic backgrounds; and special populations of any age including individuals with craniofacial abnormalities (e.g., cleft palate), Down syndrome, existing hearing loss, delays in speech and language, or a history of AOM or OME.
Interventions | - Surgical interventions: tympanostomy tubes (also referred to as pressure equalization tubes, grommets and ventilation tubes), myringotomy (also referred to as paracentesis), and adenoidectomy with or without myringotomy.; - Pharmacological treatments: oral or topical nasal steroids.; - Nonpharmacological and nonsurgical treatments or treatment strategies: watchful waiting, complementary and alternative medicine procedures, and autoinflation of the eustachian tube.
Comparator | - Different combinations of the above interventions and strategies. These include head-to-head comparisons of one or more treatments, treatment strategies (e.g., watchful waiting/delayed treatment vs. early treatment), or surgical procedures and techniques (e.g., one type of tympanostomy tube or procedure vs. another or different adjunct therapies to enhance the main intervention). We considered inactive controls in comparison with steroid treatment and usual care in comparison with autoinflation, based on the Cochrane Review inclusion criteria. We considered head-to-head trial evidence and observational study data.
Outcomes | - Clinical outcomes: changes in middle ear fluid, episodes of AOM, hearing thresholds, vestibular function (i.e., balance and coordination).; - Health care utilization: number of office visits, number of surgeries, and medication use.; - Functional and quality-of-life outcomes: hearing, auditory processing, speech and language development, cognitive functioning, academic achievement, attention and behavior, quality of life, and parental satisfaction with care.; - Harms: all reported harms for each treatment option.
Timing | - Shorter studies looking at outcomes 0 to less than 3 months postintervention.; - Longer studies looking at outcomes past 3 months and into adolescence or adulthood.
Setting | Studies conducted in the United States or internationally. Interventions provided in primary care offices where the patient is seen by a pediatrician, family physician, or nurse practitioner; subspecialist physician offices where the patient is seen by an otolaryngologist; surgical settings within a hospital or outpatient clinic; emergency departments; and craniofacial treatment centers.

AOM = acute otitis media; OME = otitis media with effusion

### Population

The population of interest for this review included individuals with OME, defined as a collection of fluid in the middle ear without signs or symptoms of ear infection. Patients had to have OME at the time of the intervention or randomization. We excluded studies that focused on the interventions of interest, such as TTs or myringotomy, but did not isolate results for individuals with only OME, because we could not measure the results in the OME population. Most commonly, studies with a mix of participants also included individuals with acute otitis media (AOM). For the same reason, we also excluded studies that focused on subpopulations of interest, such as adults or children with craniofacial abnormalities, if participants did not all have a diagnosis of OME.

### Interventions

Interventions were limited to the surgical, pharmaceutical, and nonpharmaceutical listed in Table 2. Interventions could include a combination of these interventions, such as adenoidectomy and TT. Interventions could also include adjunct therapy, such as topical substances to reduce the harms from TT.

### Comparators

All studies included in this review had to have at least two groups. Acceptable comparisons included one of the other treatment comparisons included in the review, except that for steroid treatment, we included placebo or nonintervention controls because these were the only comparison studies available. Autoinflation treatment was considered in comparison with treatment without autoinflation with the addition of usual care treatments, provided they were administered equally in both arms.

Studies that included adjunct therapies that were not the focus of the review, such as antibiotic treatment, were included if those therapeutic modalities were provided similarly to all study groups.

### Outcomes

Study outcomes were categorized as clinical (KQ 1), functional (KQ 2), and harms (KQ 3), corresponding to our KQs. Clinical outcomes were grouped as OME signs and symptoms, objective hearing, AOM, vestibular function such as balance and coordination, and use of health care services. Functional outcomes were grouped as perceived hearing ability, speech, language, and cognitive development, behavior, quality of life, and satisfaction with care. Potential harms differed across interventions (i.e., surgical, pharmaceutical, device).

### Timing

We included studies reporting outcomes of fewer than 3 months and 3 months or longer including some studies with only end-of-intervention results.

### Setting

We did not exclude studies based on geography or the setting of service provision.

### Study Designs

Table 3 describes the study design inclusion criteria developed for this report.

Table 3 Study inclusion criteria for review of otitis media with effusion

Category | Criteria for Inclusion
Study design | Meta-analyses, systematic reviews conducted by the Cochrane Collaboration or commissioned by a national governmental agency that were identified during topic refinement and during the update search, RCTs, and nonrandomized controlled trials, prospective and retrospective cohort studies, and case-control studies not included in one of these five systematic reviews.
Study duration | Unlimited.
By ear or by subject studies | Studies could separate groups by subject or by ear. For studies by ear to be considered RCTs, they needed to randomize by ear. Studies that analyzed results by ear and created groups by distinguishing between left ear and right ear are considered nonrandomized controlled trials.
Sample size | Unlimited.
Study location | Unlimited.
Time of publication | Because some of the treatment options of interest have been comprehensively addressed in recent Cochrane or national government-commissioned systematic reviews, we searched only for RCTs not included in the reviews and observational studies published at any time, when a treatment had been addressed in a review from one of these two types of sources. The following summarizes our search strategy for each included treatment option and population of interest. We searched from 1948 forward for:; - All treatments not addressed in one of the identified systematic reviews (namely comparisons of myringotomy).; - Nonrandomized and observational studies across treatment options.; - Studies concerning adults and subpopulations of interest (particularly children with comorbidities such as Down syndrome and craniofacial abnormalities), across treatment options.; - RCTs of complementary and alternative medicine.; - RCTs of treatments not covered in recent systematic reviews including:; ○ Tympanostomy tubes vs. tympanostomy tubes (one review): last search April 2007; ○ Tympanostomy tubes vs. nonsurgical interventions (two reviews): last search April 2007; ○ Adenoidectomy with or without myringotomy (one review): last search March 2008; ○ Oral and topical nasal steroids (one review that was updated): last search August 2010; ○ Autoinflation (one review): last search August 2005; In relation to otherwise healthy children, who would not be considered as members of subpopulations of interest because of comorbidities, we included relevant evidence from each of the recent systematic reviews relevant to our KQs and searched for other RCT literature not included in the reviews.
Language of publication | Given the volume of literature on this topic, we limited our search to publications in the English language.

KQs = Key Questions; RCT = randomized controlled trial

## Study Selection

Six trained members of the research team reviewed article abstracts. Two of the members of the research team independently reviewed all titles and abstracts produced by the searches to determine study eligibility against predefined inclusion and exclusion criteria. Studies marked for possible inclusion by either reviewer underwent a full-text review. Each full-text article was again independently reviewed by two members of the team to determine if it met inclusion criteria. If both reviewers agreed that a study did not meet the eligibility criteria, it was excluded; each reviewer recorded the primary reason for exclusion. If the reviewers disagreed, they resolved conflicts by discussion and consensus or by consulting a third member of the review team. The full-text review form reviewers used is reproduced in Appendix B.

The project coordinator tracked results of the abstract and full-text reviews in an EndNote database (EndNote^®^ X4). Appendix B contains a complete list of studies excluded during the full-text review, denoted by their primary reason for exclusion.

We screened unpublished studies identified through grey literature search and review of SIPs using the same title/abstract and full-text review processes.

## Data Extraction

We developed a template for evidence tables for data synthesis using the PICOTS framework. For the systematic reviews and additional studies that met inclusion criteria, we abstracted relevant information into these evidence tables using Microsoft Excel. We abstracted characteristics of study populations, interventions, comparators, settings, study designs, methods, and results. Data from studies included in the systematic reviews were abstracted as they were presented in the review, although we did refer to the original article to obtain additional information for clarification purposes, to determine if additional data concerning subgroup analyses and outcomes of interest, including harms, were contained in any of the studies and not reported in the systematic review results. Six trained members of the team participated in the data abstraction. One of the reviewers initially abstracted the relevant data from each included article and a second senior member of the team reviewed each data abstraction against the original article for completeness and accuracy.

## Risk-of-Bias Assessment

For each included systematic review and additional study identified, we assessed the potential for selection bias, performance bias, attrition bias, detection bias, and outcome reporting bias using instruments that our EPC previously used successfully (Appendix tables E-1 through E-5). The risk-of-bias assessment was conducted using two tools, one appropriate for trials based on the Cochrane risk- of-bias tool40 and modified by our EPC to be used to also evaluate observational studies (including instructions to reviewers that some questions concerning trial study design would be considered not applicable) and AMSTAR,41 appropriate for systematic reviews. We did not reevaluate the risk of bias of the individual studies included in the five systematic reviews and relied on the original authors’ assessments. In each systematic review, the authors had concluded that all included studies were not high risk of bias. Two independent reviewers rated the risk of bias for each systematic review and each study not included in one of the previous systematic reviews. Disagreements between the two reviewers were resolved by discussion and consensus or by consulting a third member of the team.

Results of this assessment are summarized by a rating of low, medium, or high risk of bias. In general, a study with a low risk of bias has a strong design (adequate randomization and allocation concealment if a trial and controls for concurrent treatments), measures outcomes appropriately including whether there was blinding of the patient and provider (if possible) and outcome assessor, uses appropriate statistical and analytical methods, and reports low attrition. Studies with a medium risk of bias are those that do not meet all criteria required for low risk of bias but do not have flaws that are likely to cause major bias. Studies with a high risk of bias include those with at least one major issue that has the potential to cause significant bias and thus might invalidate the results. Examples of flaws leading to a high risk-of-bias rating include different application of inclusion/exclusion criteria between groups, substantial differences in groups at baseline, high overall attrition, or differential attrition across study conditions, lack of control for concurrent treatment or among cohort studies, lack of control for critical potential confounding, either through design or statistical analyses. A high risk-of-bias rating was assigned to studies in which the critical information needed to make that assessment was not reported or was unclear. To maintain a focus on interpretable evidence, we opted to not include studies with a high risk in the synthesis of benefits findings in the Results chapter of this review. However, we included high risk-of-bias studies in our evidence for harms. We list each study rated as high risk of bias, reconciled reviewer responses to each question in the risk-of-bias instrument, and the main reasons we gave it that rating in Appendix E.

## Data Synthesis

Across all included studies, the populations, interventions, and outcome measures in the additional data were heterogeneous and did not lend themselves to a pooled analysis. They also did not lend themselves to updating the meta-analyses from the five earlier systematic reviews. Thus, we did all analyses qualitatively, based on our reasoned judgment of similarities in measurement of interventions and outcomes, and homogeneity of patient populations. Evidence used in the synthesis included the results from the earlier meta-analyses and additional data from individual studies as presented in the systematic reviews and in the original articles, and data from the articles included from our own searches.

## Strength of the Body of Evidence

In the key points section we present the strength of evidence for each comparison and overarching outcome (e.g., OME signs and symptoms, measured hearing) as specified for each KQ. We graded the strength of evidence based on the guidance established for the AHRQ Effective Health Care Program EPCs conducting comparative effectiveness reviews, as detailed in the paper by Owens and colleagues.37 The EPC approach incorporates four key domains: risk of bias, consistency, directness, and precision of the evidence.

- Risk of bias is determined according to the “degree to which the included studies for a given outcome or comparison have a high likelihood of adequate protection against bias.” It is graded as high, medium, or low.
- Consistency is the “degree to which reported effect sizes from included studies appear to have the same direction of effect.” Each body of evidence is graded as consistent or inconsistent. Consistency cannot be assessed when a body of evidence has only a single study (unknown or not applicable).
- Directness is determined based on “whether the evidence links the interventions directly to health outcomes.” It is graded direct or indirect. In this review, most of the included measures are direct.
- Lastly, precision is determined according to “the degree of certainty surrounding an effect estimate” for each outcome separately. “Precise” indicates a clinically useful conclusion that is statistically significant, and “imprecise” indicates that no conclusion can be drawn as to whether either treatment is superior or whether the treatments are equivalent.

The overall grades for strength of evidence, based on the scores for the above domains, are described in Table 4. Grades reflect the strength of the body of evidence to answer the KQs on the comparative effectiveness, efficacy, and harms of the interventions in this review for each key outcome.

Table 4 Definitions of the grades of overall strength of evidence

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of the effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of the effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

Source: Owens et al., 2010^37^

Two reviewers assessed each domain independently and also assigned an overall grade for intervention comparisons for each key outcome; they resolved any conflicts through consensus discussion. If they did not reach consensus, the team brought in a third party to settle the conflict. Typically, evidence from just one study was considered insufficient to permit confidence in the estimation of an effect. Exceptions were single study bodies of evidence consisting of a relatively large, low risk of bias trial, particularly if it showed a large magnitude of effect.

## Applicability

We assessed the applicability both of individual studies and of the body of evidence. For individual studies, we examined factors that may limit applicability based on the PICOTS structure. Examples of characteristics examined include:

- Population
  ○ Narrow eligibility criteria, or exclusion of patients with comorbidities;
  ○ Large differences between demographics of the study population and community patients.
- Intervention
  ○ Intensity and delivery of interventions that may not be feasible for routine use;
  ○ Highly selected intervention team or level of training/proficiency not widely available.
- Comparators
  ○ Comparison group that does not represent an available alternative treatment.

Such factors may be associated with heterogeneity of treatment effect and may lessen our ability to generalize the effectiveness of an intervention to use in everyday practice. We abstracted key characteristics of applicability into evidence tables.

During data synthesis, we assessed the applicability of the body of evidence using the abstracted characteristics. KQ 4 includes an analysis of intervention effectiveness in population subgroups.

## Peer Review and Public Commentary

Experts in OME, specifically clinicians and researchers specializing in ear, nose, and throat treatment, pediatrics, and audiology, and evidence-based interventions, were invited to provide external peer review of the draft comparative effectiveness review. AHRQ and an Associate Editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We responded to all reviewer comments and noted any resulting revisions to the text in the “Disposition of Comments Report.” This disposition report will be made available 3 months after the final comparative effectiveness revew is posted on the AHRQ Web site.