# Introduction

## Background

Otitis media with effusion (OME) is defined as a collection of fluid in the middle ear (effusion) without signs or symptoms of acute ear infection.1 OME has been known by a variety of terms including serous otitis media, chronic otitis media, secretory otitis media, nonsuppurative otitis media, mucoid otitis media, or fluid in the middle ear.1 This condition occurs commonly during childhood; as many as 90 percent of children will have at least one episode of OME by age 10.^2^ Many episodes are short-term and transient; they do not recur or recur infrequently. However, for some children, OME recurs frequently or lasts for a prolonged period of time.3

Despite the high prevalence of OME, its long-term impact on child developmental outcomes such as speech, language, intelligence, and hearing remains unclear. An Agency for Healthcare Research and Quality systematic review examining the natural history of OME2 concluded that children with OME in the first 3 years of life had a higher risk of conductive hearing loss at 6 to 10 years of age. However, the authors found no evidence of an impact of early OME on speech, language, or verbal intelligence and found insufficient evidence to establish the possibility of important effects on development.

Determining the necessity of treatment has been difficult because of OME’s uncertain effects on clinical and functional outcomes. Yet, many individuals with OME are treated: annual costs of treating OME in the United States are estimated at $4 billion.2 The near universality of this condition in children and the high expenditures for treating OME make this an important topic. This review was not designed to examine the question of whether one should treat OME but rather to compare the effectiveness of the range of treatments for OME.

### Anatomy and Cause of Otitis Media With Effusion

The physiologic changes that lead to OME begin with dysfunction of the eustachian tube. Normally this tube aerates the middle ear by connecting it to the nasopharynx. The function of the eustachian tube becomes evident during atmospheric ascent or descent. The pressure sensation one experiences when taking off in an airplane comes from middle ear barometric pressure changes. The “popping” of the ear is actually the opening of the orifice to the eustachian tube in the nasopharynx and equalization of pressure between atmospheric pressure and the barometric pressure in the middle ear.

The pathophysiology of OME is still unclear. The traditional teaching has been that OME develops when a negative pressure develops in the middle ear relative to atmospheric pressure and then exudative or transudative fluid accumulates because of that pressure.4 However, various other potential explanations involve ciliary dysfunction, proliferation of fluid producing goblet cells, allergy and residual bacterial antigens, and biofilm.5 The presence of fluid in the middle ear decreases tympanic membrane and middle ear function, leading to decreased hearing, a sensation of fullness in the ear, and occasionally pain from the pressure changes.

In addition to chronic dysfunction of the eustachian tube, the leading causes for OME are viral upper respiratory infection and acute otitis media (AOM).6,7 Several predisposing environmental factors are associated with an increased risk of developing OME: exposure to secondhand smoke, child care attendance, and environmentally induced allergies.8

### Populations With Otitis Media With Effusion

OME is typically considered a childhood affliction. In fact, although OME usually resolves spontaneously within 3 months, 30 to 40 percent of children have recurrent episodes and 5 to 10 percent of episodes last more than 1 year.1,3,9

Some subpopulations of children are at greater risk of having episodes of OME. Those with cleft palate, Down syndrome, and other craniofacial anomalies are at high risk for anatomic causes of OME and decreased function of the eustachian tube.10 Individuals of American Indian, Alaskan, and Asian backgrounds are believed to be at greater risk,11 as are children with adenoid hyperplasia. In addition, children with existing hearing loss can experience further reduction in hearing because of secondary conductive hearing loss that occurs with OME.

Although rare, OME can also occur in adults, usually after patients develop a severe upper respiratory infection such as sinusitis, severe allergies, or rapid change in air pressure (after a plane flight or a scuba dive). The incidence of prolonged OME in adults is not known, but it is much less common than in children.12

### Symptoms of Otitis Media With Effusion

OME can be associated with discomfort from pressure changes and a feeling of fullness in the ear. Individuals with OME are also prone to episodes of AOM. Temporary hearing loss is common among OME patients. This hearing loss is often mild and transient (i.e., worsened or with hearing threshold elevated by a mild hearing loss of about 10 decibels [dB]), but in some cases moderate and prolonged hearing loss can occur.13 Children with OME that leads to chronic eustachian tube dysfunction are at risk for structural damage of the tympanic membrane.14 Because protracted hearing loss in young children may delay or permanently change their communication skills and may lead to behavioral and educational difficulties,15 clinicians and others are concerned about the possible role of OME on these outcomes.

### Diagnosis of Otitis Media With Effusion

The core feature of OME is middle ear effusion (MEE)—i.e., fluid behind the eardrum in the middle ear space over a period of time, commonly 3 or more months. Tympanocentesis, use of a needle to puncture the tympanic membrane to allow for confirmation, drainage, and examination of fluid, is the gold standard for diagnosing MEE associated with OME. However, because tympanocentesis is an invasive procedure, it is rarely used for diagnosis. Instead, pneumatic otoscopy is the most reliable and readily available diagnostic method; in this technique, clinicians blow air through the otoscope, attempting to cause movement of the tympanic membrane.2 Any decreased movement when fluid is present behind the tympanic membrane can be identified through comparison to normal membrane movement. Additionally, bubbles seen behind the tympanic membrane assures that MEE is present.15 Tympanometry is a diagnostic tool that indirectly measures middle ear pressure and tympanic membrane mobility. This procedure is performed with an inexpensive, handheld tool and can be performed more easily than otoscopy on children who are resisting examination. The accuracy of tympanometry is similar to pneumatic otoscopy.16 A “flat” tympanogram (Type B tympanogram) is consistent with OME.

OME often has a corresponding conductive hearing loss as measured by pure-tone audiometry. Hearing is generally measured across the speech range, and for young children normal hearing is considered to be no worse than 15 dB (the measure of loudness needed to respond to a sound).17 In contrast, the average hearing levels for ears with OME often measure at 25 dB, with about 20 percent exceeding 35 dB, (considered a moderate hearing loss).1

OME is distinguished from AOM by the lack of acute symptoms or signs of inflammation.15 OME should not have purulent fluid or redness on examination of the ear, as found with AOM. Another distinguishing feature between AOM and OME is the appearance of the tympanic membrane, which usually bulges with AOM and is typically retracted or neutral with OME.

## Treatments and Treatment Strategies That Were Addressed in This Review: Rationale for Inclusion

During the topic refinement phase of the project, we looked at each of the following treatments in terms of uncertainty within the published literature (including gaps in the evidence), clinical importance, patient important outcomes, and relevance to the U.S. population. The interventions described below fall into one of four treatment types noted in Table 1—surgical interventions, nonpharmacologic physician interventions, pharmacotherapies, and complementary and alternative medicine (CAM) interventions. As explained more thoroughly in the Methods chapter, we have adopted specific criteria for including or excluding types of studies for the different kinds of therapies; we briefly mention the included study types below.

Table 1 Treatments for otitis media with effusion, with presumed mechanism of action

Type of Intervention | Treatment | Description | Presumed Mechanism of Action
Surgical | Tympanocentesis (or paracentesis) | A needle is used to aspirate fluid from the middle ear. | Initial relief of fluid may improve conductive hearing loss and may not recur. Considered the gold standard for diagnosis.
Surgical | Myringotomy | After anesthesia, a small incision or perforation is made in the tympanic membrane. | Air enters the middle ear and pressure to equalize with atmospheric pressure. The hole in the tympanic membrane lasts for only a short time—i.e., is open from 1 to 10 days for standard procedure.18
Surgical | Tympanostomy tube placement | After anesthesia (general anesthesia in children, can be topical anesthesia in adults) myringotomy is done in the tympanic membrane and a thin tube is inserted through the tympanic membrane. | Placement of the tube allows aeration of the middle ear, equalization of pressure in the middle ear, and drainage of fluid from the middle ear. Hearing and symptoms can improve allowing time for underlying eustachian tube dysfunction to resolve.
Surgical | Adenoidectomy | After general anesthesia, the adenoids are excised from the posterior pharynx. The overlying tonsils can also be removed at the same time. | The eustachian tube opens in the posterior pharynx in close proximity to the adenoids, and the potential benefit of removal is that the eustachian tube function may improve thereby resolving OME.
Other treatment strategies | Variations in surgical technique and procedures | Clinicians may use different or possibly newer approaches or devices. | Same as those of the original or parent surgical intervention.
Nonsurgical physical interventions | Autoinflation of the eustachian tube | Using either a closed mouth and valsalva maneuver or blowing against pressure in a device against a closed glottis, the intraoral cavity pressure is increased. | Increased intraoral pressure above the eustachian tube or middle ear pressure opens the eustachian tube into the oropharynx. Each time the procedure is repeated, it allows intermittent aeration of the middle ear and can mitigate abnormal eustachian tube function until function returns to normal.
Nonsurgical physical interventions | Hearing aids | A small electronic device that amplifies sound, worn behind the ear (children and adults) or placed into the external ear canal (adults). | This device overcomes the conductive hearing loss associated with middle ear effusion. Since hearing deficit is one of the concerning effects of OME, improving hearing may eliminate adverse effects of OME.
Pharmacological interventions | Nasal and oral steroids | Anti-inflammatory medications are applied either topically (through the nose) or systemically. | Decreased inflammation at the site of eustachian tube orifice in the posterior pharynx or in the middle ear may improve function.
Pharmacological interventions | Antihistamines | Antihistamines are used to dampen inflammatory response | See above for nasal or oral steroids.
Pharmacological interventions | Decongestants | Either topical or systemic medications are used to decrease edema of mucous membranes. | Decreased swelling at or near eustachian tube orifice may improve function.
Pharmacological interventions | Antibiotics and antimicrobials | Medications that kill or stop duplication of infectious agents such as bacteria are used. | Bacterial infections may precede OME or develop during an episode of OME. Antibiotic treatment may treat infection that is not evident by clinical examination and decrease inflammation to allow more rapid resolution of eustachian tube dysfunction.
Complementary and alternative therapies | Including, but not limited to dietary amendments and osteopathic manipulation | Varies by treatment. | Varies by treatment.
Watchful waiting | | Sometimes referred to as active observation, this choice involves delaying treatment while monitoring patient progress. It contrasts with immediately administering a treatment. | Not directly applicable.

OME = otitis media with effusion

The set of treatments examined in the review are generally limited to those that are recommended in clinical guidelines for managing OME.15 The guidelines do not recommend adenoidectomy as an initial procedure for OME unless a specific indication for it exists, but we included studies of it as a first-line procedure because a recent large trial was specifically undertaken to compare adenoidectomy and tubes.19 Nor do recent guidelines recommend the use of myringotomy alone. However, we included studies of it as a standalone treatment (with and without adenoidectomy) because we found some studies with laser-assisted myringotomy and myringotomy using radiofrequency that were not evaluated in the practice guidelines. The guidelines also do not recommend treatment with steroids but a large trial was also recently completed related to treatment with topical intranasal steroids20 In addition, we included studies of CAM procedure(s) in our search. Notably, the clinical guidelines did not have any recommendation for CAM because of a lack of studies, particularly randomized trials. On the recommendation of our Technical Expert Panel (TEP), we searched for studies that may have been published in the time since the guidelines were published. Each treatment we included in this review is discussed in turn.

The benefits and harms of tympanostomy tubes (TT) for managing OME in children have been addressed by two recent systematic reviews identified during our topic refinement.21,22 They include a 2010 Cochrane review of 11 randomized controlled trials (RCTs)22 of otherwise healthy children and a 2011 systematic review, commissioned by the Swedish Council on Technology Assessment in Health Care,21 of 10 RCTs. For this review, we began with evidence from these systematic reviews limited to patients with OME and searched for additional evidence.

TT can be broadly separated into short-term and long-term tube types based on the length of time they can be expected to remain in the ear without extrusion. The length that TT stay in the tympanic membrane is related to tube length and design.23,24 Tubes are designed to stay in the tympanic membrane for as little as 6 months, to over 2 years.23 Figure 1 presents pictures of common TT types based on average retention time.

Figure 1 Short-term tympanostomy tubes

R, Reuter-Bobbin; D, Donaldson; S, Sheehy; A, Armstrong (2 views). B. Long-term tympanostomy tubes: P, Paparella II; T, Goode t-tube; B, butterfly

Source: Isaacson G, Rosenfeld RM. Care of the child with tympanostomy tubes: A visual guide for the pediatrician. Pediatrics 1994 Jun:93(6):924–929.^24^

Figure 1 contains two photos of tympanostomy tubes. One photo shows four short-term tympanostomy tubes: Reuter-Bobbin, Donaldson, Sheehy, and Armstrong. The other photo shows three long-term tympanostomy tubes: Paparella II, Goode t-tube, and butterfly.

A growing body of literature examines variations in TT-related surgical techniques and procedures for treating patients with OME. The 2011 Swedish systematic review21 considered various characteristics of tube design and surgical procedures. We searched for other relevant studies comparing TT materials, designs, and surgical procedures.

As indicated above, the most recent guidelines for treating OME do not recommend the use of myringotomy alone,15 but more recent literature suggests that laser-assisted myringotomy or radio frequency myringotomy may be a useful alternative to myringotomy plus TT because it may allow for aeration of the ear for a longer time than would myringotomy alone. These recent studies suggest that it may provide a treatment with fewer complications for selected subgroups of children and adults.25–28 Because no systematic reviews have addressed the effectiveness of myringotomy alone, we searched for relevant RCTs and observational studies examining myringotomy alone as a treatment strategy for OME in otherwise healthy children, special populations of children, and adults.

Adenoidectomy as a treatment for OME in children was also reviewed in a 2010 Cochrane review.29 The review included seven RCTs comparing adenoidectomy (with or without TT) and nonsurgical management or TT only; studies involved children up to 18 years of age with followup of 6 months or longer, and study populations were not limited to otherwise healthy children. We searched for additional evidence. One additional study (i.e. TARGET)19 that compared adenoidectomy plus TT with TT alone and with watchful waiting was published and so included in the current review. Preliminary data from this study was included in The Cochrane Review of TT22 but not in the adenoidectomy systematic review.29

The technique of autoinflation has been used as a therapy for OME. The goal of autoinflation is to use either a Valsalva maneuver or external device to equalize middle ear and nasopharyngeal pressure, transiently opening the eustachian tube. A 2006 Cochrane review included six RCTs examining the use of autoinflation versus no treatment for hearing loss associated with OME.30 Studies included children and adults. We began with this review and searched for additional evidence.

The benefits and harms of oral and topical nasal steroids in treating children with OME and hearing loss were the focus of a 2010 Cochrane review that was updated in 2011.^31,32^ The review was limited to RCTs of either steroid use alone or in combination with another agent such as antibiotics; it included special populations of children of interest to our current review. Current guidelines developed by both the United Kingdom’s National Collaborating Centre for Women’s and Children’s Health (2008)10 and the American Academy of Pediatrics (2004)15 recommend against using oral or topical nasal steroids in treating children with OME. In consultation with our TEP, we concluded that newly identified studies should be integrated with those previously identified through the Cochrane review, because the newly integrated studies may result in conclusions different from those of the earlier review.31 We conducted a completely new search to identify studies pertaining to adults, because we did not find an existing review focusing on this population.

Very little literature addressed CAM interventions to treat patients with OME. The book “Evidence-Based Otitis Media”33 lists treatments and supportive studies for at least two CAM approaches: physical manipulation and restricted diets. Based on the recommendations of our TEP that little is known about the efficacy of CAM treatment for OME, in the current review we only searched for RCTs of CAM interventions.

Watchful waiting, or active observation as it also has been called, is the process of regular review and followup of the child, including assessments of hearing, development, and educational progress. We examined this as a treatment strategy, distinct from “no treatment.” Watchful waiting has not been the focus of a systematic review, although it has been a comparator in RCTs in systematic reviews focusing on other interventions. Current clinical practice guidelines recommend that watchful waiting be employed for 3 months and possibly longer, prior to initiating treatment in otherwise healthy children.10,15

We considered whether to exclude studies reporting outcomes by ears, rather than by subjects. Omitting studies reporting results by ears is reasonable and appropriate when (1) the treatment involved is systemic or (2) outcomes are measures of the patient’s overall function, such as academic achievement, speech production, language development, or quality of life. We included ear-specific treatments or outcomes such as hearing thresholds or presence of fluid in the current review.

## Treatments That Were Not Addressed in This Review: Rationale for Exclusion

Hearing aids are not used as a treatment option for OME in the United States. According to a 2008 National Collaborating Centre for Women’s and Children’s Health of the National Institute for Health and Clinical Excellence (NICE) guideline,10 no high-quality comparative studies have evaluated the effectiveness of hearing aids to other interventions for treating OME. Furthermore, we did not find any comparative studies on hearing aids during topic refinement, and our Key Informants did not consider hearing aids of clinical relevance in the context of OME treatment in the United States. Hearing aids, therefore, were not included in the current review.

Using antihistamines and decongestants for treating children with OME has been extensively studied in primary RCTs and summarized in recent systematic reviews34,35 and clinical practice guidelines.10,15 A Cochrane review of OME for use of these medications in children identified 16 RCTs that included more than 1,800 subjects.34 High-quality evidence of multiple short- and long-term outcomes repeatedly and unequivocally demonstrated no benefit for use of these medications over placebo for treating OME. Additionally, the reviewed studies found evidence of side effects and harms with the use of these medications. We see no reason to believe that these findings will change with future advances in the medication class or causes of OME. We, therefore, decided to exclude antihistamines and decongestants from the current review as a treatment that is definitively not effective and likely harmful.

Conflicting evidence exists regarding the effectiveness and utility of antimicrobials including antibiotics for treating patients with OME.10,15,35 They are not recommended in current U.S. guidelines.15 A Cochrane review on the use of antibiotics for the treatment of OME in children was started in 2011 and was published after the period of updating our search.36 We did not duplicate their efforts and have excluded antibiotics from the current comparative review.

## Scope and Key Questions

### Scope

This review is designed to address the comparative effectiveness of the interventions described above for all individuals with OME. We were especially interested in examining effectiveness in subpopulations based on age, including adults and in special populations such as individuals with craniofacial abnormalities, Down syndrome, and existing hearing loss. We targeted impacts of these treatments on clinical outcomes, functional and quality-of-life outcomes, health care utilization, and harms. Both short-term and long-term studies were included. We did not limit the setting where these treatments occurred.

We conducted this review (nominated by an adult patient) because of the continuing uncertainty about efficacy, effectiveness, and particularly comparative effectiveness, as well as harms, for the included therapies. This uncertainty leaves clinicians, patients, and families (e.g., parents of younger children) facing considerable dilemmas about choosing appropriate interventions, given patient characteristics and preferences. OME is a common condition and more up-to-date and comprehensive comparative information will be helpful to many stakeholder groups in making decisions about when and how to treat this condition. We also were mindful of the need to provide this information for populations not otherwise included in past reviews such as adults and children with special conditions such as Down syndrome, cleft palate, or existing hearing loss.

Thus, we aimed to provide useful information for clinical decisionmaking and policymaking. Of particular concern, as reflected in our Key Questions (KQs), were issues such as weighing benefits and harms for patients, appropriate interventions for particular population subgroups, and considering the applicability of evidence to primary versus specialty practice.

### Key Questions

We addressed five KQs in this comparative effectiveness review.

#### KQ 1 What is the comparative effectiveness of the following treatment options (active treatments and watchful waiting) in affecting clinical outcomes or health care utilization in patients with OME?

Treatment options include:

a. Tympanostomy tubes,
b. Adenoidectomy,
c. Myringotomy,
d. Oral or topical nasal steroids,
e. Autoinflation,
f. Complementary and alternative medical procedures,
g. Watchful waiting,
h. Variations in surgical technique or procedure.

Clinical outcomes include changes in:

a. OME signs (middle ear fluid) and symptoms (fullness in ear), objective hearing thresholds,
b. Episodes of acute otitis media, and
c. Vestibular function such as balance and coordination.

#### KQ 2 What is the comparative effectiveness of the different treatment options listed in KQ 1 (active treatments, watchful waiting, and variations in surgical procedures) in improving functional and health-related quality-of-life outcomes in patients with OME?

These outcomes include:

a. Perceived hearing level (i.e., patient or parent-reported hearing problems)
b. Speech and language development,
c. Auditory processing,
d. Academic achievement,
e. Attention and behavioral outcomes,
f. Health-related quality of life, and
g. Patient and parent satisfaction with care.

#### KQ 3 What are the harms or tolerability among the different treatment options?

#### KQ 4 What are the comparative benefits and harms of treatment options in subgroups of patients with OME?

Subgroups include:

a. Patients of different age groups,
b. Patients of different racial or ethnic backgrounds,
c. Patients in different socioeconomic status groups,
d. Patients with comorbidities such as craniofacial abnormalities (e.g., cleft palate), Down syndrome, and existing speech, language and hearing problems, and
e. Patients with a medical history of AOM or OME (with and without clinical hearing loss or other problems).

#### KQ 5 Is the comparative effectiveness of treatment options affected by any of the following factors

a. Health insurance coverage,
b. Physician specialty,
c. Type of facility of the treatment provider,
d. Geographic location,
e. Continuity of care, or
f. Prior inoculation with the pneumococcal vaccine?

Figure 2 gives the analytic framework for this review. The populations of interest are in the box to the far left; the interventions appear in the middle; and the two sets of outcomes (for KQ 1 and KQ 2 on benefits, and also KQ 4 on important subgroups) appear on the far right. KQ 3 concerns harm (various types of adverse events). Finally, KQ 5 relates to a set of health care delivery or clinical factors (pneumococcal vaccination) that may influence choices of treatments or their clinical and quality-of-life outcomes.

Figure 2 Analytic framework for review of treatments of otitis media with effusion

AOM = acute otitis media; KQ = Key Question; OME = otitis media with effusion

This figure is an analytic framework depicting the key questions (KQs) within the context of the populations, interventions, comparisons, outcomes, time frames, and settings (PICOTS) relevant to treatment for otitis media with effusion (OME). The figure illustrates the relationship between patients with OME, treatments and treatment strategies, and outcomes of interest. Subpopulations are depicted separately stratified by patient age (infants, 0–2 years of age, children, 3–12 years of age, adolescents, 13–17 years of age, and adults 18 years of age or older); race/ethnicity; socioeconomic status; comorbidities, specified as Down syndrome, craniofacial abnormalities, existing hearing loss and delays in speech and language; and past medical history of acute otitis media (AOM) or OME. Treatments for OME are shown as: surgical (tympanostomy tubes, myringotomy, and adenoidectomy) or non-surgical (oral and nasal steroids, autoinflation and complementary and alternative medicines). Treatment strategies for OME are shown as: watchful waiting and variations in surgical technique and procedure. Outcomes are separated into A) clinical health outcomes and health care utilization (KQ1 concerning the population as a whole and KQ 4 concerning subpopulations) and shown as: changes in middle ear fluid, changes in hearing, episodes of AOM, changes in vestibular balance and coordination, number of office visits, surgeries, medication use, and B) functional and quality of life outcomes (KQ 2 concerning the population as a whole and KQ 4 concerning subpopulations) and shown as: hearing, speech and language development, auditory processing, academic achievement, attention and behavior, quality of life, and parental and patient satisfaction with care. Adverse effects from treatments are illustrated to depict KQ3. Health care delivery factors influencing treatment are illustrated to depict KQ 5 and include physician specialty, type of facility of treatment provider, geographic location, health insurance coverage, pneumococcal vaccine inoculation, and continuity of care from the same provider.

## Organization of This Report

In the remainder of this report, the second chapter documents our methods, and the third chapter presents our key findings and data synthesis for all five KQs. Chapter 4 discusses findings in the light of ongoing debate and what is already known about therapy for patients with OME, discusses the limitations of the evidence base and this review, identifies gaps in the evidence, and suggests a future research agenda to fill those gaps.

The main report has several appendixes, as follows: Appendix A, search strategies; Appendix B, list of studies excluded at full-text review with reasons for exclusion; Appendix C, evidence tables; Appendix D, abstract and full-text forms; Appendix E, risk-of-bias tables; Appendix F, strength of evidence tables; Appendix G, glossary; and Appendix H, acronyms list.