# Peer Reviewers

Peer Reviewers are invited to provide written comments on the draft report based on their clinical, content, or methodological expertise. Peer review comments on the preliminary draft of the report are considered by the EPC in preparation of the final draft of the report. Peer Reviewers do not participate in writing or editing of the final report or other products. The synthesis of the scientific literature presented in the final report does not necessarily represent the views of individual reviewers. The dispositions of the peer review comments are documented and will, for CERs and Technical briefs, be published three months after the publication of the Evidence report.

Potential Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Invited Peer Reviewers may not have any financial conflict of interest greater than $10,000. Peer Reviewers who disclose potential business or professional conflicts of interest may submit comments on draft reports through the public comment mechanism.

- Randy Bergen M.D., M.P.H.
  Kaiser Permanente
  Walnut Creek, CA
- Tamala Bradham, Ph.D.
  Vanderbilt University Medical Center
  Nashville, TN
- Christine Dollaghan, Ph.D.
  University of Texas at Dallas
  Richardson, TX
- Joseph Kerschner, M.D.
  Children’s Hospital of Wisconsin
  Milwaukee, WI
- Lawrence C. Kleinman, M.D., M.P.H.
  Mt. Sinai School of Medicine
  New York, NY
- Sharon B. Meropol, M.D., Ph.D.
  American Academy of Pediatrics Representative
  Rainbow Babies and Children’s Hospital
  Cleveland, OH
- Diane Sabo, Ph.D.
  Children’s Hospital of Pittsburgh
  Pittsburgh, PA
- Jack Paradise, M.D.
  University of Pittsburgh School of Medicine
  Pittsburgh, PA
- Richard Rosenfeld M.D., M.P.H.
  SUNY Downstate Medical Center
  Brooklyn, NY