# Technical Expert Panel

Technical Experts comprise a multidisciplinary group of clinical, content, and methodological experts who provide input in defining populations, interventions, comparisons, or outcomes as well as identifying particular studies or databases to search. They are selected to provide broad expertise and perspectives specific to the topic under development. Divergent and conflicted opinions are common and perceived as health scientific discourse that results in a thoughtful, relevant systematic review. Therefore study questions, design and/or methodological approaches do not necessarily represent the views of individual technical and content experts. Technical Experts provide information to the EPC to identify literature search strategies and recommend approaches to specific issues as requested by the EPC. Technical Experts do not do analysis of any kind nor contribute to the writing of the report and have not reviewed the report, except as given the opportunity to do so through the peer or public review mechanism

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals are invited to serve as Technical Experts and those who present with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

- Doug Campos-Outcalt, M.D., M.P.H.
  College of Medicine
  University of Arizona
  Phoenix, AZ
- Christine Dollaghan, Ph.D.
  University of Texas at Dallas
  Richardson, TX
- Lisa Hunter, Ph.D.
  Cincinnati Children’s Hospital Medical Center
  Cincinnati, OH
- Sharon B. Meropol, M.D., Ph.D.
  American Academy of Pediatrics Representative
  Rainbow Babies and Children’s Hospital
  Cleveland, OH
- Richard Rosenfeld, M.D., M.P.H.
  SUNY Downstate Medical Center
  Brooklyn, NY
- Lawrence C. Kleinman, M.D., M.P.H.
  Mt. Sinai School of Medicine
  New York, NY