# Key Informants

Key Informants are the end users of research, including patients and caregivers, practicing clinicians, relevant professional and consumer organizations, purchasers of health care, and others with experience in making health care decisions. Within the EPC program, the Key Informant role is to provide input into identifying the Key Questions for research that will inform health care decisions. The EPC solicits input from Key Informants when developing questions for systematic review or when identifying high priority research gaps and needed new research. Key Informants are not involved in analyzing the evidence or writing the report and have not reviewed the report, except as given the opportunity to do so through the peer or public review mechanism

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals are invited to serve as Key Informants and those who present with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

- Randy Bergen, M.D., M.P.H.
  Kaiser Permanente
  Walnut Creek, CA
- Doug Campos-Outcalt, M.D., M.P.H.
  American Academy of Family Physicians Representative
  College of Medicine
  University of Arizona
  Phoenix, AZ
- Sharon B. Meropol, M.D., Ph.D.
  American Academy of Pediatrics Representative
  Rainbow Babies and Children’s Hospital
  Cleveland, OH
- Jack L. Paradise, M.D.
  University of Pittsburgh School of Medicine
  Pittsburgh, PA
- Richard Rosenfeld, M.D., M.P.H.
  SUNY Downstate Medical Center
  Brooklyn, NY
- Annie Whitney
  Chapel Hill, NC
  Patient Representative