# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Stephanie Chang, M.D., M.P.H., our former Task Order Officer, Steven Fox, M.D., and of Margaret Coopey, M.P.S., M.H.A., R.N. We thank our AHRQ Task Order Officer Stephanie Chang, M.D., M.P.H., and our Associate Editor, Lisa Hartling, Ph.D., for their helpful comments on a draft version of the report.

The authors deeply appreciate the considerable support, commitment, and contributions of the EPC team staff at the RTI-UNC EPC. We express our gratitude to the following individuals for their contributions to this project: Loraine Monroe, Laura Small, Christiane E. Voisin, Carlton Zdanski, and Karen Crotty.