# Discussion

## Key Findings and Strength of Evidence

This systematic review addressed the comparative effectiveness of treatments for otitis media with effusion (OME). OME is characterized by eustachian tube dysfunction, the accumulation of fluid in the middle ear; the condition most commonly affects children. Health care providers have been particularly concerned when fluid persists for a relatively long period of time (e.g., 3 months or more) and when the problem reduces hearing because it may result in functional limitations and have long-term sequelae.

Various approaches have been studied for treating OME. Sometimes investigators used a single treatment alone; sometimes they combined two or more approaches. In this review, we focused on the following interventions and comparisons among them: surgical procedures (tympanostomy tubes [TT], myringotomy, and adenoidectomy); nonpharmacological interventions (autoinflation); pharmacological interventions (oral or nasal steroids); complementary and alternative medicine approaches (CAM); and other treatment strategies (watchful waiting and delayed treatment). The effectiveness of these interventions has generally been studied in pediatric samples that included a wide range of ages.

The focus of this review was to compare the relative benefits and harms of these treatment approaches overall and then specifically in particular subpopulations of interest that may be particularly affected by OME (e.g., children with preexisting hearing limitations, craniofacial abnormalities, or Down syndrome) or for whom little is known (adults). As discussed in the introduction, we did not consider hearing aids, antihistamines and decongestants, or antibiotics.

### Overview

Overall, the evidence included five recent systematic reviews, relevant studies identified in those reviews, and additional studies discovered through our searches. These totaled 49 randomized controlled trials (RCTs), six nonrandomized trials (e.g., studies comparing left and right ears), and four observational studies. By treatment comparison, the literature included the following:

- Surgical approaches:
  ○ TT compared by type of tube or procedure approach;
  ○ TT versus myringotomy or nonsurgical interventions (delayed treatment or watchful waiting);
  ○ TT plus adenoidectomy versus myringotomy plus adenoidectomy;
  ○ TT plus adenoidectomy versus adenoidectomy;
  ○ Myringotomy versus myringotomy, comparison of different approaches, and various combinations of myringotomy plus adenoidectomy; and
  ○ Adenoidectomy versus nonsurgical interventions or myringotomy.
- Pharmacological interventions, specifically oral and topical nasal steroids.
- Nonpharmacological interventions, specifically, autoinflation.

We had no studies meeting inclusion criteria on any CAM interventions.

We restricted our review to treatments for OME. Although clinicians use many of these treatments for patients with recurrent acute otitis media (AOM), we included only studies from which we could obtain evidence for purely OME populations. We did not restrict inclusion by other coexisting conditions beyond AOM or disease processes that produce OME (e.g., allergies) as long as the participants had OME.

Although we had hoped to be able to provide evidence for these and other subpopulations, the review pertains mainly to typically developing children. The majority of children included in studies were older than 2 years, which may limit the applicability of the results to some treatments, such as TT, which are routinely used with infants. We were unable to find studies on individuals with cleft palate or sensorineural hearing loss that met our inclusion criteria. The studies available on individuals with cleft palate did not diagnose OME unambiguously before treatment. We found only one study that targeted individuals 16 to 75 years of age.

We tried to examine a broad range of clinical, functional, and quality-of-life outcomes and harms of treatment. Although most of the studies examined middle ear status (e.g., presence of effusion or recurrence of OME) and many examined hearing, some included harms of treatment. Only a handful, however, included measures of speech, language, behavior, or quality of life. No study examined vestibular function or health care utilization. Thus, our statements about evidence are limited primarily to middle ear status, hearing, and harms.

We summarize the strength of evidence for benefits of interventions, comparisons, and outcomes on which we had studies of at least low or medium risk of bias. We included studies with high risk of bias only for harms. Strength of evidence grades are developed from ratings on four domains: overall risk of bias, directness of the evidence or the comparisons, consistency, and precision of estimates.37 We did not evaluate other strength of evidence domains (e.g., magnitude of effect, dose-response relationships). Strength of evidence can have one of four grades—high, moderate, low, or insufficient. Insufficient evidence arises when we had no studies addressing the particular topic; when we had only a single small study; when available studies were sufficiently inconsistent, indirect, or imprecise as to preclude drawing any conclusions; or when differences in treatments appear to show no difference among studies that may be underpowered or clinical thresholds for minimal differences have not been established.

### Key Question 1 Clinical Outcomes

For this Key Question (KQ), we sought evidence on the effectiveness of surgical and other interventions on a range of clinical outcomes, including recurrent middle ear effusion, recurrent AOM, and measured hearing. As noted, we had no studies that reported on vestibular function or use of health care services.

Table 38 summarizes the OME interventions on which we had low, moderate, or high strength of evidence for clinical outcomes.

Table 38 Strength of evidence for interventions to improve clinical outcomes

Intervention and Comparator | Number of Studies (Sample Sizes) | Outcome and Results | Strength of Evidence
TT vs. watchful waiting, delayed treatment, or myringotomy | MA of 3 RCTs (N=574) | TT decreased persistent middle ear effusion at 1 year compared with watchful waiting or delayed treatment: 32% less time (95% CI, 17% to 48%). | High for benefit
TT vs. watchful waiting, delayed treatment, or myringotomy | 2 studies (N=294) | TT less time with effusion through 1 year compared with myringotomy. | Moderate for benefit
TT vs. watchful waiting, delayed treatment, or myringotomy | MA of 3 RCTs (N=426) | TT decreased persistent middle ear effusion at 2 years compared with watchful waiting or myringotomy: 13% less time (95% CI, 8% to 17%). | Moderate for benefit
TT vs. watchful waiting, delayed treatment, or myringotomy | MA of 3 RCTs (N=523) + 1 RCT (N=248) | TT had better measured hearing for up to 9 months than watchful waiting. MA results: −4.20dB (95% CI, −4.00 to −2.39). | High for benefit
TT vs. watchful waiting, delayed treatment, or myringotomy | MA of 3 RCTs (by ears) (N=230) | TT better measured hearing for up to 6 months than watchful waiting or myringotomy: −10.08 (95% CI, −19.12 to −1.05). | High for benefit
TT vs. watchful waiting, delayed treatment, or myringotomy | MA of 3 RCTs (by ears) (N=234) | No difference between TT and watchful waiting or myringotomy in measured hearing at 7–12 months: −5.18dB (95% CI, −10.43 to 0.07). | Low for no difference
TT vs. watchful waiting, delayed treatment, or myringotomy | MA of 2 RCTs (N=328); MA of 2 RCTs (N=283) | No difference between TT and watchful waiting in measured hearing at 12 months: −0.41dB (95% CI, −2.37 to 1.54) and 18 months −0.02 dB (95% CI, −3.22 to 3.18). | Low for no difference
TT + adenoidectomy vs. myringotomy + adenoidectomy | 6 studies: 3 RCTs by person (N=431); 2 RCTs (by ears) (N=338); 1 NRCT (by ears) (N=193) | No difference in measured hearing between groups at 6 and 12 months and at more than 3 years. | Low for no difference
TT + adenoidectomy vs. WW | 1 study (n = 250) | TT plus adenoidectomy improved hearing at 3 to 24 mos compared to WW. | Low for benefit
Adenoidectomy vs. no treatment | MA of 2 RCTs (by ears) (N=153); MA of 3 RCTs (by ears) (N=297) | Adenoidectomy produced better OME resolution than no treatment at 6 months. The risk difference was 0.27 (95% CI, 0.13 to 0.42) measured through otoscopy and 0.22 (95% CI, 0.12 to 0.32) measured through tympanometry. | High for benefit
Adenoidectomy vs. no treatment | MA of 3 RCTs (by ears) (N=298) | Adenoidectomy produced better OME resolution than no treatment at 12 months. The risk difference was 0.29 (95% CI, 0.19 to 0.39). | High for benefit
Adenoidectomy + myringotomy vs. myringotomy | 1 RCT (N=237) | Adenoidectomy and myringotomy produced less mean time with effusion than myringotomy alone at 24 months: −0.76 standard mean difference (95% CI, −1.02 to −0.49). | Low for benefit
Adenoidectomy + myringotomy vs. myringotomy | 1 RCT (N=237) | Adenoidectomy and myringotomy produced better hearing than myringotomy alone at 24 months, measured as standard mean difference time with hearing level ≥ 20: worse ear: −0.65 (95% CI, −0.91 to −0.39); better ear: −0.66 (95% CI, −0.93 to −0.40). | Low for benefit
Oral steroids vs. controls | MA of 3 RCTs (N=106) | No difference in persisting OME at 1–2 months (no antibiotics provided in either group): OR=0.55 (95% CI, 0.21 to 1.48). | Low for no difference
Oral steroids + antibiotics vs. controls + antibiotics | MA of 3 RCTs (N=243) | No difference in persisting OME at 1–2 months (antibiotics provided to both groups): OR=0.75 (95% CI, 0.45 to 1.27). | Moderate for no difference
Topical intranasal steroids vs. controls | 1 RCT (N=217) | No difference in OME cure rates at 1, 3, and 9 months. | Low for no difference
Topical intranasal steroids vs. controls | 1 RCT (N=217) | No difference in hearing loss at 3 and 9 months. | Low for no difference
Autoinflation vs. controls | MA of 2 RCTs (N=185) | Improvement seen in OME at ≤1month: RR=3.84 (tympanometry change C2 to C1 or A) and RR=2.72 (tympanometry change B to C1 or A). | Low for benefit

CI = confidence intervals; dB = decibels; NRCT = non-randomized controlled trial; MA = meta-analysis; N = number; OME = otitis media with effusion; OR = odds ratio; RCT = randomized controlled trial; RR = risk ratio; TT = tympanostomy tubes; vs. = versus

Evidence concerning clinical outcome comparisons of TT based on tube design differed in retention length. For example, TT that are considered longer acting, such as Goode T-tubes and Paparella tube designs, were retained longer than other tubes such as Shah and Shepard. OME recurrence at 1 year or longer was higher in shorter term TT. We found insufficient evidence to demonstrate differences in clinical outcomes based on placement technique or TT material. TT design, placement technique, or material did not affect hearing outcomes.

We found that TT are more likely to decrease the time with persistent middle ear effusion lasting more than 1 year (high strength of evidence) and 2 years (moderate strength of evidence) compared with watchful waiting or delayed treatment. Hearing, the more critical and patient-centered clinical outcome, was found to be superior with TT as well, but for a shorter period of time, up to 9 months (high strength of evidence). Shorter time periods may be more important for the youngest children (younger than 3 years of age) who are still developing their speech and language skills, but results were not available specifically for this age group.

At increasingly longer periods over which outcomes were measured, hearing differences between groups became smaller and not significantly different. These findings are based on various analyses: (1) meta-analysis results comparing TT with watchful waiting or myringotomy over 7 to 12 months, measured by ears (low strength of evidence for no difference); and (2) based on meta-analyses comparing TT with just watchful waiting over 12 and 18 months, measured by child (low strength of evidence for no difference). We found limited evidence comparing TT to either watchful waiting or myringotomy in relation to OME recurrence, ear ventilation, or episodes of AOM; thus, we are unable to comment on these outcomes.

We examined whether TT or myringotomy are more likely to improve clinical outcomes when one or the other is added to adenoidectomy. We found no differences in hearing outcomes at any time points measured in five studies. Because of this consistent finding, we concluded that the strength of evidence was low for no difference.

We compared adenoidectomy with other treatments options, either alone or with concomitant myringotomy or TT. Adenoidectomy was superior to no treatment in relation to improving the probability of OME resolution at 6 months and 1-year followup (strength of evidence high). We found mixed results in relation to hearing outcomes for this comparison. The combination of adenoidectomy and myringotomy was superior to myringotomy alone in relation to time with effusion and hearing outcomes at 24 months, based on one RCT (strength of evidence low).

From these findings, our review suggests that adenoidectomy alone or in combination with myringotomy or TT is superior to watchful waiting, myringotomy or no treatment. Given the similarity of hearing outcomes when TT or myringotomy are added to adenoidectomy, our findings also suggest that it remains unclear whether additional benefit is obtained from the myringotomy procedure. We found some evidence that adding adenoidectomy to TT may provide further benefit (above and beyond TT only), but we found no evidence comparing adenoidectomy alone with TT alone.

For nonsurgical interventions, we found evidence that oral steroids provide no short-term improvements in OME (at 1 to 2 months) either with the addition of antibiotics (moderate for no difference) or without antibiotics (low for no difference). One new low risk-of-bias study provided additional evidence that use of topical intranasal steroids does not improve OME and hearing outcomes at 9 months (low for no difference). These findings support the current American Academy of Pediatrics guidelines against the use of oral and intranasal steroids in treating OME in children.146

Evidence concerning clinical outcomes related to autoinflation found improvement in relation to middle ear effusion at 1 month or less (low strength of evidence); evidence was insufficient, however, for evaluating lengthier followup periods or in relation to hearing outcomes.

As described above, many interventions were compared with watchful waiting and, in some cases, with myringotomy. OME is different from many other medical diagnoses because nearly all cases of OME will resolve with time with no intervention. Therefore, the question for many interventions becomes whether shortening patients’ time with effusion improves other important outcomes. We found evidence that surgical interventions decrease time with effusion compared with watchful waiting and that TT improves hearing in the short term. However, KQ 2 considers whether these short-term improvements in clinically measurable outcomes improve developmental and functional outcomes; that this could be the case is plausible in physiological terms.

### Key Question 2 Health-Related Quality of Life and Functional Outcomes

For KQ 2, we sought evidence of the effectiveness of the various interventions to improve quality of life, subjective hearing, speech and language development, or behavior. Of the evidence meeting our inclusion criteria for the review overall, only a small number of studies included data on these outcomes. Evidence was limited to the following intervention comparisons: TT versus watchful waiting or delayed treatment, TT plus adenoidectomy versus myringotomy plus adenoidectomy, and topical intranasal steroids versus control.

Table 39 summarizes the OME interventions on which we had low, moderate, or high strength of evidence for clinical outcomes.

Table 39 Strength of evidence for interventions to improve health-related quality of life and functional status

Intervention and Comparator | Number of Studies (Sample Sizes) | Outcome and Results | Strength of Evidence
TT vs. watchful waiting or delayed treatment | MA of 3 RCTs (N=394) and 2 RCTs (N=503) | No difference in language comprehension at 6 to 9 months post-intervention (mean difference, 0.09; 95% CI, −0.21 to 0.39) or at preschool and elementary school age. | Moderate for no difference
TT vs. watchful waiting or delayed treatment | MA of 3 RCTs (N=393) and 2 RCTs (N=503) | No difference in language expression at 6 to 9 months post-intervention (mean difference, 0.03; 95% CI, −0.41 to 0.49) or at preschool and elementary school age. | Moderate for no difference
| 2 RCTs (N=503) | No difference in cognitive development at 9 months post-intervention or at preschool and elementary school age. | Low for no difference
| 2 RCTs (N=503) | No difference in academic achievement at elementary school age. | Low for no difference
Intranasal steroids vs. controls | 1 study (N=144) | No difference in parent-reported hearing difficulties at 3 and 9 months or in median days with hearing loss at 3 months. | Low for no difference

CI = confidence interval; MA = meta-analysis; N = number; RCT = randomized controlled trial; TT = tympanostomy tubes; vs. = versus

Language comprehension and language expression were not significantly better among children who received TT than among those who participated in watchful waiting or delayed treatment at various followup points, including 6 to 9 months post-treatment, during preschool, and at the later elementary school years (ages 3, 6, and 8) (strength of evidence moderate). Cognitive development results were similar (strength of evidence low for no difference). These findings correspond to the conclusions that clinical hearing outcomes were not superior in the TT group after both shorter and longer periods of followup. Delayed TT treatment did not negatively affect academic achievement when measured at later elementary school years. Evidence was insufficient to reach conclusions related to differences in behavioral or quality-of-life outcomes for this treatment comparison.

One small study comparing TT and adenoidectomy versus myringotomy and adenoidectomy measured quality-of-life outcomes. Therefore, we considered this evidence to be insufficient to reach conclusions.

Parents’ report of their children’s hearing difficulties did not differ in one low risk-of-bias study comparing intranasal steroids and controls (low strength of evidence for no difference).

### Key Question 3 Harms Associated With Interventions To Treat Otitis Media With Effusion

We sought evidence of the potential harms or side effects that may occur with various treatment options. We considered such concerns as otorrhea, atrophy, tympanosclerosis, cholesteatoma, tissue granulation, and surgical complications. Specifically, in relation to TT we considered otorrhea and perforation, and in relation to steroid treatment such problems as diarrhea and nasal stinging. Table 40 summarizes the OME interventions on which we had low, moderate, or high strength of evidence for harms outcomes.

Table 40 Strength of evidence for harms or tolerability of interventions

Intervention and Comparator | Number of Studies (Sample Sizes) | Outcome and Results | Strength of Evidence
TT vs. TT | 1 RCT (N=30 ears), 2 observational studies (N=779 ears) | Otorrhea occurred more frequently in ears with longer-term TT than in ears with shorter-term TT after 1 year or more. | Low for harms of longer-term TT
TT vs. watchful waiting or myringotomy | 5 studies (N=1129) | Tympanosclerosis occurred more frequently in ears that had TT, based on examinations after the TT had been extruded. | Moderate for harms of TT
TT vs. watchful waiting or myringotomy | 4 studies (N=960) | Otorrhea occurred more frequently in ears with TT. | Moderate for harms of TT
TT plus adenoidectomy vs. adenoidectomy alone or with myringotomy | 3 studies (N=485) | Tympanosclerosis occurred more frequently in ears with TT than ears with only adenoidectomy or with myringotomy. | Moderate for harms of TT
Adenoidectomy vs. other treatments | 2 studies (N=739) | Although rare, adenoidectomy increased the risk of post-surgical hemorrhage. | Low for harms of adenoidectomy
Oral steroids vs. control | 5 studies (N = 637) | No difference in mild adverse events such as nausea and diarrhea. | Low for no difference
Topical nasal steroids vs. control | 2 RCT (N=225) | No difference in mild adverse events such as nasal stinging, dry throat, and cough. | Low for no difference

N = number; NR = not reported; RCT = randomized controlled trial; SR = systematic review; TT = tympanostomy tubes; vs. = versus

Otorrhea was more common among ears with TT (strength of evidence moderate) and was more common for TT that were intended to stay in ears for a longer period of time (strength of evidence low). We found consistent evidence that tympanosclerosis was more common in children who had TT than in those who were actively monitored or who had myringotomy; these results pertained whether or not the children had an adenoidectomy (strength of evidence moderate).

We found limited evidence of differences in hemorrhage from adenoidectomy (strength of evidence low). We found insufficient evidence about surgical risks from insertion of TT or myringotomy procedures. Note, however, that the studies were not powered to detect rare but potentially serious events, such as harms from either anesthesia or the surgical procedures themselves.

The systematic review concerning nasal steroids found few mild adverse events in the studies they reviewed.121 Similarly, one new study found no differences between groups in relation to stinging nose, nose bleed, dry throat, or cough.20 We concluded, therefore, that mild adverse events are not significantly higher through the use of topical nasal steroids (low for no difference). However, evidence was insufficient to reach conclusions related to mild adverse events from oral steroids or to serious adverse events from oral or topical steroids.

### Key Question 4 Outcomes for Important Patient Subgroups

We attempted to differentiate treatment effectiveness or harms for key subgroups characterized by clinical or sociodemographic factors (such as age). For example, clinicians often treat children with preexisting hearing deficiencies, Down syndrome, or cleft palate differently than they would manage children who do not have such coexisting or congenital conditions and are otherwise following a typical development trajectory. Despite the important clinical and social questions that arise for children or adults in such subgroups, we could not identify studies that included most of our subgroups of interest.

Two studies examined different subgroups—children with sleep apnea and adults with OME. Vlastos et al. performed a study specifically with children with sleep apnea and OME. Among children with sleep apnea, all of whom had adenoidectomy to treat that condition, we found insufficient evidence to reach conclusions in terms of any measured outcomes.115 A study of autoinflation that was included in a systematic review30 found differences in rates of recovery among adults between those receiving autoinflation and those who were in the control group (low strength of evidence).

### Key Question 5 Health Care Factors

We found no studies that examined issues related to health insurance coverage, physician specialty, type of facility of the provider, geographic location of patients, presence or absence of continuity of care, or prior use of pneumococcal virus inoculation. Evidence is thus insufficient for all such considerations.

## Findings in Relation to What Is Already Known

The preponderance of the evidence included in this systematic review was obtained from recently completed reviews. Four of these reviews (including one update) were conducted by the Cochrane Collaboration22,29–31,34,147 and the fifth was sponsored by the Swedish government.21 We sought to determine whether the inclusion of non-RCT evidence (excluded from the Cochrane reviews) and newer trials would affect their findings. We also sought to obtain answers to questions not addressed in these reviews; these included the comparative effectiveness of different approaches to myringotomy, use of CAM therapies in treating OME, and the value of watchful waiting. Last, we sought evidence concerning populations not addressed in these reviews, such as findings specific to very young children, adults (an adult nominated the review), and children at greater risk for hearing deficiencies or developmental delays because of preexisting conditions.

Overall, we found few new studies that had not been included in the earlier reviews. We initially found one new RCT (low risk of bias) concerning topical steroid treatment,20,121 but this study was incorporated into a Cochrane review update while we were completing this review.32 We also found one large multicenter study comparing adenoidectomy, TT, and watchful waiting and have incorporated those findings.19

Thus, new evidence from nonrandomized trials and observational studies did not add appreciably to our understanding of these treatment comparisons. Nor were we able to uncover virtually any evidence regarding special populations. For those reasons, our conclusions are largely a compilation of those that have been made in the previous systematic reviews, supplemented with additional findings that we abstracted directly from the studies included in those reviews.

## Implications for Clinical and Policy Decisionmaking

The evidence from this review largely compiles and reconsiders in one document many of the findings that recent systematic reviews of treatments for OME have provided. We did not find evidence to refute the conclusions in current guidance concerning the lack of effectiveness of oral and intranasal steroids as treatment for OME; evidence included a recently conducted large RCT that found intranasal steroids to not be effective.20,121

TT are apparently effective in reducing effusion and in improving hearing compared with watchful waiting; nevertheless, their effect is limited, no doubt a consequence of the fact that effusion often resolves even if untreated. We found these results even though, by definition, many subjects in watchful waiting arms eventually received TT. However, questions remain on at least two points: (1) longer term TT outcomes did not generally adjust for whether the TT were still in place at the time of outcome assessments, and (2) criteria for watchful waiting groups receiving TT was discretionary, based on clinical judgment, rather than a priori criteria. TT designed to be retained in the ear for a longer period were more effective in relation to OME recurrence, but they also were related to a higher risk of some side effects. We did not find evidence about which routines for insertion are more beneficial for reducing fluid and mitigating harms and whether outcomes differ for younger versus older individuals. We still do not know for what age child it is most deleterious for fluid to remain untreated. Nor do we know whether subpopulations of children with cleft palate or Down syndrome need to follow a treatment course different from treatment that typically developing children might receive.

Overall, children with TT placement for OME lasting greater than 3 months are more likely to have resolution of middle ear effusion for up to 2 years after the procedure. We noted a similar difference for hearing loss up to 6 months after tube placement. This difference and the physiological and developmental plausibility that the hearing loss could worsen speech and language outcomes in either the short or the long term has driven clinicians to intervene on prolonged OME. Because, in the longer term, effusions resolve in the vast majority of patients without any intervention, a key clinical decision concerns the length of time that mild to moderate hearing loss needs to be present to have an important negative impact; similarly, how these outcomes may differ for individuals at different developmental stages and ages remains a crucial unanswered question. The series of studies by Paradise et al. suggests that delaying TT insertion for 9 to 12 months after OME develops with mild hearing loss does not worsen long-term functional outcomes compared with providing earlier insertion.

Many primary care providers refer patients with prolonged effusion (commonly considered to be 3 months or more) and mild to moderate hearing loss to otolaryngologists for placement of TT. However, our synthesis of the available studies found no evidence of differences in long-term functional outcomes or quality of life between subjects who had TT placement and those who had only watchful waiting for OME.

Currently, many children with craniofacial syndromes or underlying hearing loss have TT placed either prophylactically (e.g., for patients with cleft palate) or at a very low threshold of time that effusion is present. We found no evidence specific to these populations to either support or refute those practices.

Adenoidectomy alone is an effective treatment for middle ear effusion relative to myringotomy. Some evidence suggests that the combination of adenoidectomy and TT provides better outcomes than TT alone. However, surgery for adenoidectomy is more invasive and raises concern that it may threaten more serious complications than TT, but we found limited evidence describing or quantifying the risk.

For clinical questions that have insufficient evidence to provide confident answers, clinicians will need to continue to rely on the recommendations in clinical practice guidelines, clinician experience and expert opinion, and individual patient- and family-level shared decisionmaking.

## Applicability

As noted, during the review process we systematically abstracted key factors that may affect the applicability of the evidence base. We identified these key factors a priori, defining applicability as “the extent to which the effects observed in published studies are likely to reflect the expected results when a specific intervention is applied to the population of interest under real-world conditions.”148

### Population

Findings about all interventions are likely to be applicable in otherwise healthy children beyond infancy. However, the evidence base is limited for adults and for infants. In some cases, study authors did not provide sufficient information on age of the target population (e.g., provided only the average age without providing the age range) rendering it difficult to ascertain the applicability of the tested intervention. It is also limited for children with major coexisting or congenital conditions who may be at risk of having OME for longer periods of time, such as those with cleft palate or Down syndrome, and for those who may be more sensitive to hearing loss, such as those with preexisting hearing loss. Despite our goal of examining outcomes in young children, adults, and individuals with coexisting conditions, we were unable to find sufficient, if indeed any, studies on these populations. Thus, we cannot draw conclusions about whether the relative efficacy of treatment comparisons will be similar for these groups.

### Intervention and Comparators

We present evidence on all of the commonly used treatments for OME, including TT, myringotomy, adenoidectomy, and watchful waiting/delayed treatment. We present evidence on oral and intranasal steroids because, although not currently recommended in major guidelines or approved by the U.S. Food and Drug Administration for treating children with OME, our Technical Expert Panel believed that these pharmaceutical agents are still a commonly used intervention. We also include autoinflation, because, although this procedure is not typically used in the United States, it offers an alternative noninvasive treatment strategy for older children and adults. We had planned to include complementary and alternative medicine (CAM) but were unable to find any studies that met our criteria; thus, we have no evidence regarding the effectiveness of these treatments. Similarly, we planned to examine the prior use of pneumococcal virus inoculation as a moderator of the treatments for OME, but we did not find any studies. It should be noted that not all studies comparing TT to other surgical or non-surgical treatments provided information regarding the type of TT used, limiting conclusions that can be made about those comparisons.

### Outcomes

We did not limit the outcomes of interest but rather took a broad view of what kinds of benefits might occur with the treatments. We targeted clinical health outcomes, functional outcomes and quality of life, health care utilization, and harms. However, the bulk of the literature examined only whether the interventions reduced OME or improved hearing. A few studies examined language development and behavior problems, and a few of the RCTs examined quality-of-life outcomes. No studies focused on parental and patient satisfaction with care or heath care utilization. Thus, we can say little or nothing about these other important outcomes. Nor did studies uniformly examine harms, and when they did, there was not a standard set of harms measured, even for the same treatment.

We acknowledge the central role that continued effusion and hearing play in these functional outcomes, yet the broad range of outcomes is important in its own right. Moreover, investigators chose different measures to index many of these outcomes (e.g., quality of life), so even when we had two or more studies reporting an outcome, we could not perform quantitative summaries.

Our lack of evidence in these areas parallels the conclusions reported in the previous AHRQ systematic review2 of long term effects of OME—chiefly that failure to reach conclusions about effects of OME on long-term speech and language can be attributed at least in part to lack of uniformity in instrumentation as well as in when the outcomes were measured. Most of the investigators examined outcomes at a set followup point post intervention. In contrast, the large RCT of Paradise and colleagues68 collected outcome data at defined ages of children making integration with the rest of the literature difficult.

### Timeframes

Studies varied in their length of followup periods. Many included studies measured results between 3 and 12 months following treatment; the longest was 10 to 12 years. However, for some comparisons, such as differences between types of TT and autoinflation and controls, followup was generally shorter. Overall, for any given comparison, time frames were rarely uniform, making cross-study integration difficult if not impossible.

### Settings

Studies were conducted in clinical settings and generally included populations from the United States and European countries. A few studies were conducted in developing countries (e.g., Bulgaria) and in non-Western countries (e.g., Egypt, Iran, Japan).

## Limitations of the Review Process

As noted previously, we constrained our synthesis of benefits to trials or other studies with either low or medium risk of bias. Given the limitations of the included studies and their applicability to other contexts, however, including high-risk-of-bias studies for benefits would likely have increased the pool of evidence but without providing more actionable evidence. By contrast, we included harms evidence from high-risk-of-bias studies because some harms, such as otorrhea and surgical complications, could not have occurred without the procedure.

Other possible limitations of the review process included our reliance on results from existing systematic reviews and our restriction to including only articles written in English. Use of the systematic reviews meant that we accepted the authors’ assessments of risk of bias and their methodology for conducting meta-analyses. All authors documented how they classified studies and conducted meta-analyses. In all cases they appeared to use appropriate and reliable methods for determining bias and performing syntheses. Given the large literature base in English, we felt that we would have captured most of the eligible studies with this restriction. Although the Cochrane reviews did not limit their searches to English, all of their studies were, in fact, published in English. Thus, we do not believe that the evidence base of this review had serious omissions.

At the outset of the review, we established that we would only include head-to-head trials, including active monitoring. We recognize that by excluding single arm studies, we may have eliminated studies that examined important outcomes, particularly harms.

## Limitations of the Evidence Base

Our decision to restrict studies to those that examined treatments in individuals with OME limited the overall evidence base. Many studes indicated only that the participants had otitis media; the published articles typically either did not give information about the type of OME or included a mixed sample of individuals with AOM and OME. When investigators analyzed the OME samples separately, we included the study, but this was the exception rather than the rule. Thus, the body of research we included was restricted because of the lack of specificity in populations covered in published articles.

The evidence base was further restricted by a lack of studies with low risk of bias (i.e., good internal validity). Overall, we rated only 1 of the 17 new studies included in our analysis as low risk of bias. Some of the major reasons we rated studies as medium (rather than low) risk of bias included the following: (1) RCTs lacked information regarding randomization or blinding of outcome assessors and providers, and (2) the studies had high rates of attrition. Overall, the more rigorous studies had been previously identified in the systematic reviews that we included in our review.

Evidence about managing patients with OME is further confounded by a variety of methodological deficiencies. Not all studies provided detailed information about co-interventions. Although some investigators indicated how many patients received a supplementary treatment, they didn’t analyze the data separately by these treatments. Studies employed a wide range of criteria for diagnostic inclusion and a wide variety of outcomes measures; they also gave only scant descriptions of how those measures were obtained. Even when outcome measures were similar, we often encountered variations in when investigators collected the data and how the data were reported. Differences in outcome measures and timing of data collection made additional quantitative synthesis impossible. Investigators did not routinely indicate important details about the treatment (e.g., type of TT used and how long the TT remained in place). These details are critical for understanding the generalizability of the findings

Most studies included a wide range of children (2 to 14 years of age) but did not include infants. Children age 6 or older who experience OME are likely to be at different risk for negative impacts than those who experience OME as infants or very young children; however, based on the study and followup by Paradise and colleagues (2001)68 this concern may not be warranted. Nevertheless, we were not able to draw firm conclusions about the relative benefit of treatments as a function of age; only Paradise et al. (2001)68 and Rovers et al. (2000)140 recruited infants. Including all children in studies may mask the benefits of treatment of individuals at varying ages.

Aside from several exceptions—notably, studies by Paradise and colleagues8 and Black and colleagues97—most investigators did not conduct a power analysis. Without such information, we could not determine with confidence whether a failure to find differences in individual studies was because the study was underpowered. We suspect that power was low for many of these studies, given the relatively small and heterogeneous samples.

## Research Gaps

Given the severe limitations of the evidence base, with gaps both in study topics (interventions, appropriate outcomes, relevant populations) and in methods, we have several recommendations for future directions.

### Gaps in Subgroups Studied

Additional research needs to determine the appropriate criteria and waiting period before surgical intervention with children. Analyses by Paradise et al. suggest that mild hearing loss in preschool children for periods of up to 9 to 12 months does not affect subsequent speech or language outcomes. Whether toddlers are able to tolerate the same degree of hearing loss without risk to their language development is not known.

A hearing loss of any degree creates a barrier to full access to the auditory signal. Thus, infants and toddlers who are learning the rules that govern language comprehension and production may be more vulnerable to any hearing loss that OME may impose. Research on infant speech perception and later outcomes has demonstrated that babies who were able to distinguish between the two simple vowels /i/ (tea) and /u/ (two) at 6 months of age had larger vocabularies when they were 18 and 24 months of age than did babies who could not make those distinctions. Because early vocabulary development is a strong predictor of academic achievement, these clinical considerations about OME are important and warrant more extensive investigation.149

In many instances children younger than 2 years of age are underrepresented in studies; even when they are included, investigators often do not present their results by appropriate age groups. We recommend that RCTs that include children at these highly vulnerable ages examine effects of OME on morphosyntactical development (0 to 36 months) and report their results partitioned by age groups that reflect developmental vulnerability.

Evidence about the impact of interventions for OME in at-risk subpopulations is virtually nonexistent. Children with a variety of developmental or sensory delays are usually excluded from studies investigating treatment outcomes for OME; this decision often eliminates children on the autism disorder spectrum and children with Down syndrome, permanent sensorineural or conductive hearing loss, craniofacial anomalies affecting eustachian tube function such as cleft palate, and ciliary dyskinesia. All these subgroups are at risk for developing speech and language problems because of these comorbidities; adding a 15 to 20 dB hearing loss because of OME increases their vulnerability. Although RCTs may not always be feasible because of ethical concerns or because of the relatively low incidence of these conditions, carefully controlled nonrandomized or observational studies can be conducted, and are very much needed, to guide management of OME in these subgroups.

Despite the high prevalence of OME in children with cleft palate,150,151 we found no evidence on treatment of OME in this population that met our inclusion criteria. Studies were excluded mainly because TT placement occurred prophylactically during other craniofacial surgery and was not limited to children with diagnoses of OME. A recent 2009 systematic review, conducted by Ponduri and colleagues,152 assessed evidence on OME-related symptoms and hearing, speech, and language outcomes in children with cleft palate who received early placement of TT. Only three of the studies in their report were limited to children who were diagnosed with OME at the time of initial assessment.153–155 We did not include these studies in our review because they were wrong population (included children with suppurative otitis media), wrong study design (case series, no comparator), and wrong publication type (the study was not available in English), respectively.

We identified one ongoing study with adult participants. The Children’s Hospital of Pittsburgh, in collaboration with The National Institute on Deafness and Other Communication Disorders (NIDCD) and the University of Pittsburgh, is currently conducting an observational study of adults who have received TT for treatment of chronic OME or eustachian tube function (or both).156 The investigators plan to examine both standard and study-designed eustachian tube function tests that may facilitate the development and use of new medical or surgical treatments to improve eustachian tube function and outcomes associated with middle ear diseases.

### Gaps in Outcomes Measured (Benefits or Harms)

As indicated previously, outcomes were limited mainly to resolution of OME and hearing. These outcomes can be easily measured, but we do not know to what extent they are correlated with functional outcomes such as speech and language development or quality of life. We found little evidence concerning cycles of episodes of AOM and OME; thus, we could not determine whether episodes or length of time with OME were related to a greater likelihood of new or recurrent episodes of AOM. Also, we found no information on how treatment choice during one OME episode affected later use of health care services. We believe that one area for future research is to establish whether treatments can affect these health and health care outcomes.

For instance, we had targeted auditory processing as an outcome of interest because research has demonstrated that OME can affect skills such as binaural auditory perception157 and speech recognition in noise.149,158 Presumably, these skills affect children’s ability to attend to instruction in noisy classrooms. One small study by Hall et al.159 found that TT can improve one measure of auditory processing, but the recovery period is protracted. Hearing is necessary for auditory processing, but even when hearing returns to normal, auditory perception can still be impaired. This study was not a trial and included only a small number of children. The only trial that reported on auditory processing was by Paradise and colleagues; they found no differences between their early and delayed tube groups among children 6 to 9 years of age.67,69 Replication of this work with new samples of children with more serious middle ear disease would be extremely useful to increase our confidence in these findings.

No study examined either use of health care services or parent satisfaction with care. Whether any of these treatments reduce time spent at the physician’s office (by children and their parents, or adult patients, or both) or lower any costs associated with loss of productivity is not known. Anecdotally, we know that parents often request TT because they hope that this intervention will reduce the time that their children are ill and in pain. The unexamined issue is whether receiving TT or other treatment options affects these outcomes. Proxy reporting on child functional status, including baseline conditions and outcomes important to parents could provide additional criteria for deciding between alternative treatment options.

Although recurrent AOM is an important outcome, and one of the reasons for treating OME, this outcome was reported in few studies. We recommend that future research include recurrence of AOM as an outcome. It is important to know whether an OME treatment shows reductions in AOM, even if hearing and functional outcomes do not show an effect.

We had few conclusions with regard to harms, in part because the evidence base was so limited. Future studies should aim to examine a uniform body of harms for all patients. Some of the treatment complications are rare (e.g., cholesteatoma, complications from adenoidectomy surgery), making it even more important that both trials and observational studies make a concerted effort to measure these problems and side effects.

### Gaps in Interventions

This review provided little evidence regarding different types of TT or routines for insertion. An ongoing Swedish trial plans to enroll 400 children between the ages of 1 and 10 years in an RCT comparing complications from four types of TT, two different materials, and two different shapes.160 The comparisons described are the Shepard tube (double flanged, Fluoroplastic) versus Donaldson tube (double flanged, silicone); Straight tube (single flanged, Fluoroplastic) versus Armstrong (single flanged, silicone); Armstrong (single flanged, silicone) versus Donaldson tube (double flanged, silicone); and Straight tube (single flanged, Fluoroplastic) versus Shepard tube (double flanged, Fluoroplastic). Outcomes include time to complete expulsion of the TT from the tympanic membrane and various harms, including persistent tympanic membrane perforation, need for TT extraction, pain leading to health care contact, tube-related ear infection, obstruction of the TT, and presence of myringosclerosis. The trial will include both children with recurrent AOM (RAOM) and OME, but presentation of the results (i.e., complications in OME and RAOM reported separately) could inform best practices in TT choice for children with OME. Although this study will likely make an important contribution to the literature about complications as a function of TT design, it is unfortunate that neither hearing nor functional outcomes will be examined.

Despite increasing interest by the public in alternatives to surgical interventions or traditional medical management, an exhaustive review of the literature failed to identify any RCTs regarding CAM treatments. The need for carefully conducted investigations of CAM interventions, including dietary modifications, seems clear. We identified an ongoing and potentially promising RCT that addresses the benefit of dietary modification in treating patients with OME.161 The study, being conducted at the University of Missouri-Columbia, hopes to provide evidence that standard treatment options for chronic OME in children should involve food allergy assessment and, when indicated, subsequent dietary modifications in addition to standard surgical procedures. Additionally, these investigators are seeking evidence to assess whether adenoidectomy is of added benefit in a treatment course of surgical intervention and dietary modification. Investigators plan to measure recurrence of OME in two treatment groups: (1) bilateral myringotomy with TT in conjunction with food allergy testing and management and (2) bilateral myringotomy with TT in conjunction with adenoidectomy and food allergy testing and management. The incidence of recurrent OME episodes in all trial groups will be recorded at 3-month intervals until TT expulsion, with a further year of followup evaluations at 3-month intervals. At the time of this report, this study is listed as recruiting.160

Several studies have found high pepsin or pepsinogen, a component of stomach fluid, in the middle ear fluid of children with chronic middle ear fluid. Some researchers believe that gastroesophageal reflux disease (GERD) may be a cause of OME.162 We identified two unpublished trials that evaluate treating children with OME with proton pump inhibitors (PPIs, i.e., antireflux medications). One study of chronic OME is listed as completed,161 with December 2009 reported as the final data collection date for the primary outcome measure(s); we were unable to identify any related publications, however, and to the best of our ability do not know of any publications on the outcomes of this study. An ongoing pilot study of anti-acid treatment for children and adolescents with OME lists the completion date for data collection of primary outcome measures as April 2012. Although the primary goal of this study is to collect data for calculating sample size and recruitment rates required for a larger clinical trial, the secondary outcomes could potentially be of particular interest to the field; these outcomes include degree of hearing improvement, complications of OME (e.g., recurrent OME, surgery) and side effects of the PPI lansoprazole. The larger clinical trial that is set to follow could provide a clearer picture of the role that gastric reflux might play in OME and could inform treatment decisions, although recent evidence of risks associated with PPI use in children will need to be incorporated into treatment decisions.163

A prospective cohort study, ongoing since 2006, in children 3 to 6 years of age who underwent TT insertion for chronic OME aims to determine whether eustachian tube function tests and gas exchange tests can be used to predict successfully whether a child who has TT will redevelop the disease after the TT either becomes nonfunctional or is expelled.164 The investigators state that the results of their study will be used to support or contest components of existing models of middle ear pressure regulation and to develop test protocols for risk assignments of disease recurrence in individual ears after TT become nonfunctioning or are extruded.

Many cases of OME start after episodes of AOM. Additionally, sinus and pharyngeal infections can further eustachian tube dysfunction and contribute to OME. Vaccines to prevent pneumococcal disease can decrease the frequency of AOM165 and might be able to decrease episodes of sinusitis and pharyngitis in the future. As rates of vaccination increase, the character of OME may change because bacterial infections will be less likely to play a role in the disease process. The use of vaccines to prevent OME was outside the scope of this review, but it holds promise for decreasing the rate of OME in children.

### Deficiencies in Methods

Meta-analyses can strengthen the power for finding effects when trials have, individually, only a limited number of events. However, in many cases, differences in the methods used in these studies hamper or even preclude meta-analysis. This fact underscores the need for high-quality (low risk of bias), sufficiently powered RCTs comparing different TT types and comparing TT insertion with other interventions, utilizing a uniformly agreed-upon set of outcomes. Vastly different outcome measures and outcome assessment times limit the studies that can be (or ought to be) included in systematic reviews, which in turn delays reaching definitive conclusions about efficacy, effectiveness, and harms. If investigators in this field could agree about outcomes to be included in their investigations, then those conducting systematic review on the topic could pursue more and stronger quantitative analyses. At a minimum, uniform time points for outcome assessments and consistency in measures of hearing would make the task of combining research easier.

## Conclusions

Overall, a small and uneven body of evidence showed that TT decreased effusion and improved hearing over a short period of time relative to myringotomy alone, watchful waiting, or delayed treatment. However, hearing and effusion did not differ over longer time periods, and differences were not found in speech, language, and functional outcomes. Less is known about long-term outcomes of adenoidectomy, particularly with respect to functional outcomes. Steroids were not found to provide additional benefit. More research is needed to develop a sufficient evidence base to support treatment decisions, particularly in subpopulations defined by age and coexisting conditions.